# Appendix K. Acknowledgments

The Johns Hopkins University Evidence-based Practice Center expresses its appreciation to Simon Chuang, Otto Guedelhoefer and Steven Leoniak for their assistance in the preparation of this report.

We also thank Karen A. Robinson, MHS, Steven N. Goodman, M.D., M.H.S., Ph.D., Neil R. Powe, M.D., M.B.A., M.P.H., Cindy Sheffield, M.S., and Aaron Sherber M.M. for their contributions.