# Appendix J: Acronyms and Abbreviations

Abbreviation | Term
AC | anticoagulants
ARR | absolute risk reduction
ASA | aspirin
asymp | asymptomatic
BF | breastfeeding
bid | twice a day
ca | cancer
CA | California
CAD | Canadian dollars
CE | cost effectiveness
CI | confidence interval
CohP | cohort prospective
CohR | cohort retrospective
comp | compression
consec | consecutive
CT | computized tomography
CVA | cerebrovascular accident
d/c | discontinuation
DVT | deep venous thrombosis
dx | diagnosis
ED | emergency department
ELISA | enzyme-linked immunosorbent assay
FN | false negative
FP | false positive
FRF | French francs
f/u | followup
Gd | Gadolinium
GRE | gradient echo
hr | hour
HRT | hormone replacement therapy
ICU | intensive care unit
inpt | inpatient
INR | international normalized ratio
IPG | impedance plesthymography
IU | international units
IV | intravenous
IVC | inferior vena cava
LE | life expectancy
LMWH | low molecular weight heparin
LT | long term
LY | life year(s)
MD | physician
ME | Medicare
mo | month(s)
MRA | magnetic resonance angiography
MRI | magnetic resonance imaging
N/A | not applicable
NLG | Netherlands guilders
NNT | number needed to treat
NPV | negative predictive value
NR | non-response
NSAID | nonsteroidal anti-inflammatory drug
NSD | no significant difference
OCP | oral contraceptive pill
OR | odds ratio
outpt | outpatient
PA | pulmonary angiogram
PE | pulmonary embolism
Preg | pregnancy
PIOPED | Prospective investigation of pulmonary embolism diagnosis
postop | postoperative
PPV | positive predictive value
PRF | permanent risk factor
prosp | prospective
prox DVT | proximal deep vein thrombosis
PTP | pretest probability
pts | patients
PTT | partial thromboplastin time
QALY | quality adjusted life years
qd | every day
QOL | quality of life
RAS | risk assessment score
RCT | randomized controlled trial
ROC | receiver operating characteristic
RR | risk ratio
RRR | relative risk reduction
rx | prescription
sens | sensitivity
spec | specificity
SPECT | single-photon emission computerized tomography
SQ | subcutaneous
sx | symptom(s)
symp | symptomatic
tid | three times a day
tiw | three times per week
TN | true negative
TP | true positive
TRF | temporary risk factor
tx | treatment
u | units
UFH | unfractionated heparin
UE | upper extremity
U/S | ultrasound
USD | United States dollars
VDS | venous duplex sonography
V/Q | ventilation perfusion
vs | versus
VTE | venous thromboembolism
w/ | with
w/i | within
w/o | without
wk | week(s)
yr | year(s)

Not listed above:

hx