# Appendix A. Core Technical Experts and Peer Reviewers

Core Technical Experts
Expert Area and Organization | Name | Location
Partner Organization
American Academy of Family Physicians | Lee Green MD | University of Michigan, Ann Arbor, MI
Cochrane Collaboration
Dutch Cochrane Center | Jeroen van der Heijden MD | Academic Medical Centre, Amsterdam, the Netherlands
Diagnostic Testing Expert
| Steven W. Heim MD | University of Virginia, Charlottesville, VA
Payor
Center for Medicare and Medicaid Services | Steve Phurrough MD, MPA | Baltimore, MD
Primary Care Organizations
American College of Physicians- American Society of Internal Medicine | Rodney E. Hornbake MD | Gentiva Health Services, Melville, NY
| Patricia Barry MD | Merck Institute of Aging and Health, Washington, DC
Society of General Internal Medicine | Richard White MD | University of California at Davis, CA
Professional Organizations
American College of Chest Physicians | Gordan Guyatt MD | McMaster University, Hamilton, Ontario
| Jack Hirsch MD | Hamilton Civic Hospitals Research Centre, Hamilton, Ontario
| Agnes YY Lee MD | McMaster University, Hamilton, Ontario
| Phillip Wells MD | Ottawa Hospital, Ottawa, Ontario
American Association of Health Plans | | Washington DC
American College of Radiology | Michael A. Bettmann MD | Dartmouth University, Hanover, NH
Funding Organization
Agency for Healthcare Research and Quality (AHRQ) | David Atkins MD | Rockville, MD