# Appendixes

Appendix A. Core Technical Experts and Peer Reviewers

Appendix B. Priority Journals for Hand Searching

Appendix C. Literature Search Strategies

Appendix D. Abstract Review Form for Primary Literature

Appendix E. Abstract Review Form for Systematic Reviews

Appendix F. Quality Review Form for Key Questions 3 and 4

Appendix G. Quality Review Form for Key Questions 5 and 7

Appendix H. Quality Review Form for Key Questions 3b - costs

Appendix I. Quality Review Form for Systematic Reviews

Appendix J: Acronyms and Abbreviations

Appendix K. Acknowledgments