# Evidence Tables

Evidence Table 1. Costs and Work Performance

Study | Design and Interventions | Patient Population | Outcomes Reported | Results | Quality Score†/Notes
Blanc, Trupin, Eisner, et al., 2001 | Design: Population-based telephone survey | No. of subjects at start: 5,304 contacts made with individual households; 1,411 refused; 227 excluded (language); 254 excluded (no asthma or rhinitis) | 1) Severity of respiratory symptoms (self-reported) | 1) Severity of respiratory symptoms (self-reported): | Quality Scoring:
| | | | | Population similar: Yes
| | | | Severe: 22% | Intervention(s) described: No
| Intervention(s): NA | | 2) Medication use | Moderate: 49% | Comorbidities described: Yes
| | | | Mild: 29% | Diagnosis by MD: No
| Duration of study treatment: NA | | 3) Quality of life (SF-12) | | Objectively confirmed: Not applicable
| | Dropouts/withdrawals: NA | | 2) Medication use:
| | | 4) Health care utilization | Past 2 weeks: | Outcome measures valid: No
| Dates: May 28-July 21, 1999 | No. of subjects at end: 125 asthma; 175 rhinitis (and no asthma) | | Rx inhaler: 9% | Level of evidence: 1b
| | | 5) Employment status | Rx nasal spray: 25%
| Location: Northern California rural, suburban, and urban regions | | | Antihistamine: 59%
| | | 6) Work effectiveness | | Notes:
| | Inclusion criteria: Age 18–50; self-reported physician-diagnosed asthma (asthma group) or self- or physician-diagnosed “allergic rhinitis, sinusitis or hay fever” or “chronic post-nasal drip” (rhinitis group) | | Ever use steroids for breathing: 13% | Survey failed to screen for COPD (only emphysema).
| Setting: Community | | | 3) Quality of life (SF-12):
| | | | Functional status scores (mean ± SD): | Study designed to compare asthma group to rhinitis-only group. No comparison possible to subjects with no respiratory illness.
| Type(s) of providers: NA | | | SF-12 physical component: 49 ± 10
| | | | SF-12 mental component: 48 ± 11
| | | | Activity limitations due to condition (in previous month): 30%
| | Exclusion criteria: Emphysema or cystic fibrosis
| | | | 4) Health care utilization, past 12 months, for condition:
| | Age: NR
| | | | Urgent care visit: 32%
| | Sex: 72% women | | ED visit: 6%
| | Race: 74% White, 16% Latino, 9% Asian/Other, 2% Black | | 5) Employment status:
| | | | Labor force participation since onset: 97%
| | Other: | | Labor force participation given onset
| | Smoking status: | | < 18 years of age: 99%
| | Current 16% | | Changed jobs or duties due to condition: 18%
| | Former 28%
| | Never 57% | | Currently employed: 23%
| | Insured for healthcare: 89% | | 6) Work effectiveness (last 4 weeks):
| | | | Any partial or complete lost work days: 23%
| | | | Any partial lost work days: 20%
| | | | Any complete lost work days: 13%
| | | | Self-rated effectiveness on job < 90%: 36%
Burton, Conti, Chen, et al., 2001 | Design: Prospective survey of customer service representatives, weekly productivity data and Health Risk Appraisal (HRA) information from employer, and pollen counts in the community. | No. of subjects at start: Surveys sent to 1600 telephone customer service representatives in June 1998; 54% (634 subjects) completed and returned. The follow-up survey sent out in October 1998 was completed by 72% (459 subjects). Of the study population, HRA information was available for 299 in the AR group and 269 in the non-AR group. | 1) Proportion of patients with self-reported AR who reported using no medications, OTC medications, or prescription medications | 1) 21.7% reported no medication use for AR; 41.6% reported OTC medication use; and 36.7% reported prescription medication use. | Quality Scoring:
| | | | | Population similar: Yes
| | | | | Intervention(s) described: No
| | | | | Comorbidities described: Yes
| | | | | Diagnosis by MD: No
| | | | 2) 7% fewer employees with allergies met the productivity standard when pollen counts were high compared with employees without allergies | Objectively confirmed: Not applicable
| | | 2) Likelihood of meeting the productivity standard during weeks when the pollen count was high | | Outcome measures valid: Yes
| | | | | Level of evidence: 4
| To measure productivity impact of AR and its treatment
| | | | 3) Employees with or without allergies met the productivity standard as often before and after the allergy season
| | | | | Notes:
| Intervention(s): NA | Dropouts/withdrawals: NR | 3) Impact of allergies on meeting the productivity standard before or after allergy season | | Weekly productivity was measured as a dichotomous variable classified as either meeting or not meeting the overall productivity standard. As the final measure, the average of all weekly scores was computed. Those meeting the weekly productivity standard more than half the time were classified as meeting the productivity standard.
| Duration of study treatment: NA | No. of subjects at end: 634 subjects were included in analyses of productivity | | 4) 5% fewer employees with allergies met the productivity standard during allergy season compared with employees without allergies
| Dates: June 1998 through October 1998 | | 4) Impact of allergies on meeting the productivity standard during the allergy season
| | Inclusion criteria: NR
| | | | 5) 10% fewer employees with allergies who reported using no medication met the productivity standard compared to employees without allergies
| Location: Elgin, IL | Exclusion criteria: NR
| Setting: Large employer | Age: 20.5% < 25; 36.1% 25–34; 23.3% 35–44; 20.3% 45+ | 5) Impact of no medication among those with allergies on productivity during the allergy season
| Type(s) of providers: NA | | | 6) 3% fewer employees who reported using nonsedating or sedating antihistamines met the productivity standard compared to employees without allergies
| | Sex: 88.6% women | | | The results on medication type and productivity are misleading. Instead of reporting the % reduction in the likelihood of meeting the productivity standard, the authors report these percentages as the percent reduction in productivity. This interpretation is carried out through the discussion when making a case for the cost-benefit of providing pharmacy coverage for people with AR.
| | Race: Asian: 2.4%; Black:7.7%; White: 81.4%; Hispanic: 8.4%; Native American: 0.2%
| | | 6) Impact of using antihistamines (sedating or nonsedating) on productivity during the allergy season
| | | | 7) No difference in productivity was observed between those reporting the use of sedating or nonsedating antihistamines among those who used medication
| | | 7) Impact of type of antihistamine on productivity during the allergy season
Cockburn, Bailit, Berndt, et al., 1999a and Cockburn, Bailit, Berndt, et al., 1999b | Design: Retrospective analysis of claims data and daily work output records | No. of subjects at start: Health claims for 5,888 individuals | 1) Effect of antihistamines (all types combined) on average level of productivity | 1) When not controlling for the type of antihistamine, there was not a statistical difference in productivity during the 3-day period prior to filling the prescription or the 3-day period following the filling of a prescription for an antihistamine. | Quality Scoring:
| | | | | Population similar: Yes
| | | | | Intervention(s) described: No
| | Dropouts/withdrawals: NA | | | Comorbidities described: No
| To test the impact of antihistamine use on productivity, work output observations of insurance claims processors were classified into periods directly preceding and following the date on which the prescription was filled. Time periods of 3, 5, 7, 10, and 14 days were tested. | | | | Diagnosis by MD: No
| | No. of subjects at end: After removing outliers, 183,301 observations on daily work output were available for 682 individuals | 2) Effect of sedating and nonsedating antihistamines on average level of productivity | | Objectively confirmed: Not applicable
| | | | | Outcome measures valid: Yes
| | | | 2) During the 3-day period after filling a prescription for a sedating antihistamine, workers were on average 7.8% less productive (p < 0.01). Conversely, during the 3-day period after filling a prescription for a nonsedating antihistamine, workers were 5.2% more productive on average (p < 0.01). | Level of evidence: 4
| | Inclusion criteria: Individuals with prescription claim(s) for antihistamines | 3) Effect of sedating antihistamines on average level of productivity when extending the analysis time period
| | | | | Note: Study limitation: Claims for prescription drugs could have been prescribed for dependants, not employees.
| | Exclusion criteria:
| Intervention(s): NA | Age: Mean, 32 | 4) Daily cost of lost output based on hourly pay of $11.50
| Duration of study treatment: NA | Sex: 94% female | | 3) When extending the time period during which productivity is measured following a sedating antihistamine, the negative effect on productivity remains significant (p < 0.01) out to 14 days (max period tested). However, the size of the effect lessened to 3.1%.
| | Race: NR | 5) Net monetary benefit of treatment with non-sedating antihistamines compared to sedating antihistamines
| Dates: January 1993-July 1995
| | Other:
| Location: NR
| Setting: Community, large insurance company | | | 4) Daily cost of lost output:
| | | | $9 per day (ranging from $7 to $11)
| Type(s) of providers: NA | | | 5) Net monetary benefit of treatment with non-sedating antihistamines compared to sedating antihistamines:
| | | | $7.50– $8 per day assuming an incremental cost of $1–$1.50/day for nonsedating antihistamines
Crystal-Peters, Crown, Goetzel, et al., 2000 | Design: Cost of illness study (indirect costs only) based on a synthesis of data from: | No. of subjects at start: NA | 1) Prevalence of AR | 1) Prevalence of AR: 9.8% (25.7 million) | Quality Scoring:
| | | | | Population similar: Yes
| | Dropouts/withdrawals: NA | 2) Prevalence of AR by age group | | Intervention(s) described: No
| 1) 1995 National Health Interview Survey; 2) Bureau of Labor Statistics | | | 2) Prevalence of AR by age group: | Comorbidities described: No
| | No. of subjects at end: NA | | < 18yo: 6.6%; 18–64yo: 11.7%; ≥ 65yo: 9.8% | Diagnosis by MD: No
| | | 3) Average annual number and total number of work days lost per person with AR | | Objectively confirmed: Not applicable
| | Inclusion criteria: Respondents with self-reported diagnostic information that was coded as allergic rhinitis
| Intervention(s): NA | | | 3) Average annual number and total number of work days lost per person with AR: | Outcome measures valid: No
| | | | | Level of evidence: 2b
| Duration of study treatment: NA
| | | 4) Indirect costs of lost work days | 0.24 days per year, 3.6 million lost work days
| | Exclusion criteria: | | | Notes:
| Dates: 1995 | | | | Assumptions used in cost calculations:
| | Age: Of those reporting AR, 18.2% < 18, 72.9% 18–64, 8.9% ≥ 65 | 5) Total number of at-work reduced activity days | 4) Indirect costs of lost work days: $445.3 million ($1995)
| Location: US | | | | 1) At-work productivity losses were based on NHIS-reported number of days that respondents cut down on usual activities by more than half of the day and were valued at 25% of the respondent's daily salary.
| Setting: Community | | 6) Indirect costs of at-work productivity losses
| | Sex: Of those reporting AR, 53.6% women | | 5) Total number of at-work reduced activity days: Nearly 3 million at-work reduced activity days
| Type(s) of providers: NA
| | | 7) Indirect costs of reduced activity due to sedating antihistamines
| | Race: NR
| | | | 6) Indirect costs of at-work productivity losses: $92.8 million ($1995) | 2) Assumed that at-work reduced activity days reported in NHIS do not consider the effects of sedating antihistamines.
| | | 8) Total indirect costs of AR
| | | | 7) Indirect costs of reduced activity due to sedating antihistamines: $4.6 billion ($1998)
| | | | | 3) To assign indirect costs of reduced productivity due to sedating antihistamines, it was assumed based on unpublished survey data that 82% of AR patients use some treatment, and that 57% use OTC sedating antihistamines.
| | | | 8) Total indirect costs of AR: $5.2 billion ($1998)
| | | | | 4) 1989 Gallup poll: People with AR who used sedating (OTC) antihistamines reported a 25% reduction in productivity for 14 work days per year.
| | | | | This analysis double-counts productivity losses. It uses NHIS data to estimate lost productivity due to missed work days and at-work reduced productivity days. It assumes that reduced activity resulting from sedating antihistamines is not included in these estimates. Therefore, it uses the results from the 1989 Gallup poll and unpublished survey data to estimate indirect costs resulting from the use of sedating antihistamines.
Cuffel, Wamboldt, Borish, et al., 1999 | Design: Retrospective analysis of health care claims | No. of subjects at start: Claims data from 600,000 persons | 1) Prevalence of AR | 1) 13.3% (85,298/641,205) | Quality Scoring:
| | | | | Population similar: Yes
| | | 2) Proportion of AR patients with depression or anxiety disorder or both conditions | 2) Depression, 12%; anxiety disorder, 1.5%; depression and anxiety disorder, 1.5% | Intervention(s) described: No
| This analysis was designed to: 1) estimate the prevalence of coexistent AR, depression and anxiety disorder; 2) estimate the effects of the comorbid conditions on costs; and 3) determine whether treatment of AR had an impact on overall costs when these conditions were comorbid. | Dropouts/withdrawals: NA | | | Comorbidities described: No
| | | | | Diagnosis by MD: No
| | No. of subjects at end: 13% (85,298) with AR diagnosis; 9.3% (59,529) with diagnosis of depression and 2.2% (14,582) with diagnosis of anxiety | | | Objectively confirmed: Not applicable
| | | 3) Odds ratio (OR) of a depressive disorder among people with AR compared to people without AR | 3) OR = 1.7 (95% CI, 1.63–1.73) | Outcome measures valid: No
| | | | | Level of evidence: 2b
| | Inclusion criteria: Diagnosis of AR based on ≥ 2 prescriptions for allergy medication or diagnosis of AR
| Intervention(s): NA | | 4) Odds ratio (OR) of a anxiety disorder among people with AR compared to people without AR | 4) OR = 1.41 (95% CI, 1.35–1.47)
| Duration of study treatment: NA
| | Exclusion criteria: None specified
| Dates: 1995 | Age: 0–17yo: 16.1%; 18–34yo: 17.6%; 35–44yo: 21.3%, 45–54yo: 25.6%, 55–64yo: 18.9%; (65yo: 0.4% | 5) Additional annual expense from having a diagnosis of AR and depression versus a diagnosis of either AR or depression alone | 5) $363 additional per person per year
| Location: US
| Setting: NA
| | Sex: 61% women
| Type(s) of providers: NA
| | Race: NR | 6) Additional annual expense from having a diagnosis of AR and anxiety disorder versus a diagnosis of either AR or anxiety disorder alone | 6) $207 additional per person per year
| | | 7) Economic impact of AR treatment on total costs when AR and depression were comorbid | 7) $83 reduction per person per year
| | | 8) Economic impact of AR treatment on total costs when AR and anxiety disorder were comorbid | 8) $141 reduction per person per year
Donahue, Greineder, Connor-Lacke, et al., 1999 | Design: Retrospective analysis based on HMO claims data | No. of subjects at start: 122,196 diagnosed with asthma or rhinitis; of which 2,677 (2%) received ≥ 1 immunotherapy injection | 1) Median duration of immunotherapy (2–6 years of follow-up per patient) | 1) 2.7 years. Bivariate analyses showed that duration did not differ by age or gender, but duration was longest for patients with both asthma and rhinitis. Duration was similar among those with cat, ragweed and other allergens, but was shorter among patients with undocumented allergen. | Quality Scoring:
| | | | | Population similar: No
| | | | | Intervention(s) described: No
| | | | | Comorbidities described: Yes
| Intervention(s): NA | | | | Diagnosis by MD: No
| | Dropouts/withdrawals: NA | | | Objectively confirmed: Not applicable
| Duration of study treatment: NA
| | No. of subjects at end: 603 met all duration of membership, pharmacy coverage, and automated record eligibility requirements and were deemed to have actually received an immunotherapy injection | | | Outcome measures valid: No
| | | | | Level of evidence: 2b
| Dates: April 1988 through December 1994 | | 2) Distribution of number of treatments per person | 2) The distribution was bimodal with peaks at ~5 and ~65 injections per patient, 23% had no injections after the first month.
| | | | | Note: Compliance with immunotherapy was evaluated by determining the proportion of patients who received at least 50% of the recommended number of injections in each interval according to the following recommendations:≥ 20 injections in 1st 6 months, ≥ 30 injections in 1st year, an additional 31 injections over next 2.5 years, and a total of ≥ 61 injections over 3.5 years.
| Location: Northeast US
| Setting: Staff model HMO | | 3) Correlates of duration of therapy | 3) Multivariate analyses showed that duration of immunotherapy was shortest among females, those aged 10–20 years, and those for whom the allergen type was not documented.
| | Inclusion criteria: Subjects were required to have a minimum of 4 years of continuous enrollment in the HMO. Medical records were used to confirm the accuracy of asthma and rhinitis diagnoses.
| Type(s) of providers: NA
| | | 4) Compliance with immunotherapy (see Notes for definition) | 4) Of those with sufficient follow-up for assessment, 33% were classified as completing immunotherapy. 43% of those with both asthma and rhinitis completed therapy compared to 28% of those with rhinitis and 13% of those with asthma only. Patients with ragweed allergen were more likely to complete treatment and those with undocumented allergen were less likely.
| | Exclusion criteria:
| | Age: 7% age < 10 years; 15% age 10–29; 55% age 20–39; 23% age ≥ 40
| | Sex: 56% women
| | Race: NR
| | Diagnoses: | 5) Total cost of immuno-therapy (allergy testing, immunotherapy visits, visits for adverse reactions). | 5) $438 per person-year: $212 for people with asthma, $416 for people with rhinitis, and $496 for people with both conditions.
| | 58% had rhinitis without asthma, 39% had rhinitis plus asthma, 3% had only asthma
| | Allergens:
| | 6% cat (no ragweed) | 6) Immunotherapy and nonimmunotherapy costs for people who completed therapy compared to those who did not compete therapy | 6) $698 per person-year among those who completed immunotherapy vs. $247 for those who did not. Non-immunotherapy costs were $508 among people who completed immunotherapy and $421 among people who did not.
| | 45% ragweed (no cat)
| | 20% other or combination
| | 29% no documented
Fell, Mabry, and Mabry, 1997 | Design: Case series, survey | No. of subjects at start: 60 | 1) Nasal symptoms currently and before immunotherapy. | 1) 92% reported a significant improvement in symptoms | Quality Scoring:
| | | | | Population similar: Yes
| Patients administered the survey were asked to rate their nasal symptoms and QOL before undergoing immunotherapy and at the time they completed the survey. | Dropouts/withdrawals: 0 | | | Intervention(s) described: No
| | | | | Comorbidities described: No
| | No. of subjects at end: 60 | 2) General health currently and before immunotherapy. | 2) 62% reported that their general health was much better since beginning immunotherapy. | Diagnosis by MD: Yes
| | | | | Objectively confirmed: Yes
| | Inclusion criteria: patients with IgE-mediated allergy who had undergone 1or more years of immunotherapy | | | Outcome measures valid: No
| | | | | Level of evidence: 4
| | | 3) Tolerance of exercise, outdoor activities, participation in social activities and energy level for every day activities currently and before immunotherapy. | 3) 38% reported an increase in exercise tolerance. Of the 34 patients who reported regularly participating in outdoor activities, 74% were better able to perform these activities; 63% reported improvement in their social lives, and 55% reported an increased energy level.
| Intervention(s): | | | | Note: These results are limited by recall bias and selection bias as only patients who continued immunotherapy were included in the survey and all were under the care of the 2nd author. Furthermore, it was not reported how these patients were selected to participate in the survey. In addition, no statistical testing was used to compare responses.
| Immunotherapy | Exclusion criteria: NR
| Duration of study treatment: NA | Age: Men: ages 27–70; women: ages 29–72
| Dates: NR | Sex: 60% men
| | | 4) Productivity at work currently and before immunotherapy and causes for changes in productivity. | 4) Of the 56 patients who were employed, 59% reported that their allergies caused them to be less productive at work, and all of these patients reported increased productivity since beginning immunotherapy.
| Location: Texas | Race: NR
| Setting: Outpatient
| Type(s) of providers: Patients from 1 provider represented
| | | 5) Work days missed currently and before immunotherapy. | 5) 31 of 56 (55%) reported missing work as a consequence of allergies. Prior to beginning immunotherapy, 29 of the 31 missed between 1 and 6 days of work over a 6-month period. The other 2 patients reported missing 12–18 work days within 6 months. Compared to the period before immunotherapy, patients missed work 4.2 fewer days after initiation of immunotherapy.
| | | 6) Number of physician visits to treat severe allergy symptoms or infections currently and before immunotherapy. | 6) The 63% of patients making frequent physician visits for allergies prior to immunotherapy had a decrease in the number of office visits by 3.8 per 6-month period after initiation of immunotherapy.
| | | 7) Quantity of medications currently and before immunotherapy. | 7) 63% were able to decrease the amount of each medication taken. Of the 36 people who reported taking more than 3 courses of antibiotics per year, 89% were able to decrease antibiotic use by at least 50% since starting immunotherapy.
| | | 8) Patients' assessment of whether immunotherapy was worthwhile and time until they noticed a benefit of immunotherapy. | 8) 92% reported that they felt that immunotherapy was worthwhile and the average amount of time they received immunotherapy before noting a benefit was 4.2 months when excluding one patient who reported 24 months.
Gilmore, Alexander, Mueller, et al., 1996 | Design: Case-control study using a large managed care database | No. of subjects at start: NA | 1) Odds Ratio for increased risk of work-related injury within 30 days following use of antihistamines | 1) Open wounds and contusions: | Quality Scoring:
| | | | OR = 1.5 (95%CI: 1.1 to 1.9); burns: OR = 3.1 (95%CI: 1.0–9.7); and fractures: OR = 1.7 (95%CI: 0.9–3.3). | Population similar: Yes
| | Dropouts/withdrawals: NA | | | Intervention(s) described: No
| | | | | Comorbidities described: No
| Intervention(s): NA | No. of subjects at end: 3,394 incident visits for traumatic work-related injury | | | Diagnosis by MD: No
| | | | | Objectively confirmed: Not applicable
| Duration of study treatment: NA
| | | | | Outcome measures valid: No
| | Inclusion criteria: | | | Level of evidence: 3b
| Dates: 1992-1993 | Cases: people who had a clinic or emergency room visit for an acute work-related injury in 1992-1993
| Location: Washington state | | | | Notes:
| | | | | Antihistamines in this study were almost always sedating, as non-sedating antihistamines were not available on the formulary during the study period.
| Setting: Community, staff-model HMO | Controls: matched to cases on sex, decade of birth date, and employer
| Type(s) of providers: NR
| | Case:Control Ratio: 1:2
| | Exclusion criteria: NA | | | Limitation of analysis:
| | | | | Exposure to medication was based on purchase of medication within 30 days prior to the date of injury. However, misclassification was not expected to differ between cases and controls.
| | Age: 18 years or older
| | Sex: 58.2% male
| | Race: NR
Keith, Haddon, and Birch, 2000 | Design: RCT, parallel-group, method of randomization not described | No. of subjects at start: 242 (randomized and received treatment) | 1) Costs: Included costs for study and rescue meds; any immunotherapy received; unscheduled visits to physician and services provided at such visits; visits to other physicians or hospital outpatient departments; and time off work or school | 1) Costs: Cost data were provided in figures. Therefore, exact cost estimates are not available from the article. | Quality Scoring:
| | | | | Population similar: Yes
| | | | | Intervention(s) described: Yes
| | | | | Comorbidities described: Yes
| Intervention(s): | Dropouts/withdrawals: | | | Diagnosis by MD: Yes
| 1) Intranasal budesonide delivered as a dry powder (Rhinocort® Turbuhaler® 400 μg), once per day (n = 121) | | | 2) Benefits: Prior to treatment, subjects were willing to pay an average of $15.89 (1993 Canadian$) per week for an allergy treatment that would relieve all symptoms. Following treatment, subjects were willing to pay an average of $12.95 (1993 Canadian$) per week to take the drug they had been using during subsequent allergy seasons. The reduction in willingness-to-pay was significant. | Objectively confirmed: Yes
| | No. of subjects at end: 242 received treatment, 241 completed both willingness-to-pay questionnaires | | | Outcome measures valid: Mo
| | | | | Level of evidence: 4
| 2) Intranasal budesonide delivered as an aqueous spray (Rhinocort® Aqua® 256 μg), once per day (n = 121) | | | | Note: Double-dummy blinding technique employed.
| | Inclusion criteria: Age ≥ 18 years; positive skin prick test to ragweed (≥ 3 mm); symptoms of rhinitis or a clear exacerbation of perennial rhinitis symptoms during ≥ 1 previous ragweed season
| | | 2) Benefits: Indirectly assessed by willingness-to-pay questionnaire administered at beginning and end of study
| Duration of study treatment: 4 weeks
| | | | 3) Cost-benefit analysis (including sensitivity analysis): The net benefit was significantly higher than costs incurred by $5.80 per week. The net benefit was highest ($7.39) among those who felt they had fewer symptoms than in previous ragweed seasons. When excluding the time lost from work or school from the calculation of costs, the net benefit was higher at $8.30 per week. In the sensitivity analysis, the estimates that were most sensitive to change were the cost of study medication, days missed from work or school and rescue medications. Only when the cost of each was at its highest assumed value was the net benefit negative.
| Loratidine and sodium cromoglycate or naphazoline HCl-antazoline phosphate eyedrops “provided for rescue” (instructions for using not described) | Exclusion criteria: None specified | 3) Cost-benefit analysis (including sensitivity analysis)
| | Age: 36
| | Sex: 54.5% female
| | Race: NR
| Trial preceded by 7- to 10-day placebo run-in period
| Dates: 1993 ragweed pollen season
| Location: Canada
| Setting: Allergy clinic
| Type(s) of providers: NR
Kessler, Almeida, Berglund, et al., 2001 | Design: Population-based daily diary survey used to estimate indirect costs of AR | No. of subjects at start: The National Survey of Daily Experience (NSDE) (n = 3,032) was a substudy of the MacArthur Foundation Midlife Development in the US Survey (MIDUS). 83% of the target sample (n = 1,242) consented by telephone to participate. | 1) Associations between impaired work quality and sociodemographic variables | 1) Impaired work quality was inversely related to age, higher in the western areas of the US, and lower in the fall than other seasons. | Quality Scoring:
| | | | | Population similar: Yes
| | | | | Intervention(s) described: No
| | | | | Comorbidities described: No
| Intervention(s): NA | | | | Diagnosis by MD: No
| | | 2) Associations between impaired work quantity and sociodemographic variables | 2) Impaired work quantity was higher in women and higher in the western areas of the US | Objectively confirmed: Not applicable
| Duration of study treatment: NA
| | | | | Outcome measures valid: No
| | | | | Level of evidence: 1b
| Dates: March 1996 to May 1997
| | Dropouts/withdrawals: NA | 3) Average monthly indirect cost during periods of high pollen/mold exposure per person | 3) $156.27 SE = $20.04 ($1997)
| | | | | Notes:
| Location: US | No. of subjects at end: 114 w/out AR, 625 with self-reported AR | | | Assumptions used in cost calculations:
| Setting: Community | | | | 1) Data on work impairment (work quality and work quantity) was collected using self-administered diaries during 8 consecutive days (periods were randomly assigned).
| | Inclusion criteria: Age 25 to 74; self-reported “hay fever or other seasonal allergies” among a list of conditions
| Type(s) of providers: NA | | 4) Projected US annual indirect cost of AR during high pollen/mold exposure | 4) $7.7 billion ($1997)
| | Exclusion criteria: None specified | | | 2) Impaired work quality was measured using yes/no response options. Work quantity was measured on a 0–10 scale, then dichotomized as impaired (0–5) and not impaired (6–10).
| | Age: Of those with allergic rhinitis: 35.5% 25–34, 34.7% 35–49,29.7% ≥ 50
| | Sex: 60.5% women | | | 3) Individual-level wage data were combined with results from regression analyses to estimate indirect costs. It was assumed that impaired work quality was equal to 25% of the respondent's daily wage and impaired work quantity was equal to 75% of daily wage.
| | Race: NR
Kozma, Schulz, Sclar, et al., 1996 | Design: Secondary analysis of data from previously reported RCT (see Notes) | No. of subjects at start: 232 in original trial; 77 subjects randomized to placebo were excluded from the cost-effectiveness analysis | 1) Efficacy: | 1) Efficacy: | Quality Scoring:
| | | 1a) Patient-assessed symptom severity: sneezing, nasal obstruction, rhinorrhea, and nasal itching graded daily using 0- to 100-point visual analog scales | 1a) There were no differences in total symptom severity scores prior to treatment. However, scores were significantly lower in the fluticasone group during the treatment period (159 vs 201, p = 0.003). The average decrease in scores between baseline and treatment periods was also greater for the fluticasone arm (-116 vs -80, p = 0.007). | Population similar: Yes
| | | | | Intervention(s) described: Yes
| | | | | Comorbidities described: No
| Intervention(s): | | | | Diagnosis by MD: Yes
| 1) Fluticasone propionate nasal spray, 2 sprays per nostril, once per day (total dose 200 μg) (n = 78) | | | | Objectively confirmed: No
| | Dropouts/withdrawals: | | | Outcome measures valid: No
| | | | | Level of evidence: 2b
| | No. of subjects at end: 155
| 2) Terfenadine 60 mg bid (n = 77) | Inclusion criteria: Based on four 0–100 point visual analog scales for sneezing, nasal obstruction, rhinorrhea, and nasal itching, patients had to have had a combined score ≥ 200 on 4 of 7 days prior to the intervention | | | Notes:
| | | | | Efficacy assessed through a secondary analysis of data from a previously published trial (van Bavel J, Findlay S, Hampel F, et al. Intranasal fluticasone propionate is more effective than terfenadine tablets for seasonal allergic rhinitis. Arch Intern Med 1994;154:2699–704).
| | | 1b) Patient global assessment of efficacy: overall response to treatment graded at end of trial on scale of 1 (significant improvement) to 7 (significant worsening) | 1b) More patients in the fluticasone arm indicated that they improved during the treatment period (mild, moderate or significant improvement) compared to patients in the terfenadine arm (85%[R1] vs 69%, p = 0.007). 5% in the fluticasone arm and 2% in the terfenadine arm reported worsening. A greater proportion of patients in the terfenadine arm reported no change (29% vs 9%). When the criteria used to indicate improvement included only those reporting significant or moderate improvement, there was not a significant difference between treatment arms (64% vs 53%, p = 0.154). When only a significant improvement was used as the criterion, more patients in the fluticasone arm were deemed to have improved (38% vs. 19%, p = 0.007).
| Duration of study treatment: 14 days
| No mention of rescue med
| Trial preceded by 4- to 7-day run-in period | Exclusion criteria: NR
| | Age: 39 years (mean)
| Dates: NR | | | | Original trial included a placebo arm, which was not included in this re-analysis.
| | Sex: 52% female
| Location: Texas
| | Race: White: 81.3%; Black: 3.2%; Hispanic: 15.5%; Other: 0%
| Setting: Allergy clinic | | | | Double-dummy blinding technique employed in original trial.
| Type(s) of providers: NR
| | | 2) Costs: Included only direct cost for study med (average wholesale price) | 2) Cost of terfenadine during study period: $24.81; cost of fluticasone during study period: $18.14
| | | 3) Cost-efficacy analysis (including sensitivity analysis) | 3) Incremental cost-effectiveness ratios were not reported as fluticasone was found to be less costly and more effective than terfenadine when the standard for improvement included only those indicating significant improvement or when the standard for improvement included those indicating significant, moderate or mild improvement.
Lee, Cummins, and Okamoto, 2001 | Design: Retrospective analysis of health care claims | No. of subjects at start: > 16 million people in data set | 1) Proportion of patients who received treatment with second-generation antihistamines ± nasal steroids, plus breakdown by treatment | 1) Treatment included second-generation antihistamine and/or nasal steroid: 90.7%; | Quality Scoring:
| | | | | Population similar: Yes
| | | | | Intervention(s) described: No
| Intervention(s): NA | Dropouts/withdrawals: NA | | Monotherapy with second-generation antihistamines: 41.4%; | Comorbidities described: No
| | | | | Diagnosis by MD: No
| Duration of study treatment: NA | No. of subjects at end: 202,426 | | Monotherapy with nasal steroids: 19.7%; | Objectively confirmed: Not applicable
| | Inclusion criteria: People diagnosed with AR during 1997 or 1998 and with at least one prescription claim within the 12-month period following AR diagnosis. All prescription claims within the 12-month period following the first prescription claim were analyzed. | | Combination therapy with second-generation antihistamines and nasal steroids: 29.7% | Outcome measures valid: No
| Dates: 1997 and 1998 | | | | Level of evidence: 2c
| Location: US
| | | 2) Prevalence of comorbid conditions | 2) Upper respiratory infection: 32.2%; Lower respiratory infection: 3.3%; depression: 6.5%; sinusitis: 34.2%; Asthma: 14.8%; emphysema: 0.2%; COPD: 0.9%; otitis media: 11.5% | Notes:
| Setting: National managed care organization | | | | Patients' treatment was classified based on initial treatment selection. Switches or augmentations were not considered.
| Type(s) of providers: NA
| | Exclusion criteria: Patients who were not continuously enrolled during the study period | 3) Average annual charges by department | 3) Inpatient: $8.28; outpatient: $216.31; ancillary: $4.43; emergency: $0.16; pharmacy-related: $236.02
| | Age: Mean, 34 | 4) Total average annual charges | 4) $465.21
| | Sex: 61.4% women
| | | 5) Proportion of total costs attributed to prescription drugs and outpatient medical services | 5) Prescription drugs: 51%; outpatient medical services: 46%
| | Race: NR
| | Geographic region:
| | Midwest: 27.7%
| | Northeast: 12.0%
| | Southeast: 51.8%
| | West: 9.0%
Leickly, Sears-Ewald, and Ownby, 1989 | Design: RCT, parallel-group | No. of subjects at start: 20 | 1) Daily cost to druggist for study meds (based on average wholesale prices, December 1986) | 1) Daily cost to druggist for study meds: $0.92 for terfenadine, $0.37 for chlorpheniramine/pseudoephedrine | Quality Scoring:
| | | | | Population similar: Yes
| Intervention(s): | Dropouts/withdrawals: 1 | | | Intervention(s) described: Yes
| 1) Terfenadine 60 mg twice per day (n = 10) | | | | Comorbidities described: No
| | No. of subjects at end: 19 | | 2) Patient-assessed symptom severity: No significant differences in any individual symptom (p-values from 0.32 to 0.90) or combined symptoms (p = 0.97) | Diagnosis by MD: Yes
| | | 2) Patient-assessed symptom severity: sneezing; stuffy nose; runny nose; red, itchy nose; cough/wheeze; and shortness of breath graded twice daily on scale of 0 (none) to 6 (very severe) | | Objectively confirmed: Yes
| 2) Chlorpheniramine 4 mg + pseudoephedrine 60 mg, one capsule in morning and two at night (n = 9) | Inclusion criteria: History of late summer-early fall ragweed-induced allergic rhinitis for at least 2 years and a positive skin test to ragweed | | | Outcome measures valid: No
| | | | | Level of evidence: 4
| | | | 3) Adverse effects: | Note: Unable to determine how they calculated their symptom scores. Scores were collected twice daily using a 0–6 scale. They state that the average symptom scores represent the total score for the group for that symptom divided by the number of days in the study, providing an average symptoms treatment group score per day. If they did add up the scores for pts in each arm of the trial (n = 9 and n = 10) and then divide by the number of days, these results will not be valid because (1) there are more patients in one group versus the other (2) because observations are not on a per-patient basis but a per-day basis.
| Patients in both groups permitted to use nasal cromolyn as rescue med, if study med failed to relieve symptoms adequately
| | | | No significant difference in any individual adverse effect (p-values from 0.07 to 0.77), but terfenadine had significantly fewer total adverse effects (p = 0.03).
| | Exclusion criteria: Perennial allergic rhinitis, poorly controlled asthma, daily systemic steroid use, or long period of absence from study location
| | | 3) Adverse effects: drowsiness and irritability graded twice daily on scale of 0 (none) to 6 (very severe); GI complaints noted, but not scored
| Duration of study treatment: 38 days (during ragweed season) | | | 4) Treatment compliance: 1 patient in the terfenadine group reported 3 days of noncompliance
| | Age: Mean, 32 years; range, 18–59
| Dates: August- September 1986 | Sex: 53% women | | 5) Patient global evaluation of efficacy of treatment: 6 of 10 in the terfenadine group and 8 of 9 in the chlorpheniramine/ pseudoephedrine group stated that this was their ‘best year'.
| | | 4) Treatment compliance
| | Race: NR
| Location: Detroit, MI | | 5) Patient global evaluation of efficacy of treatment: experience during study rated relative to previous ragweed seasons
| Setting: Allergy clinic
| Type(s) of providers: NR | | | 6) Patient satisfaction: 7 of 10 patients treated with terfenadine would stated that they would use the medication again; 8 of 9 chlorpheniramine/ pseudoephedrine patients reported that they would use the medication again.
| | | 6) Patient satisfaction: pts asked at end of trial whether they would use the study med again
Liao, Leahy, and Cummins, 2001 | Design: Retrospective analysis of health care claims | No. of subjects at start: ~13 million people in data set | 1) Proportion of patients who received treatment with second-generation antihistamines ± nasal steroids, plus breakdown by treatment. Patients' treatment was classified based on initial treatment selection. Switches or augmentations were not considered. | 1) Treatment included second-generation antihistamine and/or nasal steroid: 66.3%; | Quality Scoring:
| | | | | Population similar: No
| | | | | Intervention(s) described: No
| Intervention(s): NA | Dropouts/withdrawals: NA | | Monotherapy with second-generation antihistamines: 24.8%; | Comorbidities described: Yes
| | | | | Diagnosis by MD: No
| Duration of study treatment: NA | No. of subjects at end: 105,696 | | Monotherapy with nasal steroids: 12.0%; | Objectively confirmed: Not applicable
| | Inclusion criteria: People diagnosed with AR during 1999 with at least one prescription claim for a nonsedating antihistamine within the 12-month period following AR diagnosis. | | Combination therapy with second-generation antihistamines and nasal steroids: 29.5% | Outcome measures valid: No
| Dates: 1999 | | | | Level of evidence: 3b
| Location: US
| | | | 2) Prevalence of comorbid conditions: | Notes:
| Setting: National managed care organization | | 2) Prevalence of comorbid conditions | Upper respiratory infection: 29.0%; lower respiratory infection: 4.7%; depression: 7.4%; sinusitis: 32.0; asthma: 18.4%; emphysema: 0.3%; COPD: 6.9%; otitis media: 8.9% | The results are not consistent with the inclusion criteria. The inclusion criteria defined cases as patients with a prescription claim for a nonsedating antihistamine, yet in the results a proportion of patients received monotherapy with steroids or neither steroids nor nonsedating antihistamines.
| | Exclusion criteria: NR
| Type(s) of providers: NA | | 3) Average annual charges by department
| | Age: Mean, 36 (SD 19); 16% age < 12; 10% age 13–18; 39% age 19–45; 29% age 46–65; 7% age > 65
| | | 4) Total average annual charges | 3) Average annual charges by department: inpatient: $14.71; outpatient: $358.84; ancillary: $5.44; emergency: $0.30; pharmacy-related: $171.32
| | Sex: 61.8% women | 5) Proportion of total costs attributed to prescription drugs and outpatient medical services
| | Race: NR | | | Also, this study was intended to update the results of the study by Lee, Cummins, and Okamoto (2001), above. However, there are substantial differences between the results of these study for some outcomes such as the proportion of pts receiving neither nasal steroids nor nonsedating antihistamines (33.7% vs. 9.3%), the proportion receiving nasal steroids only (12.0% vs. 19.7%), and average costs for pharmaceuticals ($171.32 vs. $236.02). The authors attribute these differences to differences in the study populations.
| | | | 4) Total average annual charges: $550.61
| | Geographic Region:
| | Midwest: 14.1%
| | Northeast: 13.9% | | 5) Proportion of total costs attributed to prescription drugs and outpatient medical services:
| | Southeast: 63.9%
| | West: 8.1%
| | | | Prescription drugs: 31%;
| | | | Outpatient medical services: 65%
Malone, Lawson, Smith, et al., 1997 | Design: Cost of illness study based on data from the 1987 National Medical Expenditure Survey (NMES) | No. of subjects at start: 36,259 respondents to NMES | 1) Prevalence of AR | 1) Prevalence of AR: | Quality Scoring:
| | | | 38.9 million (26.7 million adults and 12.3 million children) | Population similar: Yes
| | | 2) Proportion of AR patients who sought medical treatment | | Intervention(s) described: No
| | Dropouts/withdrawals: | | | Comorbidities described: No
| | | | 2) Proportion of AR patients who sought medical treatment: 12.1% (4.7 million persons) | Diagnosis by MD: No
| Intervention(s): NA | No. of subjects at end: | | | Objectively confirmed: Not applicable
| | | 3) Number and cost of prescriptions for AR
| Duration of study treatment: NA | Inclusion criteria: Non-institutionalized civilians in the US | | | Outcome measures valid: No
| | | | 3) Number and cost of prescriptions for AR: 11.5 million prescriptions, $184 million ($1987), $301 million ($1994) | Level of evidence: 3b
| | | 4) Number and cost of office or clinic visits to medical providers for AR
| Dates: 1987 | Exclusion criteria: Federal, military, and Department of Veterans Affairs populations, plus residents of nursing homes and other institutions
| | | | | Notes:
| Location: US | | | 4) Number and cost of office or clinic visits to medical providers for AR: 16.7 million visits, $418 million ($1987), $648 million ($1994) | Assumptions used in cost calculations:
| | | 5) Number and cost of outpatient hospital visits for AR
| Setting: Community | | | | 1) Restricted activity days collected in NMES were valued at 25% of the respondent's daily salary.
| Type(s) of providers: | Age: NR
| Allergist, 17%; ENT, 4%; GP or family practitioner, 6%; internist, 3%; pediatrician, 9%; nurse, 24%; other, 20%; not certain, 10% | | 6) Number and cost of emergency room visits for AR | 5) Number and cost of outpatient hospital visits for AR: 734,000 visits, $96 million ($1987), $180 million ($1994)
| | Sex: 45% male (of respondents with AR) | | | 2) Restricted activity days for those less than 18 years of age were not included.
| | Race: | 7) Number of missed work days and associated productivity loss | | 3) Indirect costs for missed school days based on parent's income.
| | Native American: 328,921 (1%) | | 6) Number and cost of emergency room visits for AR: 101,000 visits, $9.5 million ($1987), 17.7 million ($1994)
| | Asian/Pacific: 606,762 (1%)
| | Black: 4,215,059 (11%) | | | 4) Cost of OTC medications not included.
| | White: 32,728,023 (84%) | 8) Number of missed school days and associated productivity loss
| | Other: 1,116,999 (3%) | | 7) Number of missed work days and associated productivity loss: 811,000 missed work days, $37 million ($1987), $47 million ($1994)
| | | 9) Productivity loss associated with reduced activity days
| | | | 8) Number of missed school days and associated productivity loss: 824,000 missed school days, $13 million ($1987), $17 million ($1994)
| | | 10) Total direct cost of AR
| | | 11) Total indirect cost of AR | 9) Productivity loss associated with reduced activity days: 4,230,000 reduced activity days, $17 million ($1987), $23 million ($1994)
| | | 12) Total direct and indirect cost of AR
| | | | 10) Total direct cost of AR: $708 million ($1987), $ 1.15 billion ($1994)
| | | | 11) Total indirect cost of AR: $67 million ($1987), $ 86 million ($1994)
| | | | 12) Total direct and indirect cost of AR: $775 million ($1987), $ 1.23 billion ($1994)
Manor, Matthews, and Power, 2001 | Design: Longitudinal survey of a 1958 birth cohort administered at ages 23 and 33 | No. of subjects at start: At age 23: n = 12,525 | 1) Prevalence of hay fever at age 23 and age 33 in men and women | 1) Prevalence of hay fever by age and sex: | Quality Scoring:
| | | | | Population similar: Yes
| | | | Age 23: men 16.6%; women 16.4% | Intervention(s) described: No
| | Dropouts/withdrawals: 1,252 | | Age 33: men 15.6%; women 16.3% | Comorbidities described: No
| | | 2) Relationships between 2 global health measures and (self-rated health and limiting longstanding illness) and specific health problems. Self-rated health was grouped into 2 categories: fair/poor and good/excellent. Limiting longstanding illness was determined by asking whether respondents had a longstanding illness, disability, or infirmity that limited their daily activities in any way compared to people of their same age. Hay fever was one of the specific health problems examined. Others included psychological distress, respiratory problems, obesity, asthma, backache, eczema, diabetes, epilepsy, cancer, heart trouble, high blood pressure, arthritis, and menstrual or other gynecologic problems. | | Diagnosis by MD: No
| Intervention(s): NA | No. of subjects at end: At age 33: n = 11,273 | | 2) Self-rated health and limiting illness were associated with all specific health problems except among men for hay fever and obesity. In women, those who reported hay fever were more likely to report fair/poor health - lowest odd ratio reported for any health condition [OR = 1.47 (age 23) and 1.33 (age 33)]. | Objectively confirmed: Not applicable
| Duration of study treatment: NA | | | | Outcome measures valid: No
| | Inclusion criteria: Born in England, Wales, or Scotland during one week in March 1958 | | | Level of evidence: 1b
| Dates: Surveys administered in 1981 and 1991
| | | | | Notes:
| | Exclusion criteria: NA
| Location: England, Wales, and Scotland
| | Age: Survey administered when respondents were 23 and 33 years of age | | The association between reporting longstanding illness and hay fever was significant in men and women at age 23 (OR = 1.38 and 1.98, respectively), but only for women at age 33 (OR = 1.74). These associations were considered weak.
| Setting: Community
| Type(s) of providers: NR | Sex: 50% male
| | Race: NR
| | | 3) Association between changes in self-reported health and changes in specific health problems reported | 3) No association between changes in self-rated health and changes in reporting hay fever or eczema were found. Significant associations were found for other health problems.
Mc-Menamin, 1994 | Design: Cost of illness study based on a synthesis of data from multiple sources: | No. of subjects at start: NA | 1) Prevalence estimate from NHIS: no. of people reporting hay fever in 1988 | 1) Prevalence estimate from NHIS: no. of people reporting hay fever in 1988: 22.4 million; 9.3% prevalence rate | Quality Scoring:
| | | | | Population similar: Not adequately described
| | Dropouts/withdrawals: NA
| 1) 1988 National Health Interview Survey; 2) 1985 National Ambulatory Medical Care Survey; 3) 1989 Gallup Poll; 4) National Health Accounts from the Health Care Financing Administration 5) wage data from US Dept of Labor | | | | Intervention(s) described: No
| | No. of subjects at end: NA | 2) Number and cost of physicians' office visits for AR | | Comorbidities described: No
| | | | 2) Number and cost of physicians' office visits for AR: 9.8 million visits, $881 million ($1990) | Diagnosis by MD: No
| | Inclusion criteria: NA | | | Objectively confirmed: Not applicable
| | Exclusion criteria: Federal, military, and Department of Veterans Affairs populations, plus residents of nursing homes and other institutions | 3) Cost of medications for AR | | Outcome measures valid: No
| | | | 3) Cost of medications for AR: $276 million ($1990) | Level of evidence: 3b
| | | 4) Direct medical costs for AR (physician visits and medications) | | Notes:
| | | | 4) Direct medical costs for AR (physician visits and medications): $1.16 billion ($1990) | Assumptions used in cost calculations:
| Intervention(s): NA
| | Age: NR | | | 1) 5% growth in population from 1985 to 1990.
| Duration of study treatment: NA | | 5) Number of lost work days
| | Sex: NR | | 5) Number of lost work days: 3.4 million | 2) 1989 Gallup poll: People with AR who used sedating (OTC) antihistamines reported a 25% reduction in productivity for 14 work days per year.
| Dates: Vary | Race: NR | 6) Indirect costs of AR
| | | | 6) Indirect costs of AR: $639 million ($1990)
| Location: US | | 7) Total costs (direct + indirect)
| | | | | 3) Proportion Treated with OTC antihistamines: 1989 Gallup poll: 50%.
| Setting: Community | | | 7) Total costs (direct + indirect): $1.8 billion ($1990)
| Type(s) of providers: NA | | | | 4) Medication costs were based on the ratio of prescription and OTC medication costs to total physician costs as estimated in the National Health Accounts for HCFA (37.93%).
| | | | | 5) Cost of office visit: $50, cost of office visit with tests: $100
| | | | | 6) Average daily earnings: $96.05.
| | | | | 7) Productivity losses based on (1) total lost work days; (2) 25% of wage earners' reduced activity days; (3) 25% of home workers reduced activity days less 5%.
Meltzer, Casale, Nathan, et al., 1999 | Design: RCT, parallel-group, method of randomization not described | No. of subjects at start: 845 | 1) Disease-specific quality of life: assessed using the Rhinoconjunctivities Quality of Life Questionnaire (RQLQ) at baseline and at 1 and 2 weeks | 1) Disease-specific quality of life: | Quality Scoring:
| | | | Mean overall RQLQ score at baseline: 2.7; patients treated with both doses of fexofenadine experienced greater improvement in overall RQLQ scores. The 180-mg group reported greater improvement than placebo for all 7 RQLQ domains. The 120-mg group reported greater than placebo for 4 of the 7 RQLQ domains: practical problems, nasal symptoms, eye symptoms, and emotions. | Population similar: Yes
| | Dropouts/withdrawals: | | | Intervention(s) described: Yes
| | | | | Comorbidities described: No
| Intervention(s): | No. of subjects at end: 845 (610 eligible for inclusion in analyses of work impairment, 238 for classroom impairment) | | | Diagnosis by MD: Yes
| 1) Fexofenadine 180 mg once per day (n = 275) | | | | Objectively confirmed: Yes
| | | | | Outcome measures valid: Yes
| | | | | Level of evidence: 1b
| 2) Fexofenadine 120 mg once per day (n = 284) | | 2) Performance impairment due to allergy symptoms: assessed using the Work Productivity and Activity Impairment (WPAI) instrument at baseline and at 1 and 2 weeks
| | Inclusion criteria: Age 12–65; moderate to severe seasonal AR; history of AR during previous 2 fall seasons; positive skin prick test; symptom score ≥ 6 (max score: 16), with 2 or more symptoms rated as moderate-to-severe. After 1-week placebo run-in period, patients needed a symptom score ≥5 with ≥ 2 individual symptoms rated as moderate or severe.
| | | | | Notes:
| 3) Placebo (n = 286)
| Duration of study treatment: 2 weeks | | | 2) Performance impairment due to allergy symptoms: Overall work impairment significantly decreased 7.1% in the 120-mg group and 8.7% in the 180-mg group, compared to a 1.8% reduction in the placebo group. There were also significant reductions in both fexofenadine groups relative to placebo in activity impairment. There were no significant differences between treatment groups in the percentage of time missed from work. There were also no significant differences in classroom impairment measures.
| No mention of rescue med
| | | 3) Overall health impressions/generic quality of life: measured using 3 generic domains of the Medical Outcomes Study 36-Item Short Form Health Survey (SF-36) (Role-Physical, General Health Perceptions, Change in Health)
| Trial preceded by 1-week placebo run-in period
| Dates: August-November 1997
| | Exclusion criteria: Patients with individual symptoms rated as very severe; URI within 30 days of study; lack of response to antihistamines; clinically significant underlying medical disorder; receipt of immunotherapy; pregnancy; inability to read or understand English
| Location: US
| Setting: Community
| Type(s) of providers: NR | | | 3) Overall health impressions/generic quality of life: There were significant improvements in both fexofenadine groups as measured by the SF-36 Role-Physical domain compared to placebo. Significantly more patients treated with fexofenadine reported an improvement in health from baseline to Week 1 compared to placebo. However, there was not a significant difference between treatment groups from week 1 to week 2.
| | Age: Mean, 32–33
| | Sex: 64.6% female
| | Race: 88.2% Caucasian; 11.8% Other
| | Average no. of years since onset of seasonal AR: 17
Ray, Baraniuk, Thamer, et al., 1999 | Design: Cost of illness study based on data from 1994 National Hospital Discharge Survey, 1994 National Ambulatory Medical Care Survey, 1994 National Hospital Ambulatory Medical Care Survey, 1994 National Survey of Ambulatory Surgery, 1987 National Medical Expenditure Survey, and estimates gathered from 4 experts using a 3-round modified consensus Delphi procedure | No. of subjects at start: NR | 1) Total number of outpatient physician visits attributed to AR/AC in US | 1) Total number of outpatient physician visits attributed to AR/AC in US: 24,200,183 outpatient physician visits | Quality Scoring:
| | | | | Population similar: Yes
| | Dropouts/withdrawals: NA | | | Intervention(s) described: No
| | | | | Comorbidities described: Yes
| | No. of subjects at end: NR | 2) Total number of hospital outpatient visits attributed to AR/AC in US | | Diagnosis by MD: No
| | | | 2) Total number of hospital outpatient visits attributed to AR/AC in US: 1,410,779 hospital outpatient visits | Objectively confirmed: Not applicable
| | Inclusion criteria: All survey records with a primary diagnosis of AR or atopic conjunctivitis were attributed to AR/AC
| | | | | Outcome measures valid: No
| | | 3) Total number of emergency department visits attributed to AR/AC in US | | Level of evidence: 4
| | | | 3) Total number of emergency department visits attributed to AR/AC in US: 1,887,448 emergency department visits
| | Exclusion criteria: Federal, military, and Department of Veterans Affairs populations, plus residents of nursing homes and other institutions | | | Notes:
| | | | | This study may overestimate the cost of allergic rhinoconjunctivitis because the total cost of visits that have a primary diagnosis of 1 of 10 airway diseases were attributed to allergic rhinoconjunctivitis. It is also likely to overestimate the number of inpatient/outpatient/ER encounters because even though AR may be assumed to be a secondary diagnosis in many cases where another diagnosis is the primary, exacerbation or treatment of the principal diagnosis precipitated the medical encounter. For example, the majority of hospital costs were attributable to the assumption that 30% of those with asthma would have AR.
| | | 4) Total number of hospitalizations attributed to AR/AC in US
| | | | 4) Total number of hospitalizations attributed to AR/AC in US: 97,349 hospitalizations
| The study objective was to estimate direct medical costs associated with treatment of allergic rhinoconjuctivitis. The analysis was based on the assumption that AR is a predisposing factor for other airway disorders. The Delphi procedure was used to obtain estimates of the proportion of patients with specific airway disorders who would also be assumed to have allergic rhinoconjunctivitis (AR/AC).
| | Age: NR | 5) Total medical costs attributed to AR/AC in US Costs were estimated by the expert panel. These estimated costs were multiplied by the total number of encounters for each of 10 airway disorders (e.g. chronic otitis media, sinusitis, asthma) to estimate resource use attributable to AR/AC
| | | | 5) Total medical costs attributed to AR/AC in US: $5.93 billion ($1987), of which 31.4% was for treatment of AR/AC coded as the primary diagnosis, 25% for comorbid chronic otitis media or eustachian tube disorders, and 17% for comorbid sinusitis and 17% for comorbid asthma
| | Sex: NR
| | Race: NR
| Intervention(s): NA
| Duration of study treatment: NA
| Dates: 1994 data extrapolated to 1996 values
| Location: US
| Setting: All medical settings
| Type(s) of providers: All
Reilly, Tanner, and Meltzer, 1996 | Design: Validation study of the Allergy-specific Work Productivity and Activity Impairment (WPAI-AS) using data from 2 multicenter, double-blind, randomized, placebo-controlled trials | No. of subjects at start: 574 in the intent-to-treat dataset for Study 1, 422 completed WPAI-AS at baseline, week 1, and week 2; 962 in the intent-to-treat dataset for Study 2, 241 were students who completed Classroom WPAI-AS at baseline, week 1, and week 2 | 1) Discriminative validity: Correlations between time missed from work or classroom and total symptom score at baseline and weeks 1 and 2. | 1) Correlations were generally low: work: r = 0.11 to 0.16; classroom: r = 0.13 to 0.27 | Quality Scoring:
| | | | | Population similar: Yes
| | | | | Intervention(s) described: Yes
| | | | | Comorbidities described: No
| | | | | Diagnosis by MD: Yes
| | | | | Objectively confirmed: Yes
| | | | | Outcome measures valid: Yes
| | | 2) Discriminative validity: | 2) Correlations were higher than with time missed measures: work: r = 0.30 to r = 0.55; classroom: r = 0.25 to 0.41 | Level of evidence: 4
| Intervention(s): | | Correlations between impairment measures and total symptom score at baseline and weeks 1 and 2.
| 1) Terfenadine
| | Dropouts/withdrawals: NR | | | Note: The discriminative and evaluative validity of the WPAI-AS impairment measures (work impairment, overall work impairment, activity impairment, classroom impairment and overall classroom impairment) was established. Because absenteeism from work and school was relatively low (1.7% for work and 4.7% for classroom), establishing the validity of work time missed and classroom time missed was not possible.
| 2) Fexofenadine
| | No. of subjects at end: NR
| 3) Placebo
| | Inclusion criteria: Moderate to severe AR | 3) Discriminative validity: Results of regression analysis for total symptom scores on the prediction of work and activity impairment | 3) Higher total symptom scores were significant predictors of greater work and activity impairment, but not time missed from work at all time points.
| Duration of study treatment:
| | Exclusion criteria: Patients with asthma were NOT specifically excluded, but patients with severe asthma were not eligible because patients taking concomitant corticosteroids or cromolyn medications were excluded
| Dates: 1993 autumn allergy season for the work/activity impairment cohort (Study 1) and 1994 spring allergy season for the classroom impairment cohort (Study 2)
| | | 4) Discriminative validity: Results of regression analysis for total symptom scores on the prediction of classroom impairment | 4) Higher total symptom scores were significant predictors of classroom impairment at all time points. Higher total symptom scores were also predictive of more classroom time missed at weeks 1 and 2.
| Location: US | Age (mean): Study 1, 33; Study 2, 22.8
| Setting: Allergy clinic
| | Sex: Study 1, 63% female; Study 2, 51.5% female | 5) Evaluative validity: Correlation between average change in total symptom scores and change in time missed from work or classroom | 5) There was virtually no correlation (work: r = -0.06; classroom: r = 0.05 to 0.14).
| Type(s) of providers: NR
| | Race: Study 1, 84.8% Caucasian; Study 2, 84.2% Caucasian
| | Years of seasonal AR: Study 1, 17.5; Study 2, 12.6
| | | 6) Evaluative validity: Correlation between changes in total symptom scores and work and classroom impairment measures | 6) Correlations were positive (work: r = 0.35 to 0.42; classroom: r = 0.24 to 0.27)
| | | 7) Evaluative validity: Results of regression analysis for changes on total symptom score and changes in work and classroom impairment measures | 7) Average change in total symptom score was a significant predictor of all impairment measures except work or classroom time missed.
| | | 8) Responsiveness: changes in mean total symptom scores and WPAI-AS scores for the 5% of patients with the most improvement and the 5% of patients with the least improvement | 8) Among the 5% of patients with the most improvement, the level of work and classroom impairment decreased dramatically. Among the 5% of patients with the least improvement, the level of work and classroom impairment generally increased or stayed about the same.
| | | 9) Responsiveness: changes in total symptom scores and impairment measures for responders and nonresponders (as measured by physician evaluation) | 9) For responders in Study 1 and Study 2, total symptom scores and impairment measures decreased dramatically. For nonresponders in Study 1 and Study 2, symptom scores and impairment measures either decreased slightly or stayed about the same.
| | | 10) Sample size implications
| | | | 10) To detect a 5% difference in overall work impairment, 201 patients per treatment group would be necessary for 80% power and 5% Type 1 error for a 2-sided hypothesis test. To detect a 5% difference in overall classroom impairment, 192 patients per treatment group would be necessary.
Revicki, Leidy, Brennan-Diemer, et al., 1998 | Design: Cross-sectional surveys for instrument development | No. of subjects at start: 100 patients, of whom 20 were randomly selected to be retested at 2 weeks to evaluate test-retest reliability | 1) Average number of days over the previous month when the patient was in bed most or all of the day, had restricted activity for at least 1/2 day, and the number of days the patient missed school or work | 1) Average number of bed disability days: 0.63; restricted activity days: 2.49; and missed work days: 0.45. | Quality Scoring:
| | | | | Population similar: Yes
| | | | | Intervention(s) described: Not applicable
| The objective of the study was to design a preference-weighted instrument for rhinitis that could be used to construct rhinitis symptom-adjusted life years (distinct from quality-adjusted life years) in order to quantify outcomes of care for cost-effectiveness analyses. | | | | Comorbidities described: Yes
| | | | | Diagnosis by MD: Yes
| | Dropouts/withdrawals: NR | | | Objectively confirmed: Yes
| | | | | Outcome measures valid: Yes
| | No. of subjects at end: 100 | | | Level of evidence: 4
| | Inclusion criteria: Receiving care at the Johns Hopkins University Asthma and Allergy Center | 2) RSUI scores | 2) RSUI scores ranged from 0.15 to 1.0. Most scores were > 0.70. The mean was 0.72 (SD 0.23), the median score was 0.78.
| | Exclusion criteria: NR
| Intervention(s): NA
| | Age: Mean: 36.9 years | 3) Reproducibility of RSUI over 2 weeks. | 3) Intraclass correlation coefficient (ICC) was 0.40. (ICCs for RQLQ ranged from 0.17 to 0.77 due to instability of allergic rhinitis symptoms over time).
| Duration of study treatment: NA
| | Sex: 60% women
| Dates: NR | Race: 77% Caucasian; 15% African-American; 8% Asian or other ethnic group
| | | 4) Construct validity of the RSUI
| Location: Baltimore | | | 4) The RSUI was able to discriminate between levels of disease severity. The mean RSUI for none/mild allergic rhinitis was 0.79 and the mean RSUI for the moderate/severe group was 0.67 (p < 0.05). Mean RSUI scores were also higher for patients with HUI2 scores ≥ 0.75 (0.76) than patients with HUI2 scores 0.75 (0.57). Also, mean RSUI scores were higher for patients with no bed disability days (0.76) compared to patients with ≥ 1 bed disability day (0.62).
| Setting: Allergy clinic | Other:
| | Mean duration of illness: 21 years
| Type(s) of providers: NR | Mean age of onset: 16 years
| | Concurrent diagnosis of asthma: 52%
| | [underlined: Clinical and health-related measures:]
| | To evaluate concurrent and construct validities with the Rhinitis Symptom Utility Index (RSUI), 6 additional measures were used: (1) physician-reported disease severity; (2) disability days; (3) disease-specific quality of life using the RQLQ; (4) generic health utility using the Health Utilities Index Mark 2 (HUI2); (5) Visual Analog Scale (VAS); and (6) Standard Gamble (SG) Multiattribute utility assessment methods were used to derive the preference weighting scheme to estimate the RSUI score.
| | | 5) Correlations between the RSUI and total and subscale scores for the RQLQ.
| | | | 5) Correlation between the RSUI and total score was -0.67 (p = 0.0001). Correlation between the RSUI and each subscale was -0.47 for activity limitations, -0.58 for sleep, -0.51 for non-hay fever symptoms, -0.61 for eye symptoms, -0.69 for nasal symptoms, -0.49 for emotional symptoms, and - 0.61 for practical problems (p = 0.0001 for each).
Ross, 1996 | Design: Cost of illness study (indirect costs only) based on a synthesis of data from multiple sources: 1) 1983-1985 survey from US Department of Health and Human Services; 2) 1994 Statistical Abstract of the United States; and 3) 1989 Gallup Poll | No. of subjects at start: NA | 1) Prevalence estimate - no. of people with AR in US workforce | 1) 12.6 million | Quality Scoring:
| | | | | Population similar: Yes
| | Dropouts/withdrawals: NA | | | Intervention(s) described: No
| | | | | Comorbidities described: No
| | No. of subjects at end: NA | 2) Prevalence estimate - no. of people with AR classified into 1 of 11 employment categories for men and women | 2) 11.1 million | Diagnosis by MD: No
| | | | | Objectively confirmed: Not applicable
| | Inclusion criteria: Member of US work force
| | | | | Outcome measures valid: No
| | | | | Level of evidence: 3b
| | Exclusion criteria: NA
| | | 3) Lost productivity due to treatment of AR with sedating (OTC) antihistamines using Assumption #2 (see Notes) | 3) $3.79 billion ($2.39 billion for men and $1.40 billion for women)
| The study was designed to estimate the indirect costs associated with the use of first-generation, sedating antihistamines. | Age: NR | | | Notes:
| | | | | Assumptions used in cost calculations:
| | Sex: 51.6% men,
| | | | | 1) 5% growth in population during previous decade
| | Race: NR
| | | | | 2) Reduced productivity: 1989 Gallup poll: People with AR who used sedating (OTC) antihistamines reported a 25% reduction in productivity for 14 work days per year.
| Intervention(s): NA | | 4) Lost productivity if 10%, 20%, 30% of workers with AR lost 1 day of work per year due to AR | 4) 10%: $108 million; 20%: $216 million; 30%: $324 million
| Duration of study treatment: NA
| Dates: 1983-1986 prevalence estimates; 1993 wages | | | | 3) Proportion Treated with OTC antihistamines: 1989 Gallup poll: 50%
| Location: US
| Setting: Community
| Type(s) of providers: NR
Santilli, Nathan, Glassheim, et al., 2001 | Design: Survey | No. of subjects at start: 175 | 1) Rhinitis Outcomes Questionnaire (ROQ) consisting of 26 symptom questions each scored using a 0 to 5 Likert scale. A total score of 130 is possible, representing the most severe combination of allergy symptoms. | 1) Prior to immunotherapy, the average score on the ROQ was 52. The average score decreased to 25 following immunotherapy. | Quality Scoring:
| | | | | Population similar: Not adequately described
| Intervention(s): NA | Dropouts/withdrawals: 0
| | | | | Intervention(s) described: No
| Duration of study treatment: NA | No. of subjects at end: 175 | | | Comorbidities described: No
| | | | | Diagnosis by MD: Yes
| | Inclusion criteria: Immunotherapy for one allergen or a combination of pollens, molds, mites and animal dander for at least 1 year | | | Objectively confirmed: Yes
| Dates: NR | | | | Outcome measures valid: Yes
| | | | | Level of evidence: 4
| Location: Bridgeport, CT; Colorado Springs, CO; Fresno, CA
| | | 2) Percent of patients reporting that immunotherapy was effective | 2) 81% reported that they believed immunotherapy was effective, and 19% of patients were unsure.
| | Exclusion criteria: NR | | | Note: Patients who discontinued immunotherapy prior to 1 year were not included in the study. Also, the study is limited by recall bias, as patients completed the survey twice at one sitting (once to recall symptoms prior to immunotherapy and once to evaluate current symptoms). The absolute numbers of patients reporting antibiotic use, ER visits, lost work/school days, or hospital admission were not reported, and no statistical tests were used for comparisons.
| Setting: Private allergy practices | Age: NR
| | Sex: 68% female | 3) Change in antibiotic use, emergency room visits, days lost from work or school, and hospital admissions | 3) Patients reported a 67% decrease in antibiotic use, 68% decrease in emergency room visits, a 75% decrease in days lost from work or school, and a 79% decrease in hospital admissions.
| Type(s) of providers: Specialists
| | Race: NR
| | Other: Average duration of immunotherapy 3.3 years
| | | 4) Change in number of daily medications | 4) Patients did not report a decrease in the number of daily medications after immunotherapy.
Santos, Cifaldi, Gregory, et al., 1999 | Design: Retrospective analysis based on HMO claims data | No. of subjects at start: 15,872 (7936 allergic rhinitis patients + 7936 age- and sex-matched non-allergic rhinitis controls) | 1) Total cost to the HMO for medical care provided to the AR group and the matched control group in 1996 | 1) AR group: $5.38 million; matched control group: $3.46 million | Quality Scoring:
| | | | | Population similar: Yes
| | | | | Intervention(s) described: No
| | | | | Comorbidities described: No
| Intervention(s): | | | | Diagnosis by MD: No
Study 1 ( = retro-spective review of annual medical costs of treating allergic rhinitis) | None - billing encounter data analyzed to compute utilization of HMO system resources (specifically, service encounters and prescriptions) over a 1-year period for selected cohorts of patients with and without allergic rhinitis | Dropouts/withdrawals: NA | | | Objectively confirmed: Not applicable
| | | 2) Cost of prescription medication to HMO for AR group and matched control group in 1996 | 2) [underlined: All medication:]
| | No. of subjects at end: 15,872 | | AR group: $2.06 million; matched control group: $1.05 million. | Outcome measures valid: No
| | | | | Level of evidence: 4
| | Inclusion criteria: Age 12–64; HMO member in 1996 with continuous enrollment from 1994 to 1995; evidence of allergies based on one of the following: a visit for an allergen skin test, an ICD-9-CM code of allergic rhinitis, or a prescription for an allergy medication during the spring or fall allergy seasons | | [underlined: AR medication only:]
| | | | AR group: $1.08 million; matched control group: $0.22 million
| | | | | Notes:
| | | | [underlined: AR medication as a % of total Rx cost] | Assumptions used in cost estimation:
| | | | AR group: 53%, matched control group: 21%
| | | | | 1) Relative value units (RVUs) were used to estimate costs for the HMO ($38.82/RVU in 1996 US$).
| Duration of study treatment: NA
| | | 3) Among the AR group, costs and distribution of prescriptions for allergic rhinitis | 3) [underlined: Antibiotics:] 34.6% of AR prescriptions, 12.9% of total medication costs; [underlined: Oral Steroids]: 4.7% of AR prescriptions, 0.3% of total medication costs; [underlined: Antihistamines]: 29.4% of AR prescriptions; 21.8% of total medication costs; [underlined: Nasal Anti-inflammatory]: 27.2% of AR prescriptions; 16.5% of total medication costs; [underlined: Combination/cold]: 4.0% of AR prescriptions, 1.1% of total medication costs.
| Dates: 1996 | | | | 2) Prescription drug prices based on October 1997 AWP plus dispensing fee
| Location: New Mexico | Exclusion criteria: NR
| Setting: Community, network model HMO | Age: mean: ~41 years
| | Sex: 58% women
| Type(s) of providers: NR
| | Race: NR
| | | 4) Average AR prescription costs per person with AR | 4) [underlined: All AR medications]: $190.70; [underlined: Antibiotics]: $68.49; [underlined: Oral Steroids]: $10.06; [underlined: Antihistamines]: $187.00; [underlined: Nasal Anti-inflammatory]: $125.30; [underlined: Combination/cold]: $42.71
| | | 5) Percent of AR population who filled at least one prescription. | 5) 72%
Santos, Cifaldi, Gregory, et al., 1999 | Design: RCT, parallel-group, method of randomization not described | No. of subjects at start: 502 | 1) Direct medical costs: | 1) Direct medical costs: | Quality Scoring:
| | | included service encounters, prescriptions, and OTC medications (recorded by patients in daily symptom diaries) | Total direct medical costs: | Population similar: Not adequately described
| | Dropouts/withdrawals: NR | | Intervention group: $56,515;
| | | | Control group: $58,402 | Intervention(s) described: No
| Intervention(s): | No. of subjects at end: | | | Comorbidities described: No
Study 2 ( = prospective RCT comparing two types of clinics for treating patients with allergic rhinitis) | 1) Intervention clinics - used practice guidelines designed to improved and standardize treatment of patients with allergic rhinitis; interventions/ practice guidelines used not described (n = 247 patients) | | | Direct medical costs per person: | Diagnosis by MD: Yes
| | Inclusion criteria: Age 12–65; | | Intervention group: $229; | Objectively confirmed: Yes
| | HMO members for ≥ 12 months prior to start of intervention; present evidence of fall allergies involving nasal symptoms | 2) Indirect costs: | Control group: $229 | Outcome measures valid: No
| | | Estimated by measuring declines in work and school productivity using the Work Productivity and Activity Impairment Index - Allergy Specific (WPAI-AS) | | Level of evidence: 4
| | | | 2) Indirect costs (productivity/activity impairment):
| | | | Total indirect costs: | Notes:
| | Exclusion criteria: NR | | Intervention group: $16,561; | Results of statistical comparisons were not reported to compare differences in costs or patient outcomes.
| 2) Control clinics - did not alter diagnostic and treatment practices (n = 255 patients) | | | Control group: $21,372
| | Age: NR
| | | | Indirect costs per person:
| | Sex: NR | 3) Patient-assessed symptom severity: stuffy nose, sneezing, runny nose, itchy nose/palate/ throat, and itchy/watery eyes graded daily on scale of 0 (no symptoms) to 4 (physician visit needed); these data supplemented (how?) by data gathered in enrollment survey and periodic phone surveys | Intervention group: $67;
| Duration of study treatment: 4 weeks | | | Control group: $84 | Not relevant to key question about correlating symptom outcomes/disease-specific quality of life with workplace performance data - estimates of statistical variation (SD or SE) are not reported, nor are the results of statistical comparisons
| | Race: NR
| | | | 3) Patient-assessed symptom severity:
| Dates: 1996 fall allergy season | | | Intervention group vs. control group:
| | | | Stuffy nose: 1.60 vs 1.55; Sneezing: 1.02 vs 0.97; Runny Nose: 1.15 vs 1.10; Itchy Nose/Palate/Throat: 1.16 vs 1.02; Itchy/Watery Eyes: 1.27 vs 1.09
| Location: New Mexico
| Setting: Community, network model HMO
| | | | 4) Average behavior index score:
| Type(s) of providers: NR | | | Intervention group: 4.60;
| | | 4) Behavior index - measured compliance with suggested preventive behavior (medical compliance, avoiding smoke, wearing a dust mask, etc.); scores ranged from 0 (no action) to 11 (maximum); not clear when assessed | Control group: 4.30
| | | | 5) Quality of life measured using the RQLQ Index:
| | | | Intervention Group: 2.9;
| | | | Control group: 2.4
| | | 5) Quality of life:
| | | assessed using an index “based on items from the Rhinoconjunctivitis Quality of Life Questionnaire (RQLQ)”; scores ranged from 0 to 10, with higher scores indicating lower quality of life
Schädlich and Brecht, 2000 | Design: Cost-effectiveness analysis using a model based on secondary data. Separate models were developed for seasonal and perennial allergic rhinitis. | No. of subjects at start: NA | 1) Break-even point of accumulated costs and cost difference at 10 years between SIT and pharmacologic treatment | 1) In the base-case analysis, cumulative costs in both arms were equal during year 7. At 10 years, cumulative costs in the SIT arm were approximately DM670 (DM; DM 1 = $US 0.5764, 1997 values) lower in the SIT group. | Quality Scoring:
| | | | | Population similar: Yes
| | Dropouts/withdrawals: NA | | | Intervention(s) described: No
| | | | | Comorbidities described: Yes
| | No. of subjects at end: NA | | | Diagnosis by MD: Yes
| | | | | Objectively confirmed: No
| | Inclusion criteria: NA | | | Outcome measures valid: No
| Intervention(s): | | | | Level of evidence: 1b
| Specific immunotherapy (SIT) for 3 years versus pharmacologic treatment | Exclusion criteria: NA | 2) Incremental number of patients free from asthma due to SIT | 2) Out of 1000 hypothetical patients, the model showed that 161 additional patients were free from asthma symptoms at 10 years.
| | Age: NR | | | Note: 100% compliance with immunotherapy was assumed, the measure of effectiveness modeled was the additional patient free of asthma symptoms based on cumulative incidence and remission rates from different published sources for SIT and symptomatic treatment.
| Duration of study treatment: Model was based on a 10-year follow-up period | Sex: NR
| | | 3) Cost per additional patient free from asthma symptoms at 10 years | 3) In the best case scenario for pollen allergy, the break even point for costs was reached at 1 year, resulting in a cost savings of DM 3,620 at 10 years with 212 additional patients free from asthma. In the worst case scenario, the break even point was never reached, resulting in additional costs in the SIT arm of DM 1,420 at 10 years with 88 additional patients free from asthma.
| | Race: NR
| Dates: NA | [underlined: Cost-Effectiveness Model:]
| | [underlined: Time period:] model was based on a 10-year period.
| Location: Germany
| | [underlined: Health Outcome]: the presence or absence of asthma symptoms at 10 years. Clinical trial, observational, and epidemiological data were used to model the health outcome.
| Setting: NA
| Type(s) of providers: NA
| | [underlined: Costs:] Costs in the model were valued from 3 perspectives: society, the healthcare system, and the statutory health insurance provider (SHI). Cost estimates were derived from a variety of sources including public pharmacies for the cost of drugs and allergen extracts, government payment schedules, and published estimates. Costs were discounted at 5% per annum. | 4) Results of sensitivity analyses | 4) Sensitivity analyses:
| | | | The following variables had an important effect on cost-effectiveness:
| | | | a) Direct medical cost of anti-allergic pharmacotherapy (symptomatic treatment);
| | | | b) Cost of SIT;
| | | | c) Increase in asthma prevalence with symptomatic treatment of allergic rhinitis.
Stahl, van Rompay, Wang, et al., 2000 | Design: Retrospective cost-minimization analysis based on data from a randomized, double-blind, parallel group study | No. of subjects at start: 314 | 1) Cost of study drugs for 12 months in 1998 | 1) Budesonide: $95.80; fluticasone: | Quality Scoring:
| | | | $214.01; difference = $118.21 | Population similar: Not adequately similar
| | Dropouts/withdrawals: NR | Canadian dollars
| | | | | Intervention(s) described: Yes
| | No. of subjects at end: NR | 2) Cost of medical management (physician visits, comedication, laboratory tests/ examinations) of perennial AR for 12 months in 1998 Canadian dollars based on expert opinion | 2) Physician visits: $114.23; laboratory tests/examinations: $48.23; co-medications: $38.96; total = $201.41 | Comorbidities described: No
| | | | | Diagnosis by MD: Yes
| Intervention(s): | Inclusion criteria: Perennial allergic rhinitis | | | Objectively confirmed: No
| 1) Budesonide 256μg once daily | | | | Outcome measures valid: No
| | | | | Level of evidence: 4
| | Exclusion criteria: None specified
| 2) Fluticasone 200 μg once daily
| | Age: NR | | | Notes:
| | | | | The clinical data used in the study included all patients from Canada and Spain. However, the cost-minimization analysis was conducted using practice patterns (from an expert panel) and costs from Canada. Drug costs for study medications determined the results.
| | Sex: NR
| 3) Placebo | | 3) Cost of medical management due to lack of efficacy and side effects over 12 months in 1998 Canadian dollars | 3) Lack of efficacy: $75.18; side effects: $17.46
| | Race: NR
| Duration of study treatment: 6 weeks
| Dates: November 1994 to July 1995
| | | 4) Treatment cost for both active treatment study arms (placebo was not considered a relevant comparator and was not included in the cost minimization analysis) | 4) Because effectiveness and side effect profiles for both medications were not different, the difference in costs is attributable to the difference in drug costs. The total 12-month cost for budesonide was estimated at $389.85 and the total 12-month cost for fluticasone was estimated at $508.06. Difference = $118.21.
| Location: Canada and Spain
| Setting: Allergy clinic
| Type(s) of providers: NR
Storms, Meltzer, Nathan, et al., 1997 | Design: Population-based mail surveys | No. of subjects at start: Surveys initially sent to 15,000 households; 66.3% responded; a sample of 1450 persons were sent a 2nd survey to gather further information about AR; 73.4% responded | 1) Proportion who reported not taking medications for AR, proportion filling a prescription for AR, proportion reporting an average monthly expenditure for OTC medications for AR | 1) No medication: 13.5%; prescription medication: 45%; OTC medication: 69%. | Quality Scoring:
| | | | | Population similar: Yes
| | | | | Intervention(s) described: No
| Intervention(s): NA | | | | Comorbidities described: No
| | | | | Diagnosis by MD: No
| Duration of study treatment: NA | | | | Objectively confirmed Not applicable
| | | | | Outcome measures valid: No
| Dates: 1993 | Dropouts/withdrawals: NA | | | Level of evidence: 4
| Location: US | No. of subjects at end: 481 respondents | 2) Proportion reporting any missed work or school days or unable to perform normal activities | 2) 5%
| | | | | Notes:
| Setting: Community | | | | It is not clear whether self-reported “expenses” represent total costs or out-of-pocket expenditures.
| | Inclusion criteria: Self-reported seasonal or perennial AR and ≥ 7 days of symptoms during previous year
| Type(s) of providers: NR
| | | 3) Proportion who sought treatment from a physician for AR symptoms | 3) 63% (22.6 million people)
| | | | | Assumptions used in cost calculations:
| | Exclusion criteria: Respondents who selected one of the following options as best describing their nasal/ocular symptoms that lasted ≥ 7 days during previous year: common cold, an allergy only when exposed to certain triggers, sinus problems, or other condition
| | | 4) Average per-patient expenditure on prescription and OTC medications for AR | 4) Prescription: $56 ($1993); OTC: $56 ($1993) | 1) Cost of office visit: $50. Assumed that physician visits did not include any diagnostic tests.
| | | | | 2) Self-reported expenses equal to direct medical costs.
| | | 5) Total US expenditures for prescription and OTC medications for AR | 5) Prescription: $907 million ($1993); OTC: $1.39 billion ($1993); Total: $2.3 billion
| | Age: 11.9% < 18; 20.6% 18–34; 33.5% 35–49; 19.1% 50–64; 10.8% ≥ 65
| | | 6) Total US expenditures for physician visits for AR | 6) $1.13 billion ($1993)
| | Sex: 56% female | 7) Total direct medical costs for AR | 7) $3.4 billion ($1993)
| | Race: 93% white
Sussman, Mason, Compton, et al., 1999 | Design: RCT, parallel-group, method of randomization not described | No. of subjects at start: 710 were screened for study; 651 randomized and treated with study drug(s) | 1) Patient-assessed symptom severity: sneezing; rhinorrhea; itchy nose, palate, and/or throat; itchy, watery, or red eyes; and nasal congestion graded twice each day (7 PM and bedtime) on scale of 0 (symptom absent) to 4 (symptom so severe as to warrant an immediate visit to the physician). | 1) Patient-assessed symptom severity: When using the efficacy endpoint used to evaluate all symptoms except nasal congestion, symptoms were improved to a greater extent with combination therapy than with pseudoephedrine alone, but not when compared with fexofenadine alone. When using the efficacy endpoint to evaluate nasal congestion symptoms, again, there was a significant improvement in the combination therapy arm compared to pseudoephedrine, but not compared to fexofenadine alone. | Quality Scoring:
| | | | | Population similar: Yes
| | | | | Intervention(s) described: Yes
| | | | | Comorbidities described: No
| Interventions: | | | | Diagnosis by MD: Yes
| 1) Fexofenadine 60 mg + pseudoephedrine 120 mg (extended-release), twice per day (n = 215) | Dropouts/withdrawals: 9.7% discontinued the study; 2.8% due to adverse events; 3.8% due to subject/investigator decision. | | | Objectively confirmed: Yes
| | | | | Outcome measures valid: Yes
| | | | | Level of evidence: 4
| 2) Fexofenadine 60 mg twice per day (n = 218) | No. of subjects at end: 651 included in intent-to-treat analysis | | | Note: Double-dummy blinding technique employed.
| 3) Pseudoephedrine 120 mg (extended-release) twice per day (n = 218) | Inclusion criteria: Age 12–65; history of ragweed allergy confirmed by a positive skin prick test; evidence of a clinical response to antihistamines. At the initial visit, subjects had to have a total symptom score ≥ 6 for the previous 12 hours, with nasal congestion and ≥ 2 symptoms rated as moderate or severe. After the placebo lead-in phase, subjects had to have a total symptom score ≥ 6, moderate or severe nasal congestion, and at least 2 symptoms rated as moderate or severe for 2 of the 3 most recent evening assessments.
| | | 2) Adverse events:
| | | Patients “were required to record any adverse events” | 2) Adverse events: 43% of patients experienced ≥ 1 adverse event. There was no difference between the combination (51.2%) and pseudoephedrine only (45.4%) groups. However, the incidence of adverse events was significantly lower in the fexofenadine group (32.6%). The most frequently reported events were headache and insomnia.
| Duration of study treatment: 14–20 days
| | | 3) Work-related productivity: Assessed using the Work Productivity Activities Index (WPAI), completed at baseline and at end of treatment
| Rescue med not permitted
| Trial preceded by a 3- to 5-day placebo run-in period; no other washout period described
| | | | 3) Work-related productivity: At baseline, all patients reported an average of 44% impairment in daily activities. Working patients reported a 1.8% loss in work time, 38.7% work impairment, and 39.3% overall work impairment during the placebo lead-in phase. After treatment, daily activity impairment decreased by 9.8% in the fexofenadine group, 7.9% in the pseudoephedrine group, and 13% in the combination therapy group. Among working patients, there was a significant improvement in work productivity in the combination group (9.3%) compared to the pseudoephedrine group (6.2%). There was no improvement between the combination and fexofenadine group (8.1%). Overall work productivity in the combination (8.5%) and the fexofenadine (8.0%) groups increased compared to the pseudoephedrine group (4.9%).
| Dates: NR
| Location: Canada
| Setting: Allergy clinic
| | Exclusion criteria: History of alcoholism or drug abuse; hypersensitivity to terfenadine, fexofenadine, or pseudoephedrine; URI or sinusitis within 30 days of 1st study visit; pregnant or lactating women; any symptoms rated as very severe
| Type(s) of providers: NR
| | Age: Mean ~33 years
| | Sex: 57.8% female
| | Race: White: 86.9%; Black: 5.4%; Asian: 6.4%; Multiracial: 1.2%
| | Other:
| | Average years since first episode of seasonal AR: ~15.3 years.
Tanner, Reilly, Meltzer, et al., 1999 | Design: Results of 2 RCTs pooled, both parallel-group, method of randomization not described | No. of subjects at start: 1957 randomized; 1948 had baseline and at least one other QOL assessment; 776 of these assigned to analyzed interventions (fexofenadine 60 mg bid and placebo) | 1) Disease-specific quality of life: assessed using the Rhinoconjunctivities Quality of Life Questionnaire (RQLQ) at baseline and at 1 and 2 weeks | 1) Disease-specific quality of life: Average overall RQLQ score at baseline: 2.7; linear regression revealed significantly lower mean RQLQ scores at weeks 1 and 2 in the fexofenadine group compared to the placebo group. At week 1, patients randomized to fexofenadine had significant reductions in all RQLQ domains except sleep. By week 2, a significant reduction remained in the following domains only: activity, practical problems and nasal symptom scores. | Quality Scoring:
| | | | | Population similar: Yes
| | | | | Intervention(s) described: Yes
| | | | | Comorbidities described: No
| | | | | Diagnosis by MD: Yes
| Intervention(s): | | | | Objectively confirmed: Yes
| 1) Fexofenadine 60 mg bid (n = 389) | | | | Outcome measures valid: Yes
| | | | | Level of evidence: 4
| | Dropouts/withdrawals: | 2) Performance impairment (at work and in classroom) due to allergy symptoms: assessed using the Allergy-Specific Work Productivity and Activity Impairment Questionnaire (WPAI-AS) at baseline and at 1 and 2 weeks
| 2) Placebo (n = 387)
| | No. of subjects at end: 1948 | | | Notes:
| 3) (See Notes) | | | | Unspecified range of fexofenadine doses tested in original trials; present analysis considers 60-mg bid dose vs. placebo.
| | Inclusion criteria: Diagnosis of moderate to severe seasonal allergic rhinitis based on a positive skin prick test within previous 15 months;≥ 2 of the following symptoms rated as moderate or severe by the investigator: sneezing, rhinorrhea, itchy nose, palate and/or throat; or itchy, watery eyes; history of positive response to previous antihistamine use
| Duration of study treatment: 2 weeks
| | | | 2) Performance impairment due to allergy symptoms: Patients taking fexofenadine had significant reductions in the percentage of daily activity impairment at weeks 1 and 2. By week 2, patients taking fexofenadine had greater reductions in the percentage of overall work impairment. At baseline, only approximately 3% of usual work time was missed due to allergy symptoms. There was not a significant difference in the percent of usual work time missed between treatment groups at Week 1 or Week 2. Reductions in classroom time missed, classroom impairment or overall impairment in the classroom were significantly lower in the fexofenadine group at Week 1, but there was no difference at Week 2.
| Use of meds with antihista-mine or decongestant activity, corticosteroids, and immunotherapy in changing doses prohibited during trial
| | | | | No separate publications referenced for 2 RCTs here pooled.
| | | 3) Generic quality of life: measured using 3 generic domains of the Medical Outcomes Study 36-Item Short Form Health Survey (SF-36) (Role-Physical, General Health Perceptions, Change in Health)
| No run-in/washout period described; patient using meds with antihistamine or decongestant activity within 48 hours, corticosteroids within 30 days, or immunotherapy in changing doses within 60 days excluded
| | Exclusion criteria: Symptoms rated as very severe; pregnant or lactating women; significant hepatic, neurologic, endocrine, or major systemic disease
| Dates: Spring 1994 | Age (mean): Study 1, 32 (range, 11–65); Study 2, 33 (range, 12–68)
| Location: US
| | Sex: Study 1, 58% femal; Study
| Setting: 32 centers throughout the US | 2, 55% female | | 3) Generic quality of life: No significant differences on the generic QOL measures were detected between treatment groups at any time point.
| | Race: Study 1, 85% Caucasian, 15% Other; Study 2, 80% Caucasian, 20% Other
| Type(s) of providers: NR
| | Average number of years of seasonal allergic rhinitis: Study 1, 16; Study 2, 17
Trotter, 2000 | Design: Retrospective analysis of prescription claims | No. of subjects at start: Prescription records from > 60 million people | 1) Average number of prescriptions received annually | 1) Average number of prescriptions received annually: | Quality Scoring:
| | | | | Population similar: Not adequately described
| | | | Azelastine 2.2
| Intervention(s): NA | | | Beclomethasone 2.4 | Intervention(s) described: No
| | Dropouts/withdrawals: NA | 2) Total prescription costs for AR drugs for patients initiating therapy with various AR medications | Cetirizine 2.5 | Comorbidities described: No
| Duration of study treatment: NA | | | Fluticasone 2.6 | Diagnosis by MD: Yes
| | No. of subjects at end: 121,524 patients met inclusion criteria | | Loratadine NR | Objectively confirmed: No
| | | | Fexofenadine 2.7 | Outcome measures valid: No
| Dates: April 1997 - April 1998 | | | | Level of evidence: 2b
| | Inclusion criteria: Claim for initial prescription for = 1 of the following medications: azelastine, fexofenadine, loratadine, fluticasone, beclomethasone, or cetirizine. Initiating therapy was defined as the absence of a prior prescription claim for the AR medications or other medications, including antihistamines, nasal steroids, and medications for cough/cold. Patients had to be eligible for prescription plan benefits for the full study year. | 3) Percentage of patients receiving monotherapy with each medication | 2) Total prescription costs for AR drugs for patients initiating therapy with various AR medications:
| Location: US
| | | | | Notes:
| Setting: Outpatient | | | Azelastine $111 | The study aim was to estimate the total cost of treatment for patients initiating treatment with selected medications.
| | | | Beclomethasone $118–$129
| Type(s) of providers: NR | | | Cetirizine $134
| | | | Fluticasone $137
| | | | Loratadine $171
| | | | Fexofenadine $222 | Assumption used in cost estimation: Unit size (e.g., no of tablets, inhalations) of each prescription was combined with average wholesale price to estimate medication costs.
| | | | 3) Percentage of patients receiving monotherapy with each medication:
| | | | Azelastine 46.6%
| | | | Beclomethasone 43.3%
| | | | Cetirizine 46.2%
| | Exclusion criteria: NR | | Fluticasone 38.1% | It is not clear whether 12 months of data were available beyond the date on which the initial AR medication was filled because the claims used in the analysis covered only a 13-month period. Therefore, patients who filled their first AR medication 6 months into the study period may have had data available for only 7 months, not 1 year.
| | | | Loratadine 40.3%
| | Age: NR | | Fexofenadine 38.9%
| | Sex: NR
| | Race: NR
Yawn, Yunginger, Wollan, et al., 1999 | Design: Analysis of population-based registry of patients with asthma | No. of subjects at start: Random sample of 1245 patients with asthma | 1) Proportion of asthma patients diagnosed with AR | 1) 52.4% with concomitant AR | Quality Scoring:
| | | | | Population similar: Yes
| | | | | Intervention(s) described: ??
| | | | | Comorbidities described: Yes
| The study was designed to estimate the prevalence and incremental medical care charges (not including medications) of AR among patients with asthma. | Dropouts/withdrawals: Patients > 65 years were excluded from analysis | 2) Tri-mean (dollars/year) for patients with asthma only (total medical care charges not including medications) | 2) $249.89 ($1987) | Diagnosis by MD: Yes
| | | | | Objectively confirmed: No
| | | | | Outcome measures valid: No
| | | | | Level of evidence: 1b
| | No. of subjects at end: Analysis of charge data was based on 1065 patients; analysis of clinical data was based on 1245 patients
| | | 3) Tri-mean (dollars/year) for patients with asthma and AR (total medical care charges not including medications) | 3) $335.82 ($1987) | Notes:
| Intervention(s): NA | | | | Annual medical charges were computed for each patient and adjusted to 1987 dollars using the Medical Consumer Price Index. Charges did not include charges for medication.
| Duration of study treatment: NA | Inclusion criteria: Diagnosed with “definite asthma” based on patient history or clinical findings
| Dates: Charge data, 1987-1996 | | 4) Tri-mean (dollars/year) for patients with asthma only (total medical care charges not including medications), stratified by gender | 4) $160.26 for men ($1987)
| | Exclusion criteria: Bullous emphysema or pulmonary fibroses on chest radiograph; PiZZ α1-antitrypsin; cystic fibrosis; other major chest disease | | $392.18 for women ($1987)
| | | | | The ‘tri-mean’ is computed as the mean of the 1^st^ quartile (Q_1_), 2 times the median (Q_2_), and the 3^rd^ quartile (Q_3_): (tri-mean = (Q_1_+2Q_2_+Q_3_)/4).
| Location: Olmstead County, Minnesota
| Setting: Community
| | Age: Mean, 31 (in 1987); median, 24 | 5) Tri-mean (dollars/year) for patients with asthma and AR (total medical care charges not including medications), stratified by gender | 5) $226.93 for men ($1987)
| Type(s) of providers: NA | | | $543.96 for women ($1987)
| | Sex: 53% male
| | Race: NR

† Quality scoring criteria were as follows:

Population similar: Was the study population described and reasonably similar to an adult working US population? (Yes [described and similar], No [described, but not similar], Not adequately described)

Intervention(s) described: Were the intervention protocols referenced or described in sufficient detail to replicate? (Yes, No)

Comorbidities described: Was the presence of comorbid asthma (or other upper respiratory conditions) described in the study population? (Yes, No)

Diagnosis by MD: Was the diagnosis of allergic rhinitis based on physician diagnosis? (Yes, No, Not applicable [asthma patients only])

Objectively confirmed: If physician-diagnosed, was the diagnosis supported by objective evidence of allergy (e.g., skin prick or serum IgE antibody testing)? (Yes, No, Not applicable)

Outcome measures valid: Were the main outcomes of interest to us measured in a way that has been demonstrated empirically to be valid and reliable (e.g., using a standardized scale such the RQLQ or SF-36)? (Yes, No, Not adequately described)

Level of evidence: Based on Oxford Center for Evidence-Based Medicine Levels of Evidence (1a, 1b, 1c, 2a, 2b, 2c, 3a, 3b, 4, 5)

Evidence Table 2. Environmental Measures

Study | Design and Interventions | Patient Population | Outcomes Reported | Results | Quality Score^†^/Notes
Antonicelli, Bilò, Pucci, et al., 1991 | Design: RCT, crossover | No. of subjects at start: 9 | 1) Allergen levels: dust collected monthly from bedroom floor on day after usual room cleaning | 1) Allergen levels: | Quality Scoring:
| | | | Results reported graphically; no significant differences between groups in floor samples. | Population similar: No
| Interventions: | Dropouts/withdrawals: 0 | | | Intervention(s) described: Yes
| 1) HEPA filter (Enviracaire^®^) + routine house cleaning. HEPA filter device placed in bedroom and used 24 hours/day for 8 weeks. | | | | Comorbidities described: Yes
| | No. of subjects at end: 9 | | | Diagnosis by MD: Yes
| | | 2) Patient-assessed symptom severity: rhinitis, cough, and dyspnea graded daily on scale of 0 (asymptomatic) to 3 (maximum symptoms) | 2) Patient-assessed symptom severity: | Objectively confirmed: Yes
| | Inclusion criteria: Rhinitis and mild asthma; dust mite sensitivity by skin test | | Results reported graphically; significant period effect on rhinitis symptoms but no intervention effect. No significant effects on cough, wheezing. | Outcome measures valid: No
| | | | | Level of evidence: 2b
| | | | | Randomized: Yes
| 2) Routine house cleaning alone. | | | | Allocation concealed: Not described
| | Exclusion criteria: Long-term corticosteroid therapy, immunotherapy
| | | | 3) Use of symptomatic medication: | Double-blind: No
| Duration of study treatment: | | 3) Use of symptomatic medication (terfenadine tablets, salbutamol inhalations): recorded daily in study diaries | Results reported graphically; no significant effect. | Blinding adequate: Not applicable
| 8 weeks each treatment period; no washout between periods
| | Age: 16 (range 10–28) | | | Dropouts described: Yes
| | | | 4) Spirometry: Not abstracted | Intention-to-treat: Yes
| | Sex: 7 male; 3 female (misreported?)
| Dates: 10/1988-2/1989
| | | 4) Spirometry (morning and evening peak flow rates, FEV1, and bronchial reactivity [metacholine challenge test]) | | Note:
| Location: Italy | Race: NR | | | No assessment of carry-over effect, period effect, or treatment-by-period interaction.
| Setting: NR | Other:
| Type(s) of providers: NR | | | | Statistical power not addressed.
Bahir, Goldberg, Mekori, et al., 1997 | Design: RCT, parallel-group | No. of subjects at start: 62 | 1) Allergen levels: dust collected by vacuum and analyzed by investigators; allergenicity of dust graded on scale of 0 (none) to 4 (strong) | 1) Allergen levels: | Quality Scoring:
| | | | Baseline and f/u; p = ns | Population similar: No
| Interventions: | Dropouts/withdrawals: 16 | | Gp1: 3.6 ± 0.7; 3.3 ± 0.9 | Intervention(s) described: Yes
| 1) Acaricide (Acardust^®^ = esdepallethin 0.9% and piperonyl butoxide 7.2%) + continuous avoidance measures (n = 13). Acaricide applied twice to mattress and floors (at start of study and at 3 months); avoidance measures described below. | | | Gp2: 3.3 ± 0.6; 2.9 ± 0.8 | Comorbidities described: Yes
| | No. of subjects at end: 46 | | Gp3: 3.5 ± 0.6; 2.7 ± 0.8 | Diagnosis by MD: Not applicable
| | Inclusion criteria: Mild to moderate asthma by ATS criteria; duration ≥ 1 year; reversible airway disease document by FEV1 or PEF | | 2) Spirometry: Not abstracted | Objectively confirmed: Not applicable
| | | 2) Spirometry (FEV1, peak flow rates)
| | | | 3) Patient-assessed symptom severity: | Outcome measures valid: No
| | | | Reported graphically; p = ns | Level of evidence: 1b
| | | 3) Patient-assessed symptom severity: quality of sleep, dyspnea, wheezing, cough, sputum, rhinitis, and sneezing graded daily on scale of 0–12 | | Randomized: Yes
| | | | 4) Use of β_2_-agonists and concurrent medication: | Allocation concealed: Not described
| | Exclusion criteria: Respiratory tract infection, steroid use, or sodium cromoglycate within past month; immunotherapy or hospitalization for asthma in past 6 months
| 2) Placebo acaricide (applied to mattress and floor at start of study and at 3 months) + continuous avoidance measures (described below) (n = 17) | | | Reported graphically; p = ns | Double-blind: Yes
| | | | | Blinding adequate: Yes
| | | | 5) Parents' global assessment of severity of asthma at end of study compared to beginning; p = ns | Dropouts described: Yes
| | | | | Intention-to-treat: No
| | | 4) Use of β_2_-agonists and concurrent medication (topical steroids, cromoglycate): recorded by patients daily | Gp 1: 7 better; 6 same; 0 worse
| | Age: Range, 6–16.5 | | Gp 2: 9 better; 8 same; 0 worse | Note: Power: 80% power to detect a 0.75 difference in house dust mite antigen.
| 3) Continuous avoidance measures only (described below) (n = 16) | | | Gp 3: 6 better; 9 same; 1 worse
| | Sex: NR
| | Race: NR
| Avoidance measures (all 3 groups): | | 5) Parents' global assessment of severity of asthma at end of study compared to beginning (same, better, worse)
| | Other:
| Start of trial: Change bed-clothes, mattresses, rugs, curtains, upholstered furniture, toys, etc. Every object prone to accumulate dust to be removed. Pillows or blankets made of goose, feather, or wool forbidden. Synthetic pillows and blankets only.
| Daily: wash floors and dust furniture with damp cloth; shake bedclothes outside bedroom and leave on window sill
| Weekly: vacuum mattresses on both sides; thoroughly clean shelves, pictures, furniture, walls, drawers, and cupboards; change bed sheets and wash them in washing machine at 60° C or hotter
| Monthly: Wash blankets and pillows at 60° C or hotter
| Duration of study treatment:
| 6 months
| Trial preceded by 2-week run-in period
| Dates: NR
| Location: Israel
| Setting: Pediatric Health Centers
| Type(s) of providers: NR
Burr, Dean, Merrett, et al., 1980 | Design: RCT, parallel-group | No. of subjects at start: 55 | 1) Spirometry (morning and evening peak flow rates) | 1) Spirometry: Not abstracted | Quality Scoring:
| | | | | Population similar: No
| Interventions: | Dropouts/withdrawals: 2 | | 2) Mother and investigator global evaluation of efficacy: | Intervention(s) described: Yes
| 1) Avoidance measures (n = 26), as follows: mattress vacuumed at start of trial and weekly thereafter; blankets and sheets laundered at start, and blankets beaten in open air at least once every 2 weeks; sheets, pillow-cases, and other washable bedding laundered weekly; feather pillows replaced with synthetic pillows or enclosed in impervious cover; all pillows beaten weekly in open air; quilts and eiderdowns removed unless < 6 months old and washable; soft toys removed or washed, brushed, or vacuumed every week; bedroom carpets vacuumed several times every week; upholstery vacuumed every 2 weeks. | | | | Comorbidities described: Yes
| | No. of subjects at end: 53 | 2) Mother and investigator global evaluation of efficacy: at end of trial (8 weeks), clinician assessed child's progress “in light of the mother's report of symptoms and the changes in physical signs and lung function;” child's condition graded as much better, better, same, worse, or much worse | Intervention: 5/26 much better; 11/26 better | Diagnosis by MD: Not applicable
| | Inclusion criteria: Asthma; positive skin test for dust mites | | Control: 6/27 much better; 9/27 better | Objectively confirmed: Not applicable
| | | | 3) Allergen levels: Only reported pre-post for intervention group. Between-group comparisons not made. | Outcome measures valid: No
| | Exclusion criteria: “Asthma seemed to be exacerbated by other allergens” | | | Level of evidence: 1b
| | | | | Randomized: Yes
| | | | | Allocation concealed: Not described
| | Age: 9 (range, 4.5–14) | | | Double-blind: No
| | | | | Blinding adequate: Not applicable
| | Sex: 36 male; 17 female
| | | | | Dropouts described: Yes
| | Race: NR | 3) Allergen levels: dust samples obtained from bedding of treated group at start of trial and from both groups at end of trial; collected using special suction device | | Intention-to-treat: No
| | Other:
| | | | | Note: Power not addressed
| 2) Placebo avoidance measures (n = 27), as follows: importance of dust in living room emphasized; living room dusted daily using special duster, and other rooms similarly dusted once per week; spray-on polish recommended before each dusting; upholstered chairs in living room vacuumed or brushed at least twice a week; carpet in living room vacuumed daily.
| Duration of study treatment:
| 8 weeks
| Trial preceded by 1-week run-in period, during which baseline data collected
| Dates: NR
| Location: UK
| Setting: Pediatric outpatient clinic
| Type(s) of providers:
| Pediatricians
Burr, Neale, Dean, et al., 1980 | Design: RCT, crossover | No. of subjects at start: 21 | 1) Spirometry (morning and evening peak flow rates) | 1) Spirometry: Not abstracted | Quality Scoring:
| | | | | Population similar: No
| Interventions: | Dropouts/withdrawals: 0 | | 2) Mother's global evaluation of efficacy: | Intervention(s) described: Yes
| 1) Avoidance measures, as follows: each child issued with new sleeping bag, pillow, and blankets (if required); mattress completely enclosed in impervious plastic bag; all other bedding either enclosed in impervious bags or removed; carpets in bedroom vacuumed several times every week. | | | | Comorbidities described: Yes
| | No. of subjects at end: 21 | 2) Mother's global evaluation of efficacy: at end of treatment period, mother asked whether child's asthma better or worse | Intervention period compared to control: 6 improved, 14 no change, 1 worse (no test for significance) | Diagnosis by MD: Not applicable
| | Inclusion criteria: Asthma; positive skin test for dust mites | | | Objectively confirmed: Not applicable
| | | | 3) Allergen levels: Not meaningfully reported | Outcome measures valid: No
| | Exclusion criteria: “Asthma seemed to be exacerbated by other allergens” | | | Level of evidence: 2b
| | | | | Randomized: Yes
| | | 3) Allergen levels: mites contained in bedding counted at end of each treatment period | | Allocation concealed: Not described
| | Age: NR, but is a subset of Burr, Dean, Merrett, et al., 1980, above | | | Double-blind: No
| | | | | Blinding adequate: Not applicable
| 2) No special avoidance measures.
| | Sex: NR, but is a subset of Burr, Dean, Merrett, et al., 1980, above | | | Dropouts described: Yes
| | | | | Intention-to-treat: Can't determine
| Duration of study treatment:
| 1 month each treatment period; no washout between periods | Race: NR
| | Other: | | | Notes:
| | | | | All patients had participated in trial by Burr, Dean, Merrett, et al., 1980, described above.
| Dates: NR
| Location: UK
| | | | | No assessment of carry-over effect, period effect, or treatment-by-period interaction.
| Setting: Pediatric outpatient clinic
| Type(s) of providers: | | | | Power not addressed.
| Pediatricians
Carswell, Birming-ham, Oliver, et al., 1996 | Design: RCT, parallel-group | No. of subjects at start: 70 randomized; 62 started treatment | 1) Allergen levels: dust collected by vacuum and Petri dishes “from potentially mite allergen-rich sites” pretreatment and at 2, 6, 14 and 24 weeks | 1) Allergen levels: | Quality Scoring:
| | | | Mattress: Median change, p < 0.0001 | Population similar: No
| Interventions: | | | Intervention: 480 ng | Intervention(s) described: Yes
| 1) Acaricide (Acarosan^®^) + avoidance measures (n = 35). At start of trial, Acarosan^®^ powder (benzyl benzoate 5%) applied to bedroom carpet and Acarosan^®^ foam (benzyl benzoate 1.6%) applied to mattresses, duvets, pillows, and any upholstered furniture. All items thoroughly vacuumed with Medivac^®^ vacuum before application of acaricide, 24 hours later, and 4 weeks later. Allergen exclusion covers (Intervent^®^) fitted to mattresses, duvets, and pillows and left in place for 24 weeks. All bed linens to be washed at 60° C each week. Softy toys removed or washed at 60° C. | Dropouts/withdrawals: 19 | | Control: 215 ng | Comorbidities described: Yes
| | | | | Diagnosis by MD: Not applicable
| | No. of subjects at end: 51 (49 completers) | | Carpets: reported graphically; no significant difference
| | | | | Objectively confirmed: Not applicable
| | Inclusion criteria: Asthma (wheezing, breathlessness); skin test positive for house-dust mite; high dust-mite antigen in mattress | 2) Spirometry (peak flow rates) | 2) Spirometry: Not abstracted | Outcome measures valid: No
| | | | | Level of evidence: 1b
| | | | 3) Bronchial histamine sensitivity: Not abstracted | Randomized: Yes
| | | 3) Bronchial histamine sensitivity | | Allocation concealed: Not described
| | Exclusion criteria: Cat allergen sensitive and cat in house; no duvet or not sleeping in single bed | | 4) Patient-assessed symptom severity: results reported graphically; total symptoms decreased significantly more in the intervention group (about 30% fewer patients with symptoms vs. no change in control, p<0.05). No significant difference in individual symptoms of daytime wheeze and cough. | Double-blind: Yes
| | | 4) Patient-assessed symptom severity: presence/absence of asthma symptoms of wheeze, cough, activity impairment, and sleep disturbance recorded whenever peak flow rates measured (3 times per day during four different 2-week periods) | | Blinding adequate: Yes
| | | | | Dropouts described: Yes
| | | | | Intention-to-treat: No
| | Age: 9.8 (range, 7–10)
| | Sex: 44 males; 26 females | | | Notes:
| | | | | 10 subjects excluded because of incomplete treatment or non-adherence.
| | Race: NR
| | Other: | | 5) Use of symptomatic medication:
| | | | 50% of intervention patients took medication vs. 80% in control group, p<0.02. (From graph: about a 30% difference in bronchodilator use and about 20% difference in inhaled steroid use.) | Power: a priori sample size calculation showing 50 completers needed.
| 2) Placebo acaricide + placebo avoidance measures (n = 35). At start of trial, placebo powder (chalk dust) applied to bedroom carpet and water spray applied to mattresses, duvets, pillows, and any upholstered furniture. All items thoroughly vacuumed with Medivac^®^ vacuum before application, 24 hours later, and 4 weeks later. Placebo covers (cotton) fitted to mattresses, duvets, and pillows and left in place for 24 weeks. All bed linens to be washed at 40° C each week. Softy toys removed or washed at 40° C.
| | | 5) Use of symptomatic medication: recorded whenever peak flow rates measured (3 times per day during four different 2-week periods)
| | | | | Looked at potential confounders and found no difference except fewer cats in placebo group.
| Duration of study treatment:
| 24 weeks
| Dates: NR
| Location: UK
| Setting: Schools
| Type(s) of providers: Family practitioners
Chang, Becker, Ferguson, et al., 1996 | Design: RCT, parallel-group | No. of subjects at start: 26 | 1) Allergen levels (mattress and floor): dust collected by vacuum at baseline, 1 week, and 1 and 3 months | 1) Allergen levels (baseline; 3 months): | Quality Scoring:
| | | | | Population similar: Yes
| Interventions: | Dropouts/withdrawals: 0 | | Mattress: p = ns | Intervention(s) describe: Yes
| 1) Acaracide (Acarosan^®^ = benzyl benzoate) + avoidance measures (n = 12). Acaracide applied once at start of study to carpet in bedroom, carpet in most commonly used room, and mattress; avoidance measures described below. | | | Gp 1: 2.17 ± 2.64; 0.06 ± 1.12 | Comorbidities described: Yes
| | No. of subjects at end: 26 | | Gp 2: 1.68 ± 2.22; 0.28 ± 1.32 | Diagnosis by MD: Not applicable
| | Inclusion criteria: Asthma; dust-mite sensitivity by skin test; mite allergens > 1 μg/g of dust from mattress or bedroom floor | 2) Patient-assessed symptom severity: cough, wheeze, and breathlessness graded daily on score of 0 (no symptoms) to 3 (severe) | Floor: p < 0.05 | Objectively confirmed: Not applicable
| | | | Gp 1: 2.38 ± 2.24; 0.50 ± 1.71
| | | | Gp 2: 2.05 ± 2.05; 1.10 ± 2.17 | Outcome measures valid: No
| | | | | Level of evidence: 2b
| | | | 2) Patient-assessed symptom severity (baseline; 1; 2; and 3 months): p = ns | Randomized: Yes
| | Exclusion criteria: None specified | | | Allocation concealed: Not described
| 2) Avoidance measures only (described below) (n = 14) | | | Gp 1: 1.5 ± 2.1; 1.5 ± 1.9; 1.6 ± 2.2; 1.1 ± 1.7
| | Age: 11 children, 15 adults | 3) Spirometry (FEV1, morning peak expiratory flow rate, evening peak expiratory flow rate) | | Double-blind: No
| | | | | Blinding adequate: Not applicable
| | | | Gp 2: 0.6 ± 0.8; 1.2 ± 1.6; 0.7 ± 1.7; 0.4 ± 0.5
| Avoidance measures (both groups): Vacuum home at least once per week, wash bedding in hot water (> 58° C), and encase mattresses and pillows with vinyl covers | Sex: NR
| | | | | Dropouts described: No
| | Race: NR | | | Intention-to-treat: Can't determine
| | | | 3) Spirometry: Not abstracted
| | | 4) Methacholine inhalation test
| | Other:
| | | | 4) Methacholine inhalation test: Not abstracted
| | | | | Notes:
| Duration of study treatment: | | | | Important baseline differences between groups in symptoms.
| 3 months
| Trial preceded by 1-month run-in period, during which allergen levels tested; patients completed diary cards for 1 month pre-trial | | | | Power: not addressed.
| Dates: 12/1993-4/1994
| Location: Canada
| Setting: NR (subset of participants in another study)
| Type(s) of providers: NR
Chen and Hsieh, 1996 | Design: RCT, parallel-group | No. of subjects at start: 73 | 1) Allergen levels: dust samples collected by vacuum from mattress, quilt, and pillows at baseline and after 1, 2, 3, 6, 9, and 12 months | 1) Allergen levels: (reported graphically) | Quality Scoring:
| | | | | Population similar: No
| Interventions: | Dropouts/withdrawals: 29 | | Mattress: Intervention showed significant decreases compared to baseline. Placebo groups did not show significant decreases. No between-group differences reported. | Intervention(s) described: Yes
| 1) Avoidance measures (n = 29). Patients provided with new Microstop^®^-treated mattresses, quilts, pillows, bed linens, and quilt covers. | | | | Comorbidities described: Yes
| | No. of subjects at end: 44 | | | Diagnosis by MD: Not applicable
| | Inclusion criteria: Asthma and positive to house dust-mite | | | Objectively confirmed: Not applicable
| | | 2) Patient-assessed symptom severity: asthma symptoms of sleep disturbance, chest tightness on awakening, daytime symptoms, and cough graded twice daily on scale of 0 (none) to 4 (severe [different definitions for various specific outcomes]) | Quilt: Intervention and placebo avoidance showed significant differences compared to baseline. No between-group differences reported.
| | | | | Outcome measures valid: No
| 2) Placebo avoidance measures (n = 29). Patients provided with new non-Microstop^®^-treated mattresses, quilts, pillows, bed linens, and quilt covers. | Exclusion criteria: Pets, immunotherapy, inhaled steroids | | | Level of evidence: 2b
| | | | | Randomized: Yes
| | | | Pillow: Intervention showed lower mite count compared to placebo and control groups (p = not significant). | Allocation concealed: Not described
| | Age: 8.23 ± 2.56
| | | | | Double-blind: Yes
| | Sex: 55 male; 18 female | | | Blinding adequate: Yes
| | | | 2) Patient-assessed symptom severity: (reported graphically). Intervention group showed significantly decreased symptoms compared to baseline for 10 of 12 months. No between-group comparisons reported. | Dropouts described: Yes
| 3) No avoidance measures (n = 15). Patients continue to use their regular bedding. | Race: NR | | | Intention-to-treat: No
| | Other:
| | | 3) Spirometry (morning and evening peak flow rates) | | Notes:
| Duration of study treatment: | | | | Power: no discussion.
| 12 months
| | | | 3) Spirometry: Not abstracted | High number of dropouts.
| Trial preceded by run-in period of at least 1 month, during which baseline data collected
| | | | | No between-group comparisons.
| Dates: 1/1994 - 4/1995
| Location: Taiwan
| Setting: Allergy clinic at Women and Childrens Hospital
| Type(s) of providers: NR
Cloosterman, Hofland, Lukassen, et al., 1997 | Design: RCT, parallel-group, randomization stratified by type of floor covering (textile vs. smooth) and initial FEV1 | No. of subjects at start: 29 | 1) Spirometry (peak flow rates, peak flow variability) | 1) Spirometry: Not abstracted | Quality Scoring:
| | | | | Population similar: Yes
| | Dropouts/withdrawals: 11 (5 treatment, 6 placebo) | | 2) Patient-assessed symptom severity: | Intervention(s) described: Yes
| | | 2) Patient-assessed symptom severity: cough, breathlessness, wheezing, expectoration, tiredness, and disturbed sleep (due to cough, wheeze, or breathlessness) graded on scale of 0 (no symptoms) to 10 (severe symptoms) | Selected symptoms (sleep, breathlessness, wheeze, overall score) reported graphically; no data given for other symptoms; only within-group p- values given. | Comorbidities described: Yes
| | | | | Diagnosis by MD: No
| Interventions: | No. of subjects at end: 18 (11 treatment, 7 placebo) | | | Objectively confirmed: Yes
| 1) Acaracide (Acarosan^®^ = benzyl benzoate) + avoidance measures (n = 16). Acaricide applied to bedroom and living room floors once at start of study; avoidance measures consisted of encasing mattresses, pillows, and duvets in covers impermeable to house dust mites and house dust mite allergens. | | | | Outcome measures valid: No (?)
| | Inclusion criteria: Positive skin test for house dust mite; skin test reaction to dogs, cats, and Spergillus fumigatus < reaction to house dust mite; (all patients had mild symptoms of asthma but this was not an inclusion criteria) | | | Level of evidence: 2b
| | | | Between-group differences given for only one symptom (wheeze) at one time point, week 5 (Gp 1 change from baseline of -0.31 ± 0.1 vs Gp 2 +0.53 ± 0.24; p = “significant”). | Randomized: Yes
| | | | | Allocation concealed: Not described
| | | | | Double-blind: No
| | | | | Blinding adequate: Not applicable
| | | | | Dropouts described: Yes
| | Exclusion criteria: Confirmed diagnosis of asthma; history of receiving anti-inflammatory medication; peak flow variability > 15% or FEV1 increase by > 15% after salbutamol | | | Intention-to-treat: No
| 2) Placebo acaracide (water) + placebo avoidance measures (cotton covers permeable to house dust mites and house dust mite allergens (n = 13).
| | | | | Notes:
| | | | | Stratification and randomization resulted in unbalanced distribution of patients to treatment groups.
| | Age: Gp 1: 32.4 ± 11.5; Gp 2: 23.5 ± 6.3 (p = 0.04)
| Patients in both groups were instructed to vacuum bedroom and living room floors and wash bedding once per week. | | | | Appear to be important baseline differences in symptoms and demos.
| | Sex: 17/29 women
| | Race: NR
| | | | | Patients were minimally symptomatic.
| Duration of study treatment: | Other:
| 6 weeks
| | | | | Sample size based on peak flow; 80% power to detect a 15 l/min difference; no post-hoc power calculation on symptoms.
| Trial preceded by 2-week baseline period
| Dates: 1993
| Location: The Netherlands
| Setting: Recruited from patients referred for skin testing
| Type(s) of providers: General practitioners
Cloosterman, Schermer, Bijl-Hofland, et al., 1999 | Design: RCT, parallel-group | No. of subjects at start: 258 eligible; 204 randomized | 1) Allergen levels: dust collected by vacuum from mattress and floors at baseline and at 8, 14, and 20 weeks | 1) Allergen levels: Reported graphically (Der P 1): | Quality Scoring:
| | | | | Population similar: Yes
| Interventions: | | | Mattress: ng/g, p = 0.0001 | Intervention(s) described: Yes
| 1) Acaracide (Acarosan^®^ = benzyl benzoate) + avoidance measures (n = 76). Acaricide applied to carpets and rugs in bedroom and living room once at start of study; avoidance measures consisted of encasing mattresses, pillows, and duvets in covers impermeable to house dust mites and house dust mite allergens. | Dropouts/withdrawals: 58 | | Gp 1: 860 (95% CI, 537–1376), declined by 90.6% | Comorbidities described: Yes
| | | | | Diagnosis by MD: Not applicable
| | No. of subjects at end: 146; 157 ITT | | Gp 2: 931 (95% CI, 602–1439), declined by 31.5%
| | | 2) Spirometry (peak flow rates, peak flow variability, FEV1, bronchial hyper-responsiveness) | | Objectively confirmed: Not applicable
| | Inclusion criteria: Asthma; positive skin test for house dust mite; FEV1 > 50% and > 65% after salbutamol; PC20 ≤ 8 mg/ml or reversibility of obstruction after salbutamol | | Bedroom floor (p = 0.883) and living room floor (p = 0.9422) - only graphical | Outcome measures valid: No (?)
| | | | | Level of evidence: 1b
| | | 3) Patient-assessed symptom severity: cough, breathlessness, wheezing, expectoration, tiredness, and disturbed sleep (due to cough, wheeze, or breathlessness) graded on scale of 0 (no symptoms) to 10 (severe symptoms) | 2) Spirometry: Not abstracted | Randomized: Yes
| | | | | Allocation concealed: Not described
| | | | 3) Patient-assessed symptom severity:
| | | | Reported graphically only; no significant differences, p = 0.5474 | Double-blind: No
| | Exclusion criteria: Oral steroids; inhaled corticosteroids dependency; skin test reactivity to pets > reaction to dust mite if pets in house | | | Blinding adequate: Not applicable
| 2) Placebo acaracide (water) + placebo avoidance measures (cotton covers permeable to house dust mites and house dust mite allergens (n = 81).
| | | | | Dropouts described: Yes
| | | | | Intention-to-treat: Yes
| | Age: Gp 1: 32.7 ± 11; Gp 2: 33.9 ± 11.1 | | | Note: Power not addressed
| Duration of study treatment:
| 20 weeks | Sex: 82 men; 75 women
| Trial preceded by 4-week baseline period | Race: NR
| | Other:
| During trial, patients used only bronchodilators, and in a standardized way; exacerbations treated with prednisone and, if necessary, antibiotics in a standardized way
| Dates: 10/1993-9/1996
| Location: The Netherlands
| Setting: Allergy laboratory records with GP and Pulmonologists
| Type(s) of providers: General practitioners and pulmonologists
Dietemann, Bessot, Hoyet, et al., 1993 | Design: RCT, parallel-group | No. of subjects at start: 26 | 1) Investigator-assessed symptom severity (“clinical scores”): graded every 3 months during clinic visits on scale of 0 = no asthmatic episodes, 1 = at least one asthmatic episode per month, 2 = at least one asthmatic episode per week, 3 = at least one asthmatic episode per day, ] | 1) Investigator-assessed symptom severity (“clinical scores”): | Quality Scoring:
| | | | | Population similar: Yes
| Interventions: | Dropouts/withdrawals: 3 | | Baseline and % change, p = ns | Intervention(s) described: Yes
| 1) Acaracide (Acarosan^®^ = benzyl benzoate) (n = 11). Applied to all mattresses and upholsteries in home and to all carpets and rugs at the start of the trial and once again after an interval of at least 6 months. | | | Gp 1: 2.54 (95% CI, ± 1.5); -45% | Comorbidities described: Yes
| | No. of subjects at end: 23 | | Gp 2: 2.0 (95% CI, ± 0.4); -41% | Diagnosis by MD: Not applicable
| | Inclusion criteria: Definite history of asthma; positive skin test to Dermatophagoides pteronssinus; RAST for Dp > 3 using pharmacia screening system; Acarex value ≥ ++ | | 2) Patient-assessed symptom severity: | Objectively confirmed: Not applicable
| | | | Baseline and % change, p = ns
| | | | Gp 1: 5.7 (95% CI, ± 0.84); +36% | Outcome measures valid: No
| | | | Gp 2: 5.0 (95% CI, ± 0.78); +46.6% | Level of evidence: 1b
| | | | | Randomized: Yes
| | | | 3) Medication use: | Allocation concealed: Not applicable
| 2) Placebo acaracide, applied as above (n = 12). | | | Baseline and % change, p = ns
| | Exclusion criteria: None specified | 2) Patient-assessed symptom severity: graded every 3 months during clinic visits on VAS scale of 0 (severe dyspnea) to 10 (no dyspnea) | Gp 1: 2.27 (95% CI, ± 0.66); -12% | Double-blind: Yes
| | | | Gp 2: 1.92 (95% CI, ± 0.50); -19.8% | Blinding adequate: Yes
| Duration of study treatment: | Age: 35 ± 14.9 | | | Dropouts described: Yes
| 1 year | | | | Intention-to-treat: No
| | | | 4) Spirometry: Not abstracted
| | Sex: 12 men; 12 women
| Dates: NR | | | 5) Allergen levels: Baseline μg/g and % change of Der p I + Der f I
| | Race: NR | | | Notes:
| Location: France | | 3) Medication use: graded every 3 months during clinic visits on following scale: 0 = no medication; 1 = no more than 4 inhalations per day of β2-agonists or disodium cromoglycate intake or both; 2 = continuous bronchodilator treatment with β2-agonists, with or without long-acting theophylline (twice per day), and beclomethasone dipropionate at dose ≤ 1000 μg/day; 3 = β2-agonist inhalation with or without long-acting theophylline, and beclomethasone dipropionate at dose ≥ 1000 μg/day | Mattress: p = ns | No diary recording of symptoms. Symptom outcomes based on data collected at 3-monthly clinic visits.
| | Other: | | Gp 1: 43.53 (95% CI, ± 24.6); -19.7%
| Setting: Chest clinic | | | Gp 2: 84.66 (95% CI, ± 52.5); -17%
| Type(s) of providers:
| | | | Upholstery elements: p = ns
| Pulmonologists? | | | | Power not addressed.
| | | | Gp 1: 30.4 (95% CI, ± 31.5); -67%
| | | | Gp 2: 40.0 (95% CI, ± 18.4); - 61%
| | | | Carpets: p = ns
| | | | Gp 1: 4.95 (95% CI, ± 3.23); -74%
| | | | Gp 2: 13.0 (95% CI, ± 6.6); -27%
| | | 4) Spirometry (FEV1, FVC, FEF 25–75, peak flow rates)
| | | 5) Allergen levels: dust collected by vacuum from mattresses, carpets, and upholstery at baseline and 12 months
Dorward, Colloff, MacKay, et al., 1988 | Design: RCT, parallel-group | No. of subjects at start: 21 | 1) Patient-assessed symptom severity: presence/absence and duration of wheezing recorded daily; overall severity of asthma graded daily on 10-cm linear analog scale | 1) Patient-assessed symptom severity: (reported graphically as mean % change) | Quality Scoring:
| | | | | Population similar: Yes
| Interventions: | Dropouts/withdrawals: 3 | | | Intervention(s) described: Yes
| 1) Avoidance measures (n = 9). Mattresses and bedroom carpets soaked with liquid nitrogen at start of trial. Entire surface of bed vacuumed weekly. Blankets, pillows, and duvets cleaned at the start of trial; sheets and pillow cases washed weekly; blankets and upper sheets or duvets folded back each morning to allow mattress to air. Hard surfaces damp-dusted weekly. Plants, soft toys, cushions, and upholstered furniture removed from bedroom. | | | Wheezing hours decreased significantly in intervention group (about -50% vs. + 10%, p < 0.05); wheezing days did not differ (about -20% vs. 0%); asthma severity decreased but not significantly different (about -45% vs. +10%). | Comorbidities described: Yes
| | No. of subjects at end: 18 | | | Diagnosis by MD: Not applicable
| | Inclusion criteria: Stable asthma; positive skin test to house dust-mite; FEV1 >60% predicted | | | Objectively confirmed: Not applicable
| | | | | Outcome measures valid: No
| | | 2) Use of salbutamol inhaler: number of puffs used recorded daily | | Level of evidence: 2b
| | Exclusion criteria: Requirement for oral steroids, theophylline, sodium cromoglycate or dog or cat at home | | | Randomized: Yes
| | | | 2) Use of salbutamol inhaler: | Allocation concealed: Not described
| | | | No significant difference (about -10% vs. +10%)
| | | 3) Spirometry (morning and evening peak flow rates) | | Double-blind: No
| | | | | Blinding adequate: Not applicable
| | Age: 25.6 (range 13–48) intervention; 24.8 control (range 14–53) | | 3) Spirometry: Not abstracted
| | | | | Dropouts described: Yes
| | | 4) Bronchial reactivity (PC_20_ histamine values) | 4) Bronchial reactivity: Not abstracted | Intention-to-treat: No
| | Sex: 8 males; 10 females | | 5) Allergen levels: (Mattress, # intact mites/0.25 m2/min)
| 2) No avoidance measures (n = 9). Patients instructed to continue with their normal cleaning activities. | | 5) Allergen levels: dust samples collected from mattresses and carpets at baseline and at 4 and 8 weeks | | Note: Power: no discussion
| | Race: NR | | Intervention: 6.56 ± 6.25 baseline; 0.33 ± 1.33 8 weeks, p<0.01 for within-group change
| | Other:
| | | | Control: 7.0 ± 6.98 baseline; 4.22 ± 4.94 8 weeks , p > 0.05 for within-group change
| Duration of study treatment:
| 8 weeks | | 6) IgE and allergen-specific IgE antibody levels
| | | | No between-group comparison made
| Trial preceded by 2- to 3-week run-in period
| | | | 6) IgE and allergen-specific IgE antibody levels: Not abstracted
| Dates: 1/1984 - 6/1984
| Location: Scotland
| Setting: Hospital respiratory clinic
| Type(s) of providers: NR
Frederick, Warner, Jessop, et al., 1997 | Design: RCT, crossover | No. of subjects at start: 31 | 1) Allergen levels: dust collected from mattress, duvet, and pillow at baseline and end of each period | 1) Allergen levels: | Quality Scoring:
| | | | Median ng/g (with range), baseline and 3 months: | Population similar: No
| Interventions: | Dropouts/withdrawals: 0 | | | Intervention(s) described: Yes
| 1) Avoidance measures, consisting of encasing mattresses, pillows, and duvets in covers impermeable to house dust mites and house dust mite allergens (Intervent^®^). Patients instructed to wipe down covers with a damp cloth once per week. | | | Mattress: (active and placebo crossover), p = 0.0012 | Comorbidities described: Yes
| | No. of subjects at end: 31 | | | Diagnosis by MD: Not applicable
| | | | Gp 1 (active): 12,403 (616–24,138); 1,246 (0–66,667)
| | Inclusion criteria: Documented perennial asthma; positive skin test or RAST ≥ grade 3 to house dust mite | 2) Patient-assessed symptom severity: asthma last night, daytime wheeze, and exercise tolerance measured (twice?) daily on scale of 0–3 (not described) | | Objectively confirmed: Not applicable
| | | | Gp 2 (active): 8,500 (354–50,000); 1,086 (0–6,452)
| | | | | Outcome measures valid: No
| | | | Gp 1 (placebo): 7,275 (100–30,519); 2,737 9(53–97,143) | Level of evidence: 2b
| | | | | Randomized: Yes
| | Exclusion criteria: None specified | | Gp 2 (placebo): 14,759 (0–82,500); 13,500 (900–63,830) | Allocation concealed: No
| | | | | Double-blind: No
| | Age: 9 (range 5–15) | | Duvet (p < 0.000) and pillow (p < 0.0001) antigen levels also decreased significantly | Blinding adequate: Not applicable
| 2) Placebo avoidance measures (polycotton covers, no weekly wipe-down). | | 3) Spirometry (morning and evening peak flow rates, FEV1, PC_20_)
| | Sex: 20 male; 11 female | | | Dropouts described: Yes
| | | | | Intention-to-treat: Yes
| | Race: NR | | 2) Patient-assessed symptom severity:
| Duration of study treatment: | | 4) Use of bronchodilator (β2-agonist): recorded daily by patients in diary | Baseline; month 3; median and (range)
| 3 months each treatment period, with a 1-month washout between periods | Other: | | Asthma: p = ns | Notes:
| | | | Active: 0.2 (0–1.9); 0.1 (0–0.8) | Intervention bias (i.e., no weekly wipe-down in placebo group); could lead to unblinding.
| | | | Placebo: 0.09 (0–2.5); 0.09 (0–1.7)
| | | 5) Blood assays (ECP, EPX, EPO, sIL-2R) | Asthma, wheeze, and exercise tolerance did not differ significantly between groups
| Trial preceded by 2-week run-in period
| | | | | No assessment of period effect or treatment-by-period interaction.
| Dates: 11/1992 - 11/993 | | | 3) Spirometry: Not abstracted
| Location: UK | | | 4) Use of bronchodilator (β2-agonist):
| | | | Baseline; 3 months, median μg (range)
| Setting: General Pediatric Hospital | | | Active: 120 (0–986); 80 (0–312) | Power not addressed
| | | | Placebo: 60 (0–542); 40 (0–372)
| Type(s) of providers: ? | | | 5) Blood assays: Not abstracted
Geller-Bernstein, Pibourdin, Dornelas, et al., 1995 | Design: RCT, parallel-group | No. of subjects at start: 35 | 1) Patient-assessed symptom severity (diary data): asthma severity, nasal secretion, nasal obstruction, sneezing, ocular pruritus, and lacrimation graded twice weekly (so text; abstract has “daily”) on scale of 0 (no symptoms) to 3 (severe symptoms) | Outcomes reported monthly; data reported below are for baseline and 6 months. | Quality Scoring:
| | | | | Population similar: No
| Interventions: | Dropouts/withdrawals: 3 | | | Intervention(s) described: Yes
| 1) Acaricide (Acardust^®^ = esdepallethin 0.9% and piperonyl butoxide 7.2%), applied at baseline and 3 months to mattress (and more widely throughout bedroom?) (n = 17) | | | | Comorbidities described: Yes
| | No. of subjects at end: 32 | | 1) Patient-assessed symptom severity (diary data): means (no variance given), p = 0.001? | Diagnosis by MD: Yes
| | | | | Objectively confirmed: Yes
| | Inclusion criteria: Age 4–12 with asthma or rhinitis severe enough to require continuous medications for the 3 months prior to entry; in asthmatics, a peak flow or FEV1 ≥ 15% below predicted; positive skin test to house dust mite; Acarex test ≥ 2+ in child's mattress dust | | | Outcome measures valid: No
| | | | Gp 1: 34.83; 5.47 | Level of evidence: 1b
| | | | Gp 2: 29.88; 6.60 | Randomized: Yes
| | | | | Allocation concealed: Not described
| | | | 2) Patient-assessed symptom severity (clinic visits): means (no variance given)
| 2) Placebo acaricide, applied as above (n = 15) | | | | Double-blind: Yes
| | | 2) Patient-assessed symptom severity (clinic visits): disruption of daily activities, wheezing frequency, severity of rhinitis symptoms, frequency of rhinitis crisis graded at monthly clinic visits on scale of 0 (no symptoms/less than once per month) to 3 (severe symptoms/permanently) | | Blinding adequate: Yes
| | | | Daily Activity Disruption (p = 0.02) | Dropouts described: Yes
| Subjects in both groups cleaned their bedrooms regularly using the same procedures (change of bedsheet every week, change of blanket every month, daily dust removal with damp cloth, and weekly vacuuming of carpets and furniture). | | | Gp 1: 1.17; 0.13 | Intention-to-treat: No
| | Exclusion criteria: Allergy due to non-house dust mite allergens; use of an acaricide w/in 3 months of study entry | | Gp 2: 0.94; 0.27
| | | | Wheezing frequency (p = 0.10) | Notes:
| | | | Gp 1: 1.94; 0.67 | Poorly reported trial. Often difficult to know whether outcomes reported are based on patient-diary or clinic-visit data.
| | | | Gp 2: 2.06; 0.73
| | Age: Gp 1: 9.7 ± 2.6; Gp 2: 8.1 ± 2.6
| | | | Nasal secretion - graphical results only, p = 0.01 favoring Acardust^®^
| | Sex: 23 male; 12 female
| Duration of study treatment: | | | Other rhinitis symptoms - graphical results only, p = 0.02 favoring Acardust^®^ | 32 patients had rhinitis; 31 had asthma.
| 6 months | Race: NR | 3) Investigator-assessed symptom severity (monthly clinic visits)
| Trial preceded by 1-month run-in period | Other: | | | Power not addressed.
| | | | 3) Investigator-assessed symptom severity (monthly clinic visits): Not abstracted
| | | 4) Use of concurrent medication: recorded by patients in diary (frequency unclear)
| Dates: NR
| Location: Israel | | | 4) Use of concurrent medication: Graphical results only, p = 0.01 favoring Acardust^®^
| Setting: Pediatric Allergy Clinic | | 5) Adverse events: patients instructed to record “any unusual events, symptoms or other illnesses” in their diaries
| | | | 5) Adverse events: None
| Types(s) of providers: ?
| | | | 6) Patient/parent monthly global evaluation of asthma severity:
| | | 6) Patient/parent monthly global evaluation of asthma severity: graded at monthly clinic visits using VAS from 0–100 mm | Graphical results only, p = 0.001 favoring Acardust^®^
| | | | 7) Investigator monthly global evaluation of asthma severity: Not abstracted
| | | 7) Investigator monthly global evaluation of asthma severity
| | | | 8) Investigator final global evaluation of improvement (6 months): Not abstracted
| | | 8) Investigator final global evaluation of improvement (6 months)
| | | | 9) Spirometry: Not abstracted
| | | | 10) Blood tests: Not abstracted
| | | 9) Spirometry (morning and evening peak flow, PFF, FEV1)
| | | | 11) Allergen levels: p = 0.02
| | | | Gp 1: 10.05 ± 13.74; 4.15 ± 6.51
| | | | Gp 2: 6.01 ± 8.01; 3.01 ± 4.33
| | | 10) Blood tests (total and dust mite farinae-specific IgE levels)
| | | 11) Allergen levels: dust collected by vacuum from mattress at baseline and 2, 3, 4, and 6 months
Gillies, Littlewood, and Sarsfield, 1987 | Design: RCT, parallel-group | No. of subjects at start: 26 | 1) Allergen levels: dust collected from mattresses using a standard dusting technique at baseline and 6 weeks | 1) Allergen levels: Mattress (dust mite counts mites/m2, baseline - 6 weeks) | Quality Scoring:
| | | | | Population similar: No
| Interventions: | Dropouts/withdrawals: 1 | | Intervention: 40.0 ± 64.24; 1.23 ± 1.74 | Intervention(s) described: No
| 1) Avoidance measures (n = 13). Mattress completely enclosed by special cover; pillows enclosed in plastic covers; soft toys and pets excluded from bedroom; synthetic bedding used; damp-dusting performed weekly; bed, mattress, and bed base vacuumed thoroughly (interval not specified). | | | Control: 21.75 ± 20.3; 10.33 ± 16.22 (no between-group statistical comparison) | Comorbidities described: Yes
| | No. of subjects at end: 25 | | | Diagnosis by MD: Not applicable
| | Inclusion criteria: Children; mild to moderate asthma; positive skin test to dust mite allergen | 2) Total and allergen-specific IgE antibody levels | | Objectively confirmed: Not applicable
| | | | 2) Total IgE antibody levels: Not abstracted
| | | | | Outcome measures valid: ??
| | | | | Level of evidence: 2b
| | Exclusion criteria: Requiring regular asthma medication | 3) Bronchial reactivity (PC_20_histamine values) | 3) Bronchial reactivity: Not abstracted | Randomized: Yes
| | | | | Allocation concealed: Not described
| | | | 4) Patient-assessed symptom severity: reported in text as “no significant changes in …[symptom scores, medication requirements]…”
| | Age: 9.7 (range 6–16) | 4) Patient-assessed symptom severity: day- and nighttime cough and wheeze and daytime activity recorded daily | | Double-blind: ??
| | | | | Blinding adequate: ??
| Sex: NR | | | | Dropouts described: ??
| 2) No avoidance measures (n = 12). Patients instructed to continue their normal domestic cleaning practice. | | | | Intention-to-treat: ??
| | Race: NR | | 5) Use of bronchodilators: reported in text as “no significant changes in …[symptom scores, medication requirements]…”
| Other: | | 5) Use of bronchodilators: recorded daily | | Notes:
| | | | | All patients employed avoidance measures during weeks 7–12.
| Duration of study treatment:
| 6 weeks (controlled portion of trial) | | 6) Spirometry (morning and evening peak flow rates) | 6) Spirometry: Not abstracted
| | | | | Power: no discussion
| Dates: 11/1984?-4/1985? | | | | Poorly reported trial. No data given for symptoms, no between-group comparisons.
| Location: UK
| Setting: NR
| Type(s) of providers: NR
Huss, Huss, Squire, et al., 1994 | Design: RCT, parallel-group | No. of subjects at start: 12 | 1) Allergen levels: collected from bedroom and living room carpets by vacuum at baseline and at 3, 6, 9, and 12 months | 1) Allergen levels: | Quality Scoring:
| | | | Results shown graphically; no within-group or between-group differences. | Population similar: Yes
| Interventions: | Dropouts/withdrawals: 0 | | | Intervention(s) described: Yes
| 1) Acaracide (Acarosan^®^ = benzyl benzoate) + avoidance measures (n = 6). Acaracide applied to bedroom and living room carpets at baseline and 6 months; avoidance measures described below. | | | | Comorbidities described: Yes
| | No. of subjects at end: 12 | | 2) Spirometry: Not abstracted | Diagnosis by MD: Not applicable
| | Inclusion criteria: Symptomatic asthma using standardized criteria; positive skin test to house dust mite; high levels of house dust mite in carpets | 2) Spirometry (morning and evening peak flow, FEV1, FEF_25–75_, peak flow variability) | 3) Experience using acaracide/difficulty of use/time involved: Not abstracted | Objectively confirmed: Not applicable
| | | | | Outcome measures valid: No
| | | | | Level of evidence: 2b
| | | | 4) Patient global assessment of efficacy: | Randomized: Yes
| 2) Placebo acaracide (applied as above) + avoidance measures (described below) (n = 6) | | 3) Experience using acaracide/difficulty of use/time involved: assessed by interview at end of study (12 months) | | Allocation concealed: No
| | Exclusion criteria: “Significant” severity to dog, cat, feathers, or other potentially relevant indoor allergens | | Not reported by group | Double-blind: Yes
| | | | | Blinding adequate: Yes
| | | | 5) Patient global assessment of adverse events: | Dropouts described: Yes
| | | | | Intention-to-treat: Yes
| Avoidance measures: patients in both groups had already (at start of trial) implemented avoidance measures such as encasing mattresses, box springs, and pillows in allergen-impermeable covers and washing bed linens in hot water. During trial, were instructed to vacuum carpets weekly. | | | No adverse events reported.
| | Age: 44; (range 25–65) | 4) Patient global assessment of efficacy: graded once, at 12 months; patient asked whether he/she felt treatment had improved his/her asthma (yes/no/unsure)
| | | | 6) Medication use: | Notes:
| | Sex: 4 male; 8 female | | No data reported; statement of “not significantly different” | Small sample size (6 patients per group).
| | Race: 10 white; 1 black; 1 other
| | | | | Very little patient-assessed symptom data reported. No daily recording of symptoms.
| | Other:
| | | 5) Patient global assessment of adverse events: graded once, at 12 months; patient asked whether he/she had felt any adverse effects as result of treatment (yes/no) | | Power not addressed.
| Duration of study treatment:
| 1 year
| Dates: 10/1990-11/1991
| Location: US
| | | 6) Medication use: Not clear how assessed
| Setting: NR
| Type(s) of providers: NR
Kniest, Young, Van Praag, et al., 1991 | Design: Controlled trial (patients assigned “arbitrarily” - doesn't say randomly), parallel-group, matched-pairs design (matched by age, IgE and skin testing to house dust mite, symptoms, guanine exposure and dwelling) | No. of subjects at start: 20 | 1) Patient-assessed symptom severity: itching of eye and nose, sneezing, nose secretion, nose bleeding, eye irritation, and nasal blockage graded daily on scale of 0 (no symptoms) to 3 (symptoms present for more than 2 hours) | 1) Patient-assessed symptom severity: | Quality Scoring:
| | | | Gp 1 improved more than Gp 2 (p = 0.025, matched-pairs analysis, subject level scores given) | Population similar: Yes
| | Dropouts/withdrawals: 0 | | | Intervention(s) described: Yes
| | | | | Comorbidities described: No
| | No. of subjects at end: 20 | | | Diagnosis by MD: Yes
| | | | 2) Medication use: | Objectively confirmed: Yes
| | Inclusion criteria: House dust mite induced perennial rhinitis more evident than other allergic symptoms | | No between-group differences in medication index (no p-value or means reported) | Outcome measures valid: No
| | | | | Level of evidence: 3b
| | | | | Randomized: No
| Interventions: | | | | Allocation concealed: Not described
| 1) Acaracide (Acarosan^®^ = benzyl benzoate) + avoidance measures (n = 10). Acaracide applied to all textile objects in home (carpets, padded furniture, upholstery, mattresses, stuffed animals) at baseline and 6 months; avoidance measures described below. | | | 3) Physician global evaluation of efficacy: Not abstracted
| | Exclusion criteria: None specified | 2) Medication use: use of steroid nasal spray, cromoglycate nasal spray, and terfenadine recorded daily | | Double-blind: Yes
| | | | | Blinding adequate: Yes
| | Age: 20; (range 12–35) | | 4) Blood tests (IgE, eosinophils): Not abstracted | Dropouts described: Yes
| | | | | Intention-to-treat: Yes
| | Sex: NR
| | | | 5) Allergen levels:
| | Race: NR | 3) Physician global evaluation of efficacy | Graphical results given; guanine exposure dropped more for group 1 (70% of baseline) than group 2 (97% of baseline; p = 0.45, matched-pairs analysis) | Notes:
| | | | | Uncertain if truly randomized.
| | Other: | | | Concealment: NR
| | | 4) Blood tests (IgE, eosinophils)
| 2) Placebo acaracide (applied as above) + avoidance measures (described below) (n = 10) | | | | Power not addressed.
| | | 5) Allergen levels: dust collected from all textile objects in home by vacuum at baseline and at 3, 6, and 12 months
| Avoidance measures (both groups): Described as “normal but intensive household cleaning”
| Duration of study treatment:
| 1 year
| Dates: 6/1988 - 6/1989
| Location: The Netherlands
| Setting: Allergy Department
| Type(s) of providers: NR
Kooistra, Pasch, and Reed, 1978 | Design: RCT, crossover; groups matched for skin test sensitivity to ragweed and Alternaria | No. of subjects at start: 20 | 1) Patient-assessed symptom severity: duration of sneezing, nasal congestion, and itchy eyes, and amount of medication used, recorded for 3 periods each day (day = 8 AM to 5 PM; evening = 5–10 PM; night = 10 PM to 8 AM); values of 0–3 assigned (by investigators?) to each parameter | 1) Patient-assessed symptom severity: (difference between cleaner out - cleaner in) | Quality Scoring:
| | | | | Population similar: Not adequately described
| | Dropouts/withdrawals: 0
| | | | Daytime: 0.15 (4% reduction); p = ns | Intervention(s) described: Yes
| | No. of subjects at end: 20 | | Evening: 0.03 (.9% reduction); p = ns | Comorbidities described: Yes
| Interventions: | | | Night: 0.35 (14% reduction); p = 0.0007 | Diagnosis by MD: Yes
| 1) Air conditioning + home air cleaner (Space Gard^®^, removes particles 6.0 μ and larger with 99% efficiency) | Inclusion criteria: ≥ 5-year history of seasonal hay fever symptoms; skin test ≥ 2+ for ragweed extract | | | Objectively confirmed: Yes
| | | | Total 24 hours: 0.52 (6% reduction); p = 0.06 | Outcome measures valid: No
| | | | | Level of evidence: 2b
| | | | | Randomized: Yes
| | Exclusion criteria: Significant allergy to house dust mite, or animal dander; nasal polyps. No patients were using corticosteroids. None had had immunotherapy in past 2 years. | | 2) Pollen concentrations: | Allocation concealed: Not described
| 2) Air conditioning + placebo air cleaner (no filter) | | | Results seem uninterpretable given the crossover design. Outdoor allergen levels differ between filter-in and filter-out time periods.
| | | | | Double-blind: Yes
| | | | | Blinding adequate: No
| Duration of study treatment: | | 2) Pollen concentrations (indoor and outdoor): recorded at 2 and 4 weeks during each study period | | Dropouts described: Yes
| 4 weeks each treatment period; no wash-out between periods | | | | Intention-to-treat: Yes
| | Age: Range 15–68
| | | | | Notes:
| Dates: 8/10/1976-10/4/1976 | Sex: 11 men; 9 women | | | No statistical test for period effect.
| Location: USA | Race: NR
| | | | | Treatment-by-period interaction assessed: “order of placement of the air cleaner (first half or second half) … had no statistical effect on the symptoms of hay fever.”
| Setting: Allergy clinic? | Other:
| Type(s) of providers:
| Allergists?
| | | | | Power not addressed.
| | | | | All patients had allergic rhinitis; 6 had symptoms of mild asthma.
Korsgaard, 1983 | Design: RCT, parallel-group | No. of subjects at start: 46 | 1) Adherence to prescribed avoidance measures: assessed by questionnaire at baseline and 12 weeks | 1) Adherence to prescribed avoidance measures: | Quality Scoring:
| | | | | Population similar: Yes
| Interventions: | Dropouts/withdrawals: 0 | | Intervention group increased cleaning of bed linen, mattress, bedroom and living room floor, and airing of the bedroom significantly. | Intervention(s) described: No
| 1) Avoidance measures (n = 23), as follows: mattresses vacuumed twice a week; bedding replaced with new synthetic quilts and pillows; bed linen changed and washed twice a week; bedroom floor changed, if necessary, to linoleum or wood and cleaned twice a week; bedroom thoroughly aired for at least 20 minutes every day, and one window left half-open for 24 hours; window in living room open for at least 20 minutes every day; indoor clothes drying to be avoided, if possible; no flowers or plants in bedroom; water-vapor producing activities to be followed by thorough airing | | | | Comorbidities described: Yes
| | No. of subjects at end: 46 | | | Diagnosis by MD: Not applicable
| | Inclusion criteria: Asthma; positive skin test to house dust mites; RAST class ≥ 3 to house dust mite; positive bronchial provocation test to house dust mite | 2) Spirometry (morning and evening peak flow) | | Objectively confirmed: Not applicable
| | | | 2) Spirometry: Not abstracted
| | | | | Outcome measures valid: No
| | | 3) Medication use (terbutaline spray): assessed a) by weighing container when exchanged for a new one (every 4 weeks), and b) by daily diary recordings | 3) Medication use (terbutaline spray): | Level of evidence: 2b
| | | | Baseline (12 weeks); 12 weeks following intervention, median (IQR); p = 0.163 | Randomized: Yes
| | | | | Allocation concealed: Not described
| | Exclusion criteria: Skin test reaction to other indoor allergens (e.g., mold); unable to safely use B2 agonists | | Gp 1: 0.54 g/month (0.26–2.29); 0.33 (0.09–1.33) | Double-blind: No
| | | | | Blinding adequate: Not applicable
| | | | Gp 2: 0.71 g/month (0.42–1.15); 0.40 (0.14–1.41)
| | | | | Dropouts described: Yes
| | | 4) Patient-assessed symptom score: shortness of breath, coughing, and wheezing graded on scale of 0–3 (not described) twice daily (once for 24 hours overall and once for nighttime only) | | Intention-to-treat: Yes
| | Age: Median 30 (range 21–34) | | 4) Patient-assessed symptom score:
| | | | Baseline (12 weeks); 12 weeks following intervention, median (IQR); 24 hour score: p = 0.0184
| | Sex: 32 men; 14 women | | | Notes:
| | | | | Power not addressed.
| | Race: NR | | Gp 1: 9.0 (5.5–14.5); 3.0 (1.0–10.5)
| | | | Gp 2: 9.0 (3.0–16.5); 7.5 (2.0–10.5) | 34 patients had allergic rhinitis.
| | Other:
| | | | Night score: p = 0.0716
| 2) No special avoidance measures (n = 23) | | | Gp 1: 5.0 (0.0–8.5); 0.5 (0.0–4.0)
| | | 5) Indoor absolute humidity: measured during weeks -8, -4, 1, 5, 9, and 12 | Gp 2: 4.0 (0.0–9.5); 3.0 (0.0–7.0)
| Duration of study treatment: | | | 5) Indoor absolute humidity: Not abstracted
| 12 weeks
| Trial preceded by 12-week run-in period | | 6) Allergen levels: dust collected from mattress and bedroom and living room floors (frequency not reported) | 6) Allergen levels: median (IQR) in 0.10 g of dust
| | | | Mattress: p = 0.1532
| Dates: 12/1979-3/1981 | | | Gp 1: 55 (23–346); 122 (18–230)
| | | | Gp 2: 44 (5–398); 64 (8–378)
| Location: Denmark | | | Bedroom floor: p = 0.0001
| | | | Gp 1: 52 (8–204); 16 (5–30)
| Setting: Hospital Chest Clinic | | | Gp 2: 47 (6–201); 74 (21–463)
| | | | Living room floor: p = 0.676
| Type(s) of providers: NR | | | Gp 1: 6 (2–41); 14 (4–71)
| | | | Gp 2: 8 (2–49); 8 (3–70)
Kroidl, Göbel, Balzer, et al., 1998 | Design: RCT, parallel-group | No. of subjects at start: 118 | 1) Patient global evaluation of efficacy: at end of trial, symptoms assessed as “worse,” “same,” or “better” | 1) Patient global evaluation of efficacy: (reported graphically) - no significant difference (approximately 61% better in intervention group vs. 64% in control; p = 0.098) | Quality Scoring:
| | | | | Population similar: Not adequately described
| Interventions: | Dropouts/withdrawals: 40
| 1) Acaracide (Acarosan^®^), applied (by patients) according to manufacturer's written instructions (n = 55). Applied at the start of trial and again at 6 months. | | | | Intervention(s) described: ??
| | No. of subjects at end: 78 | | | Comorbidities described: Yes
| | | | | Diagnosis by MD: Not applicable
| | Inclusion criteria: Asthma requiring regular treatment; skin test and RAST positive for house dust mite | 2) Investigator global evaluation of efficacy | 2) Investigator global evaluation of efficacy: Not abstracted
| | | | | Objectively confirmed: Not applicable
| | | 3) Allergen-specific IgE antibody levels | 3) Allergen-specific IgE antibody levels: Not abstracted | Outcome measures valid: No
| 2) Placebo acaracide (as above, but without active ingredient [benzyl benzoate]) (n = 63). | | | | Level of evidence: 1b
| | Exclusion criteria: “Patients with other relevant allergies;” smoking within 5 years | | | Randomized: Yes
| | | 4) Skin reactivity | 4) Skin reactivity: Not abstracted | Allocation concealed: Not described
| | | 5) Bronchial reactivity | 5) Bronchial reactivity: Not abstracted | Double-blind: Yes
| Duration of study treatment: | Age: Range 8–50 (mean not reported) | | | Blinding adequate: Yes
| 12 months | | | | Dropouts described: Yes
| | | | | Intention-to-treat: No
| Dates: NR | Sex: 67 males; 51 females
| Location: Germany | Race: NR | | | Notes:
| Setting: NR | Other: | | | No outcomes based on daily recording of symptoms.
| Type(s) of providers: NR | | | | 70/118 patients had allergic rhinitis.
| | | | | Power: no discussion.
Marks, Tovey, Green, et al., 1994 | Design: RCT, parallel-group | No. of subjects at start: 35 | 1) Allergen levels: dust samples collected from bed, bedroom floor, and living room floor at baseline and at 2 weeks, 3 months, and 6 months | 1) Allergen levels: | Quality Scoring:
| | | | Results presented graphically and as mean change. | Population similar: Yes
| Interventions: | Dropouts/withdrawals: 5 | | | Intervention(s) described: Yes
| 1) Acaricide (Allersearch DMS^®^) + avoidance measures (n = 17). Acaricide applied once at start of study to both sides of mattress, pillows, duvet, and blankets, as well as to carpets and bedroom and living room furniture. Avoidance measures consisted of placing impermeable covers over mattress, pillows, and duvets. | | | Over 3 sites (bed, bedroom floor, living room floor), Der p I levels decreased significantly at 2 weeks (p = 0.038) but not at 3 months (p = 0.33) or 6 months (p = 0.76) | Comorbidities described: Yes
| | No. of subjects at end: 30 | | | Diagnosis by MD: Not applicable
| | Inclusion criteria: Clinical diagnosis of asthma; reversible airflow obstruction; (all had positive skin tests to at least one inhaled allergen and all but two were positive to house dust mite) | | | Objectively confirmed: Not applicable
| | | 2) Patient-assessed symptom severity:
| | | | | Outcome measures valid: No
| | | Symptoms assessed twice daily, as follows: | 2) Patient-assessed symptom severity: | Level of evidence: 2b
| | | | No significant differences at 1,3, or 6 months. 6-month mean change (95% CI), p = 0.20: | Randomized: Yes
| | | a) Sleep disturbance due to asthma (0 = none, to 3 = awake most of the night); | | Allocation concealed: Not described
| | Exclusion criteria: None specified | | Gp 1: 0.14 (-0.08-037) | Double–blind: No
| | | | Gp 2: -0.06 (-0.31-0.19) | Blinding adequate: Not applicable
| | Age: mean 35 | b) Chest tightness on awakening (0 = not present and didn't require extra bronchodilator during the night, to 2 = present);
| 2) Placebo acaricide (applied as above) (n = 18) | | | 3) Spirometry: Not abstracted | Dropouts described: yes
| | Sex: 18 female; 17 male | | | Intention-to-treat: Can't determine
| Duration of study treatment: | Race: NR
| 6 months | | c) Duration and frequency of daytime wheeze and breathlessness (0 = none, to 3 = most or all of the day);
| | Other: | | | Note: Power not addressed
| Trial preceded by a 3-month run-in period
| Dates: 1989-1990 | | d) Severity of daytime wheeze and breathless-ness (0 = none, to 2 = moderate to severe, distressing and/or had to limit activities);
| Location: Australia
| Setting: Hospital asthma and allergy clinics; general practices
| | | e) Cough (0 = none, to 2 = more than occasional).
| Type(s) of providers: NR
| | | 3) Spirometry (peak flow rates, peak flow variability, FEV1, airway responsiveness [PD20 FEV1])
Moon and Choi, 1999 | Design: RCT, parallel-group | No. of subjects at start: 30 | 1) Allergen levels: dust samples collected by vacuum from bedroom floor, bedding, and mattress at baseline and 1 month | 1) Allergen levels: p<0.05 | Quality Scoring:
| | | | Mean change | Population similar: No
| Interventions: | Dropouts/withdrawals: 1 | | Gp 1: -32.5 | Intervention(s) described: Yes
| 1) “Routine care” (not defined) + avoidance measures (n = 15). Avoidance measures consisted of wrapping mattress in vinyl cover, washing top bedding cover in hot (55° C) water every 2 weeks, removing soft furniture from bedroom, and wet cleaning bedroom floor every day. | | | Gp 2: 15.8 | Comorbidities described: No
| | No. of subjects at end: 29 | | | Diagnosis by MD: Yes
| | | | 2) Patient-assessed symptom severity: p < 0.05 | Objectively confirmed: Yes
| | Inclusion criteria: Allergic rhinitis; skin test ≥ 3+ to house dust mite; positive RAST; skin test for other “common inhalant allergens” was negative | | | Outcome measures valid: No
| | | 2) Patient-assessed symptom severity: symptoms graded [daily or once at beginning and once at end??] as follows: Sneezing (0 = no sneezing attacks, to 3 = more than 10 sneezing attacks); Rhinorrhea (0 = no nose blowings, to 3 = more than 10 nose blowings); Nasal obstruction (0 = no nasal obstruction, to 3 nasal obstruction with predominant mouth breathing) | Mean change | Level of evidence: 2b
| | | | Gp 1: -2.9 | Randomized: Yes
| | | | Gp 2: -0.3 | Allocation concealed: Not described
| | | | | Double-blind: No
| | Exclusion criteria: None specified | | | Blinding adequate: Not applicable
| | Age: 15.6 (range 6–31) | | | Dropouts described: Yes
| | | | | Intention-to-treat: No
| 2) “Routine care” alone (n = 15). Other treatments continued including immunotherapy (52%) and symptomatic treatment (28%). | Sex: 12 female; 17 male
| | Race: NR | | | Note: Power not addressed
| | Other:
| Duration of study treatment:
| 4 weeks
| 4 weeks
| Dates: 7/1995-10-1995
| Location: Korea
| Setting: Allergy clinic of University Hospital
| Type(s) of providers: Allergy clinic nurse
Reisman, Mauriello, Davis, et al., 1990 | Design: RCT, crossover | No. of subjects at start: 40 | 1) Airborne particle counts: measured at baseline, 4 weeks (end of 1^st^ period), and 8 weeks (end of 2^nd^ period) | 1) Airborne particle counts: | Quality Scoring:
| | | | Patient level data given; summary data given as % change without p value | Population similar: Yes
| Interventions: | Dropouts/withdrawals: 8 | | | Intervention(s) described: Yes
| 1) Active HEPA filter (ENVIRACAIRE^®^ with active filter) placed in bedroom | | | Gp 1: 73.4% decrease | Comorbidities described: Yes
| | No. of subjects at end: 32 | | Gp 2: 3.6% increase | Diagnosis by MD: Yes
| | | | | Objectively confirmed: Yes
| | Inclusion criteria: Perennial rhinitis; positive skin test to house dust or house dust mite | 2) Patient-assessed symptom severity: severity and duration of sneezing; nasal discharge; nasal congestion; itchy eyes, ears, nose, and throat; and asthma graded twice each day (for 7 AM to 7 PM and for 7 PM to 7 AM) on scale of 1 (mild/30 minutes) to 3 (severe/ more than 2 hours) | 2) Patient-assessed symptom severity: | Outcome measures valid: No
| 2) Placebo HEPA filter (ENVIRACAIRE^®^ with blank filter) placed in bedroom | | | For 7 individual symptoms and total symptoms compared separately for night- and daytime periods, there were no significant between-group differences (data presented for individual but not total scores) | Level of evidence: 2b
| | | | | Randomized: Yes
| | | | | Allocation concealed: Not described
| | Exclusion criteria: None specified
| Duration of study treatment: | | | | Double-blind: Yes
| 4 weeks each treatment period; no washout between periods | Age: 27.5 (range 6–61) | | | Blinding adequate: Yes
| | | | | Dropouts described: Yes
| | Sex: 12 male; 20 female | | Analysis restricted to final 2-week period of placebo vs. active filter showed improvement for active filter on nasal congestion (p = 0.007) and upper airway itching (p = 0.017); data not reported, only p values given | Intention-to-treat: No
| Dates: Mid-Nov to March (year?) | Race: NR
| | | | | Notes:
| | Other: | | | Carry-over effect reduced by comparing last 2 weeks on treatment.
| Location: US | | 3) Medication use: graded (twice?) daily as follows: 1 = antihistamine or decongestant tablets; 2 = theophylline tablet; 3 = nasal or systemic steroid dose
| Setting: NR | | | 3) Medication use:
| | | | No significant differences; data not presented | No tests for period effect or treatment-by-period interaction.
| Type(s) of providers: NR
| | | | 4) Patient global evaluation of response: | Power not addressed.
| | | 4) Patient global evaluation of response: graded as “improved” or “no difference” at 4 and 8 weeks (end of each treatment period) | Active filter period: 11/32 improved | 11 patients had asthma.
| | | | Placebo filter period: 7/32 improved 14 found no difference
Shapiro, Wighton, Chinn, et al., 1999 | Design: RCT, parallel-group | No. of subjects at start: 44 | 1) Parents' global evaluation of symptom severity: graded as mild, moderate, or severe at baseline, 6 months, and 12 months | 1) Parents' global evaluation of symptom severity: | Quality Scoring:
| | | | | Population similar: No
| Interventions: | Dropouts/withdrawals: 8 | | “No significant changes from baseline”; no data or p-values given. | Intervention(s) described: No
| 1) Aggressive environmental control program (n= 22). Consisted of: application of dust mite impermeable covers to mattress, box spring, and pillow; laundry service delivery of a clean blanket and 4 sets of bed linens every months; and tannic acid acaricide application to bedroom and living room carpet every 2 months. Families instructed to dust and vacuum weekly and to avoid clutter. | | | | Comorbidities described: Yes
| | No. of subjects at end: 36 | | | Diagnosis by MD: Not applicable
| | | | 2) Parents' global evaluation of quality of life:
| | Inclusion criteria: Mild to moderate persistent asthma by NHLBI criteria; ≥ 1 urgent care visit in past 6 months; albuterol use ≥ 5 times/month; positive methacholine challenge at ≤ 10 mg/ml; skin test positive to house dust mite | | | Objectively confirmed: Not applicable
| | | 2) Parents' global evaluation of quality of life: graded on scale of 0 (no symptoms) to 14 (many symptoms) at baseline, 6 months, and 12 months | “Similar for groups and did not change during the course of the year”; no data or p-values given
| | | | | Outcome measures valid: No
| | | | | Level of evidence: 2b
| | | | | Randomized: Yes
| | | | 3) Asthma exacerbations: “Similar for the two groups” | Allocation concealed: Not described
| | | | “Similar for the two groups”
| | | | | Double-blind: Yes
| | | 3) Asthma exacerbations: measured in terms of hospitalizations, ED visits, and steroid bursts | 4) Spirometry (FEV1, bronchial hyper-responsiveness (PD_20_): Not abstracted | Blinding adequate: Yes
| | Exclusion criteria: Already carrying out environmental control measures | | | Dropouts described: Yes
| | | | | Intention-to-treat: No
| | | | 5) Allergen levels: Dust mite concentration categorized as low (<2 μg/g), moderate (2-<10 μg/g), or high (≥ 10 μg/g). 50% of Gp 1 and 16.7% of Gp 2 changed to a lower category (p= 0.03).
| 2) Standard environmental control program (n= 22). Consisted of: general discussion of need to dust and vacuum house weekly and avoid clutter in the bedroom, and the application of placebo tannic acid acaricide every 2 months.
| | Age: 9.5 (range 6–15) | 4) Spirometry (FEV1, bronchial hyper-responsiveness (PD_20_) | | Notes:
| | | | | No symptom data based on daily recordings. Investigators reported that “attempts to collect daily symptom and peak flow diaries were futile.”
| | Sex: 14 male; 22 female
| | Race: 21 White; 9 African-American; 3 Asian-Pacific; 1 Hispanic; 2 other | 5) Allergen levels: dust collected from mattress, bedroom carpet, living room furniture and carpet, and kitchen floor at baseline and at 4, 8, and 12 months
| | | | Mean dust mite levels decreased 19.6% in Gp 1 and increased 33% in group 2 (p= 0.20).
| | | | | Power not addressed.
| | Other:
| Duration of study treatment:
| 1 year
| Trial preceded by 4-week run-in period
| Dates: NR
| Location: US
| Setting: Clinics serving low SES neighborhoods
| Type(s) of providers: NR
Walshaw and Evans, 1986 | Design: RCT, parallel-group | No. of subjects at start: 50 | 1) Allergen levels: dust samples collected at baseline and every 4 months thereafter from mattresses and bedroom and lounge floors using a modified hand-held vacuum | 1) Allergen levels: reported graphically, mattress and bedroom floor mite levels fell significantly for intervention group but not the control group; no between-group comparison given | Quality Scoring:
| | | | | Population similar: No
| Interventions: | Dropouts/withdrawals: 8 | | | Intervention(s) described: No
| 1) Avoidance measures (n= 25). Mattress thoroughly vacuumed and covered with a plastic cover; cover to be damp-dusted at least weekly. Pillows also enclosed in plastic covers. Feather bedding replaced with synthetic polyester or avoided; woolen blankets replaced with cotton cellular or polyester equivalents. All bedding to be washed at least weekly and/or shaken outside frequently. Bedroom carpet to be vacuumed at regular intervals or (preferably) replaced with linoleum, which was to be washed frequently. Soft furnishings and plants to be removed from bedroom. Bathroom door to be kept closed during and immediately after bathing, etc., and kitchen door during and immediately after cooking. Bedroom to be thoroughly ventilated on dry days only. Lounge floor to be vacuumed frequently. | | | | Comorbidities described: Yes
| | No. of subjects at end: 42 | | | Diagnosis by MD: Not applicable
| | Inclusion criteria: Adults with asthma; strongly positive skin test to house dust mite | | | Objectively confirmed: Not applicable
| | | | 2) Relative humidity in the bedroom:
| | | | Fell significantly in 2 of 3 measures for intervention group and 1 of 3 measures for control group compared to baseline; no between-group comparisons | Outcome measures valid: No
| | | 2) Relative humidity in the bedroom: measured at baseline and every 4 months thereafter | | Level of evidence: 2b
| | Exclusion criteria: Other chest disease | | | Randomized: Yes
| | | | | Allocation concealed: Not described
| | Age: Intervention 33 ± 2 (SEM); Control 34 ± 2 (SEM) | | 3) Spirometry: Not abstracted | Double-blind: No
| | | 3) Spirometry (FEV1, FVC, peak flow rates) | | Blinding adequate: Not applicable
| | | | 4) Bronchial reactivity: Not abstracted
| | Sex: 22 male; 28 female | | | Dropouts described: Yes
| | | 4) Bronchial reactivity (PC_20_) | 5) Use of symptomatic medication: | Intention-to-treat: No
| | Race: NR | | Results stratified by RAST positive/negative. Only within-group analysis given.
| | Other: | 5) Use of symptomatic medication (inhaled cromoglycate, broncho-dilators, and steroids; oral steroids): not clear how assessed | | Notes:
| | | | | Power: no discussion.
| | | | 6) Patient- and investigator-assessed symptom severity: (reported graphically)
| | | | | Analysis is a multiple time points with no analysis for overall effect and no consideration of multiple testing.
| | | | Results stratified by RAST positive/negative. Only the RAST positive intervention group showed improvement; no statistical tests reported; no between-group analysis reported.
| | | 6) Patient- and investigator-assessed symptom severity: symptoms assessed at each 4-monthly clinic visit by means of a detailed history
| | | | 7) Total IgE, IgA, IgM, and IgG antibody levels: Not abstracted
| 2) No avoidance measures (n= 25).
| | | 7) Total IgE, IgA, IgM, and IgG antibody levels
| Duration of study treatment:
| 1 year
| Dates: 11/1982 - 4/1984
| Location: UK
| Setting: Hospital-based chest clinics
| Type(s) of providers: NR
Warburton, Niven, Pickering, et al., 1994 | Design: RCT, crossover | No. of subjects at start: 13 | 1) Patient-assessed symptom severity: cough, phlegm production, wheeze, breathlessness, and chest tightness graded daily on visual analog scale; frequency of nocturnal wakening also recorded | 1) Patient-assessed symptom severity: | Quality Scoring:
| | | | No significant difference in mean symptom scores for any individual symptom (no variance given for means) | Population similar: Yes
| Interventions: | Dropouts/withdrawals: 1 | | | Intervention(s) described: No
| 1) HEPA filter placed in main living room. Patients advised to leave unit running continuously and to keep external windows closed as much as possible. | | | | Comorbidities described: Yes
| | No. of subjects at end: 12 | | | Diagnosis by MD: Not applicable
| | Inclusion criteria: Volunteers with asthma; positive skin test to house dust mite antigen and to ≥ 1 of 3 fungal species | | 2) Use of symptomatic medication: | Objectively confirmed: Not applicable
| | | | No significant difference in mean bronchodilator use (no variance given for means)
| | | | | Outcome measures valid: No
| | | | | Level of evidence: 2b
| 2) Placebo HEPA filter (same external unit, internal HEPA and charcoal filters removed), employed as above. | | 2) Use of symptomatic medication (broncho-dilators): recorded daily | | Randomized: Yes
| | Exclusion criteria: NR | | 3) Spirometry: Not abstracted | Allocation concealed: Not described
| | Age: 45.5 (range 19–64) | | 4) Bronchial reactivity: Not abstracted | Double-blind: Yes
| | | 3) Spirometry (FEV1, FVC, morning and evening peak flow rates) | | Blinding adequate: No
| Duration of study treatment: | Sex: 8 male, 4 female | | 5) Airborne allergen levels: | Dropouts described: Yes
| Mean duration of active treatment was 30.3 days (range, 21–45); mean duration of placebo treatment was 24.0 days (range, 20–33) | | | Intervention period: 0.038 ± 0.025 mg/m^-3^ | Intention-to-treat: No
| | Race: NR
| | | 4) Bronchial reactivity (PD_20_) | Control period: 0.028 ± 0.015 mg/m^-3^
| | Other: | | No significant difference | Notes:
| | | | | No assessment of carry-over effect, period effect, or treatment-by-period interaction.
| | | 5) Airborne allergen levels: measured using Rotheroe and Mitchell pumps at height of 1.5 m in living room; measured at baseline and at end of each treatment period
| Trial preceded by run-in period of unspecified length
| | | | | Power: no discussion.
| Dates: NR
| Location: UK
| Setting: NR
| Type(s) of providers: NR
Wood, Johnson, Van Natta, et al., 1998 | Design: RCT, parallel-group | No. of subjects at start: 38 | 1) Allergen levels: dust collected from carpet or upholstered furniture; air samples obtained with small portable pump | 1) Allergen levels: Baseline; 3-month Airborne Fel d 1, ng/m3; p = 0.045 for completers analysis; p = 0.152 for ITT | Quality Scoring:
| | | | | Population similar: Yes
| Interventions: | Dropouts/withdrawals: 3 | | | Intervention(s) described: Yes
| 1) Active HEPA filter (Envirocare^®^ with active filter) in bedroom + avoidance measures (described below) (n = 18) | | | Gp 1: 3.0 ± 1.1; 1.7 ± 1.7 | Comorbidities described: Yes
| | No. of subjects at end: 35 | | Gp 2: 2.6 ± 1.2; 2.8 ± 1.8 | Diagnosis by MD: Yes
| | | | | Objectively confirmed: Yes
| | Inclusion criteria: Adults with asthma or allergic rhinitis and symptoms associated with cat contact; symptoms requiring medication use on ≥ 50% of days; positive skin prick test and RAST to cat allergen; home with ≥ 1 cat | 2) Patient-assessed symptom severity: nasal congestion, rhinorrhea, sneezing, coughing, wheezing, and chest tightness graded on scale of 0 (none) to 3 (severe) three times per day; sleep difficulty recorded daily (yes/no) | Settled dust Fel d 1; ug/g; p = 0.407 completers analysis | Outcome measures valid: No
| | | | | Level of evidence: 1b
| | | | Gp 1: 10.1 ± 2.3; 10.5 ± 1.6 | Randomized: Yes
| 2) Placebo HEPA filter (Envirocare^®^ with filter removed) in bedroom + avoidance measures (described below) (n = 17) | | | Gp 2: 11.8 ± 0.9; 10.6 ± 1.1 | Allocation concealed: Not described
| | | | 2) Patient-assessed symptom severity: | Double-blind: Yes
| | | | Results presented separately for nasal and chest symptoms at 3 time periods (morning, afternoon, night). No significant between-group differences for any of the 6 comparisons | Blinding adequate: Yes
| | | | | Dropouts described: Yes
| | Exclusion criteria: Severe asthma | | | Intention-to-treat: Yes
| Avoidance measures (both groups): bed fitted with impervious mattress and pillow covers; subjects instructed to wash bedding once a week and to keep cats from entering bedroom at all times
| | Age: 36.3 (range 23–60)
| | | 3) Medication use: recorded in daily diaries | Nasal am: | Notes:
| | Sex: 10 male; 25 female | | Gp 1: 1.40 ± 0.60; 0.91 ± 0.61 | 28/35 patients had asthma;
| | | | Gp 2: 1.22 ± 0.63; 0.88 ± 0.64 | 35/35 had allergic rhinitis
| | Race: NR | 4) Spirometry (morning and evening peak flow rates, FEV1, MCh reactivity, cat RAST levels) | p = 0.769
| | | | Nasal pm: | Compliance: assessed using internal timers; machines operated at least 80% of the 3 months by 83% of intervention and 94% of placebo group.
| | Other: | | Gp 1: 1.16 ± 0.62; 0.74 ± 0.59
| | | | Gp 2: 1.04 ± 0.58; 0.82 ± 0.66
| Duration of study treatment: | | | p = 0.534
| 3 months | | | Nasal night:
| | | | Gp 1: 1.01 ± 0.64; 0.67 ± 0.71
| Trial preceded by 1-month baseline period | | | | Post-hoc power analysis estimated 284-14,744 subjects needed depending on outcome addressed.
| | | | Gp 2: 0.70 ± 0.55; 0.64 ± 0.69
| | | | p = 0.138
| | | | Chest am:
| Dates: NR
| | | | Gp 1: 0.82 ± 0.61; 0.29 ± 0.38
| Location: US | | | Gp 2: 0.86 ± 0.63; 0.55 ± 0.60
| | | | p = 0.388
| Setting: Advertisement; University Allergy Clinic | | | Chest pm:
| | | | Gp 1: 0.71 ± 0.60; 0.28 ± 0.39
| | | | Gp 2: 0.80 ± 0.59; 0.59 ± 0.56
| Type(s) of providers: NR | | | p = 0.179
| | | | Chest night:
| | | | Gp 1: 0.62 ± 0.62; 0.29 ± 0.49
| | | | Gp 2: 0.56 ± 0.53; 0.37 ± 0.60
| | | | p = 0.215
| | | | 3) Medication use: Reported for nasal and chest medications, prn and maintenance medications. No significant differences for any of the 4 comparisons.
| | | | 4) Spirometry: Not abstracted
Zwemer and Karibo, 1973 | Design: RCT, crossover | No. of subjects at start: 18 | 1) Patient-assessed symptom severity: day- and nighttime cough and wheezing graded daily on scale of 0 (none) to 6 (severe, intolerable); sick days (from school), number of asthma attacks, nights with normal sleep, and number of times awakened by symptoms also recorded daily | 1) Patient-assessed symptom severity: | Quality Scoring:
| | | | 7 excellent improvement; 4 good improvement; 1 fair improvement | Population similar: No
| Interventions: | Dropouts/withdrawals: 6 | | | Intervention(s) described: Yes
| 1) Pure-zone System^®^ clean air head board (air filtering system built into head board of bed). | | | | Comorbidities described: Yes
| | No. of subjects at end: 12 | | 2) Use of symptomatic medication: 5 reduced treatment | Diagnosis by MD: Not applicable
| | Inclusion criteria: Asthma; positive skin tests to house dust and other indoor allergenic materials; receiving hyposensitization and advised to practice environmental control | | | Objectively confirmed: Not applicable
| 2) Placebo system (same as above, but with filter removed). | | | | Outcome measures valid: No
| | | | | Level of evidence: 3b
| | | | | Randomized: Yes
| | | | | Allocation concealed: Not described
| Duration of study treatment:
| 2 weeks each treatment period | Exclusion criteria: None | 2) Use of symptomatic medication: recorded daily | | Double-blind: Yes
| | | | | Blinding adequate: No
| | Age: range 6–16 | | | Dropouts described: Yes
| Dates: Winter season | | | | Intention-to-treat: No
| | Sex: 7 male; 11 female
| Location: USA
| | Race: NR | | | Notes:
| Setting: University practices | | | | No assessment of carry-over effect, period effect, or treatment-by-period interaction.
| | Other:
| Type(s) of providers:
| Pediatric allergists
| | | | | Power: Not addressed
| | | | | Poorly reported; no analytic plan given and no statistics reported.
| | | | | Reports some failure of blinding (patients detected assignment).

† Quality scoring criteria were as follows:

Population similar: Was the study population described and reasonably similar to an adult working US population? (Yes [described and similar], No [described, but not similar], Not adequately described)

Intervention(s) described: Were the intervention protocols referenced or described in sufficient detail to replicate? (Yes, No)

Comorbidities described: Was the presence of comorbid asthma (or other upper respiratory conditions) described in the study population? (Yes, No)

Diagnosis by MD: Was the diagnosis of allergic rhinitis based on physician diagnosis? (Yes, No, Not applicable [asthma patients only])

Objectively confirmed: If physician-diagnosed, was the diagnosis supported by objective evidence of allergy (e.g., skin prick or serum IgE antibody testing)? (Yes, No, Not applicable)

Outcome measures valid: Were the main outcomes of interest to us measured in a way that has been demonstrated empirically to be valid and reliable (e.g., using a standardized scale such the RQLQ or SF-36)? (Yes, No, Not adequately described)

Level of evidence: Based on Oxford Center for Evidence-Based Medicine Levels of Evidence (1a, 1b, 1c, 2a, 2b, 2c, 3a, 3b, 4, 5)

Randomized: Was the study described as “randomized”? (Yes, No)

Allocation concealed: If the method for concealing allocation from the investigators was described, was it adequate (table of random numbers, computer-generated, coin tossing, etc.) or inadequate (alternating, date of birth, hospital number, etc.)? (Not described, Yes [described and adequate], No [described, but inadequate])

Double-blind: Was the study described as “double-blind”? (Yes, No)

Blinding adequate: If the method of double-blinding was described, was it adequate (e.g., identical placebo, active placebo, injection vs. tablet with double dummy) or inadequate (e.g., tablet vs. injection with no double dummy)? (Not described, Yes [described and adequate], No [described, but inadequate])

Dropouts described: Did the study describe dropouts and withdrawals so that all patients entering the trial could be accounted for? (Yes, No)

Intention-to-treat: Was the analysis performed according to the intention-to-treat principle? (Yes, No, Can't determine)

Evidence Table 3. Immunotherapy

Study | Design and Interventions | Patient Population | Outcomes Reported | Results | | | Quality Score†/Notes
Alvarez-Cuesta, Cuesta-Herranz, Puyana-Ruiz, et al., 1994 | Design: RCT, parallel-group | No. of subjects at start: 28 | 1) Adverse reactions | 1) Adverse reactions: | | | Quality Scoring:
| | | | 10 subjects had 14 “reactions,” 7 local and 3 systemic. | | | Population similar: Yes
| Interventions: | Dropouts/withdrawals: 0 | 2) Patient global evaluation of efficacy (PSE): at end of study, patients asked to grade their symptoms during direct contact with cats in relation to such symptoms before trial on scale of 0% (complete failure) to 100% (total success) | | | | Intervention(s) described: Yes
| 1) Biologically standardized cat dander extract, quantified with monoclonal antibodies (100 biological units [BU] = 33 μg of Fel d I antigen, 650 μg of albumin, and 99 μg of Fel d Bd/K30 antigen) (n = 14). Gradually increasing doses administered twice weekly until dose of 13.2 μg of Fel d I or maximum tolerated dose reached; maintenance dose then repeated monthly with extract absorbed in aluminum hydroxide gel. Average maintenance dose 11.3 ± 4.7 μg of Fel d I (34.4 ± 14.3 BU); average total cumulative dose 170 μg Fel d I (515 BU). | | | | | | Comorbidities described: No
| | No. of subjects at end: 28 | | 2) Patient global evaluation of efficacy: | | | Diagnosis by MD: Yes
| | | | Average 81.3 ± 15.5% improvement | | | Objectively confirmed: Yes
| | Inclusion criteria: Rhino-conjunctivits and asthma; 18+ months duration; exacerbated by exposure to cat; positive skin test and specific IgE to cat | | active vs. 20.7 ± 33.2% placebo; p < 0.001 | | | Outcome measures valid: No
| | | | | | | Level of evidence: 1b
| | | | | | | Randomized: Yes
| | | | 3) Patient-assessed symptom severity and use of symptomatic medication (combined in a single measure): | | | Allocation concealed: Not described
| | | | | | | Double-blind: Yes
| | Exclusion criteria: Prior immunotherapy; sensitization to other perennial antigens (not specified); contraindication to immunotherapy | | 0.14 ± 0.35 active vs. 1.42 ± 0.51 placebo; p < 0.001 | | | Blinding adequate: Not described
| | | 3) Patient-assessed symptom severity and use of symptomatic medication (combined in a single measure): unspecified symptoms graded daily on scale of 0–3 (not described); use of symptomatic medication recorded daily in study diaries
| | | | | | | Dropouts described: Yes
| | | | 4) Skin reactivity: Not abstracted | | | Intention-to-treat: Yes
| | | | 5) Conjunctival reactivity: Not abstracted
| | Age: 15–65 years old; mean 24 active 29 placebo | | | | | Notes:
| | | | | | | Subjects also had to take environmental precautions for 12 months prior to immunotherapy, which included removing cat from home.
| | | | 6) Bronchial reactivity: Not abstracted
| | Sex: 6M/22F
| 2) Placebo (constituents not described) (n = 14) | Race: NR
| | Other: | 4) Skin reactivity
| Duration of study treatment:
| 1 year | | 5) Conjunctival reactivity
| Symptomatic medication permitted, but not described | | 6) Bronchial reactivity
| Dates: NR
| Location: Spain
| Setting: University hospitals
| Type(s) of providers: Specialists
Ariano, Kroon, Augeri, et al., 1999 | Design: RCT, parallel-group | No. of subjects at start: 25 | 1) Adverse reactions: classified according to following scale: 1 = mild local = wheal/flare < 5 cm, granuloma persisting < 1 week, slight pain; 2 = moderate local = wheal/flare < 10 cm, granuloma persisting < 3 weeks; 3 = severe local = wheal/flare > 10 cm, granuloma persisting > 3 weeks, pain requiring medications; 4 = mild systemic = rhinitis, conjunctivitis, asthma, and urticaria not requiring treatment; 5 = severe systemic = as above (4), but requiring pharmacologic treatment | 1) Adverse reactions: | | | Quality Scoring:
| | | | Placebo: no systemic or local reactions | | | Population similar: Yes
| Interventions: | Dropouts/withdrawals: 0 (at end of year 1) | | Active: 2 moderate (asthma), 3 mild (rhinitis) systemic reactions. 5 mild, 3 moderate, 4 severe local reactions. All during buildup phase. | | | Intervention(s) described: Yes
| 1) Allergoid extract of Parietaria (wall pellitory) pollen (Purethal™-Parietaria) (n = 13). Glutaraldehyde-modified allergoid obtained from equal parts Parietaria judaica and P. officinalis pollens. Extract standardized to 20,000 AUeq per ml. Build-up phase: increasing doses (1,000; 2,000; 4,000; 6,000; 8,000; and 10,000 AUeq) injected each week. Maintenance phase: 10,000 AUeq injected each month. In event of AEs, dose repeated or temporarily reduced, according to international guidelines. | | | | | | Comorbidities described: Yes
| | | | | | | Diagnosis by MD: Yes
| | No. of subjects at end: 25 (end of year 1) | | | | | Objectively confirmed: Yes
| | | | | | | Outcome measures valid: No
| | | | 2) Patient-assessed symptom severity and medication use (combined in a single measure): | | | Level of evidence: 2b
| | Inclusion criteria: Single sensitization to Parietaria by skin test and RAST; 2 years of disease; rhinoconjunctivitis | | | | | Randomized: Yes
| | | | | | | Allocation concealed: Not described
| | | | Median symptom score after 1 year ˜1,250 placebo and ˜550 active (p = 0.02). However, baseline scores not given. (Values estimated from figure.)
| | | | | | | Double-blind: Yes
| | | | | | | Blinding adequate: Yes
| | Exclusion criteria: Anatomic alteration of upper airway; immunodeficiency; malignancies; severe psychologic disorders; chronic steroids; beta-blockers; SIT in last 5 years; pregnant or lactating women | | | | | Dropouts described: Yes
| | | | | | | Intention-to-treat: Yes
| | | | 3) Patient global evaluation of efficacy:
| | | | (Active vs. Placebo)
| | | | Frequency of symptoms: (p = 0.001) | | | Notes: No histamine in placebo injection.
| | | | Decr-10 v 1
| | | | Unch-3 v 9
| | | | Incr- 0 v 2
| | Age: 13–62 (mean 32.1) | | Physical Performance (p = 0.043)
| | | 2) Patient-assessed symptom severity and medication use (combined in a single measure): sneezing, rhinorrhea, nasal obstruction, nasal/conjunctival itching, lacrimation, cough, and wheezing graded daily on scale of 0 (no symptom) to 2 (severe); use of symptomatic medication recorded in daily diaries (each dose recorded as score of 1) | Imp-6 v 1
| 2) Placebo (same as above, except for allergen) (n = 12) | Sex: 17 F | | Unch-6 v 9
| | | | Worse-1 v 2
| | Race: NR | | Duration of symptoms (p = 0.024)
| Duration of study treatment: | | | Short-5 v 0
| 1 year (RCT phase); trial followed by 2-year open study during which all patients received active treatment | Other: 5 subjects had mild asthma (3 active, 2 placebo) | | Unch-8 v 7
| | | | Leng-0 v 5
| | | | Satisfaction (p = 0.002)
| | | | Yes-11 v 0
| | | | Indiff-1 v 0
| Symptomatic medication permitted: Loratadine or cetirizine (10 mg/day), beclomethasone nasal spray (100 μg/puff), and inhaled albuterol (100 μg/puff) | | | No-1 v 11
| | | | VAS % improvement
| | | | Active 31.6 v Placebo -15.0 (p = 0.01)
| | | | 4) Skin reactivity: Not abstracted
| | | 3) Patient global evaluation of efficacy: assessed at 1 year in two ways: a) with a questionnaire on frequency of symptoms, physical performance, duration of complaints, and global satisfaction (each graded as “improved,” “unchanged,” or “worsened”); and b) with a visual analog scale running from + (clinical condition improved) to - (worsening of clinical condition)
| Dates: October 1990-1991 | | | 5) Allergen-specific IgG_4_ and IgE levels: Not abstracted
| Location: Presumably Italy, but not stated
| Setting: Presumably academic Allergy and Immunology Department, but not stated
| Type(s) of providers: Presumably allergists
| | | 4) Skin reactivity
| | | 5) Allergen-specific IgE and IgG4 antibody levels
Arvidsson, Löwhagen, and Rak, 2002 | Design: RCT, parallel-group | No. of subjects at start: 49 | 1) Patient-assessed symptom severity: evaluated in two ways: | 1) Patient-assessed symptom severity: | | | Quality Scoring:
| | | | Median symptom scores | | | Population similar: Yes
| Interventions: | Dropouts/withdrawals: 3 | | 1^st^ pollen season | | | Intervention(s) described: Yes
| 1) Aluminum-adsorbed birch pollen (Betula verrucosa) extract (Alutard^®^ SQ) (n = 24). Clustered protocol, with 14 gradually increasing doses (from 10 to 100,000 SQ-U) given over 7 to 8 weeks. Maintenance injections (100,000 SQ-U) given every 6 weeks for remainder of study. | | a) runny nose/sneezing, blocked nose, eye symptoms, and bronchial symptoms graded daily during pollen season on scale of 0 (none) to 3 (severe); and | SIT 1.3 (range 0–5.2) | | | Comorbidities described: Yes
| | No. of subjects at end: 46 | | Pl 2.1 (range 0.6–5.6) | | | Diagnosis by MD: Yes
| | | | P=0.05 | | | Objectively confirmed: Yes
| | Inclusion criteria: History of birch pollen-induced symptoms from the upper airways; positive skin prick test (> 3 mm wheal) to Betula verrucosa; positive RAST; positive conjunctival provocation test | | | | | Outcome measures valid: No
| | | | 2^nd^ pollen season | | | Level of evidence: 2b
| | | | SIT 2.6 (range 0–6.5) | | | Randomized: Yes
| | | | Pl 4.3 (range 2.4–9.1) | | | Allocation concealed: No
| | | b) patient's perception of severity of symptoms graded once per week during pollen season on a VAS (0–10, end points not described) | P=0.005 | | | Double-blind: Yes
| | | | | | | Blinding adequate: Yes
| | | | 2) Use of symptomatic medication: | | | Dropouts described: Yes
| | Exclusion criteria: perennial symptoms from upper or lower airways; sensitivity to house dust mit or mold; previous treatment with SIT; treatment with topical steroids | | The placebo group used significantly more rescue medication than the active group during both seasons (p=0.004 in 1997 and p=0.004 in 1998) | | | Intention-to-treat: No
| 2) Placebo (diluent + histamine dihydrochloride) (n = 25).
| | | | | | | Notes:
| | | 2) Use of symptomatic medication: recorded daily during pollen season; scored as follows: | | | | Long-term study
| Duration of study treatment: | | | 3) Adverse reactions:
| Up to 2 years over 2 pollen seasons | | | | SIT | placebo
| | Age: mean 32 years | | Total AE | 71 | 81
| | (range 19 to 46 years) | 1 point: acrivastine capsule, terbutaline inhalation, or salbutamol inhalation; | # pts | 22 | 20
| Symptomatic medication permitted: Acrivastine capsule 8 mg; terbutaline inhalation 0.5 mg; salbutamol inhalation 0.4 mg; and sodium cromoglycate eye drops (40 mg/ml) and nasal spray (5.2 mg/ml); if needed, patients could request topical steroids (budesonide nasal powder [100 μg/dose] or inhalation powder [200 μg/dose]) | | | general sx | 40.7% | 46.7%
| | Sex: 59% women | | respiratory | 27.6% | 19.8%
| | | | (rhinitis or cough)
| | Race: NR | 2 points: sodium cromoglycate eye drop or nasal spray puff; | post-injection | 4 | 7
| | | | (all mild)
| | Other:
| | 21 patients also sensitive to grass pollen; 30 patients also sensitive to animal dander, but none had exposure to pets during the study | 4 points: budesonide nasal powder or inhalation powder dose
| | | 3) Adverse reactions
| Dates: Treatment began Nov 1996 to Jan 1997; study ended June 1998
| Location: Goteborg, Sweden
| Setting: Allergy clinic
| Type of providers: Allergists
Bernstein, Tennen-baum, Georgakis, et al., 1976 | Design: RCT, parallel-group (matched-pairs design) | No. of subjects at start: 148 | 1) Investigator global assessment of treatment response | 1) Investigator global assessment of treatment response: Not abstracted | | | Quality Scoring:
| | | | | | | Population similar: Yes
| | Dropouts/withdrawals: 17 | | | | | Intervention(s) described: Yes
| Interventions: | 13 lost to followup (10 P v 3 A); | | 2) Patient-assessed symptom severity: | | | Comorbidities described: No
| 1) Alum-adsorbed Fraction A (partially purified derivative of aqueous ragweed extract) (n = 68). Cumulative dose of 24,000 PNU to be attained in 20 doses, but more injections required when large local or systemic reactions occurred. Goal for 1972 pre-season (injections given weekly) was to attain maximum individual dose of 6,000 PNU. During season, ½ of maximum pre-seasonal dose given every week. This dose continued every 4 weeks after end of season until 2 months prior to 1973 season, when maximum dose again reached at weekly intervals. | 4 serious systemic reaction | 2) Patient-assessed symptom severity: unspecified symptoms graded daily during pollen season on scale of 0 (no symptoms/ no significant symptoms) to 3 (significant symptoms not controlled by regular medication, but controlled by steroids) | Assessed in only 112 patients. Data lost in mail on 19. | | | Diagnosis by MD: Yes
| | | | | | | Objectively confirmed: Yes
| | No. of subjects at end: 131 completed 1972 season. | | Symptom Score (active v placebo): | | | Outcome measures valid: No
| | | | 1.097 v 1.378 (p < 0.05) | | | Level of evidence: 1b
| | | | | | | Randomized: Yes
| | Inclusion criteria: Definite seasonal history; clinical findings of ragweed hayfever 3+ years; no IT for at least 1 year; positive skin test to Fraction A | | 3) Use of symptomatic medication: | | | Allocation concealed: Not described
| | | | Drug Score (active v placebo):
| | | | 0.411 v 0.584 (p < 0.05) | | | Double-blind: Yes
| | | | | | | Blinding adequate: Yes
| | | | 4) Immunologic parameters (hemagglutinating antibodies, RAST): | | | Dropouts described: Yes
| | | | | | | Intention-to-treat: No
| | Exclusion criteria: None specified | 3) Use of symptomatic medication: recorded daily during pollen season as 0 (no medication taken) or 1 (medication taken) | Not abstracted
| | Age: Mean age 30 | | 5) Adverse reactions: | | | Notes:
| | | | Systemic effects in 17 patients (1.4% of injections) in active group and 6 patients in placebo group. Of these 6 active and 2 placebo treated patients had serious systemic reactions. 3 of 6 active group patients tolerated subsequent injections. Local reactions in 24 active group patients (2.3% of injections). | | | Results reported for 1^st^ year of 2-year trial.
| | Sex: 63 F
| | Race: NR | 4) Immunologic parameters (hemagglutinating antibodies, RAST) | | | | No histamine in placebo.
| | Other: 1/3 recipients had previous ragweed immunotherapy
| 2) Placebo (n = 63)
| | | 5) Adverse reactions
| Duration of study treatment:
| Approx. 2 years; protocol began with pre-seasonal treatment before 1972 ragweed season and extended through 1973 season
| Symptomatic medication permitted: Not described
| Dates: 1972 Ragweed season
| Location: Cincinatti, OH
| Setting: Academic immunology practice
| Type(s) of providers:
| Specialists
Blainey, Phillips, Ollier, et al., 1984 | Design: RCT, parallel-group | No. of subjects at start: 39 | 1) Patient-assessed symptom scores (clinic visits): nasal blockage, sneezing, rhinorrhea, and sleep disturbance graded at each clinic visit on 10-cm visual analog scale running from “no symptoms” to “very severe symptoms” | 1) Patient-assessed symptom scores (clinic visits): | | | Quality Scoring:
| | | | | | | Population similar: Yes
| Interventions: | Dropouts/withdrawals: 16 | | No data. | | | Intervention(s) described: Yes
| 1) Tyrosine-adsorbed extract of Dermatophagoides pteronyssinus (house dust mite) (Migen®) (n = 17). | 4 patients did not complete initial 6 weekly injection series (3 placebo patients withdrew for “social” reasons, 1 active patient had severe reaction). | | | | | Comorbidities described: No
| | | | 2) Nasal reactivity: Not abstracted | | | Diagnosis by MD: Yes
| | | | | | | Objectively confirmed: Yes
| | | | 3) Total IgE, specific IgE, and specific IgG antibodies: Not abstracted | | | Outcome measures valid: No
| | | | | | | Level of evidence: 2b
| Build-up phase: 6 injections at weekly intervals, with doses increasing from 4 to 400 Noon units (10^-6^ g of whole allergen in ml of solution). | 10 patients withdrew during the monthly injection phase due to lack of response (9/18 placebo and 3 of 17 active). | | | | | Randomized: Yes
| | | | 4) Skin reactivity: Not abstracted | | | Allocation concealed: Not described
| | | 2) Nasal reactivity | 5) Use of symptomatic medication: | | | Double-blind: Yes
| | | | (see Notes) | | | Blinding adequate: Yes
| Maintenance phase: 10 monthly injections at highest dose (400 Noon units), starting 4 weeks after last weekly injection. | No. of subjects at end: 23 | 3) Total IgE, specific IgE, and specific IgG antibodies | No data. | | | Dropouts described: Yes
| | | | | | | Intention-to-treat: No
| | Inclusion criteria: Not specified, but all had history of perennial rhinitis exacerbated by dust from mattresses and bedding. All had positive ST or nasal provocation study. All were non-responders to topical corticosteroids and avoidance measures. 15 patients had symptoms after contacting domestic animals or had seasonal exacerbation between May and August. | | 6) Patient global evaluation of efficacy of treatment:
| | | 4) Skin reactivity | 11 patients in active group and 5 patients in placebo group considered treatment effective (p < 0.05)
| 2) Placebo (tyrosine-containing suspension) (n = 18) | | 5) Use of symptomatic medication: recorded daily in study diaries
| | | | | | | Notes:
| | | | 7) Adverse reactions: | | | Symptoms scored daily in study diaries, but results not reported because study participants “not thorough enough in completing their diary cards, particularly for drug usage.”
| | | | 1 withdrawal for severe reaction. 5 patients in active group and 6 in placebo group with local reaction. Exacerbation of rhinitis or asthma in 3 active and 5 placebo patients.
| Duration of study treatment: | | 6) Patient global evaluation of efficacy of treatment: assessed at end of study by asking patients, “Did your symptoms (blocked or runny nose and sneezing attacks) improve after the course of injections?”
| 13 months (including 4-week run-in); final post-treatment results taken from 1 month after last maintenance treatment (14 months)
| | Exclusion criteria: None specified | | | | | High dropout rate.
| Trial preceded by 4-week run-in phase during which patients were treated with beclomethasone dipropionate nasal spray and house dust mite avoidance measures | Age: 17–36 (mean age 26) | | | | | No histamine in placebo.
| | Sex: 20 F after initial 6 week injections.
| | | 7) Adverse reactions
| | Race: NR
| Symptomatic medication permitted: Beclomethasone dipropionate or xylometazoline; patients “encouraged to reduce therapy if they felt able to do so without recurrence of troublesome symptoms” | Other:
| Dates: Enrollment over 2 successive years — not specified
| Location: London
| Setting: Not specified, but presumably academic respiratory unit
| Type(s) of providers:
| Specialists
Bødtger, Poulsen, Jacobi, et al., 2002 | Design: RCT, parallel-group | No. of subjects at start: 35 | 1) Patient-assessed symptom severity: symptoms of the nose, eyes, and lungs graded daily from 13 March to 21 May on scale of 0 (none) to 3 (severe) | 1) Patient-assessed symptom severity: | | | Quality Scoring:
| | | | IT 31.5 (6.0–50.0) | | | Population similar: Yes
| Interventions: | Dropouts/withdrawals: 1 | | PI 44.0 (14.0–75) | | | Intervention(s) described: Yes
| 1) Aluminum-adsorbed birch pollen (Betula verrucosa) extract (Alutard^®^ SQ) (n = 17). Clustered protocol, with 11 injections of gradually increasing doses (from 10 to 100,000 SQ-U) given over 7 weeks. Dose modifications made in the event of local or systemic adverse reactions. Maintenance injections (100,000 SQ-U) given 2 and 6 weeks after maximum dose achieved, then every 8 weeks for remainder of treatment period. | | | P < 0.05 | | | Comorbidities described: Yes
| | No. of subjects at end: 34 | | | | | Diagnosis by MD: Yes
| | | | 2) Use of symptomatic medication: | | | Objectively confirmed: Yes
| | Inclusion criteria: At least 2 seasons of severe allergic symptoms in April and May (birch pollen season); poor symptom control in previous seasons on regular antiallergic treatment; positive skin prick tests (> 3 mm wheal) to Betula verrucosa; positive RAST | | IT 52.0 (2.0–114.0) | | | Outcome measures valid: No
| | | | PI 102 (2.0–186) | | | Level of evidence: 2b
| | | 2) Use of symptomatic medication: recorded in study diaries from 13 March to 21 May; scored as follows: | P < 0.02 | | | Randomized: Yes
| | | | | | | Allocation concealed: No
| | | | 3) Patient global evaluation of efficacy: | | | Double-blind: Yes
| | | | | SIT | PI | Blinding adequate: Yes
| | | | | (Y/N) | | Dropouts described: Yes
| | | 1 point: each drop or spray of levocabastine or inhalation of salbutamol; | Effect of treatment | 15/2 | 8/9 | Intention-to-treat: No
| | | | P < 0.03
| | | | Symptom decrease | 14/3 | 8/9
| | Exclusion criteria: Previous SIT toward birch; lactation or pregnancy at start of injection therapy; perennial rhinitis or asthma; continuous use of systemic beta-blockers. | 2 points: each dose of acrivastine or prednisolone | p > 0.07 | | | Notes:
| | | | Medication reduced | 10/7 | 5/12
| | | | P = 0.17
| | | | Increased well-being | 14/3 | 5/12
| 2) Placebo (diluent with gradually increasing concentrations of histamine dihydrochloride) (n = 18). | | 3) Patient global evaluation of efficacy: assessed at 1-year follow-up in two ways: a) with a visual analog scale (not described) describing the overall severity of the pollen season; and b) with a non-validated questionnaire asking patients whether they had experienced any effect of treatment, a reduction in symptoms, a reduction in medication use, or increased well-being during the pollen season (yes/no for each question) | P < 0.006
| | | | 4) Conjunctival reactivity: Not abstracted
| | Age: median 27 years (range 19 to 46)
| Duration of study treatment: | | | 5) Nasal reactivity: Not abstracted
| 10 months (Jan to Nov); symptoms monitored for one allergy season (April-May); 1-year follow-up | Sex: 60% women
| | | | 6) Skin reactivity: Not abstracted
| | Race: NR
| | | | 7) Histamine release: Not abstracted
| | Other:
| Symptomatic medication permitted: Acrivastine 8 mg; levocabastine eye drops (0.5 mg/ml) and nasal spray (50 μg/dose); and salbutamol inhalations (200 μg/dose); if necessary, a 1-week course of oral prednisone (12.5 mg/day) could be prescribed | 14 patients had seasonal asthma symptoms; 20 patients had self-reported allergy to grass pollen | | 8) Total and specific IgE: Not abstracted
| | | | 9) Adverse reactions:
| | | | | SIT | placebo
| | | | Grade 3–4 | 0 | 0
| | | | Grade 1–2 | 7 | 16
| | | | Immediate SE | 7 | 14
| | | 4) Conjunctival reactivity | Late SE | 0 | 2
| Dates: Jan 2000 through autumn 2001 | | 5) Nasal reactivity
| | | 6) Skin reactivity
| Location: Copenhagen, Denmark
| | | 7) Histamine release
| Setting: Allergy clinic | | 8) Total and specific IgE
| Type(s) of providers: Allergists | | 9) Adverse reactions
Bousquet, Frank, Soussana, et al., 1987 | Design: RCT, parallel-group | No. of subjects at start: 59 | 1) Adverse reactions | 1) Adverse reactions: 6/39 allergoid-treated pts had systemic reactions (5 mild, 1 urticaria with asthma requiring treatment) | | | Quality Scoring:
| | | | | | | Population similar: Yes
| Interventions: | Dropouts/withdrawals: 0 | 2) Nasal reactivity | | | | Intervention(s) described: No
| 1) Formalinized high-molecular-weight mixed grass pollen allergoid (n = 40 or 39). Administered “using a rather aggressive protocol.” Maximum dose reached in 9 injections (time frame not described). Mean total dose received 25,649.5 ± 17,704.3 PNU (range, 5,695 to 73,800). | | | | | | Comorbidities described: No
| | No. of subjects at end: 59 | 3) Patient-assessed symptom severity: nasal symptoms evaluated during peak of pollen season (May 1 to June 15); symptoms scored and scale used not described | 1/20 placebo-treated pts had mild systemic reaction | | | Diagnosis by MD: No
| | | | | | | Objectively confirmed: No
| | Inclusion criteria: Severe grass pollen-induced rhinitis; volunteers | | | | | Outcome measures valid: Not adequately described
| | | | 2) Nasal reactivity: Not abstracted
| | | | | | | Level of evidence: 2b
| | Exclusion criteria: None stated | | 3) Patient-assessed symptom severity: significantly reduced in allergoid group compared to placebo group (nasal symptom score 61± 35 versus 109 ± 33) | | | Randomized: Yes
| | | | | | | Allocation concealed: Not described
| | Age: 25.2 ± 12.1 years
| | | 4) Allergen-specific IgG antibody levels | | | | Double-blind: No
| | Sex: NR | | | | | Blinding adequate: Not applicable
| 2) Placebo (constituents not described) (n = 20 or 19).
| | Race: NR | | 4) Allergen-specific IgG antibody levels: Not abstracted | | | Dropouts described: Yes
| | | | | | | Intention-to-treat: Can't determine
| Duration of study treatment: | Other:
| NR (9 injections, but time frame not indicated); outcomes measured during single pollen season
| | | | | | | Notes:
| | | | | | | No significant correlation between IgG titer and nasal provocation test or symptom scores.
| Symptomatic medication permitted: NR
| Dates: NR | | | | | | Article reports conflicting numbers of patients in the two treatment groups (n = 39 or 40 for allergoid group; n = 19 or 20 for placebo group).
| Location: Montpelier, France (Northern Mediterranean area)
| Setting: Allergy clinic
| Type(s) of providers: Allergists
Bousquet, Hejjaoui, Skassa-Brociek, et al., 1987 | Design: RCT, parallel-group | No. of subjects at start: 45 | 1) Adverse reactions | 1) Adverse reactions: | | | Quality Scoring:
| | | | Allergoid group 37% | | | Population similar: Yes
| Interventions: | Dropouts/withdrawals: 0 | 2) Use of symptomatic medication: graded daily during pollen season, as follows: | Allergen group 20% | | | Intervention(s) described: Yes
| 1) Standardized orchard grass-pollen extract (n = 15). Treatment started in December or January. Rush protocol used, with rapid increase in allergen dose; maintenance dose (2 IR) reached in 4 days. Maintenance dose then given every week for 4 weeks, then every 2 weeks until April 1. Co-seasonal immunotherapy (dose reduced by half) then given every 2 weeks until October 1. | | | Placebo group 0% | | | Comorbidities described: Yes
| | No. of subjects at end: 45 | | | | | Diagnosis by MD: Yes
| | | | 2) Use of symptomatic medication: | | | Objectively confirmed: Yes
| | Inclusion criteria: Rhinitis during grass-pollen season; positive prick test (to 1/100 wt/vol standardized extract) and IgE (at RAST class 3 to 4) indicating allergy to orchard grass pollen | No medication: 0 | Results presented in graph only (could be interpolated) | | | Outcome measures valid: No
| | | Disodium cromoglycate nasal spray: 1 | | | | Level of evidence: 2b
| | | | Allergen < Placebo (p < 0.01) | | | Randomized: Yes
| | | Beclomethasone nasal spray: 2 | Allergoid < Placebo (p < 0.05) | | | Allocation concealed: Not described
| | | | Allergen vs. Allergoid (p = NS)
| | | Terfenadine: 3 | | | | Double-blind: Yes
| | | Oral prednisolone: 4 | 3) Patient-assessed symptom severity: | | | Blinding adequate: Yes
| | Exclusion criteria: Multiple pollen allergy; previous specific immunotherapy to grass pollens; use of systemic corticosteroids | | Results presented in graph only (could be interpolated) | | | Dropouts described: Yes
| | | 3) Patient-assessed symptom severity: symptoms graded daily during pollen season, as follows: | | | | Intention-to-treat: Yes
| | | | Allergen < Placebo (p < 0.005)
| | | | Allergoid < Placebo (p < 0.01)
| | | | Allergen vs. Allergoid (p = NS) | | | Note: Only the placebo (3) versus allergoid (2) comparison was double-blind because of different protocol used for allergen group (1).
| | Age: Mean 24.1 ± 10.1 years (range, 12 to 43)
| 2) Mixed grass-pollen (six species) allergoid (n = 19). Treatment started in January or February. Rush protocol used, with rapid increase in allergoid doses over 3 days; doses subsequently increased weekly to reach maintenance dose of 1000 PNU. Increases stopped if/when systemic reaction or large local reaction (diameter > 10 cm) occurred, and maintenance dose defined as dose reached before this reaction. Maintenance dose then given every week for 4 weeks, then every 2 weeks until April 1. Co-seasonal immunotherapy (dose reduced by half) then given every 2 weeks. | | No symptom: 0 | 4) Skin reactivity: Not abstracted
| | | > 5 episodes sneezing: 1
| | Sex: NR | Nasal blockage: 1 or 2 | 5) Allergen-specific IgE and IgG: Not abstracted
| | | Rhinorrhea: 1 or 2
| | Race: NR | Nasal pruritus: 1
| | Other: | 4) Skin reactivity
| | “More than half also had symptoms of asthma and/or conjunctivitis”
| | | 5) Allergen-specific IgE and IgG
| | asthma 71%
| | conjunctivitis 58%
| | “Duration of symptoms during pollen season ranged from 3 to 19 years”
| 3) Placebo (0.9% NaCl, 0.4% phenol, and 0.5 to 0.005 mg/ml histamine hydrochloride) (n = 11).
| Duration of study treatment: Approximately 10 months (December-September)
| Symptomatic medication permitted: Disodium cromoglycate nasal spray, beclomethasone nasal spray, terfenadine, oral prednisolone
| Dates: NR
| Location: Montpellier, France (Northern Mediterranean area)
| Setting: Allergy clinic
| Type(s) of providers: Allergists
Bousquet, Hejjaoui, Soussana, et al., 1990 | Design: RCT, parallel-group | No. of subjects at start: 57 | 1) Adverse reactions | 1) Adverse reactions: large local reactions ( > 10cm diameter and lasting > 24hr) in 9 patients (4/19 low dose group; 5/20 high dose);mild systemic reactions (flushing of face, rhinitis, or urticaria; resolved w/o treatment) in 8 pts (3 placebo; 2 low dose; 3 high dose) | | | Quality Scoring:
| | | | | | | Population similar: Yes
| Interventions: | Dropouts/withdrawals: 2? (unclear) | 2) Patient-assessed symptom severity: symptoms of rhinitis (rhinorrhea, sneezing, and nasal obstruction), conjunctivitis (watery eyes, red eyes, and pruritus), and asthma (wheezing and shortness of breath) graded twice daily on scale of 0 to 5 (not described) | | | | Intervention(s) described: Yes
| 1) Formalinized high-molecular-weight allergoid prepared from a six grass-pollen extract, high-dose schedule (n = 20). Grasses were: Dactylis glomerata, Festuca elatior, Holcus lanatus, Lolium perenne, Phleum pratense, and Poa pratensis. Maximal single dose (10,000 PNU) achieved with 8^th^ injection on day 28. This dose administered three times at weekly intervals, then reduced by ½ and administered every 2 weeks during allergy season. Mean cumulative dose received 45,433 ± 14,001 PNU. | | | | | | Comorbidities described: Yes
| | | | | | | Diagnosis by MD: Yes
| | No. of subjects at end: 55? (unclear) | | | | | Objectively confirmed: Yes
| | | | | | | Outcome measures valid: No
| | | | | | | Level of evidence: 2b
| | Inclusion criteria: Symptoms of rhinitis during grass-pollen season, positive prick test to 1/100 (wt/vol) standardized orchard-grass pollen extract; positive RAST to orchard-grass pollen | | severe reaction (urticaria, rhinitis, asthma w/o hypotension) | | | Randomized: Yes
| | | | | | | Allocation concealed: Not described
| | | | 2) Patient-assessed symptom severity: | | | Double-blind: Yes
| | | | Mean rhinitis symptom scores (± SD): | | | Blinding adequate: Yes
| | | | High dose: 63.6 ± 32.5 | | | Dropouts described: No
| | | | Low dose: 57.8 ± 37.5 | | | Intention-to-treat: Can't determine
| | | 3) Use of symptomatic medication: recorded daily by patients in study diaries; system for scoring not described | Placebo: 108.6 ± 33.2
| | Exclusion criteria: previous specific immunotherapy to pollen extract | | p < 0.005, high dose vs. placebo; p < 0.001, low dose vs. placebo; p = NS, high dose vs. low dose
| | | | | | | Note: Exact scores given for subgroups of pts with asthma experience or rhinitis experience, but number of subjects in these subgroups is not provided.
| | Age: 26.8 ± 10.4 years (range 11 to 45) | | Mean asthma symptom scores (± SD):
| | | 4) Nasal reactivity | High dose: 17.4 ± 20.2
| | | | Low dose: 12.8 ± 16.8
| 2) Formalinized high-molecular-weight allergoid prepared from a six grass-pollen extract (as above), low-dose schedule(n = 19). Schedule as above, except maximal single dose 2,000 PNU. Mean cumulative dose received 10,570 ± 2,808 PNU. | Sex: 24 men | 5) Skin reactivity | Placebo: 54.8 ± 23.0
| | | | p < 0.001, high dose and low dose vs. placebo; p = NS, high dose vs. low dose
| | Race: NR | 6) Allergen-specific IgE and IgG antibody levels
| | Other:
| | | | 3) Use of symptomatic medication:
| | | | Mean medication score ± (SD)
| | | | High dose: 38.6 ± 37.6
| | | | Low dose: 35.3 ± 44.5
| | | | Placebo: 66.4 ± 51.7
| 3) Placebo (saline, phenol, and histamine dihydrochloride 0.005 to 0.5 mg/ml) (n = 18). | | | p < 0.05, low dose (and high dose? - table unclear) vs. placebo
| | | | No p-value reported for high dose vs. low dose
| Duration of study treatment:
| 6 weeks pre-season, plus maintenance treatment during single allergy season
| | | | 4) Nasal reactivity: Not abstracted
| | | | 5) Skin reactivity: Not abstracted
| Symptomatic medication permitted: Nasal and ocular cromoglycate, nasal beclomethasone, terfenadine, oral corticosteroids, inhaled salbutamol, and theophylline; used according to a pre-specified protocol and only when symptoms present | | | 6) Allergen-specific IgE and IgG antibody levels: Not abstracted
| Dates: Spring 1987
| Location: Montpelier, France
| Setting: Allergy clinic
| Type(s) of providers: Allergists
Bousquet, Maasch, Hejjaoui, et al., 1989 | Design: RCT, parallel-group | No. of subjects at start: 70 | 1) Adverse reactions | 1) Adverse reactions: | | | Quality Scoring:
| | | | Placebo | 0 | | Population similar: Yes
| Interventions: | Dropouts/withdrawals: 0 | 2) Patient-assessed symptom severity: rhinorrhea, sneezing, nasal obstruction, watery eyes, red eyes, pruritus, wheezing, and shortness of breath graded (twice?) daily during allergy season on scale of 0–5 (not described) | GOID | 67% | | Intervention(s) described: Yes
| 1) Standardized and lyophilized orchard-grass pollen (Dactylis glomerata) extract (n = 18). Rush protocol used, with rapid increase in allergen dose; maintenance dose (3,000 BU) reached in 3 days. Four maintenance injections then given. Co-seasonal immuno-therapy (dose reduced by half) then given every 2 weeks from April 1 to October 1. Mean cumulative dose: 3678 ± 567 PNU. | | | HMW-GOID | 42% | | Comorbidities described: Yes
| | No. of subjects at end: 70 | | Std-ext | 72% | | Diagnosis by MD: Yes
| | | | | | | Objectively confirmed: Yes
| | Inclusion criteria: Rhinitis during grass-pollen season; positive prick test (to 1/100 wt/vol standardized extract) and IgE (at RAST class 3 to 4) indicating allergy to orchard grass pollen | | 2) Patient-assessed symptom severity: | | | Outcome measures valid: No
| | | | Symptom score: | | | Level of evidence: 2b
| | | | Placebo | 63.5 ± 54.6 | | Randomized: Yes
| | | | GOID | 38.1 ± 27.4 | | Allocation concealed: Not described
| | | | HMW-GOID | 20.4 ± 18.1
| | | | Std-ext | 14.8 ± 22.9 | | Double-blind: Yes
| | | | | | | Blinding adequate: Not described
| | Exclusion criteria: Previous specific immunotherapy to grass pollens | 3) Use of symptomatic medication: recorded daily during allergy season; method of scoring not described | Std-ext < Placebo (p < 0.001)
| | | | HMW-GOID < Placebo (p < 0.001) | | | Dropouts described: No
| | | | HMW-GOID < GOID (p < 0.02) | | | Intention-to-treat: Can't determine
| | | | GOID vs Placebo (p = NS)
| | Age: Mean 25.2 ± 12.1 years (range, 12 to 46)
| | | | Number of days of rhinitis symptoms:
| 2) Mixed-grass pollen unfractionated and lyophilized allergoid, prepared from pollens of 6 grasses (Dactylis glomerate, Festuca elatior, Holcus lanatus, Lolium perenne, Poa pratensis,and [sixth species?]) (n = 15). Injections of gradually increasing dose (50 to 2,000 PNU) given over 5 weeks (3 injections during week 1, 2 during week 2, 1 per week thereafter). Four maintenance injections (2,000 PNU) given before April 1^st^. Co-seasonal immunotherapy (dose reduced by half) given bimonthly from April 1 to October 1. Mean cumulative dose: 9,096 ± 6,304 PNU. | | 4) Skin reactivity | Placebo | 26.5 ± 8.6 | | Note: Group receiving standardized orchard-grass pollen extract not blinded.
| | Sex: NR | | GOID | 20.9 ± 10.0
| | | 5) Specific IgG and IgE levels | HMW-GOID | 9.15 ± 9.5
| | Race: NR | | Std-ext | 9.0 ± 10.7
| | Other: | | Std-ext < Placebo (p < 0.001)
| | Asthma 54% | | HMW-GOID < Placebo (p < 0.001)
| | Conjunctivitis 67% | | Std-ext < GOID (p < 0.05)
| | | | HMW-GOID < GOID (p < 0.05)
| | | | GOID vs Placebo (p = NS)
| | | | 3) Use of symptomatic medication (medication score):
| | | | Placebo | 53.7 ± 54.1
| | | | GOID | 33.1 ± 41.0
| | | | HMW-GOID | 30.5 ± 32.8
| | | | Std-ext | 22.9 ± 39.1
| | | | Std-ext < Placebo (p < 0.01)
| | | | 4) Skin reactivity: Not abstracted
| 3) High-molecular-weight, formalinized and lyophilized mixed-grass pollen allergoid, prepared from pollens of the 6 grasses described above (n = 13). Protocol same as 2), above. Mean cumulative dose: 13,735 ± 6,355 PNU. | | | 5) Specific IgG and IgE levels: Not abstracted
| 4) Placebo, with increasing doses of histamine dihydrochloride (n = 14)
| Duration of study treatment: 7 months
| Symptomatic medication permitted: For conjunctivitis, ocular cromoglycate, followed by H1 blocker, if necessary; for asthma, inhaled salbutamol (200–600 μg), plus theophylline, if necessary; patients asked to take drugs only if they had symptoms
| Dates: NR
| Location: Montpellier, France (Northern Mediterranean area)
| Setting: Allergy clinic
| Type(s) of providers: Allergists
Bruce, Norman, Rosenthal, et al., 1977 | Design: RCT, parallel-group (matched-pairs design) | No. of subjects at start: 39 | 1) Investigator-assessed severity of asthma symptoms | 1) Investigator-assessed severity of asthma symptoms: Not abstracted | | | Quality Scoring:
| | | | | | | Population similar: Not adequately described
| | Dropouts/withdrawals: Unclear. Not specified at 1-year time point.
| Interventions: | | | 2) Investigator-assessed severity of hay fever symptoms: Not abstracted | | | Intervention(s) described: Yes
| 1) Lyophilized aqueous extract of ragweed containing 10 μg AgE/ml or 3570 PNU/ml (n = 14). Weekly injections given from January through August of 1973 and 1974. Mean cumulative doses in terms of antigen E were 11.7 μg (4180 PNU) in 1973 and 31.2 μg (11,140 PNU) in 1974. | | 2) Investigator-assessed severity of hay fever symptoms | | | | Comorbidities described: Yes
| | No. of subjects at end: 32 patient data points at 1 year shown in Fig 2. 29 patients described as continuing thru second year. | | | | | Diagnosis by MD: Yes
| | | | 3) Patient-assessed severity of asthma symptoms and use of asthma medications (combined in a single measure): | | | Objectively confirmed: Yes
| | | | | | | Outcome measures valid: No
| | | 3) Patient-assessed severity of asthma symptoms and use of asthma medications (combined in a single measure): patients recorded following items twice daily during ragweed season (Aug to mid-Oct): duration of difficulty breathing and cough, number and duration of asthma attacks, amount of sputum produced, and asthma medication taken | | | | Level of evidence: 2b
| | | | | | | Randomized: Yes
| | Inclusion criteria: Symptomatic asthma during ragweed season; positive skin test to ragweed | | No significant difference. | | | Allocation concealed: Not described
| | | | 4) Patient-assessed severity of hay fever symptoms and use of hay fever medications (combined in a single measure): | | | Double-blind: Yes
| | | | | | | Blinding adequate: Yes
| | Exclusion criteria: Perennial asthma; IT in previous 2 years | | | | | Dropouts described: No
| 2) Placebo containing histamine (n = 18) | | | | | | Intention-to-treat: No
| | | | | | | No significant difference.
| | Age: NR
| Duration of study treatment: 2 years; injections given January through August of both years, symptoms monitored through ragweed pollen seasons (August to mid-October) of both years | | | 5) Bronchial reactivity: Not abstracted | | | Notes:
| | Sex: NR
| | | | 6) Leukocyte histamine release: Not abstracted
| | Race: NR
| | Other: | | 7) Allergen-specific IgE and IgG blocking antibody: Not abstracted
| | | 4) Patient-assessed severity of hay fever symptoms and use of hay fever medications (combined in a single measure): patients recorded following items twice daily during ragweed season (Aug to mid-Oct): duration of sneezing, stuffy or runny nose, red itchy eyes, and hay fever medication taken
| Symptomatic medication permitted: For hay fever, decongestants and chlorpheniramine; for asthma, aminophylline, steroids, ephedrine, and nebulized bronchodilators
| Dates: 9/72-3/73
| Location: Baltimore, MD
| Setting: Academic allergy practice | | | 5) Bronchial reactivity
| | | | 6) Leukocyte histamine release
| Type(s) of providers: Specialists
| | | 7) IgE and IgG antibodies
Brunet, Bédard, Lavoie, et al., 1992 | Design: RCT, parallel-group | No. of subjects at start: 27 | 1) Allergen-specific IgE and IgG antibody levels | 1) Allergen-specific IgE and IgG antibody levels: Not abstracted | | | Quality Scoring:
| | | | | | | Population similar: Yes
| Interventions: | Dropouts/withdrawals: 0 | | | | | Intervention(s) described: Yes
| 1) Alum-precipitated ragweed extract (n = 13). Weekly injections given over 9 weeks in following doses: 50; 100; 200; 500; 1,000; 2,000; 3,000; 3,000; and 3,000 PNU. | | 2) Patient-assessed symptom severity: sneezing, itchy nose, rhinorrhea, nasal obstruction, lacrimation, and itchy eyes graded twice per day during allergy season on scale of 0 (none, no symptoms evident) to 3 (severe, disabling and/or interfering with daily activities and/or sleep) | 2) Patient-assessed symptom severity: | | | Comorbidities described: Yes
| | No. of subjects at end: 27 | | Score: 4.7 ± 0.7 active vs. 7.5 ± 1.2 placebo; p < 0.05 | | | Diagnosis by MD: Yes
| | | | | | | Objectively confirmed: Yes
| | Inclusion criteria: Ragweed allergic rhinitis without asthma; positive prick skin test and IgE antibody to ragweed | | | | | Outcome measures valid: No
| | | | 3) Investigator-assessed symptom severity: Not abstracted | | | Level of evidence: 1b
| | | | | | | Randomized: Yes
| | | | | | | Allocation concealed: Not described
| 2) Placebo (alum-precipitated human serum albumin, with histamine phosphate and caramelized glucose) (n = 14) | | | 4) Use of symptomatic medication:
| | Exclusion criteria: NR | | Score: 0.9 ± 0.2 active vs. 0.7 ± 0.2; p = 0.6 | | | Double-blind: Yes
| | | | | | | Blinding adequate: Yes
| | Age: 19–56 | | | | | Dropouts described: Yes
| | | | 5) Nasal reactivity: Not abstracted | | | Intention-to-treat: Yes
| Duration of study treatment: Injections given over 9 weeks during allergy preseason (May to July); outcomes assessed during one allergy season (mid-August to mid-September) | Sex: Active 10M/3F; placebo 8M/6F
| | | | 6) Allergen-induced basophil histamine release: Not abstracted
| | | 3) Investigator-assessed symptom severity | | | | Notes:
| | Race: NR
| | | | 7) Adverse reactions:
| | Other: None had other serious disease or prior immunotherapy | 4) Use of symptomatic medication: type and amount used recorded daily by patients in study diaries | Unspecified number of local reactions; one subject with late phase reaction of 8 cm associated with wheezing - continued in study
| Symptomatic medication permitted: Chlorpheniramine 4-mg tablets; pseudoephedrine 60-mg tablets; and naphazoline HCl, pheniramine maleate, eyedrops
| | | 5) Nasal reactivity
| | | 6) Allergen-induced basophil histamine release
| Dates: NR | | 7) Adverse reactions
| Location: Quebec, Canada
| Setting: University
| Type(s) of providers: Specialists
Cockcroft, Cuff, Tarlo, et al., 1977 | Design: RCT, parallel-group (matched-pairs design) | No. of subjects at start: 43 | 1) Patient-assessed symptom severity: sneezing, stuffy and/or runny nose, itchy eyes, and cough graded twice per day on scale of 0 (none) to 3 (lasted longer than 3 hours) | 1) Patient-assessed symptom severity: | | | Quality Scoring:
| | | | Symptom score (active vs. placebo) | | | Population similar: Yes
| | Dropouts/withdrawals: 1 withdrew from placebo group for reasons unrelated to the trial. 6 patients in active treatment group could not complete IT regimen but continued in trial (see AEs) | | Sneezing 1.42 vs. 1.32 (ns) | | | Intervention(s) described: Yes
| Interventions: | | | Rhinorrhea congestion 2.06 vs. 2.38 (ns) | | | Comorbidities described: Yes
| 1) Glutaraldehyde-modified ragweed tyrosine adsorbate (MRTA) (n = 21). Four weekly injections given in doses of 300; 700; 2,000; and 4,000 NU per 0.5 ml. | | | | | | Diagnosis by MD: Yes
| | | | Eye 0.92 vs. 1.49 (ns) | | | Objectively confirmed: Yes
| | | | Cough 0.52 vs. 0.58 (ns) | | | Outcome measures valid: No
| | | | Total 4.95 vs. 5.75 (ns) | | | Level of evidence: 2b
| | | | | | | Randomized: Yes
| | No. of subjects at end: 42 | 2) Use of symptomatic medication: types and doses used recorded daily by patients in study diaries | 2) Use of symptomatic medication: | | | Allocation concealed: Yes
| | | | Number subjects requiring (active vs. placebo): | | | Double-blind: Yes
| 2) Placebo (tyrosine base) (n = 22) | Inclusion criteria: Moderate to severe allergic rhinitis during August/September; positive prick skin tests to ragweed | | | | | Blinding adequate: Yes
| | | | Chlorpheniramine 20 vs. 20 (ns) | | | Dropouts described: Yes
| | | | Beclomethasone 9 vs. 15 (ns) | | | Intention-to-treat: Yes
| Duration of study treatment: Injections given over 4 weeks in July; outcomes measured through one allergy season (end of September) | | 3) Patient global assessment of efficacy: patients asked at end of trial whether result of injections “very good” (minimal symptoms, minimal medication requirement), “good” (noticeably better than previous years), or “poor” (slight or no improvement) | Eye drops 10 vs. 14 (ns)
| | | | Medrysone eye drops 0 vs. 1 (ns)
| | Exclusion criteria: Positive prick skin test to mold Cladosporium and Alternaria | | Prednisone 1 vs. 2 (ns) | | | Notes:
| | | | Mean daily consumption:
| | | | Chlorpheniramine 0.77 vs. 0.96 (ns)
| Symptomatic medication permitted: Chlorpheniramine maleate 4-mg tablets; naphazoline-antazoline eyedrops (0.05 mg/ml and 0.5 mg/ml, respectively); beclomethasone dipropionate nasal aerosol (50 μg/spray); medrysone (1%) eyedrops; and prednisone 5-mg tablets. Used according to pre-defined protocol. Minimum dose required to control symptoms used. | Age: 29.9 active; 33.2 placebo | | Beclomethasone 1.01 vs. 2.10; p < 0.05
| | Sex: 7M/14F active; 8M/14F placebo | | Eye drops 0.50 vs. 1.24 (ns)
| | | | Total 2.29 vs. 4.37; p < 0.05
| | Race: NR | | 3) Patient global assessment of efficacy: (active vs. placebo)
| | | 4) Allergen-specific IgE and IgG antibody levels, eosinophil counts
| | Other: | | Very good 5 vs. 3
| | 7 active and 5 placebo patients had receive prior immunotherapy | | Good 9 vs. 5
| | | | Poor 7 vs. 13 (ns)
| | | 5) Adverse reactions
| | 7 active and 6 placebo patients with mild asthma | | 4) Allergen-specific IgE and IgG antibody levels, eosinophil counts: Not abstracted
| Dates: NR | | | 5) Adverse reactions:
| | | | Late swelling > 10 cm resulted in stopping injections in 3 patients after second injection and after third injection in another 3. These subjects were followed in intention-to-treat manner.
| Location: Hamilton, Ontario, Canada
| Setting: University practice
| Type(s) of providers: Specialists
Corrado, Pastorello, Ollier, et al., 1989 | Design: RCT, parallel-group | No. of subjects at start: 66 | 1) Nasal reactivity | 1) Nasal reactivity: Not abstractaed | | | Quality Scoring:
| | | | | | | Population similar: Yes
| Interventions: | Dropouts/withdrawals: 15 (11 active, 3 placebo): 6 withdrawn for pregnancy, 4 with severe local reactions, 2 with late or generalized reactions, one for lack of benefit, and 2 lost to followup | 2) Patient-assessed symptom severity (diary data): nasal blockage, sneezing, and rhinorrhea graded twice daily on a scale of 0–3 (not described) | 2) Patient-assessed symptom severity (diary data): | | | Intervention(s) described: Yes
| 1) Standardized extract of Dermatophagoides pteronyssinus (house dust mite) conjugated to alginate and containing known amounts of antigen P1 (Conjuvac®) (n = 22). Build-up phase: 11 weekly injections of doses increasing from 56 × 10^1^ to 448 × 10^3^ IU D. pteronyssinus. Maintenance phase: 15 monthly injections, each containing 448 × 10^3^ IU D. pteronyssinus. | | | | | | Comorbidities described: Yes
| | | | Last observation carried forward for dropouts. | | | Diagnosis by MD: Yes
| | | | | | | Objectively confirmed: Yes
| | | | Questionable compliance with diary card collections. | | | Outcome measures valid: No
| | | | | | | Level of evidence: 2b
| | | | | | | Randomized: Yes
| | No. of subjects at end: 51 | | Significant difference (p = 0.028) for final diary recordings for AM score, but not PM score (p = 0.12). Actual data not given. | | | Allocation concealed: Not described
| | | 3) Peak flow rates
| | Inclusion criteria: Not specified, although all were determined to have D. pter. as "main cause of symptoms on basis of history and nasal provocation and skin prick testing. | | | | | Double-blind: Yes
| | | 4) Patient-assessed symptom severity (clinic visits): nasal blockage, sneezing, and rhinorrhea graded on 10-cm visual analog scale (running from “no symptoms” to “could not be worse”) during clinic visits at baseline and after 5, 9, and 15 months of maintenance therapy | | | | Blinding adequate: Yes
| | | | | | | Dropouts described: Yes
| | | | 3) Peak flow rates: Not abstracted | | | Intention-to-treat: Yes
| | | | 4) Patient-assessed symptom severity (clinic visits):
| | | | | | | Notes:
| 2) Placebo (lyophilized sodium alginate diluent ± 5 μg histamine dihydrochloride) (n = 29). | Exclusion criteria: Pregnancy; nasal polyps or other nasal deformity; proven sensitivity to animals and pets kept in home; systemic corticosteroid use | | Not significant except for congestion subscore (p < 0.01). Data not given.
| | | | 5) Use of symptomatic medication:
| Duration of study treatment: | | | No data given. Both groups used little medication at end of study.
| 18 months | Age: 17–55 (mean 29.5) | 5) Use of symptomatic medication: recorded in daily study diaries and monitored via tablet counts and nasal spray canister weights
| Symptomatic medication permitted: Beclomethasone dipropionate, xylometazoline, or sodium cromoglycate nasal sprays, and chlorpheniramine; patients “encouraged to reduce their medication as much as possible” | Sex: 40 F | | 6) Adverse reactions:
| | | | No immediate systemic reactions. Immediate local reaction of < 5 cm in 29% A v 1% placebo, > 5 cm in 1% A and 0% placebo.
| | Race: NR
| | Other: 34/66 also had asthma
| | | 6) Adverse reactions: Prior to each injection, patients asked, “Did you notice anything unusual after the last injection?” Reported problems classified as local or systemic and early or late (> 30 min after injection)
| | | | Delayed systemic reactions in 3% active and 1% placebo. Local < 5 cm 12% v 2. Local > 5 cm 23% v 1%.
| Dates: 11/83-3/85
| | | | No anaphylaxis.
| Location: Italy and UK
| Setting: 3 academic centers
| Type(s) of providers: Specialists
Creticos, Reed, Norman, et al., 1996 | Design: RCT, parallel-group | No. of subjects at start: 90 randomized; 77 began treatment phase | 1) Peak flow rates | 1) Peak flow rates: Not abstracted | | | Quality Scoring:
| | | | | | | Population similar: Yes
| Interventions: | | 2) Use of asthma medication: recorded daily in study diaries from July 1 through October 31 each year | 2) Use of asthma medication: | | | Intervention(s) described: Yes
| 1) Lyophilized extract of short-ragweed pollen, prepared by a professional lab (n = 37). Initial dose of 0.05 ml of a 1:10,000 dilution of extract (0.001 mg of Amb a 1) doubled every week until maximum tolerated dose or 0.5 ml of a 1:10 dilution (10 μg of Amb a 1) reached (19 weeks). Maintenance doses then administered every 2 weeks for 3 months and every 4 weeks thereafter. | | | Score 19 active v 43 placebo in year 1 (p = 0.01), and 29 v 33 in year 2 (p = 0.7). | | | Comorbidities described: Yes
| | Dropouts/withdrawals: 13 dropouts between randomization and treatment. No reason given. 13 dropped out in year 1, 11 in year 2. | | | | | Diagnosis by MD: Yes
| | | | | | | Objectively confirmed: Yes
| | | | | | | Outcome measures valid: No
| | | | 3) Patient-assessed severity of asthma symptoms: | | | Level of evidence: 2b
| | | 3) Patient-assessed severity of asthma symptoms: unspecified symptoms of asthma recorded twice daily and graded on scale of 0 (none) to 6 (incapacitating) from July 1 through October 31 each year | | | | Randomized: Yes
| | 8 active group dropouts: 4 moved, 3 withdrew, 1 became pregnant | | Not significant in year 1 or 2. Numbers not given. | | | Allocation concealed: Not described
| | | | | | | Double-blind: Yes
| | | | 4) Patient-assessed severity of rhinitis symptoms: | | | Blinding adequate: Yes
| | | | | | | Dropouts described: Yes
| | | | Baseline: 4.1 A v 4.5 P | | | Intention-to-treat: Can't determine
| | | | Year 1: 3.5 A v 4.3 P (p = 0.1)
| | No. of subjects at end: 53 | | Year 2: 3.1 A v 3.8 P (p = 0.04)
| 2) Placebo (n = 40) | Inclusion criteria: Age 16–70; asthma for 1+ year with exacerbation during fall season requiring medication; positive skin test to ragweed with less reactivity to other possible confounding allergens; drop in FEV1 of 20% after methacholine inhalation of less than 25 mg/ml | 4) Patient-assessed severity of rhinitis symptoms: unspecified symptoms of rhinitis recorded twice daily and graded on scale of 0 (none) to 6 (incapacitating) from July 1 through October 31 each year | 5) Bronchial reactivity: Not abstracted | | | Notes:
| Duration of study treatment: 2 years | | | 6) Allergen-specific IgE and IgG antibodies: Not abstracted
| Symptomatic medication permitted: Rhinitis medication not described; asthma medications permitted and adjusted by investigators every 3 weeks during period in which diaries were kept | | | 7) Skin reactivity: Not abstracted
| | | | 8) Adverse reactions:
| | | | Year 1: 7 patients in active group had 14 systemic reactions. 5 were mild, 9 rhinitis, generalized urticaria, angioedema, or combination requiring antihistamine or epinephrine. 2 patients dropped out after several systemic reactions. 4 placebo patients had moderate reactions and received treatment. One patient in placebo group received active treatment by mistake and had severe reaction with bronchospasm and hypotension. Recovered.
| | Treatment phase inclusions criteria: Worsened asthma symptom scores during ragweed season, worsening peak flow, and worsening medication scores, return 80% of symptom diaries | 5) Bronchial reactivity (antigen and methacholine challenges)
| Trial preceded by 4-month observation phase (July 1 through October 31)
| | | 6) Allergen-specific IgE and IgG antibodies
| Dates: NR | Exclusion criteria: Asthma requiring 2+ hospitalizations in previous year; inability to wean from long-term oral steroids or cromolyn; sensitivity to animals on regular exposure; current smoking; IT in previous 3 years, or ragweed IT; systemic illness; pregnancy; inability to undergo diagnostic tests | 7) Skin reactivity
| Location: Baltimore and Rochester, MN | | 8) Adverse reactions
| Setting: Academic centers
| Type(s) of providers: Specialists
| | Age: Mean 36.0 A v 35.1 P
| | Sex: Active 18 F; placebo 20 F
| | Race: NR
| | Other:
Cvitanović, Zekan, Čapkun, et al., 1994 | Design: RCT, parallel-group | No. of subjects at start: 90 | 1) Adverse reactions | 1) Adverse reactions: | | | Quality Scoring:
| | | | Active: 4 anaphylaxis in active group. 15 patients with reduced IT dose because of local reactions or rhinorrhea. | | | Population similar: Yes
| Interventions: | Dropouts/withdrawals: | 2) Allergen-specific IgE and IgG antibody levels | | | | Intervention(s) described: Yes
| 1) Partially purified, characterized, and standardized pollen extract of Parietaria officinalis (alum-absorbed depot preparation) (n = 40). Increasing doses administered weekly until the appearance of a local reaction, then decreased and slowly increased until a new local reaction occurred; “after some time,” injections given on biweekly basis. Injections given pre-seasonally, from beginning of November to mid-March. | 10/50 active: 6 for incomplete evaluation and 4 for anaphylaxis to IT | | | | | Comorbidities described: No
| | | | | | | Diagnosis by MD: Yes
| | | 3) Histamine serum concentration | | | | Objectively confirmed: Yes
| | 5/40 study medication: cause not listed | | 2) Allergen-specific IgE and IgG antibody levels: Not abstracted | | | Outcome measures valid: No
| | | | | | | Level of evidence: 1b
| | | 4) Skin reactivity | | | | Randomized: Yes
| | No. of subjects at end: 40 active; 35 drug | | 3) Histamine serum concentration: | | | Allocation concealed: Not described
| | | 5) Eosinophil levels | Not abstracted
| | | | | | | Double-blind: Yes
| | Inclusion criteria: 2-year history of seasonal rhinoconjunctivitis; positive skin test and specific IgE antibody to P. officinalis | 6) Patient-assessed symptom severity: nasal secretion, congestion, itching, and sneezing graded daily on scale of 0 (no symptoms) to 3 (severe symptoms) | 4) Skin reactivity: Not abstracted | | | Blinding adequate: No
| | | | | | | Dropouts described: Yes
| | | | 5) Eosinophil levels: Not abstracted | | | Intention-to-treat: No
| | | | 6) Patient-assessed symptom severity:
| | Exclusion criteria: NR | | Score (active vs. ketotifen) | | | Notes:
| | | | Year 1 12.2 ± 5.0 vs. 22.2 + 7.6 | | | 15 of 40 patients failed to achieve maintenance dose because of local reactions.
| | Age: | | Year 2 9.3 ± 3.5 vs. 15.8 ± 4.3
| 2) Oral ketotifen 1 mg twice per day from March 15 to end of June (n = 35) | Active (after dropouts) 19–45 years | 7) Use of symptomatic medication: graded daily on scale of 0–3 (as above), with 1 point given for each dose of symptomatic medication | Year 3 8.1 ± 1.2 vs. 12.3 ± 3.1
| | Ketotifen (after dropouts) 18–35 years | | 7) Use of symptomatic medication: | | | IT dosing not standardized. Presumably not blinded.
| | | | Score (active vs. ketotifen)
| Duration of study treatment: 3 years | | | Year 1 5.6 ± 2.3 vs. 15.5 ± 2.8
| | Sex: Active 20M/20F; Ketotifen 17M/18F | | Year 2 5.9 ± 1.2 vs. 11.2 ± 3.0
| | | | Year 3 3.8 ± 1.0 vs. 12.1 ± 2.6
| Symptomatic medication permitted, but not described
| | Race: NR
| Dates: NR | Other: All subjects were non-allergic, but testing regimen not described. No prior corticosteroids or immiunotherapy.
| Location: Split, Croatia
| Setting: University practice | Antihistamines stopped 1 month before study.
| Type(s) of providers: Specialists
Dolz, Martínez-Cócera, Bartolomé, et al., 1996 | Design: RCT, parallel-group | No. of subjects at start: 30 | 1) Skin reactivity | 1) Skin reactivity: Not abstracted | | | Quality Scoring:
| | | | | | | Population similar: Yes
| Interventions: | Dropouts/withdrawals: 2 excluded (1 due to initiation of beta-blocker treatment; 1 for personal reasons) | 2) Conjunctival reactivity | 2) Conjunctival reactivity: Not abstracted | | | Intervention(s) described: Yes
| 1) Aluminum hydroxide-adsorbed grass-pollen extract containing allergens PDL (Phleum, Dactylis, Lolium) (Alutard® SQ) (n = 18). Rush protocol followed using aqueous extract. Doses ranging from 0.1 ml × 100 USQ/ml to 1.0 ml × 100,000 USQ/ml given over 4 days. Depot extract used after maximum dose of aqueous extract reached; repeated every 4 weeks until end of study. Regime modified if any adverse reaction occurred. | | | | | | Comorbidities described: Yes
| | | 3) Bronchial reactivity | | | | Diagnosis by MD: Yes
| | | | 3) Bronchial reactivity: Not abstracted | | | Objectively confirmed: Yes
| | No. of subjects at end: 28 | 4) Total IgE and allergen-specific IgE, IgG, and IgG4 | | | | Outcome measures valid: No
| | | | 4) Total IgE and allergen-specific IgE, IgG, and IgG4: Not abstracted | | | Level of evidence: 2b
| | Inclusion criteria: Allergy to grass pollen by history, skin test, conjunctival provocation test, and positive specific IgE | | | | | Randomized: Yes
| | | | | | | Allocation concealed: Not described
| | | 5) Adverse reactions | 5) Adverse reactions:
| | | | Local | 4 | | Double-blind: Yes
| | | 6) Patient-assessed symptom severity: nasal symptoms (itching, sneezing, rhinorrhea, and obstruction), ocular symptoms (itching, reddening, photophobia, and sensation of foreign body), and bronchial symptoms (pharyngeal and palatal itching, persistent coughing, dyspnea, and wheezing) graded daily during pollen season an a scale of 0 (no symptoms) to 3 (severe) | Systemic | 7 | | Blinding adequate: Not described
| | Exclusion criteria: Previous immunotherapy; sensitization to other pollens or aeroallergens
| | | | 6) Patient-assessed symptom severity: | | | Dropouts described: Yes
| | | | Results presented in graph only (cannot be interpolated, because daily scores are not aggregated to a single parameter) | | | Intention-to-treat: No
| | Age: Mean 19.4 (range 15 to 35)
| | | | | | | Notes:
| | Sex: NR | | Nasal symptoms significantly improved compared to placebo in 2^nd^ and 3^rd^ year (p < 0.001) | | | Duration of follow-up longer than most. Absence of statistically significant benefit during first year suggests early benefit of rush IT.
| 2) Placebo (0.01 mg histamine hydrochloride and 0.4 mg human serum albumin) (n = 10).
| | Race: NR
| | Other: | | 7) Use of symptomatic medication:
| | Asthma: 21% | | Results presented in graph only (cannot be interpolated, because daily scores are not aggregated to a single parameter)
| Duration of study treatment:
| 3 years
| Symptomatic medication permitted: Cromoglycate, oral antihistamines, inhaled bronchodilators, and inhaled corticoids | | | Medication score significantly improved compared to placebo in 2^nd^ and 3^rd^ year (p < 0.01)
| | | 7) Use of symptomatic medication: graded daily during pollen season, as follows:
| | | Cromoglycate: 1
| Dates: 1990-1992 | | Oral antihistamines: 2
| | | Inhaled bronchodilators: 3
| Location: Madrid, Spain | | Inhaled corticoids: 4
| Setting: Allergy clinic
| Type(s) of providers: Allergists
Dorward, Waclawski, and Kerr, 1984 | Design: RCT, parallel-group | No. of subjects at start: 39 | 1) Adverse reactions | 1) Adverse reactions: | | | Quality Scoring:
| | | | Severe local requiring d/c treatment | | | Population similar: Yes
| Interventions: | Dropouts/withdrawals: 1 discontinued due to adverse reaction; 10 failed to completed diary cards; 4 did not have antibody levels for before and after treatment | 2) Patient-assessed symptom severity: itching eyes, swelling of eyes, watery eyes, sneezing, nasal blockage, runny nose, and wheezing graded daily on scale of 1 (mild) to 3 (severe) | (Conjuvac) n = 1 | | | Intervention(s) described: No
| 1) Alum-precipitated five-grass extract (Allpyral®) (n = 18). Five grasses: timothy, rye, cocksfoot, Yorkshire for, and meadow grass. Nine weekly injections starting with a dose of 20 PNU and rising to 4,000 PNU. Dose reduced in event of severe local reaction. Injections completed 2–4 weeks before start of pollen season. No maintenance injections given. | | | Local | | | Comorbidities described: No
| | | | Minor 10 Conjuvac; 9 Allpyral | | | Diagnosis by MD: Yes
| | | | Frequent 0 Conjuvac; 2 Allpyral | | | Objectively confirmed: Yes
| | | | Severe 9 Conjuvac; 4 Allpyral | | | Outcome measures valid: No
| | | | Systemic | | | Level of evidence: 2b
| | | | Wheeze 1 Conjuvac; 2 Allpyral | | | Randomized: Yes
| | No. of subjects at end: 25 (could be analyzed for both antibody results and diary scores) | | Rhinitis 1 Conjuvac; 0 Allpyral | | | Allocation concealed: No (alternate allocation)
| | | | Requiring d/c treatment
| | | 3) Total IgE and allergen-specific IgE and IgG antibody levels | 1 conjuvac; 0 Allypyral | | | Double-blind: No
| | | | | | | Blinding adequate: Not applicable
| | Inclusion criteria: Seasonal pollen rhinitis for at least 2 years; attending allergy clinic; positive skin-prick tests to pollen extract | | 2) Patient-assessed symptom severity:
| | | | Allpyral significantly higher than Conjuvac (1.31 ± 0.29 versus 0.81 ± 0.18; p <0.05) | | | Dropouts described: Yes
| | | 4) Patient global evaluation of efficacy: number of patients who thought that treatment had improved their symptoms | | | | Intention-to-treat: No
| 2) Two-grass conjugated extract (Conjuvac®) (n = 21). Two grasses: timothy and cocksfoot. Eleven weekly injections rising from 1 AUR (activity units by RAST) to 800 AUR. Dose reduced in event of severe local reaction. Injections completed 2–4 weeks before start of pollen season. No maintenance injections given.
| | Exclusion criteria: None stated | | 3) Total IgE and allergen-specific IgE and IgG antibody levels: Not abstracted | | | Notes:
| | Age: 23.6 (range 8 to 52)
| | | 5) Patient satisfaction: number of patients who would repeat the same treatment again next year
| | Sex: NR | | 4) Patient global evaluation of efficacy:
| | | | Allypyral 12/18 cases
| | Race: NR | | Conjuvac 16/18 cases
| | Other: 22 patients had had immunotherapy in the past | 6) Use of symptomatic medication: Number of patients requiring antihistamine treatment to control symptoms during the pollen season | 5) Patient satisfaction:
| | | | Allypyral 15/18
| | | | Conjuvac 17/18
| Duration of study treatment: | | | 6) Use of symptomatic medication:
| Injections given over 9–11 weeks during allergy pre-season; outcomes assessed during single pollen season (mid-May to end of July) | | | Allpyral 4/18
| | | | Conjuvac 3/18
| Symptomatic medication permitted: oral antihistamines
| Dates: Spring/summer 1982
| Location: Glasgow, Scotland
| Setting: Allergy clinic
| Type(s) of providers: Allergists
D'souza, Pepys, Wells, et al., 1973 | Design: RCT, parallel-group | No. of subjects at start: 96 | 1) Adverse reactions: As observed by investigators and recorded by patients in study diaries | 1) Adverse reactions: | | | Quality Scoring:
| | | | Active: | | | Population similar: No
| Interventions: | Dropouts/withdrawals: 5 (2 placebo, 3 active); 2 failed to return after 12 injections, 2 dropped out without reason given, 1 mild asthmatic reaction and was excluded | | Local reaction in 34 patients | | | Intervention(s) described: Yes
| 1) Extract of Dermatophagoides pteronyssinus (house dust mite) prepared by professional laboratory (n = 45). A 1-g sample of mites and mite excreta, separated from the culture medium, was extracted in 100 ml of glycerinated extraction fluid to make a 1% extract. Three concentrations of vaccine made (0.005%, 0.04%, and 0.33%). Build-up phase: increasing injections of 0.1, 0.2, 0.4, and 0.8 ml given weekly from each vial in order, starting with the lowest concentration (0.005%). Dose repeated or reduced in event of adverse reactions. Treatment stopped after 12 injections (3 months), regardless of whether top dose reached or not. | | | 18 patients mild asthma and/or rhinitis | | | Comorbidities described: Yes
| | | | 4 short term generalized urticaria | | | Diagnosis by MD: Yes
| | | 2) Patient global assessment of efficacy: following parameters graded as “improved” (very much, moderately, or slightly), “not changed,” or “worse” (slightly, moderately, or very much) at 1 and 3 months: | 3 fainting and dizziness | | | Objectively confirmed: Yes
| | | | | | | Outcome measures valid: No
| | | | Placebo: 2 discontinued treatment because of mild asthma | | | Level of evidence: 2b
| | | | | | | Randomized: Yes
| | No. of subjects at end: 91 | | | | | Allocation concealed: Not described
| | | | 2) Patient global assessment of efficacy:
| | Inclusion criteria: Positive skin test to D. pter.; history of symptoms induced by house dust or positive nasal challenge with D. pter. | | | | | Double-blind: Yes
| | | | At 1 and 3 months, 91 patients assessed. No difference at 1 month in any parameter. | | | Blinding adequate: Yes
| | | | | | | Dropouts described: Yes
| | | Asthma | | | | Intention-to-treat: No
| | | Rhinitis | Results at 3 mo. (%) (active v plac):
| | | Exercise tolerance | Asthma improved: 33 v 62.5 p = 0.02
| | Exclusion criteria: Steroid therapy within previous 3 months; house dust IT within 3 years | Dust tolerance (3 months only) | Rhinitis improved: 29 v 22 NS | | | Notes:
| | | | Exercise tolerance better: 35 v 19 NS
| | | Time off work | Dust tolerance better: 55 v 30 p = 0.05
| | | Drug use (3 months only) | Time off work less: 25 v 14 NS
| | Age: 10–41+ | Overall assessment | Drug use less: 43 v 19 p = 0.05
| | | | Overall very much better: 35 v 19 NS
| | Sex: 16 F/46 placebo, 21 F/45 active | 3) Nasal reactivity
| | | | 3) Nasal reactivity: Not abstracted
| | | 4) Skin reactivity
| | Race: NR | | 4) Skin reactivity: Not abstracted
| | | 5) Patient-assessed symptom severity: wheeze, rhinitis, and night asthma graded daily on scale of 0–3
| 2) Placebo (carbol saline solution) (n = 46) | Other: 10 subjects in each group previously received house dust IT | | 5) Patient-assessed symptom severity:
| | | | Adequate data for 70 patients. No difference between groups with both groups improving.
| Patients in both groups were advised to vacuum their mattresses and pillows, damp-dust their bedrooms, and wash their blankets every 6–8 weeks, and to exclude feathers from their beds.
| | | 6) Use of permitted symptomatic medication: recorded daily in study diaries | 6) Use of permitted symptomatic medication:
| | | | No difference.
| | | | 7) Total IgE, and allergen-specific IgE and IgG antibody levels: Not abstracted
| | | 7) Total IgE, and allergen-specific IgE and IgG antibody levels
| Duration of study treatment: 3 months
| | | | 8) Lymphocyte transformation and leucocyte inhibition: Not abstracted
| Symptomatic medication permitted: Antihistamines, Mogadon®, isoprenaline inhaler, Ventolin® inhaler, and Intal® | | 8) Lymphocyte transformation and leucocyte inhibition
| | | | 9) Histamine release: Not abstracted
| | | 9) Histamine release
| Dates: NR
| Location: London
| Setting: Academic unit
| Type(s) of providers: Specialists
Durham, Walker, Varga, et al., 1999 | Design: RCT, parallel-group | No. of subjects at start: 32 | 1) Patient-assessed symptom severity (daily diary): breathlessness, coughing, wheezing, chest tightness, sneezing, blocked nose, running nose, itching eyes, red eyes, streaming eyes, swollen eyes, and itching and dryness of mouth and throat graded daily from May through September on visual analog scale of 0 (no symptoms) to 3 (severe symptoms) | 1) Patient-assessed symptom severity (daily diary): | | | Quality Scoring:
| | | | | | | Population similar: Yes
| Interventions: | Dropouts/withdrawals: 5 | | No differences | | | Intervention(s) described: Yes
| All patients had received 3–4 years of active immuno-therapy as described by Varney, Gaga, Frew, et al., 1991 and Durham, Varney, Gaga, et al., 1991, below. At start of this phase of the trial, all were randomized to one of following: | | | Nose symptoms: | | | Comorbidities described: Yes
| | No. of subjects at end: 27 | | Year | Difference b/w Maint & d/c | | Diagnosis by MD: Yes
| | | | 1993 | -74 (-325 to 266) | | Objectively confirmed: Yes
| | Inclusion criteria: Participation in IT group of previous RCT of IT for allergic rhinitis for timothy grass pollen allergy | | 1994 | 67 (-287 to 490) | | Outcome measures valid: No
| | | | 1995 | -5 (-462 to 462) | | Level of evidence: 1b
| | | | p = NS | | | Randomized: Yes
| | | | | | | Allocation concealed: Not described
| | | | 2) Use of symptomatic medication:
| | Exclusion criteria: None specified | | No differences | | | Double-blind: Yes
| 1) Continued maintenance immunotherapy (n = 16). Monthly injections of a standardized, aluminum hydroxide-adsorbed grass pollen extract (Alutard®), each containing 100,000 SQ units. Dose reduced by 40% during pollen season. | | | Year | Difference b/w Maint & d/c | | Blinding adequate: Yes
| | Age: Median 40 | | 1993 | 54 (-724 to 2009) | | Dropouts described: Yes
| | | | 1994 | 4 (-1064 to 2121) | | Intention-to-treat: No
| | Sex: 19 men, 13 women | | 1995 | 11 (-689 to 1488)
| | | 2) Use of symptomatic medication: scored daily from April to October as follows: | p = NS
| | Race: NR | | | | | Notes:
| | | | 3) Patient-assessed symptom severity (every 2 weeks): | | | Randomized patient population same as in Varney, Gaga, Frew, et al., 1991 and Durham, Varney, Gaga, et al., 1991, below. Paper also described 15 matched natural-history controls who had never received immunotherapy and were not randomized to treatment in this trial.
| | Other:
| | | Each eye drop, nasal spray, or albuterol inhalation: 1 | No differences
| | | | Year | Difference b/w Maint & d/c
| 2) Placebo maintenance immunotherapy (diluent plus 0.01 mg of histamine per ml) (n = 16) | | | 1993 | -1 (-2.6 to 0.3)
| | | Each acrivastine or prednisolone: 2 | 1994 | 0 (-3 to 3.1)
| | | | 1995 | 0.2 (-1.9 to 1.6)
| | | | p = NS
| | | 3) Patient-assessed symptom severity (every 2 weeks): During pollen season, patients asked to grade their overall symptoms every 2 weeks on a visual analog scale from 0 (minimal symptoms) to 10 (maximal symptoms) in response to question, “How has your hay fever been during the past week?”
| Duration of study treatment: 3 years | | | 4) Conjunctival reactivity: Not abstracted
| Symptomatic medication permitted: Cromolyn sodium eye drops and nasal spray, acrivastine, and albuterol; 7-day course of prednisolone could be given, if necessary | | | 5) Skin reactivity: Not abstracted
| | | | | | | Only trial examining effect of discontinuing maintenance treatment.
| | | | 6) CD3 and T cells, and interleukin-4 mRNA: Not abstracted
| | | | 7) Adverse reactions:
| | | | No substantial immediate or late systemic reactions were observedLess than 2% of injections resulted in early or delayed local reactions.
| Dates: 1992-1995
| Location: London, UK
| | | 4) Conjunctival reactivity
| Setting: Allergy clinic | | 5) Skin reactivity
| Type(s) of providers: Allergists
| | | 6) CD3 and T cells, and interleukin-4 mRNA
| | | 7) Adverse reactions
Eriksson, Ahlstedt, and Lövhagen, 1979 | Design: RCT, parallel-group | No. of subjects at start: 47 | 1) Nasal reactivity | 1) Nasal reactivity: Not abstracted | | | Quality Scoring:
| | | | | | | Population similar: Not adequately described
| Interventions: | Dropouts/withdrawals: Not specified, but analysis based on smaller number of patients than originally treated. | 2) Patient-assessed symptom severity and use of symptomatic medication (combined in a single measure): sneezing, rhinorrhea, and eye symptoms graded daily during pollen season in year 1 on scale of 0 (no symptoms) to 3 (severe symptoms); number of antihistamine and prednisolone tablets taken also scored from 0 to 3 | 2) Patient-assessed symptom severity and use of symptomatic medication (combined in a single measure):
| 1) Birch, alder, and hazel allergen extract (Allpyral^®^) (n = 17). Injections given once a week until highest tolerated dose or maximum dose of 4,000 PNU reached; this dose then given as a maintenance dose every 6–8 weeks. | | | | | | Intervention(s) described: Yes
| | | | | | | Comorbidities described: No
| | | | Data presented as graph with score vs. time. Values for medication significant p < 0.01 and symptoms scores p < 0.05. | | | Diagnosis by MD: Yes
| | | | | | | Objectively confirmed: Yes
| | No. of subjects at end: Estimated at 46 | | | | | Outcome measures valid: No
| | | | | | | Level of evidence: 1b
| | | | | | | Randomized: Yes
| | Inclusion criteria: Adult hay fever patients with positive nasal provocation test to birch pollen | | 3) Patient global evaluation of treatment efficacy: | | | Allocation concealed: Not described
| 2) Allpyral^®^ (as above) plus other aqueous tree pollen extracts, as identified by nasal provocation tests using other tree pollens (n = 16). Aqueous allergen extracts given twice a week in increasing doses until highest tolerated dose reached; this dose then administered every 4 weeks. | | | Less troublesome symptoms: | | | Double-blind: No
| | | | Group 1 83% | | | Blinding adequate: Not applicable
| | Exclusion criteria: NR | | Group 2 93%
| | | | Group 3 64% | | | Dropouts described: No
| | Age: | | all ns | | | Intention-to-treat: No
| | Group 1 (15–46) | 3) Patient global evaluation of treatment efficacy: at end of pollen season in year 1, patients asked to grade their symptoms relative to previous year's symptoms on scale of 0 (no symptoms) to 4 (worse)
| | Group 2 (15–33) | | 4) IgE and non-IgE antibody levels (against birch and beech allergens) :
| | Group 3 (14–45) | | | | | Note: Not blinded
| | | | Not abstracted
| | Sex:
| | Group 1 8M/9F | | 5) Allergen-induced histamine release:
| | Group 2 8M/8F | | Not abstracted
| 3) No immunotherapy (n = 14) | Group 3 7M/7F
| | Race: NR
| Patients in groups 1) and 2) who were also allergic to grass and/or compositae pollen were given immunotherapy with those allergens as well. | | 4) IgE and non-IgE antibody levels (against birch and beech allergens)
| | Other:
| | | 5) Allergen-induced histamine release
| Duration of study treatment:
| 3 years (“as a rule”)
| Symptomatic medication permitted: antihistamine tablets (brompheniramine 40 mg + phenylpropanololamine 167 mg) for mild symptoms and prednisolone 5 mg if symptoms intolerable in spite of treatment with antihistamine
| Dates: Treatment preceded 1974 pollen season
| Location: Sweden
| Setting: University clinic
| Type(s) of providers: Specialists
Ewan, Alexander, Snape, et al., 1988 | Design: RCT, parallel-group | No. of subjects at start: 38 | 1) Skin reactivity | 1) Skin reactivity: Not abstracted | | | Quality Scoring:
| | | | | | | Population similar: Yes
| Interventions: | Dropouts/withdrawals: NR. | 2) Nasal reactivity | 2) Nasal reactivity: Not abstracted | | | Intervention(s) described: Yes
| 1) Standardized, partially purified, freeze-dried extract of Dermatophagoides pteronyssinus (house dust mite) (Pharmalgen^®^) (n = 16). Modified “semi-rush” technique used. Injections given at 1- to 2-week intervals, using aqueous extracts in gradually increasing concen-trations. Initial dose was 70 BU (20 + 50); planned top dose was 100,000 BU. Dose increased until a reaction occurred, then reduced and slowly increased again until a second phase of reaction encountered. Dose just below this (maximum tolerated dose) then used for maintenance injections, in depot diluent, which were given monthly for remainder of 3-month period. | However, before and after skin test data provided on only 34 patients | | | | | Comorbidities described: No
| | | 3) Patient-assessed symptom severity: (unspecified) nasal symptoms graded 1 month before treatment and 3 months after start of treatment on visual analog scale (10-cm line, with “no symptoms” at 0 cm, “minimal symptoms” at 1 cm, “slight symptoms” at 4 cm, “moderate symptoms” at 7 cm, and “severe symptoms” at 10 cm) | 3) Patient-assessed symptom severity: | | | Diagnosis by MD: Yes
| | | | VAS symptoms: | | | Objectively confirmed: Yes
| | | | Active: 66.8 to 28.8 | | | Outcome measures valid: No
| | No. of subjects at end: NR | | Placebo: 50.2 to 39.3 | | | Level of evidence: 2b
| | | | Drop in active group significantly greater than in placebo group (p < 0.01). | | | Randomized: Yes
| | Inclusion criteria: Perennial rhinitis ± asthma; history suggesting allergy to D. pter. and no other active perennial allergy | | | | | Allocation concealed: Not described
| | | | | | | Double-blind: Yes
| | | | 4) Allergen-specific IgE levels: Not abstracted | | | Blinding adequate: Yes
| | | | | | | Dropouts described: No
| | Exclusion criteria: IT within last 3 years; systemic corticosteroids within last 1 year | | | | | Intention-to-treat: No
| | | | 5) Adverse reactions:
| | | | 31 generalized reactions (15% of injections) in active group. 8 were serious or potentially serious and classified as anaphylaxis. Patients responded to epinephrine. Some patients received oxygen, nebulized b-agonists and parenteral steroids. 7 had asthma exacerbation, 5 asthma/uricaria, 3 rhinitis exacerbation, 5 erythema or pruritis, 3 erythema with “other” symptoms. All were early reactions.
| | | | | | | Notes:
| | Age: 16–55 | | | | | Article reports interim (3-month) results of trial scheduled to last 1 year.
| | | 4) Allergen-specific IgE antibody levels
| | Sex: 17 F
| | Race: NR | 5) Adverse reactions | | | | No daily symptom data analyzed.
| | Other:
| | Assessment made after 3 months of treatment. | | | | | Potentially significant differences in baseline symptom scores may influence result if there was a “floor” effect on reduction of symptoms.
| 2) Placebo extract (contained histamine) (n = 20). Also given in gradually increasing doses
| | All had positive skin test response, positive nasal challenge, and serum IgE antibodies to D. pter.
| | | | 13 generalized reactions (5% of injections) in placebo group. All were mild: 10 with generalized pruritis and erythema, 2 with rhinitis, 1 with asthma.
| Duration of study treatment: 3 months (see Notes)
| | | | Localized reactions in 6% of active group (induration) and mild flare in 3% and 2% of active and placebo group respectively.
| Symptomatic medication permitted: Beclomethasone nasal spray or short-acting antihistamines (chlorpheniramine or terfenadine)
| Dates: NR
| Location: London
| Setting: Hospital-based allergy department
| Type(s) of providers: Specialists
Gabriel, Ng, Allan, et al., 1977 | Design: RCT, parallel-group | No. of subjects at start: 72 | 1) Patient-assessed symptom severity: sneezing, nasal obstruction, nasal discharge, and asthma graded daily on 4-point scale (none, mild, moderate, severe) | 1) Patient-assessed symptom severity: | | | Quality Scoring:
| | | | Symptom Improvement after weekly course-% of pts. improved (Active v Placebo) | | | Population similar: No
| Interventions: | Dropouts/withdrawals: | | | | | Intervention(s) described: Yes
| 1) Extract of Dermato-phagoides pteronyssinus (house dust mite) made up in four concentrations in a solution of 50% aqueous glycerine containing 0.5% phenol (n = 37). Vaccines prepared in concentrations of 0.0004% (for children under 12 only), 0.003%, 0.025% and 0.20%. Build-up phase: weekly injections of gradually increasing doses, with variations according to age; children aged 8–11 could complete course in 22 weeks, older children in 19 weeks, and adults in 18 weeks. Maintenance phase: monthly injections of highest concentration (1 ml of 0.20% vaccine). | 3 excluded because of lack of symptom, and 3 “defaulted” during weekly course leaving 66 patients for initial evaluation (33A, 33P). 16 pts. excluded from maintenance course (10A, 6P). 7 defaulted or left country (3A, 4P), 6 enrolled late did not complete monthly course (5A, 1P), 3 withdrawn (2A, 1P) for moderately severe reactions. | | | | | Comorbidities described: Yes
| | | | Sneezing 50 v 32 NS | | | Diagnosis by MD: Yes
| | | | Obstruction 24 v 24 NS | | | Objectively confirmed: Yes
| | | | Discharge 32 v 31 NS | | | Outcome measures valid: No
| | | | All symptoms 27 v 21 NS | | | Level of evidence: 2b
| | | | | | | Randomized: Yes
| | | 2) Investigator-assessed symptom severity | Symptom imrovement after 12 month maintenance course-% pts. improved (Active v Placebo) | | | Allocation concealed: Not described
| | | | | | | Double-blind: Yes
| | | 3) Skin reactivity | Sneezing 55 v 36 | | | Blinding adequate: Yes
| | | | Obstruction 69 v 18 | | | Dropouts described: Yes
| | | 4) Nasal reactivity | Discharge 75 v 43 | | | Intention-to-treat: No
| | No. of subjects at end: 50 (23A, 27P). | | All symptoms 55 v 19 (p = 0.02)
| | | 5) Allergen-specific IgE and IgG antibody levels
| | | | 2) Investigator-assessed symptom severity: Not abstracted | | | Notes:
| | Inclusion criteria: Chinese; age ≥ history of seasonal or perenial rhinitis for 3+ consecutive years, characterized by sneeze, nasal obstruction and discharge, ± asthma; positive skin test to D. pter.; positive nasal challenge to D. pter.
| | | 6) Eosinophil counts
| | | | 3) Skin reactivity: Not abstracted
| | | 7) Adverse reactions
| | | | 4) Nasal reactivity: Not abstracted
| | | | 5) Allergen-specific IgE and IgG levels: Not abstracted
| 2) Placebo vaccine (saline only) (n = 35)
| | Exclusion criteria: Current use of corticosteroids or nasal cromoglycate | | 6) Eosinophil counts: Not abstracted
| Duration of study treatment: 1 year | | | 7) Adverse reactions:
| | | | Weekly course: One or more reactions in 91% of active group and 33% of placebo group. Average 9.2/pt active and 0.9/pt placebo.
| | Age: 11 patients under age 12
| No description of symptomatic medication permitted (if any)
| | Sex: 34 F
| Dates: 5/73-3/74 | Race: 100% Asian | | Breakdown by group % (active v placebo)
| Location: Hong Kong | Other: | | Cutaneous local 91 v 33
| | 22 subjects in each group reported a history of asthma symptoms. | | Cutaneous general 6 v 3
| Setting: Hospital-based chest clinic | | | Rhinitis 9 v 6
| | | | Wheezing/asthma 6 v 6
| | | | Anaphylaxis 3 v 0
| Type(s) of providers: Specialists | Only 6/66 monosensitized to D. pter. | | Other 9 v 9 (not specified)
| | | | Maintenance course: 95% of active group and 11% of placebo group. 7.2/pt active and 0.1/pt placebo.
| | | | Breakdown by group % (active v placebo)
| | | | Cutaneous local 96 v 11
| | | | Cutaneous general 0 v 0
| | | | Asthma 12 v 0
Grammer, Shaughnessy, Bernhard, et al., 1987 | Design: RCT, parallel-group (matched-pairs design) | No. of subjects at start: 81 subjects who ultimately formed 35 pairs (no discussion of 11 unpaired subjects) | 1) Adverse reactions: Recorded during clinic visits and by patients on reporting forms at specified intervals up to 48 hours after each injection; also reported to treatment nurse before next injection | 1) Adverse reactions: | | | Quality Scoring:
| | | | 19/37 placebo pt with immediate local reaction (51%). 26 of 36 active group patients with immediate local reaction (72%). No systemic allergic reactions in either group. | | | Population similar: Not adequately described
| Interventions: | | | | | | Intervention(s) described: Yes
| 1) Polymerized ragweed (PRW) prepared by a professional lab (n = 35). Short and giant ragweed pollens extracted, precipitated, and fractionated, then polymerized with glutaraldehyde. Injections given weekly for 15 weeks. AU and PNU delivered gradually increased from 2.5 to 62.5 and from 30 to 746, respectively, over the course of the first 5 injections. The last 10 injections were of a constant dose (125 AU, 1492 PNU). Cumulative totals were 1359 AU and 16,218 PNU. | | | | | | Comorbidities described: Yes
| | Dropouts/withdrawals: 15 pairs (5 pairs lost to followup) | | | | | Diagnosis by MD: Yes
| | | | | | | Objectively confirmed: Yes
| | | | 2) Laboratory studies: Not abstracted | | | Outcome measures valid: No
| | No. of subjects at end: 10 “new” pairs formed under blinded status. Presumably 30 pairs were analyzed at end. | | | | | Level of evidence: 2b
| | | 2) Laboratory studies (urinalysis, CBC, etc.) | 3) Total serum AgE-binding capacity and AgE binding by IgE: Not abstracted | | | Randomized: Yes
| | | | | | | Allocation concealed: Not described
| | | 3) Total serum AgE-binding capacity and AgE binding by IgE | | | | Double-blind: Yes
| | Inclusion criteria: History compatible with AR caused by ragweed for previous 2+ years; positive skin test to ragweed; no IT for 3 years prior; healthy by H,x, PE and lab evaluation | | 4) Patient-assessed symptom severity and medication use (combined in a single measure): | | | Blinding adequate: Yes
| | | | | | | Dropouts described: No
| | | | | | | Intention-to-treat: No
| | | 4) Patient-assessed symptom severity and medication use (combined in a single measure): nasal congestion, nasal discharge, sneezing, ocular pruritus, cough, and wheeze graded 3 times daily during pollen season on scale of 0–3 (not described); use of symptomatic medication recorded in study diaries daily during pollen season | Absolute values not given, but scores significantly favored active treatment at all time points from week 1 until week 5.
| | | | | | | Notes:
| | Exclusion criteria: None specified | | Week 1 p = 0.008
| | | | Week 2 p = 0.035
| | Age: 21–60 | | Week 3 p = 0.013
| 2) Placebo (carmelized glucose and histamine phosphate, 20 μg/ml) (n = 35). Identical to active treatment in terms of volume injected. | | | Week 4 p = 0.004
| | Sex: NR | | Week 5 p = 0.05
| | Race: NR | | Primary season (Week 2–4) p = 0.005
| | | | Secondary season (Week 1–5) p = 0.02
| | Other: 12 patients with mild asthma
| Duration of study treatment: | | | Results obtained from 68 patients. No data on other patients.
| Treatment lasted 15 weeks; outcomes assessed for 6 months
| Symptomatic medication permitted: Not described
| Dates: 1985 ragweed season
| Location: Chicago, IL
| Setting: University allergy practice
| Type(s) of providers: Specialists
Grammer, Shaughnessy, Shaughnessy, et al., 1987 | Design: RCT, parallel-group | No. of subjects at start: 57 | 1) Patient-assessed symptom severity and medication use (combined in a single measure): nasal congestion and sneezing graded 3 times daily during pollen season on scale of 0–3 (not described); number of antihistamine or decongestant tablets taken recorded in study diaries daily during pollen season | 1) Patient-assessed symptom severity and medication use (combined in a single measure): | | | Quality Scoring:
| | | | | | | Population similar: Yes
| Interventions: | Dropouts/withdrawals: NR | | | | | Intervention(s) described: Yes
| 1) Polymerized ragweed (PRW) (n = 19). 15 weekly injections supplying 50,000 PNU of ragweed, equivalent to 1200 μg antigen E. No further details provided. | | | 50 of 57 patients completed diary. Allocation across groups not given. | | | Comorbidities described: Yes
| | No. of subjects at end: NR, but only 50 of 57 patients reported clinical response data | | | | | Diagnosis by MD: Yes
| | | | | | | Objectively confirmed: Yes
| | | | Primary outcome was a comparison of cumulative symptom score in treated and untreated asthmatics and treated and untreated non asthmatics. | | | Outcome measures valid: No
| | | | | | | Level of evidence: 2b
| | Inclusion criteria: Symptoms of allergic rhinitis during ragweed season | | | | | Randomized: Yes
| | | | | | | Allocation concealed: Not described
| 2) Placebo (carmelized glucose and histamine) (n = 19)
| | | | Treated asthmatics had significantly lower scores (p = 0.01) and treated non-asthmatics had significantly lower scores (p = 0.04). | | | Double-blind: Yes
| | Exclusion criteria: None specified | | | | | Blinding adequate: No
| | | | | | | Dropouts described: No
| 3) No treatment (n = 19) | Age (means): | | | | | Intention-to-treat: No
| | Untreated no asthma 29 | 2) Total serum AgE-binding capacity and AgE binding by IgE
| Duration of study treatment: | Untreated asthma 33 | | 3) Total serum AgE-binding capacity and AgE binding by IgE: Not abstracted
| Treatment lasted 15 weeks; outcomes assessed through ragweed pollen season (1^st^ week in August through 1^st^ week in October) | Treated no asthma 32 | | | | | Notes:
| | Untreated asthma 34 | | | | | Initially 3 groups were defined: treated, placebo and untreated. Analysis was performed on combination of placebo and untreated group.
| | Sex: 14 F
| | Race: NR
| Symptomatic medication permitted: Antihistamines and decongestants; patients with asthma permitted to continue with their regular asthma meds
| | Other: | | | | | Not possible to determine if treatment group improved from baseline. All we can determine is that cumulative score was lower.
| | 23 patients had diagnosis of asthma at enrollment.
| Dates: NR
| Location: Chicago, IL
| Setting: Univ allergy practice
| Type(s) of providers: Specialists
Grammer, Shaughnessy, Suszko, et al., 1983 | Design: RCT, parallel-group | No. of subjects at start: 26 | 1) Adverse reactions | 1) Adverse reactions: | | | Quality Scoring:
| | | | IT 2/10 pts had at least 1 immediate local reaction (erythema and induration); 1/10 had erythema alone; 1/10 had large late local reaction; no systemic reactions | | | Population similar: Yes
| Interventions: | Dropouts/withdrawals: 3 | 2) Immunologic studies (total serum antibody against rye grass group I [RGGI], IgE against RGGI) | | | | Intervention(s) described: Yes
| 1) Multiple (either five or six) grass-pollen polymer mixtures (n = 10). Treatment started in February. 12 weekly injections given, ranging in dose from 90 PNU (week 1) to 7200 PNU (weeks 8–12). Dose repeated in event of large local reaction (in which case additional injections given to reach target total dose, approximately 48,000 PNU). | | | | | | Comorbidities described: No
| | No. of subjects at end: 23 | | | | | Diagnosis by MD: Yes
| | | | | | | Objectively confirmed: Yes
| | Inclusion criteria: History typical of grass pollinosis; 4+ prick test to at least 1 grass pollen extract (1/20 wt/vol) of rye, timothy, redtop, June, orchard or Bermuda (ALO, Columbus, OH) | | Placebo: 2/13 had at least one immediate local reaction; 3/13 had erythema alone; 1/13 had large local reaction | | | Outcome measures valid: No
| | | 3) Patient-assessed symptom severity and medication use (combined in a single measure): symptoms (e.g., sneezing, nasal discharge, pruritus, cough) graded 3 times per day during pollen season (May - early July) on scale of 0–3 (not described); names of medication and numbers of pills taken also recorded | | | | Level of evidence: 2b
| | | | | | | Randomized: Yes
| | | | | | | Allocation concealed: Not described
| | | | 2) Immunologic studies: Not abstracted | | | Double-blind: Yes
| | | | | | | Blinding adequate: Yes
| | Exclusion criteria: Immuno-therapy within 5 years; abnormal ESR, CBC, UA | | | | | Dropouts described: Yes
| | | | 3) Patient-assessed symptom severity and medication use (combined in a single measure): | | | Intention-to-treat: No
| 2) Placebo (caramelized glucose histamine) (n = 13) | Age: Range 21 to 65 years | | IT significantly lower than placebo (p = 0.02) (Fig. 5 interpolated figures IT 210 ± 75 [mean ± SEM]; placebo 500 ± 115) | | | Notes:
| | Sex: NR
| Duration of study treatment:
| Injections given over 12 weeks (Feb-Apr); outcomes assessed through pollen season (early July) | Race: NR | 4) Patient global evaluation of efficacy of treatment: patients asked whether or not their symptoms were significantly improved (yes/no)
| | | | 4) Patient global evaluation of efficacy of treatment:
| | Other:
| | | | IT 9/10 improved
| | | | Placebo 3/13 improved
| Symptomatic medication permitted: Not specified, but implied that antihistamines could be taken | | | P < 0.01
| | | | 5) Lab tests: Not abstracted
| | | 5) Lab tests (CBC with differential leukocyte count, erythrocyte sedimentation rate, urinalysis)
| Dates: Feb-Jul 1982
| Location: Chicago, IL
| Setting: Allergy clinic
| Type(s) of providers: Allergists
Grammer, Zeiss, Suszko, et al., 1982 | Design: RCT, parallel-group | No. of subjects at start: 42 study patients + 15 no-treatment controls | 1) Adverse reactions | 1) Adverse reactions: | | | Quality Scoring:
| | | | 3/21 active treatment with local reaction. 7/21 had large reactions requiring additional dosing. No systemic reactions. | | | Population similar: Yes
| Interventions: | | 2) Antibody levels (IgE against AgE) | | | | Intervention(s) described: Yes
| 1) Polymerized ragweed (PRW) (n = 21). 15 weekly injections given. Doses for injections 1–5 were as follows (PNU per injection): 125; 312; 625; 1,250; 3,125. Dose for injections 6–15 was 6,250 PNU. Total dose approximately 50,000 PNU of ragweed, equivalent to 1,200 μg antigen E. Schedule modified in event of large local reaction. | | | | | | Comorbidities described: No
| | Dropouts/withdrawals: 2 | | | | | Diagnosis by MD: Yes
| | | 3) Patient-assessed symptom severity: sneezing, nasal discharge, nasal congestion, pruritus, and wheezing graded 3 times per day during allergy season on scale of 0 to 3 (not described) | | | | Objectively confirmed: Yes
| | No. of subjects at end: 40 study patients + 15 no-treatment controls | | 2/19 placebo subjects with local reactions. 1/19 with large local reaction requiring additional dosing. | | | Outcome measures valid: No
| | | | | | | Level of evidence: 2b
| | | | | | | Randomized: Yes
| | | | | | | Allocation concealed: Not described
| | Inclusion criteria: Symptoms of ragweed hay fever; positive prick skin test to ragweed pollen | | 2) Antibody levels (IgE against AgE): Not abstracted
| | | | | | | Double-blind: Yes
| | | | | | | Blinding adequate: Yes
| | | | 3) Patient-assessed symptom severity: | | | Dropouts described: No
| | Exclusion criteria: NR | | Average daily symptom scores plotted on graph with score vs. time. All values except final 2 weeks statistically significant. | | | Intention-to-treat: No
| | Age: 21–65
| 2) Placebo (carmelized glucose and histamine) (n = 19) | | | | | | Notes:
| | Sex: NR
| | | | Also, total symptom scores shown on a graph, with significant differences between treatment vs. no-treatment control group (p = 0.0107) and between treatment and placebo (p = 0.0224).
| | Race: NR
| 3) No treatment (n = 15)
| | Other: None had received immunotherapy within previous 5 years
| Duration of study treatment:
| Injections given over 15 weeks; outcomes measured during one allergy season (Aug-Oct)
| Symptomatic medication permitted: Not described
| Dates: Treatment prior to 1981 ragweed pollen season
| Location: Chicago, IL
| Setting: University practice
| Type(s) of providers: Specialists
Hirsch, Kalbfleisch, and Cohen, 1982 | Design: RCT, parallel-group (matched-pairs design) (see Notes) | No. of subjects at start: 34 | 1) Adverse reactions | 1) Adverse reactions: | | | Quality Scoring:
| | | | 10% of subjects in each group experienced local reactions. No systemic reactions. Two subjects in placebo group had flushing and palpitations for 10–15 minutes after the injection. | | | Population similar: Yes
| | Dropouts/withdrawals: | 2) Patient-assessed symptom severity: unidentified symptoms recorded daily “for several weeks before, during, and after” pollen season | | | | Intervention(s) described: Yes
| | Variable number of subjects at weekly assessment shown in primary data table. | | | | | Comorbidities described: Yes
| Interventions: | | | | | | Diagnosis by MD: Yes
| 1) Standard immunotherapy using glycerinated aqueous ragweed extract (n = 20). Weekly injections given from early March through late April, then twice weekly through mid-August. Maintenance injections (schedule not described) given through 1^st^ week of October. Dose increased to tolerance, limited only by local reactions. Mean cumulative dose 5,391 PNU (20.1 μg of antigen E). | | | | | | Objectively confirmed: Yes
| | | | | | | Outcome measures valid: No
| | No. of subjects at end: 32 | | | | | Level of evidence: 2b
| | | | 2) Patient-assessed symptom severity: | | | Randomized: Yes
| | Inclusion criteria: History of allergic nasal and ocular symptoms of allergic rhinitis without asthma during August and September for 2+ years; positive skin test | 3) Use of symptomatic medication: recorded daily “for several weeks before, during, and after” pollen season | Mean weekly symptom scores for the 6 weeks in which pollen was present were significantly lower in the treatment group during 5 of 6 weeks (active vs. placebo): | | | Allocation concealed: No
| | | | | | | Double-blind: Yes
| | | | | | | Blinding adequate: Yes
| | | | | | | Dropouts described: No
| | | | | | | Intention-to-treat: No
| | | | Week 1) 12.6 ± 16.0 vs. 30.9 ± 23.5;
| | | 4) Physical exam score | p < 0.02
| | Exclusion criteria: Immuno-therapy during last 2 years, except for subjects who participated in a previous trial in 1979; positive mold skin test; positive dust mite skin tests | | Week 2) 34.9 ± 22.6 vs. 51.6 ± 28.3; ns | | | Note:
| | | 5) Allergen-specific IgE antibody levels | | | | 8/20 patients in the ragweed group and 8/14 in the placebo group had participated in an earlier controlled trial of ragweed vs. placebo (Hirsch, Kalbfleisch, Golbert, et al., 1981 [status?; patients were from Milwaukee 1979 ragweed trial]). These patients continued to receive extracts of same allergen as before (ragweed or placebo), though using a different protocol. Newly recruited patients (n = 18) were randomized to treatment. Results abstracted here for 1980 trial only (SIT [Tr] vs. placebo), and not for SIT vs. RIT comparisons (1980 vs. 1979).
| | | | Week 3) 37.8 ± 21.8 vs. 62.7 ± 23.7;
| | | | p < 0.01
| 2) Placebo (glycerinated caramelized histamine) (n = 14) | | | Week 4) 33.0 ± 18.5 vs. 59.4 ± 33.4;
| | | | p < 0.02
| | | | Week 5) 18.1 ± 16.1 vs. 39.2 ± 22.3;
| | Age: | | p < 0.01
| Duration of study treatment: | Active 26–64 mean 40.7 | | Week 6) 17.4 ± 18.9 vs. 34.4 ± 19.3;
| 7 months (early March to early October) | Placebo 17–64 mean 38.6 | | p < 0.025
| | Sex: | | Mean symptoms (6 weeks of exposure): Active 24.8 ± 15.1; placebo 45.9 ± 18.6; p < 0.005
| Symptomatic medication permitted: Not described | Active 13M/7F
| | Placebo 9M/5F
| Dates: 1980 | Race: NR | | 3) Use of symptomatic medication:
| | | | Medication scores were significantly different during 2 of the 6 exposure weeks. Data presented as mean weekly scores with SD.
| Location: Milwaukee, WI | Other:
| | Several patients in the trial participated in an IT trial in the prior year. These subjects were not re-randomized in this trial but received active treatment or placebo according to what was received in the previous trial.
| Setting: University-based clinic
| | | | 4) Physical exam score: Not abstracted
| Type(s) of providers: Specialist
| | | | 5) Allergen-specific IgE antibody levels: Not abstracted
Hirsch, Kalbfleisch, Golbert, et al., 1981 | Design: RCT (?), parallel-group (matched-pairs design) | No. of subjects at start: NR | 1) Patient-assessed symptom severity: unidentified symptoms recorded daily “for several weeks before, during, and after” pollen season | Results were reported separately for multiple sites, seasons, and allergens; results summarized below are pooled results for all sites/seasons/allergens. | | | Quality Scoring:
| | | | | | | Population similar: Yes
| | Dropouts/withdrawals: NR | | | | | Intervention(s) described: Yes
| Interventions: | | | | | | Comorbidities described: No
| 1) Rinkel injection therapy using glycerinated aqueous ragweed, grass, or mountain cedar pollen extracts (n = 81). “Optimal dose” determined for each patient based on skin test by serial dilution titration and patient's clinical status. Optimal dose usually reached in 6–8 injections given at weekly intervals; maintenance injections then given weekly. Total mean cumulative dose 18.6 PNU. | No. of subjects at end: 155 | | | | | Diagnosis by MD: Yes
| | | | 1) Patient-assessed symptom severity: | | | Objectively confirmed: Yes
| | Inclusion criteria: 15+ years of age; two successive seasons of allergic rhinitis; no immunotherapy in previous 2 years | | Dot plots comparing active and placebo treatments are shown with lines designating mean and median symptom scores. Text describes differences as not significant. | | | Outcome measures valid: No
| | | 2) Use of symptomatic medication: recorded daily “for several weeks before, during, and after” pollen season | | | | Level of evidence: 2b
| | | | | | | Randomized: No
| | | | | | | Allocation concealed: Yes
| | | | | | | Double-blind: Yes
| | Exclusion criteria: History suggestive of mold, house dust, or food allergies | | | | | Blinding adequate: Yes
| | | | 2) Use of symptomatic medication: | | | Dropouts described: No
| | | 3) Physical exam score | Dot plots comparing active and placebo treatments are shown with lines designating mean and median medication scores. Text describes differences as not significant. | | | Intention-to-treat: Can't determine
| | Age: | 4) Allergen-specific IgE antibody levels
| | Active 19–70 mean 38.2
| | Placebo 14–63 mean 35.6 | | | | | Notes:
| | | | | | | Not absolutely clear whether randomized or not.
| 2) Placebo (glycerinated caramelized histamine) (n = 74) | Sex: | | 3) Physical exam score: Not abstracted
| | Active 44M/37F
| | Placebo 44M/30F
| | | | 4) Allergen-specific IgE antibody levels: Not abstracted
| Duration of study treatment: | Race: NR
| Each treatment seems to have been given “for several weeks before, during, and after” a single pollen season during 1978 and/or 1979
| | Other:
| Symptomatic medication permitted: Not described
| Dates: 1978-79
| Location: Multiple centers in US (Milwaukee; Yonkers, NY; Denver; Charleston; Washington, DC; San Antonio)
| Setting: Private allergy practices
| Type(s) of providers: Specialists
Horst, Hejjaoui, Horst, et al., 1990 | Design: RCT, parallel-group | No. of subjects at start: 24 | 1) Adverse reactions | 1) Adverse reactions: | | | Quality Scoring:
| | | | 2 patients with asthma exacerbation in active group. No systemic reactions in placebo group. | | | Population similar: Not adequately described
| Interventions: | Dropouts/withdrawals: 2 placebo patients dropped out after 6 and 8 months. One for social reasons, one for lack of efficacy. | 2) Patient global assessment of efficacy: At end of 1^st^ year, patients asked to grade efficacy of treatment on visual analog scale from 0% (complete failure) to 100% (total success)
| 1) Lyophilized and standardized mold (Alternaria) extract (n = 13). Two-day rush protocol used to initiate therapy (6 injections increasing from 40 to 2,000 BU and from 1/10,000 to 1/1,000 weight-by-volume). Maintenance injections of 2,000 BU each given every week for first 6 weeks after rush protocol, then every 2 weeks for 1 year. | | | | | | Intervention(s) described: Yes
| | | | | | | Comorbidities described: Yes
| | | | 2) Patient global assessment of efficacy: | | | Diagnosis by MD: Yes
| | | | | | | Objectively confirmed: Yes
| | No. of subjects at end: 22 | | Active 76.5 ± 27.9% | | | Outcome measures valid: No
| | | | Placebo 39.5 ± 30.4% | | | Level of evidence: 2b
| | Inclusion criteria: Clinical history of rhinitis ± asthma; perennial symptoms with possible seasonal exacerbation in summer and autumn; positive prick skin test to Alternaria; positive RAST to Alternaria; no other perennial allergy; negative skin tests and RAST to dust mite; exclusive mold sensitivity | | p < .001 | | | Randomized: Yes
| | | | | | | Allocation concealed: Not described
| | | 3) Patient-assessed symptom severity and use of symptomatic medication (combined in a single measure): patients graded asthma and rhinoconjunctivitis symptoms and medication daily on scale of 0–3 | 3) Patient-assessed symptom severity and use of symptomatic medication (combined in a single measure):
| | | | | | | Double-blind: Yes
| | | | | | | Blinding adequate: Yes
| | | | 3 patients in active and 1 in placebo group did not complete symptom diary | | | Dropouts described: Yes
| | | | | | | Intention-to-treat: No
| 2) Placebo (0.9% NaCl, 0.4% phenol, and 0.5 to 0.05 mg histamine dihydrochloride) (n = 11) | | | Global symptoms: active 0.84 ± 0.93 vs. placebo 3.55 ± 2.00 (p < 0.005)
| | | | | | | Note: Because most subjects were sensitized to multiple perennial allergens, the authors note that 6,000 subjects were screened to identify 50 potential subjects. Significant for generalizability.
| | Exclusion criteria: Prior immunotherapy | | Rhinitis: active 0.64 ± 0.83 vs. placebo 2.65 ± 1.89 (p < 0.005)
| | | 4) Skin reactivity
| Duration of study treatment: 1 year
| | Age: 5–56 years | 5) Nasal reactivity | 4) Skin reactivity: Not abstracted
| Symptomatic medication permitted: For asthma: inhaled and oral sympathomimetics, theophylline, bronchial disodium cromoglycate, ketotifen, and inhaled and system corticosteroids. For rhinoconjunctivitis: nasal and ocular disodium cromoglycate, beclomethasone, terfenadine, ketotifen, and oral steroids. | Sex: | 6) Allergen-specific IgE and IgG antibody levels | 5) Nasal reactivity: Not abstracted
| | Active 9M/4F
| | Placebo 8M/3F
| | | | 6) Allergen-specific IgE and IgG antibody levels: Not abstracted
| | Race: NR
| | Other: 38–45% with asthma
| Dates: Oct-Dec, 1986
| Location: France
| Setting: Hospital-based pulmonary clinic
| Type(s) of providers: Specialists
Iliopoulos, Proud, Adkinson, et al., 1991 | Design: RCT, parallel-group (matched-pairs design) | No. of subjects at start: 41 | 1) Patient-assessed symptom severity and medication use (combined in single measure): unspecified symptoms and medication use recorded in study diaries during pollen season (mid-Aug to mid-Oct); scoring system used not described | 1) Patient-assessed symptom severity and medication use (combined in single measure): | | | Quality Scoring:
| | | | | | | Population similar: Not adequately described
| | Dropouts/withdrawals: NR
| Interventions: | | | Significantly less symptoms in treated group (p < 0.04). Data not given. No baseline differences (data not shown). | | | Intervention(s) described: Yes
| 1) Short ragweed extract prepared by professional lab (n = 21). Initial dose equivalent to 0.0024 μg Amb a 1 (antigen E). Injections of gradually increasing strength given weekly until maintenance dose (equivalent to 1.92 μg Amb a 1) achieved (3 months). Maintenance injections then administered biweekly through final nasal challenge test (2 months after end of 1986 pollen season). Cumulative dose approximately 24 μg Amb a 1. | No. of subjects at end: Presumably 41 | | | | | Comorbidities described: No
| | | | | | | Diagnosis by MD: Yes
| | | | | | | Objectively confirmed: Yes
| | Inclusion criteria: Ragweed hay fever history; positive skin test to ragweed | | 2) Allergen-specific IgE and IgG antibodies: Not abstracted | | | Outcome measures valid: No
| | | | | | | Level of evidence: 1b
| | | | | | | Randomized: Yes
| | | | 3) Adverse reactions: | | | Allocation concealed: Not described
| | Exclusion criteria: None specified | 2) Allergen-specific IgE and IgG antibodies | 6/21 systemic reaction with wheezing, coughing, hives, stuffy/runny nose. 4/6 required epinephrine. One subject had lip swelling.
| | | | | | | Double-blind: Yes
| | Age: NR | | | | | Blinding adequate: Yes
| | | 3) Adverse reactions | | | | Dropouts described: Yes
| | Sex: NR | | | | | Intention-to-treat: Yes
| | | 4) Nasal reactivity | 4) Nasal reactivity: Not abstracted
| | Race: NR
| | | 5) Skin reactivity | 5) Skin reactivity: Not abstracted | | | Notes:
| | Other:
| 2) Placebo (vehicle + histamine) (n = 20). Increasing doses of histamine administered to simulate local reactions in treated group.
| Duration of study treatment: ˜10 months; immunotherapy started Feb 1986 and continued until 2 months after end of pollen season
| Symptomatic medication permitted: Not described
| Dates: 1986 ragweed season
| Location: Baltimore, MD
| Setting: Univ allergy practice
| Type(s) of providers: Specialists
Juniper, Kline, Ramsdale, et al., 1990 | Design: RCT, parallel-group (matched-pairs design) | No. of subjects at start: 60 | 1) Patient-assessed symptom severity: severity and duration of sneezing, stuffy nose, runny nose, itchy nose, and eye symptoms graded daily on scale of 0 (none) to 3 (severe/ continuous) | 1) Patient-assessed symptom severity: Mean daily symptom scores significantly better in med group vs IT group: | | | Quality Scoring:
| | | | | | | Population similar: Yes
| | Dropouts/withdrawals: | | | | | Intervention(s) described: Yes
| Interventions: | After randomization, 3 withdrew (one joined military, one with chicken pox, one with severe asthma exacerbation requiring corticosteroids) | | | | | Comorbidities described: Yes
| 1) Modified ragweed tyrosine adsorbate (Pollinex^®^-R), an aqueous extract of short ragweed pollen (n = 30). Four 0.5-ml injections of increasing strength (110, 250, 710, and 2100 PNU/0.5 ml) given during the 6 weeks before the start of the ragweed pollen season. | | | Sneezing p < 0.0001, stuffy nose p < 0.0001, runny nose p = 0.0004, itchy nose p = 0.0008. Numbers not given. Eye symptoms: no difference | | | Diagnosis by MD: Yes
| | | | | | | Objectively confirmed: Yes
| | | | | | | Outcome measures valid: No
| | | | | | | Level of evidence: 1b
| | 1 IT subject withdrew after 1^st^ dose because of systemic reaction, 5 in IT group withdrew after 1^st^ injection, 1 after 2^nd^ injection and 7 after 3^rd^ dose because of large local reactions. Seven patients completed all 4 injections. 1 patient in med group had systemic symptoms after 2^nd^ injection and withdrew. | | | | | Randomized: Yes
| | | 2) Use of symptomatic medication: amount of terfenadine and eye drops used recorded daily | 2) Use of symptomatic medication: Terfenadine use higher in IT group: p < 0.0001 | | | Allocation concealed: Not described
| | | | | | | Double-blind: Yes
| | | | Eye drop use: no difference | | | Blinding adequate: Yes
| | | | | | | Dropouts described: Yes
| | | 3) Adverse reactions: recorded during clinic visits at 1, 3, and 7 weeks after starting nasal spray | 3) Adverse reactions: | | | Intention-to-treat: Yes
| 2) Budesonide aqueous nasal spray (n = 30). 100 μg given twice daily into each nostril beginning 1 week before the start of ragweed pollen season and continuing for a total of 7 weeks (encompassing entire pollen season). | | | Number of subjects (IT v Med):
| | | | Headache 6 v 9
| | | | Nasal irritation 4 v 4 | | | Note: Double-dummy blinding technique employed.
| | 8 from IT group withdrew during pollen season. All for uncontrolled symptoms. | | Drowsiness/fatigue 1 v 2
| | | | Injection reaction leading to withdrawal 13 v 1
| | No. of subjects at end: Not clear. 30 med and 27 IT analyzed.
| Duration of study treatment: 12 weeks: 6 weeks of pre-season immunotherapy overlapping at end with 1^st^ week of nasal spray, plus 6 additional weeks of nasal spray | Inclusion criteria: Moderate to severe rhinoconjunctivitis during ragweed season for at least 2 years; positive skin test to ragweed; no more mild skin test reactivity to fungal spores
| Symptomatic medication permitted: Terfenadine 60 mg, up to 240 mg per day; naphazoline HCl with pheniramine maleate eye drops, one drop in each eye, up to 4 times per day; salbutamol inhaler, 200 μg, up to 800 μg daily | Exclusion criteria: Perennial rhinitis; polyps; chronic nasal obstruction; serious illness; inhaled or oral corticosteroids for 1 month prior to enrollment; IT in prior 12 months; pregnant or lactating women
| | Age: Mean 43.5 IT, 45.8 med
| | Sex: 14 F/30 IT, 16 F/30 med
| Dates: 1988 ragweed season
| | Race: NR
| Location: Hamilton, Ontario
| | Other:
| Setting: Univ hospital clinic
| Type(s) of providers: Specialists
Krouse and Krouse, 2000 | Design: RCT, parallel-group (matched-pairs design) | No. of subjects at start: 18 | 1) Patient-assessed disability: assessed using the Rhinosinusitis Disability Index (RSDI) and the Sino-Nasal Outcome Test-16 (SNOT-16), completed before and after treatment | 1) Patient-assessed disability: | | | Quality Scoring:
| | | | Significant difference in Emotional Scale Score of RSDI | | | Population similar: Yes
| | Dropouts/withdrawals: 8 failed to complete 6-month study | | | | | Intervention(s) described: Yes
| Interventions: | | | | | | Comorbidities described: No
| 1) Experimental group: twice weekly immunotherapy injections in an accelerated protocol over 6 months (n = 5). Injections consisted of active serum containing all specific positive antigens identified in pre-study skin end-point titration, including all of the 3 study antigens (oak, short ragweed, and D. pteronyssinus [house dust mite]) to which they tested positive. | | | 2) Patient-assessed symptom severity: Not significant. | | | Diagnosis by MD: Yes
| | No. of subjects at end: 10 (5 each group) | | | | | Objectively confirmed: Yes
| | | | | | | Outcome measures valid: Yes
| | | | 3) Nasal endoscopy: Not abstracted | | | Level of evidence: 2b
| | Inclusion criteria: Symptoms of rhinosinusitis; positive skin prick test to short ragweed and oak or D. pteronyssinus | | | | | Randomized: Yes
| | | 2) Patient-assessed symptom severity: assessed using the Sinus Symptom Questionnaire (SSQ), completed before and after treatment | 4) Nasal reactivity: Not abstracted | | | Allocation concealed: Not described
| | | | | | | Double-blind: Yes
| | | | | | | Blinding adequate: Yes
| | Exclusion criteria: ?? | | | | | Dropouts described: Yes
| | | | | | | Intention-to-treat: No
| | Age: 42.4 A, 57.8 P
| | | 3) Nasal endoscopy (purulent rhinorrhea, mucosal erythema nasal obstruction, and nasal edema)
| | Sex: NR | | | | | Notes:
| | | | | | | No outcomes based on daily recording of symptoms.
| 2) Control group: twice weekly immunotherapy injections in an accelerated protocol over 6 months (n = 5). Injections consisted of active serum containing all specific positive antigens identified in pre-study skin end-point titration, except for the 3 study antigens (oak, short ragweed, and D. pteronyssinus [house dust mite]). | Race: NR
| | Other: | | | | | No standardization of experimental intervention.
| | | 4) Nasal reactivity
| | | | | | | No restrictions on concomitant use of other medications, including steroids, which could have a substantial effect on symptoms.
| Duration of study treatment: 6 months
| Symptomatic medication permitted: Patients “able to use whatever adjuvant therapies they chose to assist them with managing their symptoms”
| Dates: NR
| Location: Florida
| Setting: Community ENT practice
| Type(s) of providers: Specialist-ENT
Leynadier, Banoun, Dollois, et al., 2001 | Design: RCT, parallel-group | No. of subjects at start: 29 | 1) Patient-assessed symptom severity: sneezing, blocked nose, running nose, itching nose, red eyes, itching eyes, tearing eyes, coughing, wheezing, and breathlessness graded daily during allergy season on scale of 0–3 (not described) | 1) Patient-assessed symptom severity (area under curve): | | | Quality Scoring:
| | | | | | | Population similar: Yes
| Interventions: | Dropouts/withdrawals: 2 | | Total symptoms: | | | Intervention(s) described: Yes
| 1) Purified, standardized, calcium phosphate-adsorbed allergen extract composed of equal parts of five grass pollens (orchard, meadow, rye, sweet vernal, and timothy) (n = 16). Build-up phase: 16 weekly injections given in increasing doses (0.01 IR to 30 IR). | | | IT 49.5 | | | Comorbidities described: Yes
| | No. of subjects at end: 27 | | Placebo 56 | | | Diagnosis by MD: Yes
| | | | Difference 6.4 (-18.6 to 31.5; p = NS) | | | Objectively confirmed: Yes
| | Inclusion criteria: Allergy to grass pollen; typical symptoms of rhinoconjunctivitis during the grass pollen season from May to July; positive skin prick test to 5 grass pollen extracts (wheal > 5 mm); serum grass pollen specific IgE antibody levels > class 2, as determined by RAST; positive grass pollen nasal provocation test | | | | | Outcome measures valid: Not adequately described
| | | | Nose:
| | | | IT 33.5 | | | Level of evidence: 2b
| | | | Placebo 38.6 | | | Randomized: Yes
| | | | Difference 5.1 (-12.7 to 23.1; p = NS) | | | Allocation concealed: Not described
| | | 2) Use of symptomatic medication: scored daily during allergy season, as follows: | Eyes: | | | Double-blind: Yes
| Maintenance phase: injections given once every 2 weeks before the beginning of pollen season, then once a month during pollen season (with a 50% reduction in volume of solution injected). Dose/schedule modifications ”allowed for medical indications according to the routine specific immunotherapy procedure.“ | | | IT 16.0 | | | Blinding adequate: Not described
| | | | Placebo 17.3
| | | | Difference 1.2 (-8.6 to 11.2; p = NS) | | | Dropouts described: Yes
| | | Each levocabastine eye drop or puff of salbutamol or beclomethasone: 1 | | | | Intention-to-treat: No
| | | | 2) Use of symptomatic medication:
| | Exclusion criteria: Specific immunotherapy during last 5 years; perennial rhinitis; severe seasonal asthma; patients receiving systemic corticosteroids; contraindications to immunotherapy | | IT: 11.1
| | | Each cetirizine tablet: 2 | Placebo: 40.8
| | | Each betamethasone tablet: 3 | Difference 29.6 (6.5 to 52.7; p = 0.005) | | | Notes:
| | | | 3) Nasal reactivity: Not abstracted
| | | 3) Nasal reactivity
| | | | 4) Skin reactivity: Not abstracted
| 2) Placebo (diluent, no histamine) (n = 13). | Age: 30 (range 18–44 years) | | 5) Specific IgE and IgG4 levels: Not abstracted
| | | 5) Specific IgE and IgG4 levels
| | Sex: 15 women; 14 men
| Duration of study treatment: 1 year | | | 6) Adverse reactions:
| | Race: NR | 6) Adverse reactions | Local reactions (swelling and erythema > 5 cm at injection site):
| Symptomatic medication permitted: Antihistamines (levocabastine eye drops and cetirizine 10 mg tablets) and inhaled β-agonist (salbutamol) permitted on regular basis; max of 2 short courses of betamethasone (0.5 mg) could be prescribed during pollen season if symptoms not controlled by antihistamines; inhaled beclomethasone (250 μg) permitted in case of severe asthma | Other: | | IT 6/16
| | | | Placebo 0/13
| | | | Systemic reactions (mild exacerbations of rhinoconjunctivitis and urticaria):
| | | | IT 7/16
| | | | Placebo 2/13
| Dates: Sep 1997 to Sep 1998
| Location: France
| Setting: NR
| Type(s) if providers: NR, but presumably allergists
Leynadier, Herman, Vervloet, et al., 2000 | Design: RCT, parallel-group | No. of subjects at start: 17 | 1) Patient-assessed symptom severity: symptoms of rhinitis (rhinorrhea, nasal itching, nasal blockage, sneezing), conjunctivitis (tearing, itching, edema, erythema), and cutaneous signs (pruritus, urticaria, eczema) graded weekly on scale of 0 (absent) to 3 (intolerable); asthma symptoms also graded weekly on scale of 0 (absent) to 3 (asthma attack making patient unable to perform everyday activities) | 1) Patient-assessed symptom severity: | | | Quality Scoring:
| | | | Rhinitis scores: | | | Population similar: Yes
| Interventions: | Dropouts/withdrawals: 3 in placebo group: 1 underwent surgery, 1 withdrew consent, 1 lost to followup. | | Baseline (active vs. placebo) | | | Intervention(s) described: Yes
| 1) Standardized natural rubber latex extract (n = 9). Treatment started with a 2-day course of rush immunotherapy in hospital (doses progressing from 0.001 IR to 2 IR). First month thereafter, weekly injections of gradually increasing doses given. Maximum tolerated dose achieved within 2 months, with maintenance doses given every month thereafter. | | | 2.8 ± 2.15 vs. 4.8 ± 1.85 | | | Comorbidities described: Yes
| | | | 6 months (active vs. placebo) | | | Diagnosis by MD: Yes
| | | | 1.6 ± 2.9 vs. 4.0 ± 2.11 (p < 0.04) | | | Objectively confirmed: Yes
| | | | 12 months (active vs. placebo) | | | Outcome measures valid: No
| | No. of subjects at end: 14 | | 0.9 ± 1.22 vs. 2.9 ± 2.26 | | | Level of evidence: 2b
| | | | | | | Randomized: Yes
| | Inclusion criteria: Rhinitis and cutaneous allergy to latex demonstrated by skin test and specific IgE | | 2) Use of symptomatic medication: | | | Allocation concealed: Not described
| | | | Line graph shown. Calculated area under the curve showed ratio of active to placebo of 21%, indicating 79% improvement.
| | | | | | | Double-blind: Yes
| | | | | | | Blinding adequate: Yes
| | | | | | | Dropouts described: Yes
| | Exclusion criteria: Clinically significant dust mite allergy; animal allergy if pet lived in home; severe asthma; immunotherapy for another allergen | | | | | Intention-to-treat: No
| | | | 3) Conjunctival reactivity: Not abstracted
| 2) Placebo (no histamine) (n = 8) | | | | | | Note: No histamine in placebo injections.
| | | | 4) Adverse reactions:
| | | 2) Use of symptomatic medication: quantities consumed each week recorded ; doses scored as follows: | Half of patients in active group with local reaction.
| Duration of study treatment: 1 year | Age: 22–41 years
| | Sex: 1M/16F | | Active vs. placebo (%)
| Symptomatic medication permitted: antihistamines, cromones, short-acting β_2_-agonists, or inhaled cortiocosteroids | | | Rhinitis: 15.2 vs. 5.6
| | Race: NR | 1 point: local antiallergic treatment or puff of β_2_-agonist; | Conjunctivitis: 10.4 vs. 2.0
| | | | Asthma attack: 2.7 vs. 0.8
| | Other: | | Pharyngeal edema: 1.2 vs. 0
| | | 2 points: antihistamine tablet; | Giant urticaria: 1.2 vs. 0
| | | | Angioedema: 0.6 vs. 0
| Dates: Enrollment 1995-1997 | | 2.5 points: inhaled corticosteroid equivalent to 250 μg beclo-methasone; | Hypotension: 0.3 vs. 0.4
| | | | Other 14.9 vs. 4.4
| Location: France
| | | 18 points: corticosteroid tablet equivalent to 20 mg prednisolone
| Setting: Hospital-based clinics
| Type(s) of providers: | | 3) Conjunctival reactivity
| Specialists
| | | 4) Adverse reactions
Lichtenstein, Norman, and Winken-werder, 1968 | Design: RCT, parallel-group (matched-pairs design) (see Notes) | No. of subjects at start: 48 | 1) Blocking antibody levels | 1) Blocking antibody levels: Not abstracted | | | Quality Scoring:
| | | | | | | Population similar: Not adequately described
| | Dropouts/withdrawals: 2 dropouts and incomplete clinical data on 6 others
| | | 2) Cell sensitivity (amount of antigen E required to evoke a 50% response from leukocytes) | 2) Cell sensitivity: Not abstracted | | | Intervention(s) described: No
| Interventions: | | | | | | Comorbidities described: No
| 1) Immunotherapy using ragweed antigen E (n = 24 at start; 22 included in analysis). Injections given weekly for 14 weeks. Dosage “based on the patient's tolerance to the injections;” total dose ranged from 16.9 to 800 µg antigen E (mean: 285.5 µg). | | | 3) Patient-assessed symptom severity and use of symptomatic medication (combined in a single measure): | | | Diagnosis by MD: Yes
| | No. of subjects at end: 40 | | | | | Objectively confirmed: Yes
| | | | | | | Outcome measures valid: No
| | Inclusion criteria: Hay fever symptoms during ragweed season | 3) Patient-assessed symptom severity and use of symptomatic medication (combined in a single measure): sneezing, stuffy/runny nose, red/itchy eyes, and coughing graded daily during allergy season on scale of 0 to 3 (not described); number of antihistamine tablets taken recorded daily and “added to the symptom score” | Average symptom score 7.2 active vs. 9.8 placebo. | | | Level of evidence: 2b
| | | | | | | Randomized: Yes
| | | | | | | Allocation concealed: Not described
| | Exclusion criteria: NR | | Table presents symptom scores for matched pairs. Average peak season symptom in active group 6.5 vs. placebo group 9.8 (p < 0.01 Wilcoxon signed rank test)
| | | | | | | Double-blind: No
| | Age: NR | | | | | Blinding adequate: Not applicable
| 2) Placebo (dilutions of buffer containing 0.5 mg histamine/ml (n = 24 at start; 18 included in analysis). | Sex: NR | | | | | Dropouts described: Yes
| | | | | | | Intention-to-treat: No
| | Race: NR | | 4) Investigator-assessed symptom severity: Not abstracted
| | Other: | | | | | Notes:
| Duration of study treatment: | | | 5) Adverse reactions: | | | 10/24 patients in the antigen-E group and 10/24 in the placebo group were recruited from a previous trial (Lichtenstein, Norman, Winkenwerder, et al., 1966, below). All continued with the therapy to which they were assigned in the earlier trial, except two patients who had been receiving crude ragweed extract, who were assigned to the antigen-E group. Only newly acquired patients (n = 28) were randomized to treatment.
| Injections given over 14 weeks; symptoms monitored for one allergy season (early Aug to early Oct) | | | 11 experienced local reactions in active group; 1 with systemic reaction of hives and wheezing.
| | | 4) Investigator-assessed symptom severity
| Symptomatic medication permitted: Chlorpheniramine 4 mg or tripellenamine 50 mg; no corticosteroid therapy required | | 5) Adverse reactions
| Dates: 1965-66
| Location: Baltimore, MD
| Setting: Academic allergy clinic
| Type(s) of providers:
| Specialists
Lichten-stein, Norman, and Winken-werder, 1971 | Design: RCT, parallel-group | No. of subjects at start: NR | 1) Adverse reactions | 1) Adverse reactions: | | | Quality Scoring:
| | | | One moderate to severe local reaction per patient. Systemic reactions 1.6 per patient with crude extract vs. 0.4 per patient with purified. | | | Population similar: Not adequately described
| Interventions: | Dropouts/withdrawals: “Few” (actual numbers NR) | 2) Patient-assessed symptom severity: unspecified symptoms recorded daily in study diaries during ragweed season; method of scoring not described
| 1) Whole or crude ragweed pollen extract, supplied as a lyophilized powder for reconstitution (n = 19). Initial dose 0.012 μg (0.2 PNU). Further dosing schedule described below. Mean cumulative dose 0.55 mg protein (8800 PNU) in 26.7 injections. | | | | | | Intervention(s) described: No
| | | | | | | Comorbidities described: No
| | No. of subjects at end: 88 | | | | | Diagnosis by MD: Yes
| | | | 2) Patient-assessed symptom severity: | | | Objectively confirmed: No
| | Inclusion criteria: Questionnaire data suggesting allergic rhinitis | | Treatment groups had symptom scores 35–40% lower than placebo. No mean given. | | | Outcome measures valid: No
| | | | | | | Level of evidence: 2b
| | | | | | | Randomized: Yes
| | Exclusion criteria: NR | 3) Blocking antibody levels | | | | Allocation concealed: Not described
| | | | Average seasonal symptom scores estimated at 11 for placebo group and 7–7.5 for treatment groups. Scatter-gram given with means.
| | Age: NR | | | | | Double-blind: No
| | | 4) Leukocyte histamine release | | | | Blinding adequate: Not applicable
| 2) Antigen E, prepared by professional lab (n = 18). Initial dose 0.02 μg protein. Further dosing schedule described below. Mean cumulative dose 1.0 mg in 23.1 injections. | Sex: NR
| | | | P < 0.01 | | | Dropouts described: No
| | Race: NR | | | | | Intention-to-treat: No
| | | | 3) Blocking antibody levels: Not abstracted
| | Other:
| | | | | | | Note: Apparently only single-blinding.
| | | | 4) Leukocyte histamine release: Not abstracted
| 3) Antigens E + K (in 2:1 ratio), prepared by professional lab (n = 21). Initial dose 0.02 μg protein. Further dosing schedule described below. Mean cumulative dose 1.4 mg in 23.7 injections.
| 4) Placebo (diluent with histamine) (n = 21). Dilutions prepared from 0.5 mg/ml histamine base, so that graded increase in local reaction was attained as dose was increased.
| All treatments: Injections given every week beginning Mar 6. Doses doubled each week, unless local or systemic reactions warranted a slower increase. Near end of injection period (1^st^ week of Aug), patients who had fallen behind in dosage because of adverse reactions received injections twice per week to increase total dose.
| Duration of study treatment:
| Approximately 8 months; injections given Mar 6 - 1^st^ week of Aug; outcomes monitored through ragweed season (mid-Aug through mid-Oct)
| Symptomatic medication permitted: Not described
| Dates: 1968 ragweed season
| Location: Baltimore, MD
| Setting: Academic hospital allergy practice
| Type(s) of providers:
| Specialists
Lichten-stein, Norman, Winken-werder, et al., 1966 | Design: RCT, parallel-group (matched-pairs design) (see Notes) | No. of subjects at start: 41 | 1) Cell sensitivity (amount of antigen E required to evoke a 50% response from leukocytes) | 1) Cell sensitivity: Not abstracted | | | Quality scoring:
| | | | | | | Population similar: Not adequately described
| | Dropouts/withdrawals: 7 | | 2) Patient-assessed symptom severity and use of symptomatic medication (combined in a single measure):
| | Crude antigen group: 3 | | | | | Intervention(s) described: Yes
| Interventions: | Antigen E group: 1 | | | | | Comorbidities described: Yes
| 1) Crude ragweed pollen extract (n=15). Given as 15 weekly injections. First injection 0.001 μg protein N; dose doubled every week provided previous dose had produced no reaction. Total dose ranged from 0.39 to 28.8 μg protein N, containing 0.15 to 11 μg antigen E (0.026 to 1.84 μ protein N). | Control (placebo): 3 | 2) Patient-assessed symptom severity and use of symptomatic medication (combined in a single measure): sneezing, stuffy/runny nose, red/itchy eyes, and coughing graded twice daily during allergy season on scale of 0 (no symptoms) to 3 (symptoms lasting more than 2 hours); number of antihistamine tablets taken recorded daily and added to the symptom score | Graph showing symptom score vs. time given for each treatment group. | | | Diagnosis by MD: Yes
| | Only reason given was “various technical reasons”. | | | | | Objectively confirmed: Yes
| | | | | | | | Outcome measures valid: No
| | | | Table with average daily symptom scores given. Differences not significant | | | Level of evidence: 2b
| | No. of subjects at end: 34 | | | | | Randomized: Yes
| | | | | | | Allocation concealed: Yes
| | Inclusion criteria: Hay fever symptoms restricted generally to ragweed pollen season; “adequate” in vitro histamine release to ragweed antigen | | Control 3.7 (0.3–11.8) | | | Double-blind: No
| | | | Crude antigen 3.0 (0.9–6.5) | | | Blinding adequate: Not applicable
| | | | 6Antigen E 3.4 (1.1–7.3)
| | | | | | | Dropouts described: Yes
| | | | 3) Investigator-assessed symptom severity: Not abstracted | | | Intention-to-treat: No
| 2) Ragweed antigen E (n = 11). Given as 15 weekly injections. First injection 0.0003 μg protein N; dose doubled every week provided previous dose had produced no reaction. Total dose ranged from 4.0 to 61.7 μg antigen E (0.7 to 11.2 μg protein N). | Exclusion criteria: Asthma
| | | | 4) Adverse reactions: | | | Notes:
| | Age: NR | | 2/15 patients completed the full dose escalation for crude ragweed allergen. Doses limited by local injection site reactions. 4 subjects had systemic reactions (hives). | | | Patients were drawn from a larger trial (no publication cited). 11/41 had been receiving antigen E and continued with this therapy. Remaining 30 patients were randomly divided between crude ragweed and placebo groups.
| | Sex: NR
| | | 3) Investigator-assessed symptom severity
| | Race: NR
| | Other: | 4) Adverse reactions | 5/10 patients receiving antigen E achieved the highest dose level. 4 patients had local reactions and 1 patient had a systemic reaction.
| 3) Placebo (saline) (n = 15).
| Duration of study treatment: | | | No data are given for AEs in the control group.
| Injections given over 15 weeks; symptoms monitored for one allergy season (early August to late September)
| Symptomatic medication permitted: Dexchlor-pheniramine maleate 2 mg
| Dates: 1964
| Location: Baltimore, MD
| Setting: Academic allergy practice
| Type(s) of providers: Specialists
Lowell and Franklin, 1965 | Design: RCT, parallel-group (matched-pairs design) | No. of subjects at start: 27 | 1) Patient- and investigator-assessed symptom severity: | 1) Patient- and investigator-assessed symptom severity: | | | Quality Scoring:
| | | | | | | Population similar: Not adequately described
| | Dropouts/withdrawals: 3 | | This is a joint score negotiated based upon discussion between patient and physician.
| Interventions: | | symptoms recorded daily by patients; these records reviewed and discussed with patient at each clinic visit, and consensus scores for duration and severity of symptoms reached by patient and investigator; severity of symptoms graded on numerical scale from 0 (none) to 100 (incapacitating) | | | | Intervention(s) described: No
| Recruited patients had all been receiving injections of “ragweed and other pollen extracts” for an unspecified period of time before the study started. Were then randomized to: | No. of subjects at end: 24 | | | | | Comorbidities described: No
| | | | | | | Diagnosis by MD: Yes
| | Inclusion criteria: Symptoms of allergic rhinitis coinciding with 1962 ragweed pollen season ± prior or ongoing immunotherapy; absence of symptoms of AR at other times of the year | | Data presented as graph of symptoms over time. | | | Objectively confirmed: No
| | | | | | | Outcome measures valid: No
| | | | | | | Level of evidence: 2b
| | | | Data also presented as a Table with symptom scores compared between treated and untreated subjects each week. All values for symptom scores favored the treated group. Values were significant during the weeks corresponding to ragweed pollen exposure. | | | Randomized: Yes
| | | | | | | Allocation concealed: Yes
| 1) Continued treatment with same mixture of extracts (n = ?); or | | | | | | Double-blind: Yes
| | | | | | | Blinding adequate: Yes
| | Exclusion criteria: Pregnancy | | | | | Dropouts described: Yes
| 2) Continued treatment with previous mixture of extracts minus ragweed-pollen extract (n = ?). | | | | | | Intention-to-treat: No
| | Age: NR
| | Sex: NR | 2) Use of symptomatic medication: recorded daily by patients in study diaries | | | | Notes:
| | | | 2) Use of symptomatic medication: | | | This is actually a withdrawal of therapy study.
| Duration of study treatment: | Race: NR | | Data presented as graph of medication score over time.
| 8 months (early March to end of October)
| | Other: | | | | | Pollen counts not performed during experimental period.
| | | 3) Total symptom-medication scores: combines above two measures | Data also presented as a Table with medication scores compared between treated and untreated subjects each week. All values for medication scores favored the treated group. Values were significant during the weeks corresponding to ragweed pollen exposure.
| Symptomatic medication permitted: Not described
| | | | | | | Of a clinic population of 500 patients, only 27 met entry criteria.
| Dates: 1963
| Location: Boston, MA
| Setting: Hospital Allergy Clinic
| | | | 3) Total symptom-medication scores:
| | | | Data from symptom and medication scores merged. Week-by-week analysis shows statistical significance during weeks of presumed ragweed pollen exposure.
| Type(s) of providers:
| Specialists
McAllen, 1969 | Design: RCT, parallel-group | No. of subjects at start: 110 | 1) Patient global evaluation of efficacy: at end of pollen season, patients graded treatment as “satisfactory” or “unsatisfactory” | 1) Patient global evaluation of efficacy: | | | Quality Scoring:
| | | | | ITT | Completers | Population similar: Yes
| Interventions: | Dropouts/withdrawals: 19 | | alum extract: | 30/47 | 30/41 | Intervention(s) described: Yes
| 1) Alum-precipitated extract of pollens of 5 grasses (Allpyral G®) (n = 47). Given in nine weekly injections, with dose gradually increasing from 50 to 10,000 PNU. | | | depot emul: | 21/40 | 21/30 | Comorbidities described: Yes
| | No. of subjects at end: 91 | | placebo: | 7/23 | 7/20 | Diagnosis by MD: Yes
| | | | alum vs. placebo; p = 0.01 | | | Objectively confirmed: Yes
| | Inclusion criteria: Symptoms of hay fever for at least 2 previous years; positive skin prick test to grass pollen extract | | depot vs. placebo; p = 0.046 | | | Outcome measures valid: No
| | | 2) Patient-assessed symptom severity: unspecified symptoms graded daily during pollen season on scale of 0 (clear of symptoms all day) to 3 (severe symptoms which were not controlled by tablets or nasal decongestants) | (chi-square test) | | | Level of evidence: 2b
| | | | | | | Randomized: Yes
| | | | 2) Patient-assessed symptom severity: | | | Allocation concealed: Not described
| 2) Depot emulsion extract of pollens of 12 grasses (D-Vac®) (n = 40). Three injections of 750; 3,500; and 7,500 Noon units given at 4-week intervals. | | | Symptom-free days
| | Exclusion criteria: Age < 12 or > 60; symptoms outside months of May-July; perennial rhinitis; systemic corticosteroids; previous satisfactory response to antihistamine drugs | | Alum: 35 | | | Double-blind: Yes
| | | | Depot: 38.5 | | | Blinding adequate: No
| | | | Placebo: 28.5 | | | Dropouts described: Yes
| | | | Alum vs. placebo: p = 0.087 | | | Intention-to-treat: Yes
| | | | Depot vs placebo: p = 0.038
| 3) Placebo (normal saline) (n = 23). Given in three injections at 4-week intervals. | | | Mean points count | | | Notes:
| | Age: 26 years | 3) Adverse reactions | Alum: 54 | | | Placebo was normal saline rather than weak histamine solution; local reactions not reported, but this could have unblinded placebo patients.
| | | | Depot: 49
| | Sex: 60 women; 50 men | | Placebo: 72
| Duration of study treatment: | | | Alum vs. placebo: p = 0.074
| Injections given over 9 or 12 weeks; outcomes measured during single pollen season | Race: NR | | Depot vs. placebo: p = 0.054
| | Other: | | 3) Adverse reactions:
| | | | Generalized urticaria within 1 hour
| Symptomatic medication permitted: “Tablets” and nasal decongestants | | | Alum 1 pt; depot 2 pts
| | | | Asthma and rhinitis after 12 hours
| | | | Alum 8 pt; depot 1 pt
| Dates: Nov 1966 - Feb 1967
| | | | Small persistent nodules at injection site
| Location: London, UK
| | | | Depot 10 pts
| Setting: Allergy clinic
| Type(s) of providers:
| Allergists
McHugh and Ewan, 1992 | Design: RCT, parallel-group | No. of subjects at start: 80 (20 of 80 enrolled in single blind trial of an alternate agent) | 1) “Clinical index”: | 1) “Clinical index”: | | | Quality Scoring:
| | | composite measure derived from: a) visual analog symptom score; b) diary card symptom score; c) nasal challenge results; d) skin prick test results; e) medication score | Scores are baseline, 3 mo, 12 mo. | | | Population similar: Yes
| Interventions: | | | Pharmalgen: 27.0, 42.5, 49.5 | | | Intervention(s) described: Yes
| 1) House dust mite (Dermatophagoides pteronyssinus) extract (Pharmalgen®) (n = 30). | | | Placebo: 27.0, 32.5, 32.0 | | | Comorbidities described: No
| | Dropouts/withdrawals: | | Allpyral: 27.0, 36.5, 38.0 | | | Diagnosis by MD: Yes
| | 2 in Pharmalgen group | | | | | Objectively confirmed: Yes
| | 1 in placebo | | Pharmalgen vs. placebo (p < 0.002 and p > 0.001 at 3 and 12 months) | | | Outcome measures valid: No
| Administered according to protocol described in Ewan, Alexander, Snape, et al., 1988 (above), and McHugh, Lavelle, Kemeny, et al., 1990 | 3 in Allpyral group | | | | | Level of evidence: 2b
| | | | | | | Randomized: No
| | Reasons not given | 2) Patient-assessed symptom severity: rhinitis symptoms (sneezing, discharge, and obstruction) graded a) daily (?) on visual analog score where 0% = asymptomatic and 100% = very severe; and b) twice daily on categorical scale of 0–3 (not described) | Allpyral vs. placebo (p = 0.15) | | | Allocation concealed: Not described
| | No. of subjects at end: 74 | | Pharmalgen vs. Allpyral (p < 0.006) favoring Pharmalgen | | | Double-blind: No
| | | | | | | Blinding adequate: Not applicable
| 2) House dust mite extract (Allpyral®) (n = 20). | Inclusion criteria: Described in prior publication. Patients had known allergy to dust mite with positive prick skin tests and nasal challenge studies.
| | | | 2) Patient-assessed symptom severity: | | | Dropouts described: Yes
| Administered according to protocol described in McHugh, Lavelle, Kemeny, et al., 1990 | | | Comparison of baseline vs. 12 mo. | | | Intention-to-treat: No
| | | | SE shown
| | | | Pharmalgen: 30.9 ± 4.0, 16.0 ± 2.7
| | | | Allpyral: 14.7 ± 4.1, 14.5 ± 3.2 | | | Notes:
| 3) Placebo (histamine dihydrochloride) (n = 30) | Exclusion criteria: NR | | Placebo: 28.8 ± 3.5, 22.4 ± 2.4 | | | Interim results for some patients (n = 38) in this trial reported in Ewan, Alexander, Snape, et al., 1988 (above).
| | Age: 15–72 | 3) Nasal reactivity | 3) Nasal reactivity: Not abstracted
| Duration of study treatment: 12 months
| | Sex: 44M/36F | 4) Skin reactivity | 4) Skin reactivity: Not abstracted
| Symptomatic medication permitted: beclomethasone nasal spray, terfenadine, chlorpheniramine | Race: NR | 5) Use of symptomatic medication: recorded daily on study diary cards | 5) Use of symptomatic medication:
| | | | Comparison is 0 and 12 months. SE shown
| | Other:
| | | | Pharmalgen: 1.42 ± 0.42, 0.19 ± 0.12
| | | | Allpyral: 0.94 ± 0.29, 1.05 ± 0.57
| Dates: NR | | | Placebo: 1.28 ± 0.55, 0.96 ± 0.37
| Location: Cambridge, UK
| Setting: Academic allergy unit
| Type(s) of providers:
| Specialists
Mischler, O'Brien, Rugloski, et al., 1981 | Design: RCT, parallel-group | No. of subjects at start: 366 (177 active, 189 placebo) | 1) Patient-assessed symptom severity: sneezing, stuffy and/or runny nose, itchy eyes, and cough graded twice daily on scale of 0 (none) to 3 (lasted more than 2 hours) | 1) Patient-assessed symptom severity: | | | Quality Scoring:
| | | | Active vs. placebo | | | Population similar: No
| Interventions: | | | Sneeze: 27.8 vs. 38.6 (ns) | | | Intervention(s) described: Yes
| 1) Gluteraldehyde-modified ragweed pollen tyrosine adsorbate (MRTA) (n = 177). Four weekly injections given in doses of 300; 700; 2,000; and 6,000 NU/0.5 ml. | Dropouts/withdrawals: | | Nose: 40.7 vs. 56.9 (ns) | | | Comorbidities described: Yes
| | 119 active | | Eye: 21.1 vs. 39.4 (p = 0.0183) | | | Diagnosis by MD: Yes
| | 103 placebo | | Cough 4.3 vs. 8.1 (ns) | | | Objectively confirmed: Yes
| | | | | | | Outcome measures valid: No
| | No. of subjects at end: | | 2) Use of symptomatic medication: | | | Level of evidence: 1b
| | Completing injections and diary data: | | Antihistamine: | | | Randomized: Yes
| | | 2) Use of symptomatic medication: use of investigator-supplied antihistamine and (separately) other symptomatic meds recorded by patients in study diaries | Active 9.9 vs. placebo 22.0 (p = 0.0352) | | | Allocation concealed: Not described
| 2) Placebo (tyrosine suspension) (n = 189). | 58 active
| | 86 placebo | | | | | Double-blind: Yes
| | | | Other medications: | | | Blinding adequate: Yes
| Duration of study treatment: | Inclusion criteria: Seasonal AR for 2+ years; positive skin test to ragweed | | Active 71.3 vs. placebo 151.2 (p = 0.0646) | | | Dropouts described: Yes
| Injections given over 4 weeks; outcomes assessed for one allergy season. | | | | | | Intention-to-treat: No
| | | | 3) Total symptom-and-medication score (combination of above measures, called “combined efficacy score” by investigators):
| | Exclusion criteria: Pregnancy; chronic asthma or other respiratory disease; immunotherapy within 12 months | | | | | Notes:
| Symptomatic medication permitted: Chlorpheniramine maleate 4 mg supplied; however, “many patients also took medication on their own, without consent of their physician” | | 3) Total symptom-and-medication score (combination of above measures, called “combined efficacy score” by investigators) | | | | Patients who participated in RCT phase (1^st^ year) given opportunity to receive MRTA (in open fashion) during 2^nd^ year.
| | | | Active 181.1 vs. placebo 318.3 (p = 0.0154)
| | Age:
| | 266 adults (15–73, mean 32.8) | | 4) Allergen-specific IgE and IgG antibody levels: Not abstracted | | | Symptom data reported for only 5/8 centers in 1976 phase of study.
| | 100 children (5–16, mean 11.2)
| | | 4) Allergen-specific IgE and IgG antibody levels
| Dates: 1976 | Sex: 195M/171F | | 5) Adverse reactions:
| | | | 13% overall discontinued therapy because of late local reactions or sneezing and wheezing (n = 1). | | | Data abstracted from from RCT phase (1976) only.
| Location: Eastern Canada | Race: NR | 5) Adverse reactions
| Setting: Multicenter (presumably) allergy practices | Other: | | | | | High dropout rate.
| Type(s) of providers:
| Specialists (presumed)
Movérare, Vesterinen, Metso, et al., 2001 | Design: RCT, parallel-group | No. of subjects at start: 46 | 1) Total IgE and allergen-specific IgE, IgG, and IgG4 antibody levels | 1) Total IgE and allergen-specific IgE, IgG, and IgG4 antibody levels: Not abstracted | | | Quality Scoring:
| | | | | | | Population similar: Not adequately described
| Interventions: | Dropouts/withdrawals: 7
| 1) Immunotherapy using extracts of birch (n = 26) or timothy (n = 4) pollen. Initial rush phase with standardized aqueous extracts (Aquagen^®^). Three injections given daily using gradually increasing doses up to highest tolerated dose at end of 1^st^ week (target dose: 10,000 SQ). Treatment then continued with standardized depot preparations (Alutard^®^), given every 3 weeks in increasing doses until individual maintenance dose reached (target: 60,000 to 100,000 SQ). Maintenance dose continued every 3 weeks for 3 years. | | | | | | Intervention(s) described: Yes
| | No. of subjects at end: 39 | 2) Patient-assessed symptom severity: symptoms graded once per allergy season (pretreatment, 1^st^ year, and 3^rd^ year) on visual analog scale from 0 to 100 (not described) | 2) Patient-assessed symptom severity: | | | Comorbidities described: Yes
| | | | RIT 21.2 ± 19.5; n = 24 | | | Diagnosis by MD: Yes
| | Inclusion criteria: History of birch- or timothy-pollen allergy; rhinitis or conjunctivitis during at least 3 pollen seasons; positive skin prick test to birch- or timothy pollen; specific serum IgE to birch or timothy pollen | | Control 39.0 ± 15.1; n = 11 | | | Objectively confirmed: Yes
| | | | P = 0.002 | | | Outcome measures valid: No
| | | | | | | Level of evidence: 2b
| | | | 3) Use of symptomatic medication: | | | Randomized: Yes
| | | | a) Medication scores Year 1 | | | Allocation concealed: Not described
| | | | RIT 20.4 ± 19.9; n = 24 | | | Double-blind: No
| | | 3) Use of symptomatic medication: assessed two ways: a) graded once per allergy season (pretreatment, 1^st^ year, and 3^rd^ year) on visual analog scale from 0 to 100 (not described); and b) graded once every month from March to October of 1^st^ year on scale of 0 (no use of medication) to 2 (regular use of medication) (“monthly medication index”) | Control 45.4 ± 23.3; n = 11 | | | Blinding adequate: Not applicable
| | Exclusion criteria: NR | | P = 0.0077
| | | | | | | Dropouts described: Yes
| | Age: 20 years | | b) Average monthly med index | | | Intention-to-treat: Can't determine
| | | | RIT 1.59 ± 1.82
| | Sex: 21 women; 25 men | | control 3.29 ± 1.77
| | | | p < 0.05
| | Race: NR | | | | | Notes:
| | | | 4) Adverse reactions: | | | No attempt at blinding.
| | Other: | | RIT - systemic reaction (fever after injection) 1 case; generalized urticaria 3 cases; mild asthmatic symptoms 1 case (all pts continued RIT at decreased dose)
| | 41 birch pollen | | | | | No outcomes based on daily recording of symptoms or medication use.
| 2) No immunotherapy (n = 16). | 5 timothy grass pollen
| Duration of study treatment: 3 years (active treatment; see Notes) | | | | | | Control patients offered active treatment after 1 year; those who accepted left the study. Five control patients followed up for 3 years.
| | | 4) Adverse reactions
| Symptomatic medication permitted: Not specified
| | | | | | | Imbalance in conjunctivitis symptoms at baseline.
| Dates: NR
| Location: Helsinki, Finland | | | | | | Year 3 data compromised by > 50% dropout rate in control group.
| Setting: Allergology clinic
| Type(s) of providers:
Naclerio, Proud, Moylan, et al., 1997 | Design: RCT, parallel-group | No. of subjects at start: 20 | 1) Nasal reactivity | 1) Nasal reactivity: Not abstracted | | | Quality Scoring:
| | | | | | | Population similar: Not adequately described
| Interventions: | Dropouts/withdrawals: 0 | 2) Patient-assessed symptom severity and medication use (combined in a single measure): unspecified rhinitis symptoms and medication use recorded in daily diaries during ragweed season; scoring system not described | 2) Patient-assessed symptom severity and medication use (combined in a single measure):
| All included patients had been receiving maintenance immunotherapy with aqueous ragweed extract at a dose of approximately 12 μg of Amb a 1 (5000 AU) every 2 weeks for a minimum of 3 years when they entered trial. Then randomized to receive either: | | | | | | Intervention(s) described: Yes
| | No. of subjects at end: 20 | | | | | Comorbidities described: No
| | | | Data available for 16/20 (8 per group). | | | Diagnosis by MD: Yes
| | Inclusion criteria: Receiving ragweed IT for 3+ years | | No significant difference. Data could be interpreted from graph. | | | Objectively confirmed: Yes
| | | | | | | Outcome measures valid: No
| | | | | | | Level of evidence: 2b
| | Exclusion criteria: Significant nasal abnormalities or pathology | | Determined that study power would have allowed 90% chance to miss significant difference. | | | Randomized: Yes
| | | | | | | Allocation concealed: Not described
| 1) Continued maintenance therapy (as above) (n = 10); or | Age: NR | | | | | Double-blind: Yes
| | | 3) Allergen-specific IgE and IgG antibodies | 3) Allergen-specific IgE and IgG antibodies: Not abstracted | | | Blinding adequate Yes
| | Sex: NR | | | | | Dropouts described: Yes
| 2) Placebo maintenance therapy (saline mixed with histamine) (n = 10). | | | | | | Intention-to-treat: Yes
| | Race: NR
| | Other: | | | | | Note: Does not provide efficacy data, since this was a withdrawal of therapy study with pre-determined laboratory endpoints.
| Duration of study treatment: 1 year
| Baseline measurements taken during ragweed season before randomization (symptoms and antibody levels) and in December or early January immediately before randomization (nasal reactivity)
| Symptomatic medication permitted: Not described
| Dates: Year not given. Included one ragweed season.
| Location: Baltimore, MD
| Setting: Academic hospital clinic
| Type(s) of providers: Specialists
Norman, Lichten-stein, Kagey-Sobotka, et al., 1982 | Design: RCT, parallel-group (matched triplets) | No. of subjects at start: 66 | 1) Adverse reactions | 1) Adverse reactions: | | | Quality Scoring:
| | | | Allergen group: | | | Population similar: Not adequately described
| | Dropouts/withdrawals: | 2) Patient-assessed symptom severity and use of symptomatic medication (combined in a single measure): duration of sneezing, rhinitis, conjunctivitis, and cough, and use of symptomatic medication recorded twice daily during allergy season | All patients had at least one local reaction and “most” had multiple reactions. Large local reactions in 5 patients.
| Interventions: Patients in all 3 treatment groups divided into “average” and higher-than-average" sensitivity groups. | 2 dropouts before completion of screening; then: | | | | | Intervention(s) described: Yes
| | | | | | | Comorbidities described: No
| | 2 dropouts allergen group | | | | | Diagnosis by MD: Yes
| | 6 dropouts allergoid group | | | | | Objectively confirmed: Yes
| | 5 dropouts placebo group | | Nine systemic reactions occurred in 8 patients who completed the injection series. | | | Outcome measures valid: No
| 1) Ragweed allergoid administered in a clustered regimen (n = 22 at start; 16 completed). “Average” sensitivity patients: 5 clinic visits totaling 11 injections. 1^st^ visit, three injections at 30-min intervals in doses of 5, 10, and 20 allergoid units. Two injections given at each subsequent visit for cumulative projected dose of 1,925 units (168,000 PNU). Approximately 3 weeks between 1^st^ and 2^nd^ visit; 2–3 weeks between subsequent visits. “Higher-than-average” sensitivity patients: 6 clinic visits totaling 13 injections. 1^st^ visit, three injections at 30-min intervals in doses of 0.5, 2, and 3 allergoid units. Two injections given at each subsequent visit for cumulative projected dose of 1,175.5 units (103,000 PNU). Approximately 3 weeks between 1^st^ and 2^nd^ visit; 2–3 weeks between subsequent visits. Mean cumulative dose actually administered 727 units (364μg AgE; 63,600 PNU). | | | | | | Level of evidence: 2b
| | No. of subjects at end: 53 completed first year | | | | | Randomized: No
| | | | | | | Allocation concealed: Not described
| | | | Allergoid group:
| | Inclusion criteria: 3+ years of seasonal rhinitis; positive intradermal skin test to ragweed antigen | | 11 systemic reactions in 5 patients. | | | Double-blind: No
| | | 3) Cell sensitivity (amount of antigen E required to evoke a 50% response from leukocytes) | Similar incidence of large local reactions compared to allergen group. | | | Blinding adequate: Not applicable
| | | | | | | Dropouts described: Yes
| | | | 2) Patient-assessed symptom severity and use of symptomatic medication (combined in a single measure): | | | Intention-to-treat: No
| | Exclusion criteria: NR
| | | 4) Total and allergen-specific IgE, and IgG-against-AgE antibody levels
| | Age: NR | | Analyzable data reported on 16 allergen, 16 allergoid and 20 placebo patients | | | Notes:
| | | | | | | Assignment not described; may not have been random. Also, blinding not described.
| | Sex: NR
| | Race: NR | | Mean score:
| | | | Allergen 5.3 | | | At end of initial trial, patients in allergoid and extract groups invited to continue with booster injections of same materials; results reported for this open follow-up.
| | Other: | | Allergoid 5.1
| | | | Placebo 8.8
| | | | Active vs. placebo (p<0.01)
| | | | 3) Cell sensitivity (amount of antigen E required to evoke a 50% response from leukocytes): Not abstracted
| | | | 4) Total and allergen-specific IgE, and IgG-against-AgE antibody levels: Not abstracted
| 2) Unaltered ragweed extract (glycerinated extract of short ragweed pollen) administered in a weekly regimen (n = 22 at start; 20 completed).
| “Average” sensitivity patients:
| 17 weekly injections, starting at 1.0 allergen unit and progressing to 500 units (1,200 PNU, for a projected cumulative dose of 2,083 units (5,000 PNU). “Higher-than-average” sensitivity patients: 20 weekly injections, starting at 0.1 allergen unit and progressing to 500 units, for a projected cumulative dose of 2,084 units. Mean cumulative dose actually administered 856 units (8.56 μg AgE; 2,000 PNU).
| 3) Placebo administered in a clustered regimen (n = 22 at start; 17 completed).
| Duration of study treatment:
| Varied, depending on treatment (see above); outcomes assessed during a single allergy season
| Symptomatic medication permitted: Antihistamine “and other medication”
| Dates: 1978
| Location: Baltimore, MD
| Setting: University allergy clinic
| Type(s) of providers:
| Specialists
Ortolani, Pastorello, Incorvaia, et al., 1994 | Design: RCT, parallel-group | No. of subjects at start: 35 (18 active, 17 placebo) | 1) Patient-assessed symptom severity and medication use (combined in a single measure): eye (itching, redness, or weeping), nasal (sneezing, rhinorrhea, or blockage), and lung (cough, dyspnea, or asthma) symptoms graded daily on scale of 0–3 (not described); use of symptomatic medication recorded daily in study diaries | 1) Patient-assessed symptom severity and medication use (combined in a single measure): | | | Quality Scoring:
| | | | | | | Population similar: Yes
| Interventions: | | | | | | Intervention(s) described: Yes
| 1) Alginate-conjugated extract of Parietaria judaica (wall pellitory) pollen (Conjuvac^®^-Parietaria) (n = 18). Extract used was biologically standardized and partially purified; 1 U of preparation represented 61.2 μg of pollen. Build-up phase: 12 weekly injections of increasing dose (1, 2, 4, 8, 10, 20, 40, 80, 100, 200, 400, and 800 U). | Dropouts/withdrawals: 4 | | Complete assessment on 17 active and 14 placebo patients who submitted diaries. Significantly lower S-M scores in active vs. treatment group (p < 0.05). Sub-symptom analysis showed significance for runny nose (p = 0.0087), sneezing (p = 0.0488), but not nasal blockage. No means or SDs given. | | | Comorbidities described: No
| | | | | | | Diagnosis by MD: Yes
| | No. of subjects at end: 31 | | | | | Objectively confirmed: Yes
| | | | | | | Outcome measures valid: No
| | Inclusion criteria: Severe rhinoconjunctivitis ± asthma during Parietaria season for 2+ years; positive prick skin test to Parietaria; negative skin tests to grass, tree, weed, mite, mold, and pet allergens; positive RAST to Parietaria | | | | | Level of evidence: 1b
| | | | | | | Randomized: Yes
| | | | | | | Allocation concealed: Not described
| | | | | | | Double-blind: Yes
| | | | | | | Blinding adequate: Yes
| | | | 2) Nasal, conjunctival, and skin reactivity: Not abstracted | | | Dropouts described: No
| | | | | | | Intention-to-treat: No
| Maintenance phase: top dose or maximum tolerated dose given at monthly intervals. | | 2) Nasal, conjunctival, and skin reactivity
| | Exclusion criteria: Prior IT for Parietaria; other active respiratory diseases; nasal polyps; systemic corticosteroid use; pregnancy | | 3) Adverse reactions:
| | | | 16/18 active and 1/17 placebo patients had local reactions. 5/18 active and 2/17 placebo had systemic reactions. 5 rhinitis and 1 urticaria in active group. 2 rhinitis in placebo group. All but one reaction immediate. | | | Notes:
| | | 3) Adverse reactions: recorded and described as local vs. systemic and immediate (within 30 minutes) vs. late
| 2) Placebo (lyophilized sodium alginate ± 5 μg histamine dihydrochloride) (n = 17)
| | Age: Range, 14–59; mean, 41
| | Sex: 20 F
| Duration of study treatment: | | 4) Allergen-specific IgE, IgG, IgG1, and IgG4 antibody levels | 4) Allergen-specific IgE, IgG, IgG1, and IgG4 levels: Not abstracted
| 1 year | Race: NR
| Symptomatic medication permitted: Terfenadine tablets and salbutamol spray | Other:
| Dates: NR
| Location: Milan, Italy
| Setting: Academic internal medicine department
| Type(s) of providers: NR
Parker, Whisman, Apaliski, et al., 1989 | Design: RCT, parallel-group (matched-pairs design) | No. of subjects at start: NR | 1) Patient-assessed symptom severity and medication use (combined in a single measure): itchy nose, nasal congestion, sneezing, nose blowing, itchy eyes or throat, wheezing, shortness of breath, chest tightness, and cough graded daily during the pollen season on scale of 1 to 5 (not described); use of symptomatic medication recorded daily in study diaries (scored as 1 point per standard dose) | 1) Patient-assessed symptom severity and medication use (combined in a single measure): | | | Quality Scoring:
| | | | | | | Population similar: Yes
| | Dropouts/withdrawals: NR | | | | | Intervention(s) described: Yes
| Interventions: | | | Mean score 57.0 active, 129.9 placebo (p = 0.0001). Individual data provided. | | | Comorbidities described: No
| 1) Extract of Juniperus ashei (mountain cedar) pollen (n = 26). Extract prepared in a single lot by lab in Spokane, WA. “Conventional high-dose” protocol used, beginning with 0.1 ml of 1:50,000 wt/vol dilution and progressing by 0.05- to 0.1-ml increments until 0.5 ml was reached. A 10-fold higher concentration then administered in the same dosing increments until the highest tolerated dose or 0.5 ml of 1:50 wt/vol was reached. 1–3 injections per week given during build-up phase; weekly injections given during maintenance phase. | No. of subjects at end: 51 | | | | | Diagnosis by MD: Yes
| | | | | | | Objectively confirmed: Yes
| | Inclusion criteria: History consistent with Juniperis rhinoconjunctivitis; positive skin prick test to Juniperis | | 2) Skin reactivity: Not abstracted | | | Outcome measures valid: No
| | | | | | | Level of evidence: 2b
| | | | 3) Allergen-specific IgE, IgG1, and IgG4 levels: Not abstracted | | | Randomized: Yes
| | | | | | | Allocation concealed: Not described
| | Exclusion criteria: Age < 18; pregnancy; use of β-blocker; IT within prior 5 years | | | | | Double-blind: No
| | | | | | | Blinding adequate: Not applicable
| | | | | | | Dropouts described: No
| | Age: 22–75 (mean 43.4 active, 47.1 placebo) | | | | | Intention-to-treat: No
| | Sex: 26 F | 2) Skin reactivity | | | | Notes:
| | Race: NR | 3) Allergen-specific IgE, IgG1, and IgG4 antibody levels
| | Other:
| 2) Placebo (carmelized glucose, HSA, and histamine phosphate) (n = 25)
| Duration of study treatment:
| NR
| No description of symptomatic medication permitted (if any)
| Dates: Jan-July 1987
| Location: Lackland AFB, Tx
| Setting: Military hospital allergy clinic
| Type(s) of providers:
| Specialists
Pastorello, Pravettoni, Incorvaia, et al., 1992 | Design: RCT, parallel-group | No. of subjects at start: 19 | 1) Adverse reactions | 1) Adverse reactions: | | | Quality Scoring:
| | | | IT group: | | | Population similar: Yes
| Interventions: | Dropouts/withdrawals: NR | 2) Patient-assessed symptom severity and medication use (combined in a single measure): unspecified nasal, conjunctival, and bronchial symptoms graded daily during pollen season on scale of 0–3 (not described); use of symptomatic medication scored daily during pollen season as follows: | Late local reactions 3/10 pts | | | Intervention(s) described: Yes
| 1) Alum-absorbed grass allergoid obtained by mild formalinization of a mixed grass-pollen extract (six grasses: Dactylis glomerata, Festuca elatior, Holcus lanatus, Phleum pratense, Lolium perenne, Poa pratensis) (n = 10). Treatment started in January. Weekly injections of increasing doses given to a top dose of 20,000 PNU or maximum tolerated dose. Weekly doses administered until mid-April, after which a 50% equivalent dose was given every 3 weeks as maintenance. Mean pre-seasonal cumulative dose 46,050 PNU (range, 20,700 to 54,500). Mean maximum dose administered in a single injection 16,250 PNU (range, 4500 to 20,000). | | | Late systemic reactions 1/10 pt | | | Comorbidities described: No
| | No. of subjects at end: NR | | | | | Diagnosis by MD: Yes
| | | | Placebo group: | | | Objectively confirmed: Yes
| | Inclusion criteria: Seasonal rhinoconjunctivitis for at least 3 years; positive skin prick test for a mix of grass pollen extracts with wheal at least twice area of wheal induced by 1 mg/ml histamine; negative SPT for other pollens (birch, hazel, alder, mugwort, and wall pellitory; positive RAST for grass pollen (at least class 3) | | No adverse reactions | | | Outcome measures valid: No
| | | | | | | Level of evidence: 2b
| | | | 2) Patient-assessed symptom severity and medication use (combined in a single measure): | | | Randomized: Yes
| | | | | | | Allocation concealed: Not described
| | | | IT patient had significantly lower symptom and medication scores (p < 0.01). Data shown in figure of scores over time. | | | Double-blind: Yes
| | | | | | | Blinding adequate: Not described
| | | | | | | Dropouts described: No
| | | Nasal vasoconstrictor: 1 per drop | | | | Intention-to-treat: Can't determine
| | | | 3) Skin reactivity: Not abstracted
| | Exclusion criteria: Previous specific IT with grass pollen extracts | Antihistamine: 1 per tablet β-2-agonist: 1 per puff
| | | | 4) Nasal reactivity: Not abstracted
| | | | | | | Notes:
| | | 3) Skin reactivity | 5) Allergen-specific IgE and IgG: Not abstracted
| | Age: 27.4 years (range 18–56)
| | | 4) Nasal reactivity
| | Sex: 12 women; 5 men
| | | 5) Allergen-specific IgE and IgG
| | Race: NR
| | Other:
| 2) Placebo (caramel NF acid solution ± histamine hydrochloride [randomly added to approximately 50% of vials]) (n = 9)
| Duration of study treatment:
| 1 year
| Symptomatic medication permitted: Xylometazolin, terfenadine, and salbutamol
| Dates: Jan 1986 - Jun 1986
| Location: Milan, Italy
| Setting: Allergy clinic
| Type(s) of providers:
| Allergists
Pence, Mitchell, Greely, et al., 1976 | Design: RCT, parallel-group | No. of subjects at start: 40 | 1) Patient-assessed symptom severity and medication use (combined in a single measure): presence and duration of stuffy/runny nose, sneezing, itchy/watery eyes, cough, and shortness of breath/wheezing recorded twice daily (persisted for ½ hour, ½ to 2 hours, or > 2 hours); use of symptomatic medication recorded daily in study diaries | 1) Patient-assessed symptom severity and medication use (combined in a single measure): | | | Quality Scoring:
| | | | | | | Population similar: Yes
| Interventions: | Dropouts/withdrawals: 8 | | | | | Intervention(s) described: Yes
| 1) Aqueous extract of Juniperus sabinoides (mountain cedar) pollen (n = 17). Extract prepared in a single lot by lab in Lenoir, NC. Build-up phase: gradually increasing doses given twice weekly, beginning with thousand-fold dilution of the full-strength concentration, until maintenance dose was reached. Maintenance phase: maintenance dose (6 mg of extracted pollen) given weekly. Total dose given ranged from 1 mg to 157 mg of extracted pollen, with mean dose of 58 mg. | | | Mean daily symptom-medication scores (± SD) were lower for treated patients (5.46 ± 3.22) than for control patients (8.83 ± 3.15) (p < 0.01) | | | Comorbidities described: No
| | No. of subjects at end: 32 | | | | | Diagnosis by MD: Yes
| | | | | | | Objectively confirmed: Yes
| | Inclusion criteria: History of seasonal hay fever or asthma during Nov-March; strongly positive intradermal skin test to mountain cedar pollen; not currently on IT | | | | | Outcome measures valid: No
| | | | | | | Level of evidence: 1b
| | | | 2) Skin sensitivity: Not abstracted | | | Randomized: Yes
| | | | | | | Allocation concealed: Not described
| | | | 3) Allergen-specific IgE levels: Not abstracted
| | | | | | | Double-blind: Yes
| | | | | | | Blinding adequate: Yes
| | Exclusion criteria: None specified | | | | | Dropouts described: Yes
| | | | | | | Intention-to-treat: No
| | Age: Active group 15–78, mean 37; placebo group 27–62, mean 44
| | | 2) Skin sensitivity | | | | Note: SDs calculated from raw data presented in paper.
| | Sex: Active 10 F/17 M, placebo 9 F/15 M
| | | 3) Allergen-specific IgE antibody levels
| | Race: NR
| 2) Placebo (caramelized glucose with histamine added) (n = 15)
| | Other: 8 patients with prior IT. None to mountain cedar.
| Duration of study treatment:
| 1 year
| Symptomatic medication permitted: Antihistamines or antihistamine-decongestant combinations
| Dates: 1974–75 mountain cedar pollen season
| Location: Texas
| Setting: Military hospital allergy clinic
| Type(s) of providers:
| Specialists
Pichler, Marquard-sen, Sparholt, et al., 1997 | Design: RCT, parallel-group | No. of subjects at start: 33 | 1) Adverse reactions | 1) Adverse reactions: | | | Quality Scoring:
| | | | 2 patients with local swelling > 8 cm. 3 patients with mild systemic reaction (rhinorrhea, broncho-spasm), 1 with late exacerbation of rhinoconjunctivitis, 2 with late increase in asthma symptoms. 1 with systemic symptoms requiring epinephrine. | | | Population similar: Yes
| Interventions: | Dropouts/withdrawals: 3 (non-compliance or pregnancy) | 2) Skin reactivity | | | | Intervention(s) described: Yes
| 1) Standardized extract of Dermatophagoides pteronyssinus and D. farinae (house dust mite) adsorbed to aluminum hydroxide (Alutard^®^) (n = 16). “Clustered rush protocol” used: 2–3 injections given at 30-min intervals during weekly visits until maintenance dose (100,00 SQ Units) reached; maintenance dose given every 8 weeks thereafter. | | | | | | Comorbidities described: Yes
| | | 3) Conjunctival reactivity | | | | Diagnosis by MD: Yes
| | No. of subjects at end: 30 | | | | | Objectively confirmed: Yes
| | | 4) Patient-assessed symptom severity: rhinitis and bronchial asthma “complaints” recorded daily during two 4-week periods and quantified on a visual analog scale, of which the length was measured | | | | Outcome measures valid: No
| | Inclusion criteria: Typical history of perennial rhinopathy and/or asthma; positive prick ST to D. pteronyssinus and/or D. farinae; positive test for specific IgE to D. pteronyssinus and/or D. farinae; positive conjunctival or nasal provocation test with mixture of D. pteronyssinus and/or D. farinae; FEV1 >80% predicted | | | | | Level of evidence: 1b
| | | | | | | Randomized: Yes
| | | | 2) Skin reactivity: Not abstracted | | | Allocation concealed: Not described
| | | | 3) Conjunctival reactivity: Not abstracted | | | Double-blind: Yes
| | | | | | | Blinding adequate: Yes
| | | | | | | Dropouts described: No
| | | | 4) Patient-assessed symptom severity: | | | Intention-to-treat: No
| | | | Values based upon analysis of data from 30 patients because of missing data points.
| | | 5) Bronchial hyperreactivity to methacholine
| 2) Placebo extract (n = 14) | | | | | | Notes:
| | Exclusion criteria: Immunologic or cardiovascular diseases; pregnancy; poor compliance; severe asthma (defined as requiring emergency treatment in last 3 years, nocturnal symptoms despite treatment in past 3 months, need for oral corticosteroids, asthma associated with aspirin or bisulfites); allergy to animal dander if exposed to animals | | Rhinitis symptoms:
| Duration of study treatment: | | | Active: 22 before and 9 after (p = 0.0064)
| 1 year (RCT phase); trial followed by 1-year period during which some (but not all) patients in the placebo group elected to receive active treatment | | 6) Use of symptomatic medication: recorded daily during two 4-week periods
| | | | Placebo: 39.5 before and 28 after (p = 0.5762)
| | | | Active vs. placebo before p = 0.1972
| | | | Active vs. placebo after p = 0.0383
| | | | Asthma symptoms:
| Symptomatic medication permitted: Antihistamine-containing eye drops or nasal spray (levocabastine) and topical steroids (budesonide) for nasal or bronchial use were allowed freely | | | Active: 5.5 before and 3.5 after (p = 0.0140)
| | | | Placebo: 13 before and 7 after (p = 0.8467)
| | Age: Active, 20–46 (mean 28.8); placebo, 20–42 (mean 31.7) | | Active vs. placebo before p = 0.4551
| | | | Active vs. placebo after p = 0.0903
| | Sex: Active, 5 F/10 M; placebo, 4 F/10 M | | 5) Bronchial hyperreactivity to methacholine: Not abstracted
| Dates: Not given
| Location: Switzerland | Race: NR | | 6) Use of symptomatic medication:
| | | | Use of b-agonists/inhaled corticosteroids (baseline v 1 year):
| Setting: Hospital allergy practice | Other: 10 asthmatics in active group and 8 in placebo group
| | | | Active: 8/11 v 4/8
| | | | Placebo: 4/9 v 2/6
| Type(s) of providers:
| Specialists | | | Use of nasal corticosteroids (baseline v 1 year):
| | | | Active: 5 v 2
| | | | Placebo: 2 v 2
Radcliffe, Lampe, and Brostoff, 1996 | Design: RCT, crossover | No. of subjects at start: 39 | 1) Patient preference: patients asked at end of trial whether they had a preference for one treatment over another based on overall symptom improvement | 1) Patient preference: | | | Quality Scoring:
| | | | 78% preferred active treatment (p = 0.006) | | | Population similar: Yes
| Interventions: | Dropouts/withdrawals: 3 | | | | | Intervention(s) described: Yes
| 1) Allergen-specific, low-dose immunotherapy using the maximum intradermally tolerated dose (MITD). MITD determined individually for each allergen and defined as 0.05 ml of the strongest concentration in a 1:5 dilution series that did not produce a positive intradermal wheal (positive = mean diameter ≥ 3 mm or more than 2 mm larger than wheal occurring with negative control). Skin-prick testing done to establish MITD for following allergens: house dust, house dust mite, mixed mold spores, cat dander, dog dander, mixed feathers, mixed grass pollen, histamine (positive control), and phenol + glycerin (negative control). Multiple-dose, multiple-allergen MITD injection solution prepared for each patient. Treatment consisted of daily self-administered subcutaneous injection of 0.2 ml of the solution. | | | | | | Comorbidities described: No
| | No. of subjects at end: 36 | | 2) Patient-assessed rhinitis symptom severity: | | | Diagnosis by MD: Yes
| | | | | | | Objectively confirmed: Yes
| | Inclusion criteria: Symptoms of perennial allergic rhinitis | | Total (active period vs. placebo period) | | | Outcome measures valid: No
| | | | Total symptoms: -6.81 vs. 1.03 p = 0.006 | | | Level of evidence: 2b
| | | 2) Patient-assessed rhinitis symptom severity: nasal blockage, nasal discharge, postnasal drip, sneezing, and anosmia graded daily on scale of 0 (none) to 4 (severe) | | | | Randomized: Yes
| | Exclusion criteria: Positive response to the negative control skin test; well controlled on drug therapy; lack of positive skin test to relevant allergen; nasal polyps | | Nasal blockage -2.31 vs. 0.19 | | | Allocation concealed: Yes
| | | | p = 0.02 | | | Double-blind: Yes
| | | | Nasal discharge -1.86 vs. 0.47 | | | Blinding adequate: Yes
| | | | p = 0.006 | | | Dropouts described: Yes
| | | | Postnasal drip -1.42 vs. 0.75 | | | Intention-to-treat: No
| | | | p = 0.02
| | Age: 16–66 mean 38.78 | | Sneezing: -0.28 vs. -0.28 p = 1.00
| | | 3) Patient-assessed non-rhinitis symptom severity: assortment of CNS, respiratory, gut, musculo-skeletal, and skin symptoms also graded daily on scale of 0 (none) to 4 (severe) | Anosmia -0.94 vs. -0.11 p = 0.02 | | | Note: This is a crossover study with intervention periods of 2 weeks. Carry-over effect very likely. Also, adequacy of blinding is an issue, with no histamine in the placebo vaccine.
| | Sex: 16M/20F
| | | | 3) Patient-assessed non-rhinitis symptom severity:
| | Race: NR
| | | | No data given
| | Other:
| | | | 4) Use of symptomatic medication:
| | | | No data given, as concurrent medication use minimal.
| | | 4) Use of symptomatic medication: recorded daily in study diaries
| 2) Placebo (diluent [benzyl alcohol + saline] alone)
| Duration of study treatment:
| 2 weeks per treatment period (2-week run-in / 2 weeks treatment A / 2-week wash-out / 2 weeks treatment B)
| Symptomatic medication permitted: “mainly” oral antihistamines and nasal steroids; patients instructed to keep doses to minimum compatible with reasonable comfort
| Dates: NR
| Location: England
| Setting: University Clinic
| Type(s) of providers: NR
Rak,Heinrich,Jacobsen,etal.,2001 | Design: RCT, parallel-group | No. of subjects at start: 41 | 1) Patient-assessed symptom severity: eye and nose symptoms graded on scale of 0 (no symptoms) to 3 (severe); recorded daily during three 1-week periods (winter [baseline], just before start of pollen season, and during pollen season) | 1) Patient-assessed symptom severity: | | | Quality Scoring:
| | | | Mean daily symptom scores for combined eyes and nose shown on graph for each of the 6 weeks of pollen season. Numeric values not given. Values were significantly different favoring nasal steroids during weeks 5 and 6 (p < 0.03 and p < 0.04, respectively). | | | Population similar: Yes
| Interventions: | Dropouts/withdrawals: 0 | | | | | Intervention(s) described: Yes
| 1) Standardized depot preparation of birch pollen allergen extract (Alutard^®^ SQ) (n = 21 ). Treatment given before start of pollen season. Dosage schedule described in Nielsen et al. All patients reached the maintenance dose of 1 ml of 100,000 SQ and received a total of 120– 150 μg of allergen before the start of the pollen season. | | | | | | Comorbidities described: Yes
| | No. of subjects at end: 41 | | | | | Diagnosis by MD: Yes
| | | | | | | Objectively confirmed: Yes
| | Inclusion criteria: Rhino-conjunctivitis symptoms during birch pollen season; positive prick skin test to birch allergen; specific IgE antibody to birch pollen; if designated asthmatic, positive methacholine challenge test | | | | | Outcome measures valid: No
| | | | | | | Level of evidence: 2b
| | | | | | | Randomized: Yes
| | | | | | | Allocation concealed: Not described
| | | | 2) Spirometry: Not abstracted
| | | 2) Spirometry (morning and evening peak flow rates) | | | | Double-blind: Yes
| | | | 3) Use of symptomatic medication: | | | Blinding adequate: Yes
| | | | Composite medication scores shown on a graph. No significant differences between groups at any time point. | | | Dropouts described: Yes
| | Exclusion criteria: Daily contact with animals in animal allergic subjects; patients with perennial rhinitis symptoms and/or positive skin test response to mites and molds | | | | | Intention-to-treat: Yes
| | | 3) Use of symptomatic medication: recorded daily during three 1-week periods (winter [baseline], just before start of pollen season, and during pollen season); anti-rhinitis drugs scored as follows: decongestant drops, 0.5; acrivastine, 1; and levocabastine, 1 .5; use of salbutamol assessed separately
| 2) Budesonide nasal spray 200 μg in each nostril once daily in the morning (n = 20). Treatment started 2 weeks before the predicted start of birch pollen season and continued throughout the entire season (mid-April to end of May = 6 weeks).
| | | | 4) Bronchial reactivity: Not abstracted | | | Note: Double-dummy blinding technique employed.
| | | | 5) Eosinophil measures: Not abstracted
| | Age: 19–42 mean 29
| | Sex: 22M/19F
| | Race: NR
| Duration of study treatment:
| Unclear for immunotherapy (1 pre-season); 6 weeks for nasal steroid; outcomes assessed just before and during one birch pollen season | Other:
| | | 4) Bronchial reactivity
| | | 5) Eosinophil measures (count, cationic protein, chemotactic activity)
| Symptomatic medication permitted: decongestant drops, local antihistamine drops (levocabastine), antihistamine tablets (acrivastine), and for asthmatics, salbutamol
| Dates: 1992-93
| Location: Sweden
| Setting: ENT clinic in country hospital
| Type(s) of providers: Specialists
Tari, Mancino, Ghezzi, et al., 1997 | Design: RCT, parallel-group | No. of subjects at start: 40 | 1) Patient-assessed symptom severity and medication use (combined in a single measure): nasal, conjunctival, and bronchial symptoms graded daily on 4-point severity scale (not described); “corresponding scores” compiled for medication use | 1) Patient-assessed symptom severity and medication use (combined in a single measure): | | | Quality Scoring:
| | | | | | | Population similar: Yes
| Interventions: | Dropouts/withdrawals: 1 placebo subject (noncompliance) | | | | | Intervention(s) described: Yes
| 1) Alum-adsorbed Parietaria judaica (wall pellitory) pollen allergoid (Allergovit^®^) (n = 20). Pollen extracts standardized against a well-characterized, biologically standardized reference extract. Build-up phase: weekly injections of 0.1, 0.2, 0.4, and 0.8 ml of strength A preparation (1,000 TU/ml) (with slight variations for individual patients), followed by weekly injections of increasing concentrations of strength B preparation (10,000 TU/ml), to a maximum of 1.0 ml (mean cumulative dose of 24,500 TU). Maintenance phase: injections of half the maximum dose administered every 3–4 weeks. | | | Described as significant (p ≤ 0.05) improvement in symptom score for active treatment group. No means or statistics given. | | | Comorbidities described: Yes
| | | | | | | Diagnosis by MD: Yes
| | No. of subjects at end: 39 | | | | | Objectively confirmed: Yes
| | | | | | | Outcome measures valid: No
| | Inclusion criteria: Clinical history of rhinitis to Parietaria ± asthma for 3+ consecutive years; positive prick ST to Parietaria; positive nasal provocation with Parietaria; positive Parietaria-specific IgE test | | | | | Level of evidence: 1b
| | | | 2) Peak flow rates: Not abstracted | | | Randomized: Yes
| | | | | | | Allocation concealed: Not described
| | | | 3) Adverse reactions:
| | | | Active: 9 immediate local reactions in 6 patients, and 9 late local reactions in 5 patients. 3 late systemic reactions in 2 patients. No anaphylaxis. | | | Double-blind: Yes
| | | 2) Peak flow rates | | | | Blinding adequate: Yes
| | | | | | | Dropouts described: Yes
| | Exclusion criteria: IT in previous 3 years; acute or chronic respiratory infections; active immunologic or systemic disease | 3) Adverse reactions: all possible adverse reactions (immediate and late reactions, and systemic responses) were recorded by investigators and graded as mild, moderate, or severe | | | | Intention-to-treat: No
| | | | Placebo: No local, systemic or anaphylactic reactions
| | | | | | | Notes:
| | Age: Active, 20–46 (mean 33.65); placebo, 13–50 (mean 31.65) | | 4) Specific nasal reactivity: Not abstracted
| | Sex: Active, 10 F/10 M; placebo, 10 F/10 M | | 5) Skin prick test: Not abstracted
| | | 4) Nasal reactivity
| | | | 6) Total IgE and allergen-specific IgE, IgG, IgG1, and IgG4: Not abstracted
| 2) Placebo (alum suspension colored with caramel NF acid) (n = 20) | Race: NR | 5) Skin reactivity
| | Other: Asthma present in 14 active and 10 placebo patients | 6) Total IgE and allergen-specific IgE, IgG, IgG1, and IgG4 antibody levels | 7) Lymphocyte populations: Not abstracted
| Duration of study treatment:
| 1 year (RCT phase); trial followed by 1-year open study during which all patients received active treatment
| | | 7) Lymphocyte populations
| No description of symptomatic medication permitted (if any)
| Dates: 1989-90
| Location: Italy
| Setting: Academic hospital allergy practice
| Type(s) of providers: Specialists
Van Metre, Adkinson, Amodio, et al., 1980 | Design: RCT, parallel-group | No. of subjects at start: 52 | 1) Patient-assessed symptom severity and medication use (combined in a single measure): calculated based on daily diary recordings, but symptoms recorded and method of scoring not described | 1) Patient-assessed symptom severity and medication use (combined in a single measure): | | | Quality Scoring:
| | | | | | | Population similar: Yes
| Interventions: | Dropouts/withdrawals: Text states that 15 patients randomized to placebo group which would have totaled 53 patients. However all data discuss 14 patients in placebo group. Possible typographic error in methods section? | | | | | Intervention(s) described: Yes
| 1) Ragweed pollen extract, administered according to standard immunotherapy schedule (n = 15). 24 weekly injections given in gradually increasing doses (from 0.15 ml of a 1:312,500 concentration to 0.5 ml of a 1:20 concentration), as tolerated. Maintenance dose then given (?) through pollen season. | | | Graph of symptom-medication score vs. time given. Mean daily scores reported as significantly lower in the standard treatment group compared to placebo or Rinkel method (p < 0.01). No significant difference in comparing Rinkel vs. placebo groups (p = 0.3). | | | Comorbidities described: No
| | | | | | | Diagnosis by MD: Yes
| | | | | | | Objectively confirmed: Yes
| | | | | | | Outcome measures valid: No
| | | | | | | Level of evidence: 2b
| | | | | | | Randomized: Yes
| | | | | | | Allocation concealed: Not described
| | | 2) Total IgE and allergen-specific IgE and IgG antibody levels
| | No. of subjects at end: 52 | | | | | Double-blind: Yes
| | | | Data also presented as dot plot with median values given. No numeric data given. | | | Blinding adequate: Yes
| | Inclusion criteria: History of seasonal rhinitis in Aug/Sept for 2 preceding years; positive skin test response to ragweed pollen extract and ragweed antigen E; positive in vitro leukocyte histamine release to ragweed pollen extract | | | | | Dropouts described: No
| | | 3) Patient global evaluation of efficacy of treatment: at end of trial, symptoms graded in comparison with those of previous year as “less severe,” “same,” or “more severe” | | | | Intention-to-treat: No
| 2) Ragweed pollen extract, administered by the Rinkel method (n = 23). “Optimal dose” determined for each patient based on skin test by serial dilution titration and patient's clinical status. This dose (normally 0.5 ml of the end-point dilution) achieved via a series of weekly injections of gradually increasing strength given from February 27 to August 31; maintenance injections then given weekly during ragweed season. Median cumulative dose approx. 0.0285 μg AgE; range, 0.005 to 0.827. | | | 2) Total IgE and allergen-specific IgE and IgG antibody levels: Not abstracted
| | | | | | | Note: 9/23 pts in the Rinkel-method group were continuing treatment started in the course of an earlier RCT. Results were reported separately for this group.
| | | | 3) Patient global evaluation of efficacy of treatment:
| | Exclusion criteria: Major rhinitis symptoms during mold season of July and Oct/Nov | | Patients reporting “hay fever symptoms less severe in 1979”
| | | 4) Adverse reactions
| | | | Less severe, same, more severe:
| | Age: 18–50 | | Standard: 15, 0, 0
| | | | Placebo: 9, 2, 1
| | Sex: 39M/13F | | Rinkel 1979: 11, 2, 1
| | | | Rinkel 1978/79: 9, 0, 0
| | Race: NR
| | | | 4) Adverse reactions:
| | Other: | | One local and no systemic reactions in Rinkel groups or placebo group.
| 3) Placebo (histamine caramelized glucose), administered according to Rinkel schedule (n = 14). | | | 7/15 patients in standard group had 1+ systemic reactions: 6 moderate treated with epinephrine, 3 mild treated with antihistamine, and 10 very mild requiring no medication. 5 local reactions occurred in 4 subjects in standard therapy group.
| Duration of study treatment:
| February 27-October 8
| Symptomatic medication permitted: Chlorpheniramine maleate 4 mg or carbinoxamine maleate 4 mg + pseudoephedrine 60 mg, every 4 hours, as needed
| Dates: 1979
| Location: Baltimore, MD
| Setting: University allergy practice
| Type(s) of providers: Specialist
Van Metre, Adkinson, Amodio, et al., 1982 | Design: RCT, parallel-group (matched-pairs design) | No. of subjects at start: 44 | 1) Adverse reactions | 1) Adverse reactions: | | | Quality Scoring:
| | | | No large local or systemic reactions in placebo group. | | | Population similar: Yes
| | Dropouts/withdrawals: 0 | 2) Patient-assessed symptom severity and medication use (combined in single measure): unspecified symptoms and medication use recorded in study diaries from June 16 to Oct 6; scoring system used not described | | | | Intervention(s) described: Yes
| Interventions: | | | | | | Comorbidities described: No
| 1) Short ragweed pollen extract concentrate (187 μg AgE/ml), weekly injections (n = 15). Initial dose 0.1 ml of 1:10,000 dilution. Dose increased every week over 21 weeks to maximum tolerated or maintenance dose (0.1 ml of concentrate). Maintenance injections given every 1–3 weeks thereafter. Median cumulative dose 70 μg of AgE (range, 16.4 to 252). | No. of subjects at end: 44 | | Active group: | | | Diagnosis by MD: Yes
| | | | Large local: 33 reactions in 13 subjects (weekly); 15 reactions in 9 subjects (cluster) | | | Objectively confirmed: Yes
| | Inclusion criteria: History of seasonal rhinitis in late Aug and Sep for 2+ preceding years; positive prick ST to ragweed | | | | | Outcome measures valid: No
| | | | | | | Level of evidence: No
| | | | Systemic: 13 reactions in 7 subjects (weekly); 19 reactions in 10 subjects (cluster) | | | Randomized: Yes
| | | | | | | Allocation concealed: No
| | | | | | | Double-blind: No
| | Exclusion criteria: Major rhinitis symptoms in mold-dominated seasons | | | | | Blinding adequate: Not applicable
| | | 3) Total IgE and allergen-specific IgE and IgG antibody levels | 2) Patient-assessed symptom severity and medication use (combined in single measure):
| | | | | | | Dropouts described: Yes
| | | | | | | Intention-to-treat: Yes
| | Age: 27 pts age 18–35 and 17 patients age 36–50 | | Mean daily symptom-medication scores in both treatment groups significantly lower than placebo (p < 0.01). Score: weekly 3.79, cluster 2.21, placebo 11.14
| | | 4) Skin reactivity
| | | | | | | Note: Two placebo groups combined for purposes of analysis.
| 2) Short ragweed pollen extract concentrate (187 μg AgE/ml), clustered injections (n = 18). Injections (3, 2, or 1) given every 3 weeks. Initial treatment 3 doses (0.1, 0.5, and 0.9 ml) of 1:10,000 dilution. Doses increased every 3 weeks over 19 weeks to maximum tolerated or maintenance dose (0.1 ml of concentrate). Maintenance injections given approximately every 3 weeks thereafter. Median cumulative dose 17.5 μg of AgE (range, 2.2 to 147). | Sex: 14 F | 5) Patient global evaluation of efficacy: At end of study, patients compared symptoms experienced during study pollen season with those experienced during previous year's pollen season (“less severe,” “same,” “more severe”)
| | Race: NR
| | | | 3) Total IgE and allergen-specific IgE and IgG antibody levels: Not abstracted
| | Other:
| | 11 patients had prior ragweed IT but none in last 6 years.
| | | | 4) Skin reactivity: Not abstracted
| | Preferentially recruited patients with negative mold ST responses.
| | | | 5) Patient global evaluation of efficacy:
| | | | Less severe, same, more severe:
| | | | Active weekly: 14, 1, 0
| | | | Active cluster: 16, 1, 1
| | | | Placebo weekly: 4, 1, 0
| | | | Placebo cluster: 4, 1, 1
| 3) Placebo extract with histamine, weekly injections, gradually escalating to include 0.014 mg of histamine phosphate (n = 5).
| 4) Placebo extract with histamine, clustered injections, gradually escalating to include 0.014 mg of histamine phosphate (n = 6).
| Duration of study treatment: 7+ months (injections given between Feb 25 and Oct 6)
| Symptomatic medication permitted: Chlorpheniramine maleate 4 mg or carbinoxamine maleate 4 mg + pseudo-ephedrine 60 mg every 4 hours as needed
| Dates: 1980 ragweed season
| Location: Baltimore, MD
| Setting: Academic hospital based allergy practice
| Type(s) of providers: Specialists
Varney, Gaga, Frew, et al., 1991 and Durham, Varney, Gaga, et al., 1991 | Design: RCT, parallel-group | No. of subjects at start: 40 | 1) Patient-assessed symptom severity (daily diary): breathlessness, coughing, wheezing, chest tightness, sneezing, blocked nose, running nose, itching eyes, red eyes, streaming eyes, swollen eyes, and itching and dryness of mouth and throat graded daily from April to October on visual analog scale of 0–3 (not described) | 1) Patient-assessed symptom severity (daily diary): | | | Quality Scoring:
| | | | | | | Population similar: Yes
| Interventions: | Dropouts/withdrawals: 3 | | IT | 360 | | Intervention(s) described: Yes
| 1) Partially purified, standardized, alum-adsorbed grass pollen (Phleum pratense) extract (Alutard^®^ SQ) (n = 21). Treatment started in April. Build-up phase: Twice weekly injections of gradually increasing doses, from 0.1 ml × 100 SQ/ml (injection 1) to 1.0 ml × 100,000 SQ/ml (injection 15). Adjustments in schedule made on an individual basis, with no further increases after May 28. Maintenance doses (volume reduced by 40%) given | | | Placebo | 928 | | Comorbidities described: No
| | No. of subjects at end: 37 | | Difference | 522 (238 to 825) | | Diagnosis by MD: Yes
| | | | P = 0.001 | | | Objectively confirmed: Yes
| | Inclusion criteria: History of severe summer hay fever; poor symptom control despite symptomatic treatment; positive skin prick test (wheal > 5 mm) to timothy grass pollen extract | | | | | Outcome measures valid: Not adequately described
| | | | 2) Use of symptomatic medication:
| | | | IT | 129 | | Level of evidence: 2b
| | | | Placebo | 627 | | Randomized: Yes
| | | | Difference | 335 (178 to 574) | | Allocation concealed: yes
| | | | P = 0.002 | | | Double-blind: Yes
| | | | | | | Blinding adequate: Yes
| | Exclusion criteria: Appreciable clinical history of other allergies; previous IT in 5 years; chronic asthma | | 3) Patient-assessed symptom severity (every 2 weeks): | | | Dropouts described: Yes
| | | | | | | Intention-to-treat: Can't determine
| | | 2) Use of symptomatic medication: scored daily from April to October as follows: | 19 June analysis:
| | | | IT | 2.2
| | | | Placebo | 5.5
| | Age: 35 years (range 19 to 52) | | Difference | -3 (-4.8 to -0.5) | | Notes:
| | | Each eye drop, nasal
| monthly. | Sex: 18 women; 22 men | spray, or salbutamol | 3 July analysis:
| | | inhalation: 1 | IT | 1.7
| 2) Placebo ± histamine (“intermittently ‘spiked’ with histamine”) (n = 16) | Race: NR | Each acrivastine or | Placebo | 4.0
| | | prednisolone: 2 | Difference | -2.3 (-5 to -1)
| | Other:
| | | 3) Patient-assessed symptom severity (every 2 weeks): During pollen season, patients asked to grade their overall symptoms every 2 weeks on a visual analog scale from 0–10 | Symptom-free days:
| Duration of study treatment: | | | IT | 29 days
| 8 months (April-November) | | | Placebo | 8 days
| | | | Diff 21 d (-26 to -1) p = 0.04
| Symptomatic medication permitted: Sodium cromoglycate eye drops and nasal spray, acrivastine, and salbutamol permitted as required; 7-day course of oral prednisolone could be prescribed if these failed to control symptoms
| | | | 4) Conjunctival reactivity: Not abstracted
| | | | 5) Skin reactivity: Not abstracted
| | | 4) Conjunctival reactivity
| | | | 6) Patient global assessment of efficacy of treatment:
| | | 5) Skin reactivity
| | | | IT | +3 median
| | | 6) Patient global assessment of efficacy of treatment: At end of pollen season, patients asked to assess the severity of their hay fever in comparison to previous years on scale of +3 (much better) to -3 (a lot worse) | Placebo | +1
| Dates: | | | P< 0.001 (Mann-Whitney U test)
| Location: London, UK | | | 7) Investigator global assessment of efficacy of treatment: Not abstracted
| Setting: Allergy clinic
| | | | 8) Adverse reactions:
| Type(s) of providers: Allergists | | | 22 delayed local reactions (swelling < 8 cm diameter)
| | | | 2 systemic reactions (chest tightness and flushing at 10 min; 1 case of delayed urticaria)
| | | 7) Investigator global assessment of efficacy of treatment
| | | 8) Adverse reactions
Walker, Pajno, Lima, et al., 2001 and Wilson, Nouri-Aria, Walker, et al., 2001 | Design: RCT, parallel-group | No. of subjects at start: 44 | 1) Patient-assessed symptom severity: breathlessness, cough, wheezing, chest tightness, sneezing, nasal blockage, running nose, itching eyes, red eyes, streaming eyes, swollen eyes, and itching and dryness of mouth and throat graded daily from May to August on visual analog scale of 0–3 (not described) | 1) Patient-assessed symptom severity: | | | Quality Scoring:
| | | | Difference IT vs. placebo | | | Population similar: Yes
| Interventions: | Dropouts/withdrawals: 7 | | 1186.5 (241.5 to 1928.6; p = 0.01) | | | Intervention(s) described: Yes
| 1) Partially purified, standardized, alum-adsorbed grass pollen (Phleum pratense) extract (Alutard(r) SQ) (n = 22). Treatment started in October. Modified “cluster” regimen used: twice-weekly injections given of gradually increasing doses (from 0.1 ml × 100 SQ/ml to 1.0 ml × 100,000 SQ/ml) over 4 weeks. Adjustments in doses made on an individual basis, “according to published guidelines.” Maintenance injections given monthly for further 2 years (dose reduced up to 40% during pollen season). | | | | | | Comorbidities described: Yes
| | No. of subjects at end: 37 | | 2) Use of symptomatic medication: | | | Diagnosis by MD: Yes
| | | | | | | Objectively confirmed: Yes
| | Inclusion criteria: History of severe hay fever uncontrolled by conventional symptomatic treatment; positive skin prick test (wheal > 5 mm) to grass pollen | | 1043.0 (332.0 to 2667.1; p = 0.007) | | | Outcome measures valid: Yes
| | | | | | | Level of evidence: 1b
| | | | 3) Bronchial reactivity: Not abstracted | | | Randomized: Yes
| | | | | | | Allocation concealed: Not described
| | | | 4) Skin reactivity: Not abstracted
| | | | | | | Double-blind: Yes
| | Exclusion criteria: History of multiple allergies; IT in past 5 years; methacholine PC_20_ (concentration of inhaled methacholine that caused a 20% decrease in FEV_1_ < 2 mg/mL (normal range > 16 mg/mL) | | 5) Eosinophils, T cells, and IL-5: Not abstracted | | | Blinding adequate: Yes
| | | | | | | Dropouts described: Yes
| | | 2) Use of symptomatic medication: scored daily from May to August as follows: | | | | Intention-to-treat: No
| | | | 6) Quality of life (overall):
| | | | Difference IT vs. placebo
| | | | 0.8 (0.18 to 1.5; p = 0.02) | | | Notes:
| | | Each eye drop, nasal spray, or salbutamol inhalation: 1
| | | | 7) Adverse reactions:
| | Age: 32 years (range 22 to 64) | | No immediate (within 1 hr) systemic reactions or large local reactions observed during induction or maintenance.
| | | Each acrivastine or prednisolone tablet: 2
| | Sex: 21 women; 23 men
| 2) Placebo containing 0.01 mg/ml histamine acid phosphate in diluent (n = 22)
| | Race: NR | 3) Bronchial reactivity | 9 delayed mild systemic reactions during induction period
| | Other: | 4) Skin reactivity | 4IT group
| Duration of study treatment: | | | 5 placebo group
| Approximately 26–27 months (October 1996-December 1998); patients kept pre-trial symptom and medication diaries from May to August 1996 | | 5) Eosinophils, T cells, and IL-5 | 3 delayed mild systemic reactions during maintenance period
| | | | 3 IT group
| | | 6) Quality of life: assessed using the Rhinoconjunctivitis Quality of Life Questionnaire (RQLQ); completed at baseline and during allergy season | 0 placebo group
| Symptomatic medication permitted: Sodium cromoglycate eye drops and nasal spray, acrivastine, and salbutamol permitted as required; 7-day course of oral prednisolone could be prescribed if these failed to control symptoms
| | | 7) Adverse reactions
| Dates: 1996 to 1998
| Location: London, UK
| Setting: Allergy clinic
| Type(s) of providers: Allergists
Weyer, Donat, L'Heritier, et al., 1981 | Design: RCT, parallel-group | No. of subjects at start: 33 | 1) Patient-assessed symptom severity: sneezing, stuffy nose, running nose, itchy eyes, watery eyes, red eyes, chest tightness, and asthma graded daily during the pollen season on scale of 0 (no symptoms) to 2 (strong symptoms) | 1) Patient-assessed symptom severity: | | | Quality Scoring:
| | | | IT | 16 ± 10 | | Population similar: Not adequately described
| Interventions: | Dropouts/withdrawals: 1 | | Placebo | 24 ± 8
| 1) Crude extract of the pollen of four grasses (Dactylis glomerata, Lolium perenne, Secale cereale, and Phelum pratense) (n = 17). Five weekly injections of diluted aqueous extract given in increasing doses (from 0.0025 to 0.05 μg protein contained in 0.2 ml). Then 12 (weekly?) injections of Al(OH)_3-_adsorbed extract given in gradually increasing doses (1–6.25 μg protein in 0.2 ml of solution). Previous dose repeated in event of strong local or general reaction. Mean dose administered 19.3 ± 3.4 μg protein. | | | P< 0.09 | | | Intervention(s) described: No
| | No. of subjects at end: 32 | | | | | Comorbidities described: Yes
| | | | 2) Use of symptomatic medication: | | | Diagnosis by MD: Yes
| | Inclusion criteria: Symptoms of seasonal allergic rhinitis with worsening or symptoms from April to July in previous 2 years; positive skin prick test (wheal at least 8 mm) to four-grass pollen extract; | | IT | 3 ± 5 | | Objectively confirmed: Yes
| | | | Placebo | 11± 13 | | Outcome measures valid: No
| | | | P< 0.07 | | | Level of evidence: 2b
| | | | | | | Randomized: Yes
| | | | 3) Patient-assessed symptom severity and medication use (combined in a single measure): | | | Allocation concealed: Not described
| | | 2) Use of symptomatic medication: Meds taken recorded daily (with dose) during the pollen season in study diaries; scored by investigators as follows: | | | | Double-blind: Yes
| | | | IT | 10 ± 7 | | Blinding adequate: No
| | Exclusion criteria: Previous IT treatment with grass pollen extracts; history of corticosteroid treatment during grass pollen season; very severe symptoms | | Placebo | 18 ± 15 | | Dropouts described: No
| | | | P< 0.03 | | | Intention-to-treat: Can't determine
| | | | 4) Adverse reactions:
| | | No meds taken: 0 | No quantitative data given “Very few reactions were observed” “A few patients had symptoms, both in the treated and in the placebo group.”
| | | Mean of 2 tabs of antihistamine per day: 10 | | | | Notes:
| | Age: 26 years (range 9 to 46)
| | | Mean of 3 doses of sodium cromoglycate per day: 20
| | Sex: 17 women; 16 men
| 2) Placebo (saline-phenol diluent) (n = 16)
| | Race: NR | Mean of 2 inhalations of salbutamol per day: 20
| Duration of study treatment: | Other: Patients with “very severe symptoms” were excluded “for ethical reasons” | 1-week prednisone course: 25
| 5 months (Nov 1978-Apr 1979); outcomes recorded in study diaries from May 15 to June 30, 1979
| | | 3) Patient-assessed symptom severity and medication use (combined in a single measure)
| Symptomatic medication permitted: Antihistamine (Mequitazine^®^), up to 2 tablets per day, at first sign of symptoms; if not sufficient, then sodium cromoglycate nasal spray, up to 4 nebulized doses per day; if still not sufficient and pulmonary symptoms present, then salbutamol, 2 inhalations per day; if still not sufficient, then 6-day course of prednisone given
| | | 4) Adverse reactions
| Dates: Nov 1978 - Apr 1979
| Location: Paris, France
| Setting: Allergy clinics
| Type(s) of providers: Allergists
Winther, Malling, Moseholm, et al., 2000 | Design: RCT (see Note), parallel-group | No. of subjects at start: 52 | 1) Patient-assessed symptom severity: sneezing, rhinorrhea, nasal congestion, itchy nose and/or throat, and itchy eyes graded once daily from April to August on scale of 0 (no symptoms) to 3 (severe symptoms) | 1) Patient-assessed symptom severity: Year 1 | | | Quality Scoring:
| | | | | | | Population similar: Yes
| | Dropouts/withdrawals: 3/7/2 in years 1/2/3 | | Birch group had fewer symptoms than untreated group (p = 0.015) | | | Intervention(s) described: Yes
| Interventions: | | | | | | Comorbidities described: Yes
| 1) Aluminum-adsorbed birch pollen (Betula verrucosa) extract (Alutard^®^ SQ) (n = 26). Clustered regimen given, with gradually increasing doses (from 10 to 100,000 SQ-U) given weekly for 6 weeks. Dose/schedule adjusted in event of adverse reactions. Interval between maintenance injections gradually increased to 2 months. Median cumulative dose 613,110 SQ-U (range, 266,210–645,110). | | | Grass group had similar symptoms as untreated group (p = 0.355) | | | Diagnosis by MD: Yes
| | No. of subjects at end: 40 | | | | | Objectively confirmed: Yes
| | | | | | | Outcome measures valid: No
| | Inclusion criteria: History of severe allergy to birch and grass pollen with symptoms in Apr-Jul; positive skin prick (wheal area > 7 mm2) to birch and grass pollen; positive RAST for specific IgE (class 2 or greater) to birch and grass pollen | | 2) Use of rescue medication: Year 1 | | | Level of evidence: 2b
| | | | | | | Randomized: Unclear (see Note)
| | | | Birch group had less medication use than untreated group (antihistamine tablets p = 0.015; eye-drops, p = 0.001; mg prednisolone, p = 0.002) Grass group had less use of antihistamine, but similar use of other medications as untreated group (antihistamine tablets, p = 0.001; eye-drops, p = 0.345; mg prednisolone, p-0.873)
| | | | | | | Allocation concealed: Not described
| | | 2) Use of rescue medication: intake recorded daily from April to August
| | | | | | | Double-blind: Yes
| | | | | | | Blinding adequate: Not described
| | | | | | | Dropouts described: Yes
| | Exclusion criteria: Perennial rhinitis; clinical allergy to animal dander with contact at least weekly; IT within previous 5 years | | | | | Intention-to-treat: Can't determine
| 2) Aluminum-adsorbed grass pollen (Phleum pratense) extract (Alutard^®^ SQ) (n = 26). Protocol as above. Median cumulative dose 724,110 SQ-U (range, 68,110–6948,110).
| | Age: 26 years (range 18 to 52)
| | | | | | | Notes:
| | Sex: 24 women; 28 men | | | | | Though study not explicitly described as “drandomized,” likely to be RCT.
| | Race: NR
| Duration of study treatment:
| 1 year (RCT phase); trial preceded by 1-year observation (no treatment) period and followed by a 1-year period during which all patients received treatment with both grass and birch pollen extracts | Other:
| Symptomatic medication permitted: Acrivastine and antazoline-naphazoline eye drops; if symptoms inadequately controlled, course of prednisolone could be prescribed
| Dates: 1992-1994
| Location: Copenhagen, Denmark
| Setting: Allergy clinic
| Type(s) of providers: Allergist
Zenner, Baumgarten, Rasp, et al., 1997 | Design: RCT, parallel-group | No. of subjects at start: 87 | 1) Patient-assessed symptom severity: nasal, conjunctival, and bronchial symptoms scored daily during allergy season on scale of 0 (no symptoms) to 3 (severe symptoms) | 1) Patient-assessed symptom severity: | | | Quality Scoring:
| | | | Overall: | | | Population similar: Yes
| Interventions: | Dropouts/withdrawals: 6 | | STI | 82.2 ± 10.1 (mean ± SD) | | Intervention(s) described: Yes
| 1) Short-term immunotherapy using a partially purified, standardized, and aluminum hydroxide adsorbed extract containing equal parts of six grasses (Dactylis glomerata, Lolium perenne, Avena elatior, Phleum pratense, Poa pratensis, and Festuca pratensis) and rye (Secale cereale) (n = 45). Seven weekly injections given in increasing doses (from 3 to 1,000 SE [1,000 SE contains between 1.0 and 2.0 μg of individual grasses]). Dose/schedule modifications made “for medical indications according to the routine procedure of specific immunotherapy.” | | | | 54 (39–96) median, CI | | Comorbidities described: Yes
| | No. of subjects at end: 81 | | Placebo | 116.0 ± 13.2 | | Diagnosis by MD: Yes
| | | | | 97.5 (81–117) | | Objectively confirmed: Yes
| | Inclusion criteria: Allergic rhinitis history; positive skin prick (wheal at least 5 mm diameter) to grass and/or rye pollen | | P = 0.02 (one-tailed Mann-Whitney U test) | | | Outcome measures valid: No
| | | | | | | Level of evidence: 2b
| | | 2) Use of symptomatic medication: graded daily during the allergy season as follows: | | | | Randomized: Yes
| | | | 2) Use of symptomatic medication: | | | Allocation concealed: Not described
| | | | STI | 26% of 70 days
| | Exclusion criteria: need for treatment for allergic asthma, perennial rhinitis, or acute infected nasal mucosa; current use of systemic corticosteroids; IT in past 3 years | | Placebo | 33% | | Double-blind: Yes
| | | No drugs: 0 | P = 0.296 | | | Blinding adequate: Yes
| | | Disodium cromoglycate: 1 | | | | Dropouts described: No
| | | Topical corticosteroids or antihistamines: 2 | 3) Skin reactivity: Not abstracted | | | Intention-to-treat: No
| | | Nasal decongestants: 3 | 4) Specific IgE and IgG4: Not abstracted
| | | | | | | Notes:
| | Age: 28.5 (range 16 to 53) | 3) Skin reactivity
| | | | 5) Adverse reactions:
| | Sex: 27 women; 59 men | 4) Specific IgE and IgG4 | Local reactions (swelling, erythema > 5 cm diameter at injection site):
| | Race: NR | 5) Adverse reactions | STI | 30/309 injections
| | | | Placebo | 6/284 injections
| | Other:
| 2) Placebo containing increasing doses of histamine dihydrochloride (n = 41) | | | Systemic reactions (moderate exacerbations of rhinoconjunctivitis, urticaria, edema of eyelid):
| | | | STI | 9 pts (12 injections)
| Duration of study treatment: 7 weeks before start of allergy season | | | Placebo | 5 pts (7 injections)
| | | | No severe systemic reactions
| Symptomatic medication permitted: Disodium cromoglycate eyedrops and nasal spray, local and systemic antihistamines, sympatho-mimetics and local glucocorticosteroids all permitted
| Dates: NR
| Location: Germany
| Setting: NR
| Type(s) of providers: Allergists

† Quality scoring criteria were as follows:

Population similar: Was the study population described and reasonably similar to an adult working US population? (Yes [described and similar], No [described, but not similar], Not adequately described)

Intervention(s) described: Were the intervention protocols referenced or described in sufficient detail to replicate? (Yes, No)

Comorbidities described: Was the presence of comorbid asthma (or other upper respiratory conditions) described in the study population? (Yes, No)

Diagnosis by MD: Was the diagnosis of allergic rhinitis based on physician diagnosis? (Yes, No, Not applicable [asthma patients only])

Objectively confirmed: If physician-diagnosed, was the diagnosis supported by objective evidence of allergy (e.g., skin prick or serum IgE antibody testing)? (Yes, No, Not applicable)

Outcome measures valid: Were the main outcomes of interest to us measured in a way that has been demonstrated empirically to be valid and reliable (e.g., using a standardized scale such the RQLQ or SF-36)? (Yes, No, Not adequately described)

Level of evidence: Based on Oxford Center for Evidence-Based Medicine Levels of Evidence (1a, 1b, 1c, 2a, 2b, 2c, 3a, 3b, 4, 5)

Randomized: Was the study described as “randomized”? (Yes, No)

Allocation concealed: If the method for concealing allocation from the investigators was described, was it adequate (table of random numbers, computer-generated, coin tossing, etc.) or inadequate (alternating, date of birth, hospital number, etc.)? (Not described, Yes [described and adequate], No [described, but inadequate])

Double-blind: Was the study described as “double-blind”? (Yes, No)

Blinding adequate: If the method of double-blinding was described, was it adequate (e.g., identical placebo, active placebo, injection vs. tablet with double dummy) or inadequate (e.g., tablet vs. injection with no double dummy)? (Not described, Yes [described and adequate], No [described, but inadequate])

Dropouts described: Did the study describe dropouts and withdrawals so that all patients entering the trial could be accounted for? (Yes, No)

Intention-to-treat: Was the analysis performed according to the intention-to-treat principle? (Yes, No, Can't determine)

Evidence Table 4. Combined Treatments

Study | Design and Interventions | Patient Population | Outcomes Reported | Results | Quality Score^†^/Notes
Andri, Senna, Betteli, et al., 1992 | Design: RCT, parallel-group | No. of subjects at start: 30 | 1) Investigator-assessed symptom severity | 1) Investigator-assessed symptom severity: Not abstracted | Quality Scoring:
| | | | | Population similar: Yes
| Interventions: | Dropouts/withdrawals: 2 (left area during pollen season) | | | Intervention(s) described: Yes
| 1) Terfenadine 60 mg bid + nimesulide (NSAID) 100 mg bid (n = 15) | | 2) Paient-assessed symptom severity: nasal itching, nasal obstruction, sneezing, running nose, eye irritation, and eye watering graded daily by patients scale of 0 (none) to 3 (severe) | 2) Patient-assessed symptom severity: | Comorbidities described: Yes
| | | | Mean symptom score shownFigure 2, P ≤ 0.005 terfenadine + nimesulide vs. terfenadine + placebo | Diagnosis by MD: Yes
| | No. of subjects at end: 28 | | | Objectively confirmed: Yes
| | | | | Outcome measures valid: No
| 2) Terfenadine 60 mg bid + placebo (n = 15) | Inclusion criteria: History of parietaria pollen AR; positive skin test; RAST positivity; positive nasal provocation | | | Level of evidence: 2b
| | | | Table 2Average symptom score (no SD reported): | Randomized: Yes
| | | | | Allocation concealed: Not described
| Duration of study treatment:30 days | | | Terfenadine + nimesulide:
| | | | Day 1, 8.4; day 15, 2.9; day 30, 1.1 | Double-blind: No
| | Exclusion criteria: “Other major disease;” ASA sensitivity | 3) Patient global assessment of efficacy: recorded once at end of trial - categorical scale keyed to perceived degree of improvement in symptoms (< 50%, 50–80%, > 80%) | Terfenadine + placebo: | Blinding adequate: Not applicable
| No other drugs “likely to affect hay fever” permitted | | | Day 1, 7.4; day 15, 3.6; day 30, 2.6
| | | | P ≤ 0.001 at days 15 and 30 | Dropouts described: Yes
| | Age: 18–48 (mean 32.1, SD 8.9) | | | Intention-to-treat: Can't determine
| No pre-trial washout period described | | | 3) Patient global assessment of efficacy:
| | Sex: 18 M, 12 F
| | | | Terfenadine + nimesulide:
| Dates: 5/2/89 - 5/30/89 | Race: NR | | Recovering n = 10, good improvement 2, no or slight improvement 2 | Notes:
| | | | | Local pollen counts conducted daily during trial.
| Location: Italy | Other: | 4) Adverse events: Not clear how reported/ recorded | Terfenadine + placebo:
| | | | Recovering 5, good improvement 2, no to slight improvement 7
| Setting: Outpatient allergy clinic | | | | No sample size or power calculation.
| | | | 0.1 < P ≤ 0.12, by Chi-square
| Type(s) of providers: Allergist | | | 4) Adverse events:
| | | | 3 terfenadine + nimesulide, 2 terfenadine + placebo reported occasional sleepiness and sedation (5 total, with no withdrawal)
Backhouse, Finnamore, and Gosden, 1986 | Design: RCT, parallel-group | No. of subjects at start: 99 | 1) Investigator-assessed symptom severity | 1) Investigator-assessed symptom severity: Not abstracted | Quality Scoring:
| | | | | Population similar: Yes
| Interventions: | Dropouts/withdrawals: 22 total 17 from T group (10 poor symptom control, 1 headache, 1 pregnancy, 1 glandular fever, 2 lack of symptoms, 1 personal reasons, 1 lost to follow-up) 5 from T+F group (2 poor symptoms control, 2 personal reasons, 1 left country) | | | Intervention(s) described: Yes
| 1) Terfenadine 60 mg bid + flunisolide (two 25-mcg spray to each nostril bid) (T+F) (n = 49) | | 2) Patient-assessed symptom severity: sneezing, runny nose, blocked nose, and eye symptoms assessed on scale of 1–4 by patients in daily diary recordings and at clinic visits at 3,7, and 11 weeks | 2) Patient-assessed symptom severity: | Comorbidities described: Yes
| | | | (see Table 2 for week 3 and 7 results) | Diagnosis by MD: No
| | | | Week 11 mean scores (SD): | Objectively confirmed: No
| | | | Sneezing: T group 1.3 (0.6), T+F group 1.0 (0.2), P = 0.12 | Outcome measures valid: No
| | | | | Level of evidence: 2b
| 2) Terfenadine 60 mg bid (T) (n = 50) | | | Nose blowing: T group 1.3 (0.8), T+F group 1.0 (0.2), P = 0.15 | Randomized: Yes
| | | | | Allocation concealed: Not described
| | | | Runny nose: T group 1.4 (0.8), T+F group 1.2 (0.5), P = 0.03
| Duration of study treatment: | P < 0.005 | | | Double-blind: No
| 11 weeks | | | Stuffy nose: T group 1.3 (0.7), T+F group 1.2 (0.5), P = 0.28 | Blinding adequate: No
| | No. of subjects at end: 75 | 3) Investigator-and-patient global assessment: overall effect of treatment rated (“by both the doctor and the patient”) as excellent, good, poor, none, or symptoms worse at clinic visits at 3, 7, and 11 weeks | | Dropouts described: Yes
| No mention of rescue med | | | Eye symptoms: T group 1.4 (0.8), T+F group 1.1 (0.3), P = 0.18 | Intention-to-treat: Can't determine
| | Inclusion criteria: 2-year history of moderate-severe seasonal allergic rhinitis
| No pre-trial washout period described; patients who had received systemic steroid therapy within previous 3 months or anti-allergic treatment within previous 2 weeks were excluded | | | Note: significant p-values mostly at week 7, when pollen count was high
| | | | | Notes:
| | Exclusion criteria: Pregnant, lactating, URI, nasal obstruction abnormalities, systemic steroids within 3 months, allergy treatment within 2 weeks | | 3) Investigator-and-patient global assessment: | Single-blind trial.
| | | | Week 7, good or excellent response 96% T&F group, 62% T group, P = 0.001 | Local pollen counts recorded during weeks 3–9 of study.
| | | 4) Adverse events: Not clear how reported/ recorded
| Dates: May and Aug (1985?) | | | Not reported for Week 11
| | Age: 13–65, mean age
| Location: England | | | 4) Adverse events:
| | Sex: 51 M, 48 F | | 29 pts T group (9 drowsiness, 5 nausea/vomiting, 3 headache, 2 loss of concentration, 1 loss of balance, 1 depression, 8 other), only 12 felt to be due to study drug
| Setting: Outpatient
| | Race: NR
| Type(s) of providers:
| Specialist | Other:
| | | | 35 pts T+F group (10 nasal/throat irritation, 7 drowsiness, 2 headache, 2 hangover, 1 irritation, 1 husky voice, 3 dry throat, 9 other), only 21 felt to be due to study drug
Benincasa and Lloyd, 1994 | Design: RCT, parallel-group | No. of subjects at start: 455 screened, 454 randomized (227 per group) | 1) Patient-assessed symptom severity: nasal symptoms, eye symptoms, and headache graded daily on scale of 0 (no symptoms) to 7–9 (severe symptoms). Diaries used weeks 3–8. | 1) Patient-assessed symptom severity: no significant differences in any symptoms or symptom-free days | Quality Scoring:
| | | | | Population similar: Yes
| Interventions: | | | | Intervention(s) described: Yes
| 1) Fluticasone propionate nasal spray 200 μg (2 actuations per nostril) + oral cetirizine 10 mg, once per day (n = 227) (Combo group) | | | | Comorbidities described: No
| | Dropouts/withdrawals: 68 (1 withdrew prior to randomization, 37 from FPANS group, 30 from Combo group). | | Symptom scores (mean [SD]): | Diagnosis by MD: Yes
| | | | Nasal: 1.5 (1.4) FPANS, 1.5 (1.6) Combo | Objectively confirmed: No
| | | | | Outcome measures valid: No
| | | | Eye: 1.3 (1.3) FPANS, 1.1 (1.3) Combo | Level of evidence: 1b
| | | | | Randomized: Yes
| 2) Fluticasone propionate nasal spray 200 μg once per day (n = 227) (FPANS group) | No. of subjects at end: 387 | 2) Use of rescue med (eye drops): recorded daily in study diaries | Headache: 0.4 (0.9) FPANS, 0.4 (0.7) Combo | Allocation concealed: Not described
| | Inclusion criteria: Required treatment for hay fever symptoms during June in previous 2 years; at least 2 of following symptoms (1 nasal symptom): sneezing, nasal itching, runny nose, or nasal congestion, eye watering/irritation, or headache. Patients with asthma included if unlikely to require change in medication over 8-week study period. | | | Double-blind: Yes
| | | | Proportion symptom-free days (mean [SD]): | Blinding adequate: Yes
| Duration of study treatment: | | 3) Patient global evaluation of efficacy of treatment: patients asked at end of study whether treatment had adequately controlled their nasal, eye, and headache symptoms (yes/no) | | Dropouts described: Yes
| 8 weeks | | | Nasal: 0.45 (0.38) FPANS, 0.46 (0.4) Combo | Intention-to-treat: Yes
| Patients provided with eye drops containing a mixture of antazoline and xylometazoline (Otrivine-Antistin^®^) to be used “if eye symptoms became troublesome” | | | Eye: 0.56 (0.36) FPANS, 0.57 (0.36) Combo
| | | | | Note: No sample size calculation reported.
| | | | Headache: 0.86 (0.22) FPANS, 0.85 (0.25) Combo
| | | | 2) Use of rescue medication:
| | | 4) Investigator global evaluation of efficacy | No significant difference
| No pre-trial washout period described; patients who had taken following drugs, in time frames indicated, were excluded: intranasal or oral corticosteroids, ketotifen, or sodium cromoglycate (4 weeks); astemizole (6 weeks); depot corticosteroids (8 weeks); immunotherapy injections (grass pollen) (6 months) | Exclusion criteria: Prescription med for respiratory infection in past 2 weeks; treatment for allergic rhinitis in past week; intranasal or oral corticosteroids, ketotifen or sodium cromoglycate in past 4 weeks; astemizole in past 6 weeks, depot steroids in past 8 weeks, or immunotherapy to grass pollen in past 6 months; nasal surgery past 2 months, nasal pathology (polyp, turbinate hypertrophy, septal deviation), chronic sinusitis; recurrent conjunctivitis, or soft contact lens use; pregnant or lactating | | Proportion of days without rescue medication, mean (SD):
| | | 5) Adverse events: not clear how reported/ recorded; all AEs recorded regardless of possible relationship to study drugs | FPANS: 0.81 (0.29)
| | | | Combo: 0.82 (0.26)
| | | | 3) Patient global evaluation of efficacy of treatment:
| | | | Percentage reporting adequate control:
| | | | Nasal: 88% FPANS, 89% Combo
| | | | Eye: 75% FPANS, 82% Combo
| | | | Headache: 83% FPANS, 86% Combo
| | | | 4) Investigator global evaluation of efficacy: Not abstracted
| Dates: Start date 5/14/90, end date 8 weeks later
| | | | 5) Adverse events:
| Location: UK | | | Serious AEs: 12 pts (5%) FPANS group, 10 pts (4%) Combo group Highest reported serious AE was drowsiness: 2 FPANS, 3 Combo. Only 1 SAE in FPANS group and 4 serious AEs in Combo group were judged to be related to study medication.
| | Age: FPANS group: mean 31 (range 12–80); Combo group: mean 30 (12–66)
| Setting: 64 general practice clinics
| Type(s) of providers: Primary care | Sex: 194 M (95 FPANS, 99 Combo); 260 F (132 FPANS, 128 Combo)
| | | | Minor AEs: 295 events from 124 pts (55%) FPANS group; 286 events from 133 pts (59%) Combo group. Most AEs were symptoms of seasonal allergic rhinitis (highest reported AE was headache, 28% of FPANS group, 22% of Combo group). Only 14 (5%) of reports in FPANS group and 17 (6%) in Combo group were considered by MD to be related to study treatment.
| | Race: NR
| | Other:
Berger, Fineman, Lieberman, et al., 1999 | Design: RCT, parallel-group | No. of subjects at start: 1070 from 3 separate studies | 1) Investigator global assessment | 1) Investigator global assessment: | Quality Scoring:
| | | | Not abstracted | Population similar: Yes
| Interventions: | | | | Intervention(s) described: Yes
| 1) Azelastine nasal spray, 2 sprays per nostril bid (1.1 mg/day) + placebo capsule once per day (AZ) (n = 538) | Dropouts/withdrawals: 15 total 10 pts in AZ group: 1 intercurrent illness, 4 protocol violation, 1 withdrew consent, 1 treatment failure, and 3 pts discontinued due to AEs (1 sinusitis, 1 sneezing, 1 upper respiratory infection) 5 pts in BEC+LOR group: 2 intercurrent illness, 1 protocol violation, 2 discontinued due to AEs (1 vertigo/N/CP, 1 nasal burning) | 2) Patient global assessment: Patients asked to compare how they felt on last day of treatment (day 7) with how they felt prior to treatment on scale ranging from +2 (much better, near complete or complete symptom relief) to -2 (much worse, marked deterioration of symptoms), assessment of +1 or +2 considered improvements | 2) Patient global assessment: | Comorbidities described: Yes
| | | | Improved Study 1: AZ 80%, BEC+LOR 90% | Diagnosis by MD: Yes
| | | | | Objectively confirmed: No
| | | | Improved Study 2: AZ 77%, BEC+LOR 86% | Outcome measures valid: No
| | | | | Level of evidence: 1b
| 2) Intranasal beclomethasone dipropionate monohydrate, 2 sprays per nostril bid (336 μg/day) + loratadine 10 mg once per day (BEC+LOR) (n = 532) | | | Improved Study 3: AZ 84%, BEC=LOR 85% | Randomized: Yes
| | | | | Allocation concealed: Yes
| | | | | Double-blind: Yes
| | | | 3) Adverse events: | Blinding adequate: Yes
| | | | AZ group: 8% aftertaste, 5% headache, 3% rhinitis, 2% somnolence | Dropouts described: Yes
| | | | | Intention-to-treat: Yes
| | | | BEC=LOR group: 1% aftertaste, 6% headache, 1% rhinitis, 1% somnolence
| Duration of study treatment:
| 7 days | No. of subjects at end: 1055 | | | Notes:
| | | | | Bottles of nasal steroid looked different.
| Rescue med: chlorphenir-amine maleate 4 mg prn during washout, but not 48 hrs prior to randomization | Inclusion criteria: Age ≥ 12; documented seasonal allergic rhinitis; on monotherapy with either oral antihistamine or nasal steroid; MD-determined candidate for combination therapy due to lack of adequate symptom control; symptoms rating score ≥ 18 (range 0–50), with at least 3 symptoms of moderate or greater intensity
| | | 3) Adverse events: Not clear how reported/ recorded
| | | | | Reports results of 3 separate RCTs.
| Trial preceded by 1- to 2-week washout period (1 week for pts on oral antihistamine, 2 weeks for pts on nasal steroid) | | | | Treatment lasted only 7 days.
| Dates: 1998 spring allergy season
| | Exclusion criteria: Unable to use/tolerate nasal spray; asthma; investigational drug w/in 30 days; use of antidepressants; upper respiratory infection within 30 days; any clinically significant acute/chronic illness
| Location: US
| Setting: 71 outpatient allergy/ENT centers
| Type(s) of providers: Specialist
| | Age: Mean 35 (range 12–80)
| | Sex: 57–63% F, 37–43% M
| | Race: 81–90% white
Bertrand, Jamart, Marchal, et al., 1996 | Design: RCT, parallel-group | No. of subjects at start: 210 | 1) Investigator-assessed symptom severity | 1) Investigator-assessed symptom severity: Not abstracted | Quality Scoring:
| | | | | Population similar: Yes
| Interventions: | Dropouts/withdrawals: 39 total 7 CTZ group (1 inefficacy, 2 AEs, 4 protocol violation/personal reasons); 19 PER group (2 inefficacy, 9 AEs, 8 protocol violation/personal reasons); 13 COM group (4 AEs, 9 protocol violation/personal reasons) | | | Intervention(s) described: Yes
| 1) Pseudoephedrine 120 mg (extended-release) bid + cetirizine 5 mg bid (n = 70) (COM group) | | 2) Patient-assessed symptom severity: blocked nose, sneezing, runny nose, itchy nose, and itchy eyes graded on scale of 0 (no symptoms) to 4 (severe symptom interfering with daily activities and/or sleep) at end of every day throughout trial | 2) Patient-assessed symptom severity: | Comorbidities described: No
| | | | Figure 1–5, daily symptom scores per group: | Diagnosis by MD: Yes
| | | | | Objectively confirmed: Yes
| | | | Nasal obstruction: P < 0.0001, COM vs. CTZ; P = 0.004, COM vs. PER; P = 0.128, CTZ vs. PER | Outcome measures valid: No
| | | | | Level of evidence: 1b
| 2) Pseudoephedrine 120 mg (extended-released) bid (n = 70) (PER group) | | | | Randomized: Yes
| | | | Rhinorrhea: P = 0.174, COM vs. CTZ; P = 0.001, COM vs. PER; P = 0.072, CTZ vs. PER | Allocation concealed: Not described
| | No. of subjects at end: 210 included in analysis | | | Double-blind: Yes
| 3) Cetirizine 5 mg bid (n = 70) (CTZ group) | | | Sneezing: P = 0.790, COM vs. CTZ; P = 0.021, COM vs. PER; P = 0.012, CTZ vs. PER | Blinding adequate: Yes
| | | | | Dropouts described: Yes
| | Inclusion criteria: Perennial allergic rhinitis of at least 1 year duration; positive skin or RAST allergy test; presence of nasal obstruction, sneezing, and rhinorrhea | | | Intention-to-treat: Yes
| Duration of study treatment: | | 3) Investigator global assessment | Nasal itching: P = 0.384, COM vs. CTZ; P = 0.158, COM vs. PER; P = 0.018, CTZ vs. PER
| 3 weeks
| | | | | Note: Double-dummy blinding technique employed.
| No mention of rescue med | | 4) Adverse events: Not clear how reported/ recorded | Eye itching: P = 0.204, COM vs. CTZ; P = 0.080, COM vs. PER; P = 0.006, CTZ vs. PER
| Pre-trial washout period ranged from 2 days to 6 weeks, depending on pre-trial medication
| | Exclusion criteria: Pollen-sensitive patients excluded during pollen season; infectious rhinitis; nasal polyposis; nasal septal deviation; dermatitis; infections requiring antibiotic treatment; pregnancy; childbearing potential; breastfeeding
| | | | 3) Investigator global assessment:
| | | | Not abstracted
| Dates: NR | | | 4) Adverse events:
| | | | 31 CTZ (6 somnolence, 4 bronchitis, 3 headache, 2 asthenia, 1 each insomnia and nervousness)
| Location: 8 centers in Belgium and Luxembourg
| | | | 38 PER (7 insomnia, 6 dry mouth, 6 nausea, 5 headache, 4 asthenia, 3 somnolence, 1 nervousness)
| Setting: Outpatient | Age: 12–65
| Type(s) of providers: | Sex: 97 M, 113 F | | 35 COM (9 somnolence, 8 headache, 4 each asthenia, dry mouth, nervousness, and insomnia)
| Otolaryngologist
| | Race: NR
| | Other:
Bronsky, Boggs, Findlay, et al., 1995 | Design: RCT, parallel-group | No. of subjects at start: 879 | 1) Investigator-assessed symptom severity: rhinor-rhea, nasal stuffiness, nasal itching, sneezing, burning or itching eyes, watering eyes, red eyes, and itching of the ears or palate graded on scale of 0 (none) to 3 (severe) during clinic visits on days 4, 8, and 15 of the treatment period. | 1) Investigator-assessed symptom severity: Not abstracted | Quality Scoring:
| | | | | Population similar: Yes
| Interventions: | Dropouts/withdrawals: | | | Intervention(s) described: Yes
| 1) Loratadine 10 mg + pseudoephedrine 240 mg (extended-release) once per day (Combo group) (n = 212) | 5 dropouts prior to treatment 54 total discontinuations 11 Combo group (5 treatment failure, 4 AEs, 1 noncompliance, 1 lost to follow-up) | | 2) Patient-assessed symptom severity: | Comorbidities described: No
| | | | No quantitative data reported. Results described as “similar” to those of investigator assessment of symptom severity. | Diagnosis by MD: Yes
| | | | | Objectively confirmed: Yes
| | | | | Outcome measures valid: No
| | | | | Level of evidence: 1b
| 2) Loratadine 10 mg once per day (LOR group) (n = 212) | 17 LOR group (12 treatment failure, 1 AEs, 4 noncompliance) 13 PSE group (4 treatment failure, 9 AEs) | | Total symptom score reduction significantly greater (P ≥ 0.05) in Combo group than in other three treatment groups. | Randomized: Yes
| | | | | Allocation concealed: Not described
| 3) Pseudoephedrine 120 mg (extended-release) bid (PSE group) (n = 211) | | | | Double-blind: Yes
| | 13 placebo group (11 treatment failure, 2 AEs) | | Total symptom score reduction also greater in LOR group than in placebo group (P = 0.04). Repeated measures analysis P ≤ 0.01 in Combo and LOR groups compared to placebo (plus Combo vs. PSE group). | Blinding adequate: Yes
| | | 2) Patient-assessed symptom severity: | | Dropouts described: Yes
| | | | | Intention-to-treat: No
| 4) Placebo (n = 212) | No. of subjects at end: 874 included in safety analysis, 847 in efficacy analysis (27 protocol violations) | Patients kept daily diary of symptom severity (presumably using same scale as above, though this is not stated).
| Duration of study treatment: | | | | Notes:
| 2 weeks | | | | Double-dummy blinding technique employed.
| | | | Similar results for nasal and nonnasal symptom scores.
| No mention of rescue med | Inclusion criteria: Seasonal allergic rhinitis for at least 1 year, confirmed by skin test to ragweed or other prevalent seasonal allergens; total symptom score ≥ 11 on 50% of days during placebo phase; ≥ 80% compliance with placebo phase drug
| | | 3) Investigator global assessment of response to treatment | | Pollen counts determined twice weekly during trial at all study sites.
| Trial preceded by washout period ranging from 1 day to 1 month (depending on pre-trial medication) and a 4- to 7-day placebo run-in phase (baseline) | | | 3) Investigator global assessment of response to treatment: Not abstracted
| | | 4) Patient global assessment of response to treatment: graded on scale of 1 (excellent) to 5 (treatment failure) during clinic visits on days 4, 8, and 15 of the treatment period. | 4) Patient global assessment of response to treatment:
| | | | Excellent or good response
| | | | 125 (61%) Combo, 106 (52%) PSE, 95 (47%) LOR, 73 (35%) placebo
| Dates: Fall allergy season, 1989 | Exclusion criteria: Immuno-therapy within 6 months; asthma requiring steroids; multiple drug allergies; nonresponders or previous reaction to anti-histamines; upper respiratory infection, investigational drug within 1 month; pregnancy/ lactation; significant medical condition
| | | | 5) Adverse events:
| Location: US | | | 124 Combo (55 headache, 17 dry mouth, 14 pharyngitis, 13 somnolence, 12 insomnia, 11 nervousness)
| Setting: 14 outpatient allergy centers | | 5) Adverse events: Not clear how reported/ recorded
| | | | 102 LOR group (50 headache, 18 pharyngitis, 9 somnolence, 7 dry mouth, 1 each insomnia and nervousness)
| Type(s) of providers: Allergists
| | | | 133 PSE group (57 headache, 19 insomnia, 16 dry mouth, 11 pharyngitis, 10 somnolence, 8 nervousness)
| | Age: Range 12–82, median 28–30
| | Sex: Of 847 pts, 395 (47%) male, 452 (53%) female | | 100 placebo group (60 headache, 15, pharyngitis, 8 somnolence, 6 dry mouth, 1 nervousness)
| | Race: Of 847 pts, 747 (88%) white, 43 (5%) black, 57 (7%) other
| | | | More AEs in Combo and PSE groups than in placebo group, P ≤ 0.05
| | Other: | | Hyperkinesia higher in PSE group compared to placebo or loratadine.
Brooks, Francom, Peel, et al., 1996 | Design: RCT, parallel-group | No. of subjects at start: 60 | 1) Patient-assessed symptom severity: congestion, running/ blowing, sneezing, itching, and eye symptoms graded twice daily on scale of 1 (no symptoms) to 5 (maximum symptoms) | 1) Patient-assessed symptom severity: | Quality Scoring:
| | | | Mean changes shown in Figures 1–5 for 3 segments (days 2–3, days 5–7, days 8–10). | Population similar: Not adequately described
| Interventions: | Dropouts/withdrawals: NR
| 1) Loratadine 10 mg once per day + beclomethasone nasal spray, 2 sprays (about 84 μg) in each nostril twice a day (LOR+BEC) (n = 20) | | | | Intervention(s) described: Yes
| | No. of subjects at end: 60 | | | Comorbidities described: Yes
| | | | Overall similar improvement with BEC and LOR+BEC for congestion, eye symptoms, and runny nose. LOR+BEC better than BEC alone for itching (p = 0.13) and sneezing (p = 0.589), but was not statistically significant. LOR+BEC was significantly better than LOR alone (p < 0.001) for all symptoms. | Diagnosis by MD: Yes
| | Inclusion criteria: History of ragweed seasonal allergic rhinitis with strongly positive skin tests | | | Objectively confirmed: Yes
| | | | | Outcome measures valid: No
| | | | | Level of evidence: 2b
| 2) Loratadine 10 mg once per day (LOR) (n = 20) | | 2) Patient global evaluatin of efficacy of treatment: on last day of study, patients asked to grade overall effectiveness of treatment as “excellent,” “good,” “fair,” or “poor” | | Randomized: Yes
| | Exclusion criteria: Evidence of significant complicating disease on history, physical, or laboratory testing; pregnancy | | | Allocation concealed: Not described
| 3) Beclomethasone nasal spray, 2 sprays (about 84 μg) in each nostril twice a day (BEC) (n = 20) | | | | Double-blind: No
| | | | | Blinding adequate: Not applicable
| | Age: Reported as “roughly comparable” | | 2) Patient global evaluation of efficacy of treatment: | Dropouts described: Yes
| | | | | Intention-to-treat: Can't determine
| Duration of study treatment: | | | LOR+BEC superior to BEC alone (p = 0.042), and to LOR alone (p = 0.001). No difference between BEC and LOR alone (p = 0.122).
| 9 days (2-week study period included 5-day no-treatment run-in period) | Sex: 10M/10F LOR
| | 7M/13F BEC
| | 7M/13F LOR+BEC group | | | Notes:
| | | | | Double-dummy blinding technique employed.
| Patients instructed not to take any other drugs that might affect their hay fever during study period | Race: NR | | Excellent: 6 BEC, 4 LOR, 11 LOR+BEC
| | Other: | | Good: 9 BEC, 5 LOR, 8 LOR+BEC | No sample size estimate or adverse events reported.
| | | | Fair: 4 BEC, 9 LOR, 1 LOR+BEC
| | | | Poor: 1 BEC, 2 LOR, 0 LOR+BEC
| Trial preceded by 5-day no-treatment run-in period
| Dates: Aug 18 - Sept 1 (year unknown)
| Location: US (Kalamazoo, MI)
| Setting: Pharmaceutical (Upjohn) research clinic
| Type(s) of providers: NR
Brooks and Karl, 1988 | Design: RCT, parallel-group | No. of subjects at start: 28 | 1) Patient-assessed symptom severity: discrete symptoms graded 4 times per day on different scales, with 0 always indicating no symptoms and highest number always indicating maximum symptoms; symptoms graded were: congestion (0–8); drainage/postnasal drip (0–3); running nose/ blowing (0–4); sneezing in last 1/2 hour (0–4); hay fever-related itching (0–4); hay fever-related eye symptoms (0–4) | 1) Patient-assessed symptom severity: | Quality Scoring:
| | | | Mean daily symptoms scores show in Figures 1–4. No values reported. P-values are based on comparison of mean daily totals. | Population similar: Yes
| Interventions: | Dropouts/withdrawals: 1 | | | Intervention(s) described: Yes
| 1) Terfenadine 60 mg bid + flurbiprofen 100 mg tid (n = 14) | | | | Comorbidities described: No
| | No. of subjects at end: 27 | | | Diagnosis by MD: Yes
| | | | | Objectively confirmed: Yes
| | Inclusion criteria: “Credible” history of seasonal rhinitis and positive skin test | | P-values significant ( < 0.05) on day 3 (congestion, P = 0.043; sneeze score, P = 0.026) and day 4 (running/blowing nose, P = 0.006) | Outcome measures valid: No
| 2) Terfenadine 60 mg bid (n = 14) | | | | Level of evidence: 2b
| | | | | Randomized: Yes
| | | | | Allocation concealed: Not described
| Duration of study treatment: | Exclusion criteria: Significant complicating disease; aspirin sensitivity
| 1 week | | | 2) Adverse events: | Double-blind: No
| | | | Several volunteers reported side effects, mostly moderate gastrointestinal symptoms. Not quantified further. | Blinding adequate: Not applicable
| No mention of rescue med
| | Age: | | | Dropouts described: Yes
| Trial preceded by 1-week run-in period, during which patients first took the symptomatic treatment of their choice (first 1/2 of run-in week), then terfenadine 60 mg bid (second 1/2 of run-in week) | Terfenadine + flurbiprofen: mean 36.8 (SD 10.3) | | | Intention-to-treat: Yes
| | Terfenadine alone: 37.9 (SD 9.7) | | One dropout after day 1 after experiencing cramps & nausea (received terfenadine + flurbiprofen).
| | | | | Notes:
| | Sex: | 2) Adverse events: not clear how reported/ recorded | | Patients assigned to 1 of 4 strata based on total symptom score, then randomized.
| | Terfenadine + flurbiprofen: 5M/9F
| | Terfenadine alone: 9M/5F
| Dates: NR | Race: NR | | | P-values are based on comparison of mean daily totals. No overall assessment of treatment (e.g., pre- and post-treatment summary scores). Analysis is incorrect. Time period of treatment may be too short.
| Location: Bronson Clinical Research Unit, Kalamazoo MI
| Setting: Outpatient
| Type(s) of providers: NR
Bukstein, Biondi, Blumenthal, et al., 1996 | Design: RCT, parallel-group | No. of subjects at start: 371 | 1) Patient-assessed symptom severity: stuffy nose, runny nose, itchy nose, sneezing, and overall nasal symptoms graded daily on scale of 0 (none) to 4 (very severe) | 1) Patient-assessed symptom severity: | Quality Scoring:
| | | | Symptom summary mean (SD): | Population similar: Yes
| Interventions: | Dropouts/withdrawals: | | Nedocromil + astemizole: 1.02 (0.78), p < 0.001 vs. placebo, p < 0.01 vs. astemizole | Intervention(s) described: Yes
| 1) Nedocromil sodium 1% nasal spray (1 spray per nostril, 4 times per day) + astemizole (one 30-mg dose on Day 1, one 20-mg dose on Day 2, and one 10-mg dose per day thereafter) (n = 147) | 20 dropouts from treatment failure (12), protocol violation/ noncompliance (6), other (2) | | | Comorbidities described: No
| | | | | Diagnosis by MD: Yes
| | | | Astemizole: 1.21 (0.84), p < 0.001 vs. placebo | Objectively confirmed: Yes
| | | | | Outcome measures valid: No
| | 6 not included in analysis (4 withdrawn from poor use of treatment, 1 upper respiratory infection, 1 travel out of pollen area) | | Placebo: 1.49 (0.90) | Level of evidence: 1b
| | | 2) Patient-assessed sleep disturbance due to rhinitis: graded daily on scale of 0 to 2 (not described) | | Randomized: Yes
| | | | Mean change from baseline (SD): | Allocation concealed: Not described
| | | | Nedocromil + astemizole: -0.39 (0.76), p < 0.001 vs. placebo, p < 0.01 vs. astemizole
| 2) Astemizole (as above) + placebo nasal spray (n = 150) | | | | Double-blind: Yes
| | | | | Blinding adequate: Yes
| | No. of subjects at end: 365 | 3) Use of rescue med (recorded by patients in daily diaries) | Astemizole: -0.22 (0.68), p < 0.001 vs. placebo | Dropouts described: Yes
| 3) Double-dummy placebo (n = 74) | | | | Intention-to-treat: Yes
| | Inclusion criteria: Seasonal allergic rhinitis to ragweed for 2 years requiring continuous treatment; positive skin test | | Placebo: +0.21 (0.77)
| Duration of study treatment: 4 weeks | | 4) Investigator assessment of clinical signs of rhinitis | 2) Patient-assessed sleep disturbance due to rhinitis: | Note: Pollen counts measured daily at each site.
| | | | Nedocromil + astemizole 0.58 (0.63), p = 0.11 vs. placebo
| Pseudoephedrine and artificial tears permitted “for relief of intolerable symptoms” | Exclusion criteria: Women of childbearing potential; sinusitis; polyposis; immunotherapy; recent astemizole, corticosteroids, cromolyn sodium, short-acting antihistamines, decongestants, vasoconstrictors, or theophylline
| | | 5) Investigator global assessment of treatment efficacy | Astemizole 0.69 (0.62), p < 0.18 vs. placebo
| | | | Placebo 0.73 (0.61)
| Trial preceded by washout period ranging from 16 hours to 4 weeks (depending on pre-trial medication) and 1-week baseline period timed to coincide with start of local ragweed pollen season
| | | 6) Patient global assessment of treatment efficacy: graded as “good” (symptoms fully or mostly controlled), “fair” (symptoms fairly well controlled), or “poor” (symptoms controlled poorly or not at all) during clinic visits at 1 and 4 weeks | 3) Use of rescue med (pseudo-ephedrine) (tabs/day):
| | | | Nedocromil + astemizole 0.34 (0.86), p = 0.02 vs. astemizole
| | Age: 12–64; means 33.9 (nedocromil + astemizole), 35.1 (astemizole), and 31.8 (placebo)
| | | | Astemizole 0.55 (1.03)
| | | | Placebo 0.68 (1.15)
| Dates: Local ragweed season | Sex: 279 (76%) male; 86 (44%) female | | 4) Investigator assessment of clinical signs of rhinitis: Not abstracted
| Location: US
| | Race: NR | | 5) Investigator global assessment of treatment efficacy: Not abstracted
| Setting: 13 outpatient sites
| | Other: | 7) Adverse events: Not clear how reported/ recorded
| Type(s) of providers: | | | 6) Patient global assessment of treatment efficacy:
| Allergists
| | | | Symptoms controlled fully/mostly:
| | | | Nedocromil + astemizole: 64%, p < 0.001 vs. placebo, p < 0.01 vs. astemizole alone
| | | | Astemizole: 47%, p < 0.01 vs. placebo
| | | | Placebo: 28%
| | | | 7) Adverse events:
| | | | 63 (43%) Nedocromil + astemizole
| | | | 52 (35%) Astemizole
| | | | 20 (27%) Placebo
| | | | Trend towards more headache in combo group (p = 0.058)
Busse, Janssens, and Eisen, 1996 | Design: RCT, parallel-group | No. of subjects at start: 1015 | 1) Patient-assessed symptom severity: nasal congestion, rhinorrhea, nasal itching, sneezing, itching eyes, lacrimation, and redness of eyes graded daily using scale of 0 (absent) to 3 (severe) | 1) Patient-assessed symptom severity: | Quality Scoring:
| | | | Reported mean change in Area Under Curve (AUC) from baseline. Statistical significance calculated versus placebo. | Population similar: Yes
| Interventions: | Dropouts/withdrawals: 38 (7 levocabastine, 5 levocabastine-D, 12 oxymetazoline, 14 placebo | | | Intervention(s) described: Yes
| 1) Nasal spray containing levocabastine (0.5 mg/ml) and oxymetazoline (0.5 mg/ml), 2 sprays per nostril twice per day (n = 251) | | | | Comorbidities described: Yes
| | | | | Diagnosis by MD: Yes
| | | | Total all symptoms (mean change AUC): | Objectively confirmed: Yes
| | No. of subjects at end: 977 | | | Outcome measures valid: No
| | | | -1.7 placebo | Level of evidence: 1b
| | Inclusion criteria: Age 18–60 with 1-year history of seasonal allergic rhinitis; positive skin test to ragweed allergen (= 3 mm); moderate-severe nasal congestion and at least one other moderate-severe nasal symptom | | -3.3 levocabastine-D *** | Randomized: Yes
| 2) Levocabastine nasal spray, 2 sprays per nostril twice per day (n = 255) | | 2) Investigator-assessed symptom severity | -3.5 levocabastine *** | Allocation concealed: Not described
| | | | -1.8 oxymetazoline
| | | | *** P = 0.001 compared to placebo | Double-blind: Yes
| | | 3) Patient global evaluation of efficacy: effect of treatment on overall severity of rhinitis graded at end of trial as “excellent,” “good,” “fair,” “poor,” or “worse” | | Blinding adequate: Yes
| 3) Oxymetazoline nasal spray, 2 sprays per nostril twice per day (n = 252) | | | 2) Investigator-assessed symptom severity: Not abstracted | Dropouts described: Yes
| | | | | Intention-to-treat: Yes
| | Exclusion criteria: Other forms of rhinitis or sinusitis; moderate-severe asthma; serious comorbid disease; systemic steroids within 1 month; topical steroids or sodium cromoglycate within 2 weeks; decongestants or antihistamines within 3 days; astemizole within 6 weeks; any use of tricyclic antidepressants, MAOI, other CNS depressants; antihypertensive drugs; change in immunotherapy in past 6 months; pregnant or lactating; investigational drug within 30 days; hypersensitivity to antihistamines; travel outside of pollen area for longer than 1 day | | 3) Patient global evaluation of efficacy:
| 4) Placebo nasal spray (n = 257) | | | Report of excellent or good: | Note: Data pooled from 3 RCTs sharing a common protocol.
| | | | 26% placebo
| | | | 52% levocabastine-D
| Duration of study treatment: | | 4) Investigator global evaluation of efficacy | 44% levocabastine
| 1 week | | | 39% oxymetazoline
| No mention of rescue med | | 5) Adverse events: spontaneously reported during clinic visits (after 3 days of treatment and at end of week) | 4) Investigator global evaluation of efficacy: Not abstracted
| No pre-trial washout period described; patients who had taken following drugs, in time frames indicated, were excluded: systemic cortico-steroids (1 month); topical corticosteroids or sodium cromoglycate (2 weeks); astemizole (6 weeks); other decongestants or anti-histamines (3 days)
| | | | 5) Adverse events:
| | | | 32% placebo
| | | | 40% levocabastine-D
| | | | 30% levocabastine
| | | | 40% oxymetazoline
| | | | Headache and application site reactions most frequently reported AEs
| | Age: Eligible 18–60; mean (yrs) reported per group | | Headache:
| | | | 31 placebo
| Dates: 1990 fall ragweed pollen season | 36.5 placebo | | 26 levocabastine-D
| | 35.8 levocabastine-D | | 15 levocabastine
| | 36.5 levocabastine | | 31 oxymetazoline
| Location: US and Canada | 35.7 oxymetazoline
| | | | Application site reactions:
| Setting: Outpatient | Sex: | | 15 placebo
| | 167M/90F placebo | | 23 levocabastine-D
| Type(s) of providers: specialists | 173M/78F levocabastine-D | | 17 levocabastine
| | 168M/87F levocabastine | | 34 oxymetazoline
| | 161M/91F oxymetazoline
| | Race: NR
| | Other:
Diamond, Gerson, Cato, et al., 1981 | Design: RCT, parallel-group | No. of subjects at start: NR | 1) Nasal airway resistance: measured every hour using two | 1) Nasal airway resistance: Not abstracted | Quality Scoring:
| | | | | Population similar: Not adequately described
| Interventions: (34–40 pts per group) | Dropouts/withdrawals: NR
| | | Validyne MP45 transducers and an oscilloscope | 2) Patient-assessed symptom severity: | Intervention(s) described: Yes
| 1) Triprolidine 2.5 mg + pseudoephedrine 60 mg, given in a single tablet 3 times per day (n = NR) | No. of subjects at end: 151 | | Nasal congestion: changes in mean scores shown in Figure 2; combination caused greater reduction than placebo at 6, 7, and 8 hours (P ( 0.025), and greater reduction than tripolidine alone at 6 and 8 hours (P ( 0.025) | Comorbidities described: No
| | | | | Diagnosis by MD: Yes
| | Inclusion criteria: Allergic rhinitis by symptoms, scratch test, and nasal airway resistance | | | Objectively confirmed: Yes
| | | 2) Patient-assessed symptom severity: nasal congestion, sneezing, rhinorrhea, lacrimation, and itching of the eyes, nose, and throat graded on scale of 1–6 (with higher numbers indicating increasing severity) every hour, at time of NAR assessment | | Outcome measures valid: No
| | | | | Level of evidence: 2b
| 2) Triprolidine 2.5 mg, 3 times per day (n = NR) | | | | Randomized: Yes
| | Exclusion criteria: Nasal defect or pathology | | | Allocation concealed: Not described
| | | | Symptom complex score: changes shown in Figure 3; combination (P ( 0.025) and triprolidine had greatest reduction in mean scores
| 3) Pseudoephedrine 60 mg, 3 times per day (n = NR) | | | | Double-blind: Yes
| | Age: 18 or older | | | Blinding adequate: Yes
| | | | | Dropouts described: No
| 4) Placebo, 3 times per day (n = NR) | Sex: 100 M, 51 F | | | Intention-to-treat: Can't determine
| | | | 3) Adverse events:
| | Race: NR | | Drowsiness most frequently reported AE due to antihistamine; few reports of jitteriness due to decongestant
| Duration of study treatment:
| 1 day, from 10:00 AM to 6:00 PM (drugs administered and outcomes measured on-site) | Other: | 3) Adverse events: | | Notes:
| | | Patients queried every hour about the occurrence of adverse events in general and specifically about whether or not they had experienced dizziness, drowsiness, nervousness, or nausea | | Patients assessed for a total of 8 hours over the course of a single day.
| No mention of rescue med
| Patients instructed to refrain from antihistamines for 48 hours and nasal decongestants for 16 hours before reporting for treatment
| | | | | Number of patients in each treatment group not reported: stated only that there were 34– per group.
| Dates: Grass and ragweed season (Apr-Jun and Aug-Oct)
| Location: US, Kentucky
| Setting: Outpatient (academic medical center)
| Type(s) of providers: NR
Dockhorn, Aaronson, Bronsky, et al., 1999 | Design: RCT, parallel-group, nonallergic and allergic patients stratified separately | No. of subjects at start: 553 (279 allergic, 274 nonallergic) | 1) Patient-assessed symptom severity: rhinorrhea, congestion, and sneezing graded daily on scale of 1 (none) to 5 (unbearable); duration of rhinorrhea assessed by having patient record each day the number of hours nose ran between 8 AM and 8 PM | 1) Patient-assessed symptom severity: | Quality Scoring:
| | | | Mean rhinorrhea severity and duration reduced in all three treatment groups compared to placebo (values shown in figures, P < 0.05). Combination therapy caused 45% reduction in rhinorrhea severity and 47% reduction in duration from baseline. | Population similar: Yes
| | | | | Intervention(s) described: Yes
| | Dropouts/withdrawals: 43 total | | | Comorbidities described: No
| Interventions: | 525 completed Part II | | | Diagnosis by MD: Yes
| 1) Ipratropium bromide nasal spray 0.03% (42 μg per nostril tid) + beclomethasone dipropionate nasal spray (84 μg per nostril bid) (n = 207) | 510 completed Part III | | | Objectively confirmed: Yes
| | 17 (3%) dropouts due to AEs | | | Outcome measures valid: Yes
| | 18 (3%) dropouts due to administrative reasons | | | Level of evidence: 1b
| | | | | Randomized: Yes
| | 3 protocol violations | | Subgroup analysis of patients with substantial reduction: | Allocation concealed: Yes
| | 5 lack of efficacy | | | Double-blind: Yes
| 2) Ipratropium bromide nasal spray 0.03% (42 μg per nostril tid) (n = 103) | | | Rhinorrhea severity reduction: 74% combination, 57% ipratropium, 64% beclomethasone, 47% placebo. | Blinding adequate: Yes
| | No. of subjects at end: 510 | 2) Investigator global assessment of efficacy | | Dropouts described: Yes
| | | | | Intention-to-treat: Can't determine
| | Inclusion criteria: Allergic rhinitis (positive skin test and history) or nonallergic rhinitis (negative skin test)
| 3) Beclomethasone dipropionate nasal spray (84 μg per nostril bid) (n = 109) | | 3) Patient global assessment of efficacy: graded on weekly basis using scale of 1 (no symptom control) to 4 (excellent symptom control); separate assessments for rhinorrhea, nasal congestion, and sneezing | Rhinorrhea duration reduction: 66% combination, 50% ipratropium, 54% beclomethasone, and 38% placebo.
| | | | | Notes:
| | | | Combination more effective than ipratropium or placebo in reducing severity of nasal congestion or sneezing, P < 0.05. | Trial had 4 phases:
| 4) Placebo nasal sprays (n = 106) | Exclusion criteria: Complete nasal obstruction; abnormal sinus film; upper respiratory infection; rhinitis medicamentosa; glaucoma; BPH | | | Phase I: 1-week run-in period during which patients took no medication (baseline values from this period);
| Duration of study treatment:
| 2 weeks (Phase III of trial, see Notes) | | | Nasal congestion reduction: 31% combination, 23% ipratropium, and 23% placebo. | Phase II: 2-week RCT comparing monotherapies (ipratropium vs. beclomethasone vs. placebo);
| | Age: 8–75 (mean 36.7, SD 16.7, 18% age 8–18)
| No mention of rescue med
| | | Assessed using the SF-36 to treatment | Sneezing reduction: 37% combination, 26% ipratropium, and 26% placebo.
| Multiple-phase trial - see Notes | Sex: 63% F, 37% | Health Survey and the Rhinoconjunctivitis Quality of Life Questionnaire (RQLQ), administered at baseline and at end of treatment (2 weeks) | 26% ipratropium, and 26% placebo. | Phase III: 2-week RCT comparing combination therapy vs. monotherapies vs. placebo (described here);
| | Race: 90% white, 2% black, 8% other | | 2) Investigator global assessment of efficacy: Not abstracted
| Dates: NR
| Location: US | Other: | | 3) Patient global assessment of efficacy: | Phase IV: 1-week washout period, during which patients were monitored for signs of rebound of nasal symptoms.
| Setting: 10 outpatient clinics | | 5) Adverse events: | Good or excellent control of rhinorrhea:
| Type(s) of providers: | | Patients queried about adverse events at each clinic visit; AEs recorded regardless of possible relation to treatment | 73% combination, 65% ipratropium, 68% beclomethasone, 51% placebo | Double-dummy blinding technique employed.
| Allergy specialists and general practitioners | | | All three active treatments rated as more effective than placebo for nasal congestion, P < 0.05. Combination more effective than placebo for control of sneezing, P < 0.05.
| | | | 4) Quality of life:
| | | | RQLQ scores improved for all 4 treatments compared to baseline, P < 0.05, combined > ipratropium or placebo.
| | | | SF-36 less able to discriminate between treatment groups, although combination treatment superior to ipratropium for 3 domains (role functioning, vitality, health transition)
| | | | 5) Adverse events:
| | | | 56 (27%) combined (33 possibly drug-related)
| | | | 31 (30%) ipratropium (10 possibly drug-related)
| | | | 27 (25%) beclomethasone (10 possibly drug-related)
| | | | 32 (30%) placebo (9 possibly drug-related)
| | | | Most common AEs were pain, headache, nasal dryness, and epistaxis
Dockhorn, Williams, and Sanders, 1996 | Design: RCT, parallel-group | No. of subjects at start: 702 | 1) Patient-assessed symptom severity: runny nose; sneezing; itchy nose/throat; tearing, itching, or redness of eyes; nasal congestion; and mouth breathing graded 3 times per day on scale of 0 (absent) to 5 (very severe) | 1) Patient-assessed symptom severity: | Quality Scoring:
| | | | Mean diary symptom score (no SD): | Population similar: Yes
| Interventions: | Dropouts/withdrawals: 56 total | | 10.3 combination, 12.3 acrivastine, | Intervention(s) described: Yes
| 1) Acrivastine 8 mg + pseudoephedrine 60 mg, given in one capsule, 4 times per day (n = 176) | 5% combination, 10% placebo 20 due to AEs | | 11.8 pseudoephedrine, 13.4 placebo | Comorbidities described: No
| | | | P < 0.001 combo vs. acrivastine | Diagnosis by MD: Yes
| | 19 due to worsening allergy symptoms (9 placebo, 5 acrivastine, 4 pseudoephedrine, 1 combination) | | P = 0.002 combo vs. pseudoephedrine | Objectively confirmed: Yes
| | | | P < 0.001 combo vs. placebo | Outcome measures valid: No
| | | | | Level of evidence: 1b
| 2) Acrivastine 8 mg, 4 times per day (n = 175) | | | Mean nasal congestion score (no SD): | Randomized: Yes
| | 7 protocol violations | | 3.8 combination, 4.7 acrivastine, 4.1 pseudoephedrine, 4.9 placebo | Allocation concealed: Not described
| | 6 lost to follow-up
| 3) Pseudoephedrine 60 mg, 4 times per day (n = 177) | 4 withdrew consent | 2) Investigator global assessment of efficacy | P < 0.001 combo vs. acrivastine | Double-blind: Yes
| | | | | Blinding adequate: Yes
| | No. of subjects at end: 646 | | Mean allergy symptoms score (no SD): | Dropouts described: Yes
| 4) Placebo (n = 174) | | 3) Adverse events: | 6.5 combination, 7.6 acrivastine, 7.6 pseudoephedrine, 8.6 placebo | Intention-to-treat: No
| Duration of study treatment: | Inclusion criteria: Seasonal allergic rhinitis (2-year history), positive skin test to ragweed, | Evaluated by spontaneous reports of AEs and changes in vital signs | P < 0.001 combo vs. pseudoephedrine
| 2 weeks | | | | Notes:
| No mention of rescue med | Exclusion criteria: Anatomic nasal obstruction; vasomotor rhinitis; women of childbearing potential not on birth control; use of antihistamines/nasal decongestants/MAOIs, cromolyn sodium, or steroids | | 2) Investigator global assessment of efficacy: Not abstracted
| No pre-trial washout period described (1-day baseline phase); individuals taking antihistamines, nasal decongestants, MAOIs, cromolyn sodium, or corticosteroids within specified times prior to study (based on half-lives of respective drugs) were excluded | | | 3) Adverse events:
| | | | Combination therapy: 9% dry mouth, 7% somnolence, 4% nervousness, 4% insomnia
| | Age: 11–73, mean age 32 | | 20 dropouts due to AEs (6 combination, 5 acrivastine, 6 pseudoephedrine, 3 placebo)
| | Sex: 53–60% female
| | Race: 86–90% white
| Dates: NR (during ragweed season) | Other:
| Location: US
| Setting: 13 outpatient clinics
| Type(s) of providers: NR
Drouin, Yang, Horak, et al., 1995 | Design: RCT, parallel-group | No. of subjects at start: 156 | 1) Patient-/investigator-assessed symptom severity: nasal discharge, nasal stuffiness, nasal itching, sneezing, itching eyes, tearing, redness of eyes, and ear/palate itching graded daily (by patients) and on days 3 and 7 (by investigator) on scale of 0 (none) to 3 (severe, very disturbing most of the time) | 1) Patient-/investigator-assessed symptom severity: | Quality Scoring:
| | | | | Population similar: Yes
| Interventions: | Dropouts/withdrawals: 2 (1 per group) failed to return for follow-up visit. | | Improvement in total symptom score (“improvement” not defined; mean scores not reported): | Intervention(s) described: Yes
| 1) Beclomethasone dipropionate nasal spray (100 μg in each nostril twice daily) + loratadine 10 mg once per day (Combo) (n = 76) | | | | Comorbidities described: No
| | | | | Diagnosis by MD: Yes
| | | | Day 3: 54% Combo, 46% BEC alone (P = 0.08) | Objectively confirmed: Yes
| | No. of subjects at end: 154 | | | Outcome measures valid: No
| | | | Day 7: 68% Combo, 58% BEC alone (P < 0.05) | Level of evidence: 1b
| | Inclusion criteria: Moderately severe seasonal allergic rhinitis with positive skin test; patient on immunotherapy must be on stable dose for at least 1 month prior to study | | | Randomized: Yes
| 2) Beclomethasone dipropionate nasal spray (100 μg in each nostril twice daily) (BEC) (n = 78) | | | | Allocation concealed: Not described
| | | | 2) Patient global evaluation of efficacy: | Double-blind: Yes
| | | | Combo: | Blinding adequate: Yes
| | | | Excellent 39% | Dropouts described: Yes
| Duration of study treatment: | | 2) Patient global evaluation of efficacy: | Good 51% | Intention-to-treat: Yes
| 1 week | Exclusion criteria: Severe asthma or COPD; nasal polyps or other structural abnormality; pregnant, lactating or not on medically accepted birth control; significant comorbid disease that might interfere with treatment evaluation | | Fair 3%
| | | graded on last day of treatment on scale of 1 (excellent) to 5 (treatment failure) | Poor or Failure 7%
| No mention of rescue med | | | | Note: Not clear whether symptom data reported was assessed by patients or investigators.
| | | | BEC alone:
| Trial preceded by washout period ranging from 24 hours to 1 month, as follows: topical or oral decongestants (24 hours); oral antihistamines (48 hours, except astemizole [1 month]); intranasal steroids (72 hours); cromolyn sodium (1 week); systemic or orally inhaled steroids (1 month) | | | Excellent 19%
| | | | Good 54%
| | | 3) Investigator global evaluation of efficacy | Fair 18%
| | | | Poor or Failure 9%
| | Age: 18–65
| | Mean 31 yrs Loratadine + Beclomethasone | 4) Adverse events: recorded by patients in study diaries and elicited by investigators during clinic visits on days 3 and 7 | Good to excellent response, 90%
| | | | Combo vs. 73% BEC, P < 0.05.
| | Mean 32 yrs Beclomethasone
| | | | 3) Investigator global evaluation of efficacy: Not abstracted
| | Sex:
| Dates: NR | 48 M/33 F Loratadine + Beclomethasone | | 4) Adverse events:
| | 38 M/40 F Beclomethasone | | 23 pts (30%) Combo
| Location: Austria, Belgium, Canada, Germany, England | Note: Sex had significant treatment-by-center interaction (P = 0.03) but was determined to have no impact on overall efficacy comparison. | | 20 pts (26%) BEC
| | | | Most common AE was somnolence 5% in Combo group, 6% in BEC only group.
| Setting: 5 medical centers
| Type(s) of providers:
| specialists (2 allergy, 1 ENT, 1 unknown) | Race: Noted to be comparable, actual % not reported
| | Other:
Falliers and Redding, 1980 | Design: RCT, parallel-group | No. of subjects at start: 120 | 1) Patient-assessed symptom severity: | 1) Patient-assessed symptom severity: | Quality Scoring:
| | | | Active treatments superior to placebo, P < 0.10; combination treatment superior (P < 0.05) to both azatadine and placebo. | Population similar: Not adequately described
| Interventions: | Dropouts/withdrawals: 3 | frequency of nose blowing and sneezing graded on scale of 1 (1) to 8 (more than 15); severity of runny nose, nasal stuffiness, watery eyes, and itching of eyes, nose, and throat graded on scale of 0 (none) to 3 (severe); scores recorded hourly from 8:00 AM to 4:00 PM (both days), then again from 6:00 to 10:00 PM (first day only)
| 1) Azatadine maleate 1 mg + pseudoephedrine 120 mg, combined in one repeat-action tablet; 3 doses over 2 days (n = 30) | | | | Intervention(s) described: Yes
Study 1 (seasonal allergic rhinitis) | | No. of subjects at end: 117 | | | Comorbidities described: No
| | | | | Diagnosis by MD: Yes
| | Inclusion criteria: Seasonal allergic rhinitis based on history and positive skin test | | Reductions in mean total symptom score: | Objectively confirmed: Yes
| | | | | Outcome measures valid: No
| | | | 70% combination | Level of evidence: 1b
| 2) Azatadine maleate 1 mg, 3 doses over 2 days (n = 30) | | | 52% azatadine | Randomized: Yes
| | Exclusion criteria: Pregnant women; hypersensitivity to study drugs; illnesses that contraindicate antihistamine or sympathomimetic amine use | | 43% pseudoephedrine | Allocation concealed: Yes
| | | | 11% placebo | Double-blind: Yes
| 3) Pseudoephedrine 120 mg, in a repeat-action tablet (60 mg in coating and 60 mg in core), 3 doses over 2 days (n = 30) | | | | Blinding adequate: Yes
| | | | Reductions in mean nasal congestion symptom score: | Dropouts described: Yes
| | | | | Intention-to-treat: No
| | | | 68% combination
| | Age: 18 or older | | 35% azatadine
| | | 2) Adverse events: | 62% pseudoephedrine | Notes:
| 4) Placebo, 3 doses over 2 days (n = 30) | Sex: No difference among groups, values not reported | Symptom scoring cards given to patients included questions about drowsiness, dizziness, jitteriness, nausea, and headache | 11% placebo
| | | | 2) Adverse events:
| Duration of study treatment: | Race: NR | | Most common = drowsiness (mild-moderate severity) in 30 of 111 (27%), higher in azatadine (50%) and combination groups (30%), P < 0.10.
| 2 days (treatment given and patients assessed on-site)
| | Other:
| No mention of rescue med
| | | | Jitteriness higher in pseudoephedrine group (P < 0.10). Other reactions insomnia, dizziness, nervousness, dry nose, nausea, and headache. No withdrawals due to AEs.
| Patients abstained from antihistamines and decongestants for 12 hours and systemic steroids for at least 4 weeks before reporting for treatment
| Dates: Single pollen season, 1978
| Location: Denver, CO
| Setting: Outpatient
| Type(s) of providers: NR
Falliers and Redding, 1980 | Design: RCT, parallel-group | No. of subjects at start: 41 | 1) Patient-assessed symptom severity: | 1) Patient-assessed symptom severity: | Quality Scoring:
| | | | Active treatments superior to placebo, P < 0.10; combination treatment superior (P < 0.05) to both azatadine and placebo. | Population similar: Not adequately described
| Interventions: | Dropouts/withdrawals: 2 | rhinorrhea, sneezing, itchy nose, itchy eyes, tearing, conjunctivitis, and nasal congestion graded by patients on scale of 0 (none) to 3 (severe) during clinic visits at baseline and weeks 2, 4, and 6
| 1) Azatadine maleate 1 mg + pseudoephedrine 120 mg, combined in one repeat-action tablet, 2 times per day (n = 10) | | | | Intervention(s) described: Yes
Study 2 (perennial allergic rhinitis) | | No. of subjects at end: 39 | | | Comorbidities described: No
| | | | | Diagnosis by MD: Yes
| | Inclusion criteria: Perennial allergic rhinitis (based on history) | | Reductions in mean total symptom score: | Objectively confirmed: Yes
| | | | | Outcome measures valid: No
| 2) Azatadine maleate 1 mg, 2 times per day (n = 10) | | | 82% combination | Level of evidence: 1b
| | Exclusion criteria: Pregnant women; hypersensitivity to study drugs; illnesses that contraindicate antihistamine or sympathomimetic amine use | | 58% azatadine | Randomized: Yes
| | | | 55% pseudoephedrine | Allocation concealed: Yes
| 3) Pseudoephedrine 120 mg, in a repeat-action tablet (60 mg in coating and 60 mg in core), 2 times per day (n = 11) | | 2) Investigator global assessment of efficacy | 9% placebo | Double-blind: Yes
| | | | | Blinding adequate: Yes
| | | | Reductions in mean nasal congestion symptom score: | Dropouts described: Yes
| | | 3) Patient global assessment of efficacy: | | Intention-to-treat: No
| | Age: 18 or older | | 73% combination
| 4) Placebo, 2 times per day (n = 10) | | Assessed at last clinic visit (6 weeks); method of assessment not described | 27% azatadine
| | Sex: No difference among groups, values not reported | | 63% pseudoephedrine | Notes:
| | | | 10% placebo
| Duration of study treatment:
| 6 weeks | Race: NR | 4) Adverse events: | 2) Investigator global assessment of efficacy: Not abstracted
| | | Patients asked about AEs at each clinic visit (2, 4, and 6 weeks); physicians specifically asked to note presence/absence of drowsiness
| No mention of rescue med | Other:
| | | | 3) Patient global assessment of efficacy:
| No pre-trial washout period described
| | | | Overall response, all active preparations superior to placebo, P < 0.01, in decreasing order of preference:
| Dates: Single pollen season 1978
| | | | combination therapy, azatadine, pseudoephedrine, placebo
| Location: Denver, CO
| | | | 4) Adverse events:
| Setting: Outpatient | | | Most common = drowsiness (mild-moderate severity) in 8 of 41 (20%), higher in azatadine (50%) and combination groups (30%), P < 0.10
| Type(s) of providers: NR
Finn, Aaronson, Korenblat, et al., 1998 | Design: RCT, crossover, allergic and nonallergic patients randomized separately | No. of subjects at start: 205 | 1) Patient-assessed symptom severity: | 1) Patient-assessed symptom severity: | Quality Scoring:
| | (114 allergic, 91 nonallergic) | | Rhinorrhea severity decreased from 2.85 at baseline to 1.78 (38% reduction) with combined therapy (P = 0.0001); 10% additional reduction over terfenadine + placebo. | Population similar: Yes
| | | rhinorrhea graded for severity once daily on a scale of 0 (none) to 5 (very severe) and for duration by the number of hours daily between 8 AM and 8 PM; severity of sneezing and congestion graded once daily on scale of 0–5 (as above) | | Intervention(s) described: Yes
| | Dropouts/withdrawals: | | | Comorbidities described: No
| | 16 excluded from efficacy analysis:
| | | | | Diagnosis by MD: Yes
| Interventions: | | | | Objectively confirmed: Yes
| 1) Terfenadine (60 mg bid) + ipratropium bromide nasal spray 0.03% (42 μg per nostril tid) | 3 with seasonal allergic rhinitis | | | Outcome measures valid: No
| | 13 completed only 1st treatment period | | Rhinorrhea duration decreased from 6.04 at baseline to 1.78 (46% reduction) with combined therapy (P = 0.0001); 16% additional reduction over terfenadine + placebo. | Level of evidence: 1b
| | | | | Randomized: Yes
| | | | | Allocation concealed: Not described
| | 15 noncompleters:
| 2) Terfenadine (60 mg bid) + placebo nasal spray tid | 8 patients due to AEs | | | Double-blind: Yes
| | 5 administrative reasons | | | Blinding adequate: Yes
| | 2 protocol violations | 2) Investigator global assessment of efficacy | No statistical differences between treatment groups for congestion and sneezing. | Dropouts described: Yes
| Duration of study treatment: | | | | Intention-to-treat: No
| 2 weeks for each treatment, with a 1-week washout period between periods | No. of subjects at end: 190 completed; 189 used in efficacy and safety evaluations
| | | 3) Patient global assessment of efficacy:
| | | overall control of nasal symptoms graded at biweekly clinic visits on scale of 0 (none) to 3 (excellent)
| | | | 2) Investigator global assessment of efficacy: Not abstracted | Notes:
| 1-week run-in/baseline period; no anticholinergic agents, antihistamines, sympatho-mimetic decongestants, nasal/ocular cromolyn, prostaglandin inhibitors, tranquilizers with anti-cholinergic effects, or gluco-corticosteroids permitted before or during study. | Inclusion criteria: Perennial rhinitis (allergic or nonallergic) with clinically significant rhinorrhea; allergic rhinitis defined by positive skin tests; rhinorrhea severity score ≥ 2 for 2 hours per day
| | | | 3) Patient global assessment of efficacy:
| | | | Good to excellent control of rhinorrhea: 69% in combined therapy vs. 53% in terfenadine + placebo (P = 0.0008).
| | | 4) Adverse events:
| | | Patients queried about AEs at each biweekly clinic visit; investigators instructed to record all AEs regardless of possible relationship to study drugs
| | | | Good to excellent control of sneezing:
| | Exclusion criteria: Complete nasal obstruction; sinusitis; abnormal radiograph; upper or lower respiratory infection; rhinitis medicamentosa; glaucoma; BPH; hypersensitivity to study meds | | higher in combined therapy group, P = 0.0452.
| Dates: NR | | | No difference in control of congestion.
| Location: US | | | 4) Adverse events:
| | | | N = 63 (32%) combined therapy (31 [16%] possibly drug-related)
| Setting: 7 outpatient centers | Age: Range 18–75, mean 40.1
| | | | N = 31 (16%) terfenadine + placebo
| Type(s) of providers: | Sex: 59% F, 41% M | | (14 [7%] possibly drug-related).
| Specialists
| | Race: 90% white | | Higher % of blood-tinged nasal mucus
| | | | 6.6% vs. 0.5% (combined vs. terfenadine alone), epistaxis (5.1% vs. 1.5%), and nasal dryness (2.5% vs. 1.5%).
| | Other:
Grosclaude, Mees, Pinelli, et al., 1997 | Design: RCT, parallel-group | No. of subjects at start: 687 | 1) Patient-assessed symptom severity: nasal obstruction, sneezing, rhinorrhea, nasal pruritus, and ocular pruritus graded once per day on scale of 0 (absent) to 3 (severe/ hampering daily activities or sleep) | 1) Patient-assessed symptom severity: | Quality Scoring:
| | | | Median proportion of “comfortable” days (symptoms absent or mild): | Population similar: Yes
| Interventions: | Dropouts/withdrawals: 71 total | | | Intervention(s) described: Yes
| 1) Pseudoephedrine 120 mg | n = 30 lack of efficacy | | 53.3% combination, 30.8% cetirizine, | Comorbidities described: No
| (extended-release) bid + | n = 22 adverse events | | 33.3% pseudoephedrine, P < 0.001 | Diagnosis by MD: Yes
| cetirizine 5 mg bid (n = 230) | n = 19 unrelated to drug, mostly protocol violations | | | Objectively confirmed: Yes
| | | | 5-symptom mean score over total treatment: 0.85 combination, 1.03 cetirizine, and 1.14 pseudoephedrine, P < 0.001 for combo vs. cetirizine, P < 0.001 for combo vs. pseudoephedrine | Outcome measures valid: No
| 2) Pseudoephedrine 120 mg | | | | Level of evidence: 1b
| (extended-released) bid (n = 226) | No. of subjects at end: 616 completers | | | Randomized: Yes
| | | | | Allocation concealed: Not described
| | | 2) Investigator-assessed symptom severity
| 3) Cetirizine 5 mg bid (n = 231) | Inclusion criteria: Pollen-associated allergic rhinitis of 1 year or more; positive skin or | | | Double-blind: Yes
| | | | Results of 4-symptom score, excluding blocked nose, showed similar difference between combination vs. cetirizine or pseudoephedrine, P < 0.001. | Blinding adequate: Yes
| | | 3) Investigator global assessment of efficacy | | Dropouts described: Yes
| Duration of study treatment: 2 weeks | RAST tests to seasonal allergens | | | Intention-to-treat: No
| | Exclusion criteria: Asthma requiring change in treatment or systemic/inhaled steroids; atopic dermatitis requiring antihistamines or systemic/topic steroids; upper respiratory infection; nasal polyposis; septal deviation; infection requiring antibiotics; many comorbid illnesses; escalating doses of desensitization therapy; drug trial in previous 3 months | 4) Adverse events: Not clear how reported/ recorded; all AEs recorded regardless of possible relationship to study drugs
| No rescue med permitted | | | | Notes:
| | | | Individual symptom scores showed significant difference for combination vs. cetirizine (P ( 0.01) for all symptoms except itchy eyes, and vs. pseudoephedrine for all symptoms except nasal congestion.
| No pre-trial washout period described; patients who had taken following drugs, in time frame indicated, were excluded: astemizole (6 weeks); systemic cortico-steroids, ketotifen, or MAOIs (2 weeks); topical cortico-steroids or sedative (1 week); nasal decongestants, anti-histamines, or nasal or ocular cromoglycate (2 days)
| | | | 2) Investigator-assessed symptom severity: Not abstracted
| | | | 3) Investigator global assessment of efficacy: Not abstracted
| | Age: Range 9–66, mean 32
| | Sex: 48–53% M, 47–52% F | | 4) Adverse events:
| Dates: Mar-Sept 1992 | | | 68 (29.6%) combination
| | Race: NR | | 68 (30.1%) pseudoephedrine
| Location: France and Germany | | | 54 (23.4%) cetirizine
| | Other:
| | | | Severe AEs:
| Setting: 43 centers (30 France, 13 Germany) | | | 17 (7.4%) combination
| | | | 15 (6.6%) pseudoephedrine
| | | | 7 (3%) cetirizine
| Type(s) of providers: NR
| | | | Withdrawals due to AEs:
| | | | 9 (3.9%) combination
| | | | 7 (3.1%) pseudoephedrine
| | | | 6 (2.6%) cetirizine
| | | | Common AEs:
| | | | Combination: Headache, insomnia
| | | | Cetirizine: Somnolence, headache, asthenia
| | | | Pseudoephedrine: Insomnia, headache, dry mouth
Henauer, Seppey, Huguenot, et al., 1991 | Design: RCT, parallel-group | No. of subjects at start: 50 | 1) Investigator global assessment of improvement | 1) Investigator global assessment of improvement: Not abstracted | Quality Scoring:
| | | | | Population similar: Yes
| Interventions: | Dropouts/withdrawals: 3 withdrew due to AEs (2 combo, 1 terfenadine) | | | Intervention(s) described: Yes
| 1) Terfenadine 60 mg (rapid-release) + pseudoephedrine 120 mg (extended-release), combined in one tablet, taken twice per day (n = 25) | | | 2) Investigator-assessed symptom severity: Not abstracted | Comorbidities described: No
| | | 2) Investigator-assessed symptom severity | | Diagnosis by MD: No
| | | | | Objectively confirmed: No
| | No. of subjects at end: Results reported on 50 patients | | 3) Patient-assessed symptom severity: | Outcome measures valid: No
| | | 3) Patient-assessed symptom severity: nasal congestion, sneezing, rhinorrhea, itchy nose and/or throat, itchy eyes, watery eyes, and red eyes graded once daily on a scale of 0 (no symptom) to 3 (symptom very troublesome) | All 7 symptoms improved according to patient ratings, appeared to favor combination, but differences between groups were not statistically significant (actual data not shown). | Level of evidence: 1b
| | | | | Randomized: Yes
| 2) Terfenadine 60 mg (rapid-release) bid (n = 25) | Inclusion criteria: Perennial rhinitis | | | Allocation concealed: Yes
| | | | | Double-blind: Yes
| | | | | Blinding adequate: Yes
| Duration of study treatment: 2 weeks | Exclusion criteria: Allergy to animals; other relevant concomitant diseases and therapies | | | Dropouts described: Yes
| | | | 4) Adverse events: | Intention-to-treat: Yes
| | | | 20/25 patients in combination group
| No mention of rescue med | | | 9/25 patients in terfenadine group
| | | | P = 0.004 | Notes:
| No pre-trial washout period described | Age: 35 (SD, 9) M; 27 (8) F
| | | 4) Adverse events: | Frequent AEs: Insomnia (13 vs. 3), dry mouth (11 vs. 2), headache (8 vs. 4)
| | Sex: 21 M, 29 F | Assessed at clinic visits at 1 and 2 weeks using check list of potential AEs (drowsiness, nervousness, headache, insomnia, dry mouth, nausea, palpitation)
| Dates: NR | Race: NR | | 5) Rhinoscopy assessments: Not abstracted
| Location: Switzerland
| | Other:
| Setting: Outpatient | | | 6) Acceptability of treatment:
| | | | 15 (65%) combination
| | | | 18 (78%) terfenadine
| Type(s) of providers:
| Allergy specialist | | 5) Rhinoscopy assessments (swelling and hyperemia of nasal mucosa, nasal secretion, and nasal obstruction)
| | | 6) Acceptability of treatment: Patients asked at at final visit (2 weeks) if they would take the medication again
Juniper, Kline, Hargreave, et al., 1989 | Design: RCT, parallel-group; randomization stratified according to degree of sensitivity to ragweed | No. of subjects at start: 90 | 1) Patient-assessed symptom severity: severity and duration of sneezing, stuffy nose, runny nose, eye symptoms, and asthma graded twice per day on scale of 0 (absent) to 3 (severe/continuous) | 1) Patient-assessed symptom severity (mean daily scores): | Quality Scoring:
| | | | | Population similar: Yes
| | Dropouts/withdrawals: 1 due to med noncompliance | | Sneezing: | Intervention(s) described: Yes
| | | | Astemizole 0.395 | Comorbidities described: Yes
| | | | Beclomethasone 0.193 | Diagnosis by MD: Yes
| Interventions: | No. of subjects at end: 89 | | Combination 0.155 | Objectively confirmed: Yes
| 1) Beclomethasone dipropionate aqueous nasal spray, 50 μg per nostril four times per day + astemizole 10 mg once per day (n = 30) | | | p < 0.05, BEC vs. astemizole | Outcome measures valid: No
| | Inclusion criteria: Rhino-conjunctivitis requiring treatment during 2 previous ragweed-pollen seasons; positive skin test to ragweed-pollen | | p < 0.05, combination vs. astemizole | Level of evidence: 1b
| | | | p = ns, combination vs. BEC | Randomized: Yes
| | | | | Allocation concealed: Not described
| | | 2) Use of rescue med: recorded by patients at end of each day in study diaries | Stuffy nose:
| | | | Astemizole 0.594 | Double-blind: Yes
| 2) Beclomethasone dipropionate aqueous nasal spray, 50 μg per nostril four times per day (n = 30) | | | Beclomethasone 0.319 | Blinding adequate: Yes
| | Exclusion criteria: Pregnant; lactating; astemizole, steroid nasal spray, or oral steroid within 6 weeks | | Combination 0.322 | Dropouts described: Yes
| | | | p < 0.05, BEC vs. astemizole | Intention-to-treat: Yes
| | | 3) Adverse events: Patients asked at regular clinic visits (weeks 1, 3, and 6) to report all non-rhinoconjunctivitis symptoms experienced since the previous visit, regardless of whether they perceived them to be related to study treatment | p < 0.05, combination vs. astemizole
| | | | p = ns, combination vs. BEC
| 3) Astemizole 10 mg once per day (n = 30) | | | | Notes:
| | Age: Mean 39.8–42.2 (SD 11.8–13.8) | | Runny nose: | Double-dummy blinding technique employed.
| | | | Astemizole 0.406
| Duration of study treatment: | | | Beclomethasone 0.152
| 6 weeks | Sex: 46 M, 44 F | | Combination 0.192 | Intermittent pollen counts made throughout the study.
| | | | p < 0.05, BEC vs. astemizole
| Patients instructed to take rescue med as follows if symptoms inadequately controlled by study med: for nasal symptoms, freon-propelled beclomethasone dipropionate nasal spray, one puff (50 μg) in each nostril, up to 4 times per day; for eye symptoms, naphazoline HCl and anatazoline ophthalmic drops, one drop in each eye, up to 4 times per day; sodium cromoglycate eye drops, up to 4 times per day, permitted if this treatment insufficient | Race: NR | | p < 0.05, combination vs. astemizole
| | | | p = ns, combination vs. BEC
| | Other:
| | | 4) Treatment compliance: assessed by weighing nasal spray bottles and counting unused tablets (at end of study or at each clinic visit?) | Eye symptoms:
| | | | Astemizole 0.424
| | | | Beclomethasone 0.563
| | | | Combination 0.335
| | | | Asthma:
| | | | Astemizole 0.030
| | | | Beclomethasone 0.015
| | | | Combination 0.048
| | | | 2) Use of rescue med:
| | | | Beclomethasone use:
| | | | Astemizole 0.871
| | | | Beclomethasone 0.206
| No astemizole, steroid nasal spray, or oral steroids permitted within 6 weeks prior to enrollment | | | Combination 0.241
| | | | p < 0.05, BEC vs. astemizole
| | | | p < 0.05, combination vs. astemizole
| | | | p = ns, combination vs. BEC
| Dates: Ragweed season | | | Eye drop use:
| | | | Astemizole 0.707
| Location: Canada | | | Beclomethasone 1.016
| | | | Combination 0.354
| Setting: Outpatient
| | | | Asthma aerosol use:
| Type(s) of providers: | | | Astemizole 0.195
| Allergy specialists | | | Beclomethasone 0.049
| | | | Combination 0.113
| | | | 3) Adverse events:
| | | | 16 astemizole (9 drowsiness, 3 hunger, 3 dryness, 1 headache)
| | | | 16 beclomethasone (4 drowsiness, 3 hunger, 2 dryness, 2 nasal bleeding, 1 headache, 2 thirst, 2 skin irritation)
| | | | 20 combination (4 drowsiness, 4 hunger, 2 dryness, 3 nasal bleeding, 3 headache, 1 thirst, 1 skin irritation, 2 nausea)
| | | | 4) Treatment compliance:
| | | | No differences between groups:
| | | | Astemizole 99.3% pills, 91.8% placebo spray
| | | | Beclomethasone 100.2% placebo pills, 94.1% spray
| | | | Combination 99.2% pills, 91.3% spray
Lanier, Gross, Marks, et al., 2001 | Design: RCT, parallel-group | No. of subjects at start: 94 | 1) Patient-assessed symptom severity (in-clinic): During clinic visits on days 0, 3, and 7, patients graded ocular itching on scale of 1 (none/never) to 4 (very frequently/2 or more times each day) | 1) Patient-assessed symptom severity (in-clinic): | Quality Scoring:
| | | | | Population similar: Yes
| Interventions: | Dropouts/withdrawals: | | Itching (day 7): | Intervention(s) described: Yes
| 1) Loratadine 10 mg once per day + olopatadine ophthalmic solution 0.1%, one drop in each eye 2 times per day (n = 45) | 10 pts without follow-up or did not meet criteria for efficacy analysis | | Combination 2.21, loratadine 2.74, P = 0.0436 | Comorbidities described: No
| | | | | Diagnosis by MD: Not applicable
| | 12 pts (6 per group) withdrew (3 AEs, 2 lost to follow-up, 4 protocol violations, 3 screen failure - numbers overlap with above). | | 2) Patient-assessed symptom severity (diary data for 7 days): | Objectively confirmed: Not applicable
| | | | Values shown in figures. Itching significantly lower on days 3, 4, and 6 in combination group (P < 0.05). Redness significantly lower on day 6 for combination. | Outcome measures valid: Yes
| 2) Loratadine 10 mg once per day (n = 49) | | | | Level of evidence: 2b
| | | 2) Patient-assessed symptom severity (diary data): ocular itching and redness graded 4 times each day on scale of 0 (none) to 9 (severe) | | Randomized: Yes
| | No. of subjects at end: 84 | | | Allocation concealed: Not described
| Duration of study treatment:
| 1 week | Inclusion criteria: Age ≥ 7; moderate-severe seasonal allergic conjunctivitis for at least one season (ocular itching, conjunctival redness); positive skin test | | | Double-blind: No
| | | | 3) Investigator-assessed symptom severity: Not abstracted | Blinding adequate: Not applicable
| No mention of rescue med; immunotherapy and inhalers OK if use greater than 3 months
| | | | | Dropouts described: Yes
| | | 3) Investigator-assessed symptom severity (immediate, post-dose ocular itching and redness) | 4) Patient global assessment of efficacy for ocular symptoms: | Intention-to-treat: Yes
| | | | Ocular symptoms (day 7):
| Trial preceded by 1-week washout period | Exclusion criteria: Pregnant; lactating; other ocular disorder; ocular surgery within 3 months; concomitant systemic, ocular, or nasal medications with potential to interfere with response to therapy | | Combination 1.49, loratadine 2.15, P = 0.0022 | Note: Patients not blinded to treatment (no placebo eye drops).
| Dates: May- Nov 1998 | | 4) Patient global assessment of efficacy for ocular symptoms: graded relative to baseline during clinic visits on days 3 and 7 on scale of 0 (clinical cure) to 5 (significantly clinically worse) | 5) Investigator global assessment of efficacy for ocular symptoms: Not abstracted
| Location: US
| Setting: 3 outpatient sites | Age: Mean 38, range 9–74 | | 6) Quality of life:
| | | | Overall mean score day 7:
| Type(s) of providers: | Sex: 33 (35%) M, 61 (65%) F | | Combination 1.45
| Family practice | | | Loratadine 2.09
| | Race: 81 (86%) white, 9 (10%) black, 4 (4%) other | | P < 0.05
| | | 5) Investigator global assessment of efficacy for ocular symptoms | Significant differences also noted for sleep, eye symptoms, activities, and emotions domains.
| | Other:
| | | 6) Quality of life: | 7) Adverse events:
| | | Assessed using the Rhinoconjunctivitis Quality of Life Questionnaire (RQLQ) at baseline and end-of-treatment (day 7) clinic visits | 13 total AEs from 10 patients
| | | | 2 AEs due to loratadine use (1 asthenia and dry mouth, 1 dyspepsia); patients continued with study
| | | | 2 AEs caused withdrawal (1 bronchitis, 1 allergy exacerbation)
| | | 7) Adverse events: Both spontaneous and elicited AEs recorded throughout study (method of eliciting not described); AEs defined as “any changes from baseline other than efficacy parameters in a patient's ophthalmic or medical condition”
Lau, Wei, Van Hasselt, et al., 1990 | Design: RCT, parallel-group | No. of subjects at start: 142 | 1) Patient-assessed symptom severity: | 1) Patient-assessed symptom severity: | Quality Scoring:
| | | | Values shown in figures. | Population similar: Yes
| Interventions: | Dropouts/withdrawals: 12 | blocked nose, runny nose, itchy nose, sneezing bouts, sore eyes, and runny eyes graded once per day on scale of 0 (no symptoms) to 3 (severe/ sufficiently troublesome to interfere with daily activity or sleep) | Improvement for all nasal symptoms in the two budesonide groups compared to baseline (P < 0.05). Terfenadine improved only in nasal blockage compared to baseline (P < 0.05). | Intervention(s) described: Yes
| 1) Budesonide nasal aerosol 200 μg bid + oxymetazoline nasal drop pipette (0.5 mg/ml), 3 drops 15 minutes before administration of budesonide for first 3 days only (n = 47) | 4 due to AEs (1 nasal pain due to budesonide, 1 HA from budesonide, 2 ulcer pain from taking terfenadine) | | | Comorbidities described: No
| | | | | Diagnosis by MD: No
| | | | | Objectively confirmed: No
| | | | | Outcome measures valid: No
| | 8 lost to follow-up | | | Level of evidence: 2b
| | | | Between-group comparison showed two budesonide groups better than terfenadine group (P < 0.05) | Randomized: Yes
| | No. of subjects at end: 130 | | | Allocation concealed: Not described
| 2) Budesonide nasal aerosol 200 μg bid (n = 48)
| | Inclusion criteria: Age 15–70; perennial rhinitis for 2 years; blocked nose and 2 other symptoms (runny nose, itchy nose, sneezing) | | | Double-blind: Yes
| | | 2) Patient global assessment of efficacy: treatment graded as ineffective, slightly effective, moderately effective, and extremely effective during last clinic visit (3 weeks) | Budesonide with oxymetazoline showed faster relief than budesonide alone, 1 day vs. 7 days, P < 0.05. | Blinding adequate: Yes
| 3) Terfenadine 60 mg bid (n = 47) | | | | Dropouts described: Yes
| | | | | Intention-to-treat: Can't determine
| Duration of study treatment: | | | 2) Patient global assessment of efficacy:
| 3 weeks | Exclusion criteria: Steroid treatment within 4 weeks; infection; nasal polyps; septal deviation; pregnant; lactating
| | | | No significant differences among the three groups. | Note: Double-dummy blinding technique employed.
| No mention of rescue med
| No pre-trial washout period; pts who had received other steroid treatment during previous 4 weeks were excluded | | 3) Adverse events: AEs noted on diary cards; patients asked non-leading question about AEs during clinic visits at 1 and 3 weeks | 3) Adverse events:
| | Age: Mean 26.7 (range 15–68) | | N = 6 budesonide + oxymetazoline (2 nasal irritation, 2 throat irritation, 2 headache, 1 GI distress)
| | Sex: 65 M, 77 F
| | Race: 140 Chinese, 2 Indian | | N = 10 budesonide (3 nasal irritation, 2 headache, 2 GI distress, 1 each dizziness, nausea, and other)
| Dates: June 1986-May 1988
| | Other:
| Location: Hong Kong
| | | | N = 17 terfenadine (10 gi distress, 3 nasal irritation, 1 each dizziness, nausea, dry mouth, and other)
| Setting: Outpatient
| Type(s) of providers:
| Otolaryngology
| Setting: Outpatient
Meran, Morse, and Gibbs, 1990 | Design: RCT, crossover | No. of subjects at start: 40 (3 with perennial rhinitis, 37 with seasonal rhinitis) | 1) Patient-assessed symptom severity: | 1) Patient-assessed symptom severity: | Quality Scoring:
| | | | Overall symptom score: | Population similar: Yes
| Interventions: | | sneezing, itchy nose/throat, runny nose, blocked nose, watery eyes, itchy eyes, and overall symptoms graded at end of each day on scale of 0 (no symptoms) to 9 (very severe) | Placebo 3.37, pseudoephedrine 2.92, acrivastine 2.04 **, combination 1.66** ** P < 0.01 vs. placebo. No significant difference between acrivastine and combination. | Intervention(s) described: Yes
| 1) Acrivastine 8 mg + pseudoephedrine 60 mg, 3 times daily | | | | Comorbidities described: No
| | Dropouts/withdrawals: | | | Diagnosis by MD: Yes
| | 5 noncompleters - 3 withdrew due to lack of treatment effect (placebo group), 1 left country, 1 due to headache associated with pseudoephedrine. Data up to withdrawal included in analysis. | | | Objectively confirmed: Yes
| | | | | Outcome measures valid: No
| 2) Acrivastine 8 mg, 3 times daily | | | | Level of evidence: 1b
| | | | Combination significantly better than acrivastine, P < 0.01, for symptoms of sneezing, itchy nose/throat, runny nose, blocked nose, and watery eyes (mean values available from table). | Randomized: Yes
| | | | | Allocation concealed: Not described
| 3) Pseudoephedrine 60 mg, 3 times daily
| | | 2) Patient global assessment of efficacy: | | Double-blind: Yes
| | No. of subjects at end: 40 | | | Blinding adequate: Yes
| 4) Placebo | | graded on day 7 of each treatment period as excellent, good, satisfactory, poor, or abysmal | | Dropouts described: [??]
| | Inclusion criteria: Age 12–70; seasonal allergic rhinitis; positive skin test to mixed grasses | | 2) Patient global assessment of efficacy: | Intention-to-treat: Yes
| Duration of study treatment:
| 6 days each treatment period, with a 1-day washout between periods | | | Values shown combine patient and investigator responses; no significant differences between patient and MD responses. Pseudoephedrine better than placebo (P < 0.01); acrivastine alone or in combination better than placebo or pseudoephedrine (P < 0.01).
| | | | | Note: Double-dummy blinding technique employed.
| | Exclusion criteria: Nasal deformity; patients who operated dangerous machinery; other acute or chronic disease; pregnant, lactating, or not on contraception
| | | 3) Investigator global assessment of efficacy
| No rescue med permitted
| Trial preceded by washout period of 24 hours to 1 month, depending on pre-trial medication | | 4) Acceptability/patient preference: Patients asked on day 7 of each treatment period if they would continue with the current treatment if that treatment were available
| | Age: Mean 28, range 17–56
| | | | 3) Investigator global assessment of efficacy: Not abstracted
| | Sex: 15 M, 25 F
| Dates: Apr-Jul 1984
| | Race: NR | | 4) Acceptability/patient preference:
| Location: Switzerland | | | 45% placebo, 69% pseudoephedrine, 82% acrivastine,** 87% for combination**
| | Other: | 5) Adverse events:
| Setting: Outpatient | | Incidence of AEs recorded during day 7 clinic visit of each treatment period, as reported spontaneously or in response to indirect questioning
| | | | **P < 0.01 vs. placebo
| Type(s) of providers:
| Otolaryngology | | | 5) Adverse events:
| | | | 16 placebo group
| | | | 18 pseudoephedrine group
| | | | 7 acrivastine group
| | | | 19 combination group
| | | | More insomnia with pseudoephedrine than with placebo or acrivastine, P < 0.05. More fatigue with placebo than with pseudoephedrine, P < 0.01.
Negrini, Troise, Voltolini, et al., 1995 | Design: RCT, parallel-group | No. of subjects at start: 204 | 1) Use of rescue med (eye drops): recorded by patients in study diaries | 1) Use of rescue med (eye drops): | Quality Scoring:
| | | | Astemizole-D: 16% of patients, mean frequency of use 5.5% of treatment days (P < 0.05 compared to beclomethasone) | Population similar: Yes
| Interventions: | Dropouts/withdrawals: Total of 31 patients (15 astemizole-D group, 16 beclomethasone); 12 withdrew due to AEs (9 and 3, respectively); 8 withdrew from treatment inefficacy (4 per group); 1 lost to follow-up; 1 lack of symptoms in beclomethasone group | | | Intervention(s) described: Yes
| 1) Astemizole 10 mg + pseudoephedrine 240 mg once daily (n = 102) | | | | Comorbidities described: No
| | | 2) Investigator-assessed symptom severity | | Diagnosis by MD: Yes
| | | | Beclomethasone: 29%, mean frequency of use 10% of treatment days | Objectively confirmed: Yes
| | | | | Outcome measures valid: No
| 2) Beclomethasone nasal spray (0.05 mg/ml), 2 puffs per nostril twice per day (n = 102) | | 3) Patient-assessed symptom severity: | | Level of evidence: 1b
| | | | | Randomized: Yes
| | | sneezing, rhinorrhea, nasal itching, congestion, and concurrent ocular symptoms graded daily on scale of 0 (absent) to 3 (severe); severity of rhinitis also graded daily using a visual analog scale ranging from “absent” to “very severe” | 2) Investigator-assessed symptom severity: Not abstracted | Allocation concealed: Not described
| | No. of subjects at end: 173 | | | Double-blind: Yes
| Duration of study treatment: | | | 3) Patient-assessed symptom severity: | Blinding adequate: Yes
| 4 weeks | Inclusion criteria: Age 12–70 with 1-year history of seasonal allergic rhinitis requiring therapy; positive skin test or RAST for pollen; moderately severe nasal congestion and at least one other nasal symptom of moderate severity | | Mean (SEM) Area under the Curve results shows in Figure 1(1st 2 weeks of therapy) and Figure 2 (entire study period) | Dropouts described: Yes
| | | | | Intention-to-treat: Yes
| Vasoconstrictor eye drops (phenylephrine, xylo-metazoline, or naphazoline) provided for use as rescue med
| | | | | Note: Double-dummy blinding technique employed.
| | | | No significant difference in nasal congestion, sneezing, rhinorrhea, nasal itching, VAS rhinitis, total nasal, or total symptom scores.
| | | 4) Investigator global evaluation of efficacy
| Trial preceded by washout period ranging from 3 days to 6 weeks, as follows:
| | Exclusion criteria: Pregnancy; serious concurrent medical illness; concomitant therapy that could interfere with assessment | | Trend towards fewer ocular symptoms on astemizole-D (P = 0.07) at end of study (at 2 weeks P = 0.03).
| | | 5) Patient global evaluation of efficacy:
| decongestants (3 days); oral
| antihistamines (3 days, except for astemizole [6 weeks]); topical corticosteroids and sodium cromoglycate (2 weeks); oral corticosteroids (1 month); immunotherapy (1 month) | | effect of therapy graded at end of trial as “excellent,” “good,” “moderate,” or “poor”
| | | | 4) Investigator global evaluation of efficacy: Not abstracted
| | Age:
| | Astemizole-D mean 28.4 (range 12–66)
| | | | 5) Patient global evaluation of efficacy:
| | Beclomethasone mean 29.2 (13–66) | 6) Adverse events: | Excellent or good response:
| | | recorded by patients in study diaries | Astemizole-D: 63%
| | | | Beclomethasone: 72%
| Dates: 1992 hay fever season | Sex:
| | Astemizole-D 56 M/46 F | | 6) Adverse events:
| Location: Austria, Belgium, Germany, Italy | Beclomethasone 54 M/48 F | | Astemizole-D 38 pts (38%)
| | | | Beclomethasone 26 pts (27%)
| | Race: NR | | No statistically significant difference
| Setting: Outpatient
| | Other: | | Most common = headache (7 pts asthemizole, 3 beclomethasone), dry mouth (9, 1), nausea (4,4), somnolence (5,2) and fatigue (4,1)
| Type(s) of providers:
| Specialists (allergy and ENT)
Panda and Mann, 1998 | Design: RCT, parallel-group | No. of subjects at start: 41 | 1) Patient and investigator global assessment of efficacy: graded by patient and physician together (?) at 2 weeks on scale ranging from excellent (virtually all signs and symptoms stopped [reduction of 90% or more]) to poor/no response/deterioration | 1) Patient and investigator global assessment of efficacy: | Quality Scoring:
| | | | | Population similar: Yes
| Interventions: | Dropouts/withdrawals: | | Excellent: 10/22 (45.5%) combination group, 2/19 (10.5%) single treatment group | Intervention(s) described: Yes
| 1) Terfenadine 60 mg + pseudoephedrine 120 mg (10 mg immediate-release and 110 mg extended-release), combined in one tablet, 2 times per day (n = 22) | 4 due to AEs (2 per group) | | | Comorbidities described: No
| | 5 lost to follow-up (5 combo, 1 single) | | | Diagnosis by MD: No
| | | | Good: 6/22 (27.3%) combination group, 7/19 (36.8%) single treatment group | Objectively confirmed: No
| | | | | Outcome measures valid: No
| | No. of subjects at end: 32 completers, but results shown for 31 subjects | | | Level of evidence: 2b
| | | | Fair: 4/19 (21%) single treatment group | Randomized: Yes
| | | | | Allocation concealed: Not described
| 2) Terfenadine 60 mg 2 times per day (n = 19) | | | Poor: 3/19 (5.7%) single treatment group.
| | Inclusion criteria: Moderate-severe allergic rhinitis | | | Double-blind: Yes
| | | 2) Patient global assessment of efficacy and adverse events: graded at 2 weeks on scale ranging from excellent (excellent efficacy with no or mild side effects) to poor | P = 0.0485 | Blinding adequate: Yes
| Duration of study treatment: | | | | Dropouts described: Yes
| 2 weeks | Exclusion criteria: Hyper-sensitivity to study meds; pregnant, lactating, or not on contraception; renal, cardiac, or respiratory disorder; non-responsive to antihistamines (new and classic); immunotherapy | | 2) Patient global assessment of efficacy: | Intention-to-treat: No
| Rescue med not permitted | | | Excellent: 10/22 (45.5%) combination group, 2/19 (10.5%) single treatment group
| | | | | Notes:
| No pre-trial washout period described; patients who had taken oral or topical steroids or sodium cromoglycate in the previous month, and those who had taken antihistamines or decongestants in the previous 48 hours, were excluded
| | | | Good: 6/22 (27.2%) combination group, 6/19 (31.5%) single treatment group
| | | 3) Investigator global assessment of efficacy and adverse events
| | Age: Range 15–56 | | Fair: 5/19 (26.3%) single treatment group
| | Sex: 23 M, 18 F | | Poor: 3/19 (15.7%) single treatment group.
| | | 4) Adverse events:
| | Race: NR | Recorded at clinic visits at 1 and 2 weeks | P = 0.0236
| Dates: NR | Other: | | 3) Investigator global assessment of efficacy and adverse events: Not abstracted
| Location: India
| Setting: Outpatient | | | 4) Adverse events (treatment discontinued):
| Type(s) of providers: | | | 2 AEs in combination group (cloudy urine, dizziness/insomnia)
| Otolaryngology
| | | | 2 AEs in single treatment group (somnolence, insomnia)
Purello-D'Ambrosio, Isola, Ricciardi, et al., 1999 | Design: RCT, parallel-group | No. of subjects at start: 30 | 1) Patient-assessed symptom severity: | 1) Patient-assessed symptom severity: | Quality Scoring:
| | | | Flunisolide + loratadine group had decrease in sneezing compared to flunisolide alone (change of 73.4% vs. 46.6%, P < 0.000001); rhinorrhea (66.7% vs. 26.7%, P < 0.0006). No differences in nasal blockage (19.9% vs. 20.0%). | Population similar: Yes
| Interventions: | Dropouts/withdrawals: 0 | sneezes, rhinorrhea, and nasal blockage graded daily on scale of 0 (no symptoms) to 3 (severe symptoms) | | Intervention(s) described: Yes
| 1) Flunisolide, two 25-μg puffs per nostril twice per day + loratadine 10 mg once per day (n = 15) | | | | Comorbidities described: No
| | No. of subjects at end: 30 | | | Diagnosis by MD: Not applicable
| | Inclusion criteria: Nonallergic rhinitis with eosinophilia for at least 3 years; symptom score ≥ 5; eosinophil count > 10% | | | Objectively confirmed: Not applicable
| 2) Flunisolide, two 25-μg puffs per nostril twice per day + placebo once per day (n = 15) | | 2) Investigator-assessed symptom severity | | Outcome measures valid: No
| | | | 2) Investigator-assessed symptom severity: Not abstracted | Level of evidence: 1b
| | | | | Randomized: Yes
| | Exclusion criteria: Positive skin test or positive IgE tests to common allergens; nasal polyposis or sinusitis; on drugs that would interfere with treatment; severe disease; pregnant or lactating women | 3) Eosinophil counts | | Allocation concealed: Yes
| | | | 3) Eosinophil counts: Not abstracted | Double-blind: Yes
| Duration of study treatment: | | 4) Adverse events: | | Blinding adequate: Yes
| 3 weeks | | Patients instructed to record any unexpected symptom on their diary cards, along with its duration, severity, and presumed relationship to treatment | 4) Adverse events: | Dropouts described: Yes
| | | | 2 AEs total (1 per group), both subjects with nasal irritation. | Intention-to-treat: Yes
| Rescue med not permitted
| Trial preceded by 8-week washout period | | | | Notes:
| | Age: Mean 38.7 (range 32–48)
| Dates: NR | Sex: 12 M, 18 F
| Location: Italy | Race: NR
| Setting: Outpatient | Other:
| Type(s) of providers:
| Allergy specialist
Ratner, van Bavel, Martin, et al., 1998 | Design: RCT, parallel-group | No. of subjects at start: 600 | 1) Investigator-assessed symptom severity | 1) Investigator-assessed symptom severity: Not abstracted | Quality Scoring:
| | | | | Population similar: Yes
| | Dropouts/withdrawals: 31 total | | | Intervention(s) described: Yes
| Intervention(s): | 8 due to AEs | 2) Patient-assessed symptom severity: sneezing, nasal blockage, rhinorrhea, and nasal itching graded once per day on visual analog scale ranging from 0 (absent) to 100 (severe) | 2) Patient-assessed symptom severity: | Comorbidities described: No
| 1) Fluticasone propionate aqueous nasal spray (two 50-μ2 sprays per nostril once per day + loratadine 10 mg once per day (FP+LOR) (n = 150) | 13 due to lack of efficacy | | Values shown in Figure 1 | Diagnosis by MD: Yes
| | 7 withdrew from other reasons | | FP+LOR vs. FP alone, P = 0.006 days 1–7, and P = 0.017 days 8–14 | Objectively confirmed: Yes
| | 3 lost to follow-up | | | Outcome measures valid: Yes
| | | | FP+LOR and FP alone vs. LOR, P < 0.05; vs. placebo, P < 0.001 | Level of evidence: 1b
| | No. of subjects at end: 569 | | | Randomized: Yes
| | | | | Allocation concealed: Not described
| 2) Fluticasone propionate aqueous nasal spray (two 50-μg sprays per nostril once per day (FP) (n = 150) | Inclusion criteria: Seasonal AR (positive skin test to mountain cedar allergen, nasal mucosa allergic changes, seasonal symptoms over 2 or more seasons); moderate-severe symptoms on diary during run-in period | | 3) Investigator global evaluation of treatment efficacy: Not abstracted
| | | | | Double-blind: Yes
| | | 3) Investigator global evaluation of treatment efficacy | | Blinding adequate: Yes
| | | | 4) Patient global evaluation of treatment efficacy: | Dropouts described: Yes
| | | | | Intention-to-treat: Yes
| 3) Loratadine 10 mg once per day (LOR) (n = 150) | | | Values shown in Figure 3
| | | 4) Patient global evaluation of treatment efficacy: overall response to treatment graded at end of trial on 7-point scale ranging from “significant improvement” to “significant worsening” | FP alone and FP+LOR more effective than placebo or LOR alone (P < 0.001). No difference between FP alone vs. FP+LOR. No difference between placebo and LOR.
| | | | | Notes:
| 4) Placebo (n = 150) | | | | Double-dummy blinding technique employed.
| | Exclusion criteria: Loratadine within 1 week; astemizole within 6 weeks; cromolyn NA within 2 weeks; OTC nasal meds within 72 hours; steroids (MDI, nasal, oral) within 1 month; septal deviation, nasal polyp; history of nasal septal surg/perforation; candida infection; pregnant/lactating; other impairment
| Duration of study treatment:
| 2 weeks | | | | Patient population: 90% PC, 10% allergy
| | | | 5) Quality of life (global RQLQ score):
| No rescue med permitted | | | Mean change score (SEM):
| | | | Placebo: -1.3 (0.1)
| Trial preceded by 7- to 30-day run-in period. In addition, patients who had taken following drugs, in time frame indicated, were excluded: loratadine (1 week); astemi-zole (6 weeks); cromolyn sodium (2 weeks); other OTC or prescription drugs that might affect rhinitis symptomatology (e.g., nasal decongestants) (72 hours); inhaled, intranasal, or systemic corticosteroids (1 month). | | 5) Quality of life: assessed using the Rhinoconjunctivities Quality of Life Questionnaire (RQLQ) at baseline and 2 weeks | LOR alone: -1.3 (0.1)
| | | | FP alone: 2.2 (0.1), P < 0.05 vs. placebo or LOR
| | | | FP+LOR: 2.3 (0.1), P < 0.05 vs. placebo or LOR
| | Age: 12 or older
| | | | 6) Adverse events:
| | Sex: 272 M (45.3%), 328 (54.7%)
| | | 6) Adverse events: Defined as any untoward medical occurrence, drug-related or not; recorded by clinicians during clinic visits at 1 and 2 weeks | 5–8% each group with AEs due to study drug
| | Race: 462 white (77%); 106 Hispanic (17.7%); 32 other (5.3%) | | 1–2% blood in nasal mucus in active treatment groups, 3% blood in nasal mucus in placebo
| | Other: | | ≤1% epistaxis all groups
| | | | ≤2% xerostomia all groups
| Dates: Actual dates NR, during mountain cedar allergy season
| Location: South central Texas
| Setting: Professional research centers
| Types(s) of providers: Research center MDs
Simpson, 1994 | Design: RCT, parallel-group | No. of subjects at start: 143 | 1) Patient-assessed symptom severity: blocked nose, sneezing, nasal itching, runny nose, sore eyes, and runny eyes graded at end of each day on scale of 0 (no symptoms) to 3 (severe symptoms/discomfort experienced during most waking hours) | 1) Patient-assessed symptom severity: | Quality Scoring:
| | | | Mean symptom scores at 1 week shown in figure. Terfenadine reached maximum efficacy within 1–2 days; budesonide scores were lower than terfenadine after 2–3 days and continued to improve over days 3–7. Combination treatment had similar effect to budesonide alone. | Population similar: Yes
| Interventions: | Dropouts/withdrawals: | | | Intervention(s) described: Yes
| 1) Budesonide nasal spray, 200 μg (2 puffs in each nostril) bid + terfenadine 60 mg bid (n = 32) | 6 records unusable | | | Comorbidities described: No
| | 20 withdrew due to lack of efficacy (12 from placebo group) | | | Diagnosis by MD: No
| | | | | Objectively confirmed: No
| | 3 withdrew due to AEs | | | Outcome measures valid: No
| | 5 noncompliant with follow-up | | | Level of evidence: 2b
| 2) Terfenadine 60 mg bid (n = 23) | 3 protocol violations | | | Randomized: Yes
| | | | | Allocation concealed: Not described
| | No. of subjects at end: 106 | | Mean symptom scores at week 3 graphically shown. Terfenadine resulted in significant (P < 0.05) reductions in symptom scores for runny and itchy nose compared to placebo. Budesonide alone reduced all mean symptom scores compared to placebo (P < 0.05); also more than terfenadine but only statistically significant for nasal blockage. Combination therapy symptom scores were similar to budesonide for blocked/itchy/runny nose. Combination reduced mean sneezing score than terfenadine or budesonide alone (P < 0.05).
| 3) Budesonide nasal spray, 200 μg (2 puffs in each nostril) bid (n = 30) | | | | Double-blind: Yes
| | Inclusion criteria: Age ≥ 15; hay fever between May 1 and Aug 31 for ≥ 2 years; 2 symptoms (blocked nose, runny nose, itching nose, sneezing) | 2) Patient global assessment of efficacy: graded on scale of 0 (ineffective) to 3 (very effective) at end-of-trial clinic visit (3 weeks) | | Blinding adequate: Yes
| | | | | Dropouts described: Yes
| | | | | Intention-to-treat: No
| 4) Placebo (n = 21)
| Duration of study treatment: | | | | Note: Double-dummy blinding technique employed.
| 3weeks | Exclusion criteria: Oral steroids; upper respiratory infection; desensitization treatment within 12 months; hay fever symptoms outside specified period; pregnancy
| | | 3) Use of rescue med (eye drops): Number of drops used recorded each day by patients on diary cards
| Xylometazoline or metazoline eye drops could be used for “troublesome eye symptoms”; no other rescue med permitted
| | Age: Mean 25.7–29.7 (SD 7.8–12.4) | 4) Adverse events: Not clear who reported/ recorded
| No pre-trial washout period described; patients taking oral corticosteroids at the time of recruitment, or who had had desensitization therapy in previous 12 months, were excluded | | | 2) Patient global assessment of efficacy:
| | Sex: | | Proportion rating treatment as noticeably effective or very effective:
| | Placebo 71% M, 29% F
| | Budesonide 43% M, 57% F | | Placebo 40%, terfenadine 46%, 85% budesonide alone or in combination. P < 0.05 for budesonide alone or in combination vs. placebo or terfenadine.
| | Terfenadine 53% M, 47% F
| | Combination 41% M, 39% F
| | Higher proportion of men in placebo group
| Dates: May 1-Aug 31
| | | | 3) Use of rescue med (eye drops):
| Location: UK | Race: NR
| Setting: Outpatient | Other:
| Type(s) of providers: | | | 4) Adverse events:
| Primary care | | | 19 total AEs (5 placebo, 2 terfenadine, 7 budesonide, 8 combination). Most common sneezing and nasal irritation (1 combination pt with palpitations)
| | | | 3 withdrawals due to AE (1 placebo pt with nausea, 1 budesonide patient with fatigue, 1 combination patient with sneezing and headache)
Sussman, Mason, Compton, et al., 1999 | Design: RCT, parallel-group | No. of subjects at start: 651 | 1) Patient-assessed symptom severity: | 1) Patient-assessed symptom severity: | Quality Scoring:
| | | | Primary outcome: reduction in 7 PM | Population similar: Yes
| Interventions: | Dropouts/withdrawals: | sneezing; rhinorrhea; itchy nose, palate, and/or throat; itchy, watery, or red eyes; and nasal congestion graded twice each day (7 PM and bedtime) on scale of 0 (symptom absent) to 4 (symptom so severe as to warrant an immediate visit to the physician) | reflective total symptom/nasal congestion score (TSS-NCS): | Intervention(s) described: Yes
| 1) Fexofenadine 60 mg + | 63 discontinued therapy (3.8% subject/MD decision, 2.8% AEs) | | | Comorbidities described: No
| pseudoephedrine 120 mg (extended-release), twice per day (n = 215) | | | Combination therapy reduction (2.32) significantly greater than pseudo-ephedrine alone (1.42, P < 0.0001), but not significantly different than fexofenadine alone (2.05, P = 0.1579). | Diagnosis by MD: Yes
| | | | | Objectively confirmed: Yes
| | No. of subjects at end: 588 | | | Outcome measures valid: No
| | | | | Level of evidence: 1b
| 2) Fexofenadine 60 mg twice per day (n = 218) | Inclusion criteria: Age 12–65; ragweed allergy confirmed by positive skin test; clinical response to antihistamines | | | Randomized: Yes
| | | | | Allocation concealed: Not described
| | | | Change in 7 PM NCS:
| 3) Pseudoephedrine 120 mg (extended-release) twice per day (n = 218) | | | Combination therapy reduction (0.56) significantly greater than fexofenadine (0.36, P < 0.0005), but not significantly different from pseudoephedrine (0.45, P = 0.059). | Double-blind: Yes
| | | | | Blinding adequate: Yes
| | Exclusion criteria: Hyper-sensitivity to drug, URI or sinusitis within 30 days, alcohol or drug abuse, pregnant or lactating women | | | Dropouts described: Yes
| | | TSS = total symptom score; NCS = nasal congestion score | | Intention-to-treat: Yes
| Duration of study treatment: 14–20 days
| | | | Change in individual symptom scores showed significantly greater reductions in combination therapy compared to pseudoephedrine for all symptoms (P-values 0.0002 for all symptoms except P < 0.0001 for sneezing). | Notes:
| Rescue med not permitted | | 2) Adverse events: Patients “were required to record any adverse events” | | Double-dummy blinding technique employed.
| | Age: Mean 31.7–34.9 (SD 11.12–12.35)
| Trial preceded by a 3- to 5-day placebo run-in period; no other washout period described
| | | | | Pollen levels measured daily throughout study.
| | Sex: 275 M (42%), 376 F (58%)
| | | 3) Work-related productivity: Assessed using the Work Productivity Activities Index, completed at baseline and at end of treatment
| | Race: 566 (87%) white, 35 (5%) black, 42 (6%) Asian, 8 (1%) multiracial | | Combination therapy had greater improvement than fexofenadine for nasal congestion only (P = 0.0005).
| Dates: NR
| Location: Canada
| | Other: | | 2) Adverse events:
| Setting: 18 medical centers | | | 280/651 (43%) had at least 1 AE.
| | | | Combination 51.2%, pseudoephedrine 45.4%, 36.2% fexofenadine. P < 0.001 in fexofenadine group.
| Type(s) of providers: NR | | | 29% of 651 had treatment-related AEs. Combination 34.9%, pseudoephedrine 36.7%, 16.5% fexofenadine. P < 0.001 compared to fexofenadine group.
| | | | Most common were headache (combo 9.3%, pseudoephedrine 12.4%, fexofenadine 7.3%) and insomnia (combo 11.2%, pseudoephedrine 12.8%, fexofenadine 1.8%).
| | | | 3) Work-related productivity:
| | | | Reduction in work impairment scores:
| | | | Fexofenadine 9.8%, pseudoephedrine 7.9%, combination 13% (P < 0.0001 for each group compared to baseline). Reductions in combination group significant (P = 0.006) compared to pseudoephedrine group, but not different compared to fexofenadine group.
| | | | Improvement in work productivity among employed patients: combination 9.3% compared to pseudoephedrine 6.2%, P < 0.05. No difference compared to fexofenadine group 8.1%.
| | | | Overall work productivity in combination (8.5%) and fexofenadine (8.0%) groups significantly improved from baseline (P < 0.001) compared to pseudoephedrine (4.9%, P < 0.12).
Vuurman, van Veggel, Sanders, et al., 1996 | Design: RCT, parallel-group (see Notes) | No. of subjects at start: 68? with seasonal allergic rhinitis (see Table 1) | 1) Patient-assessed symptom severity (training and examination phases): | 1) Patient-assessed symptom severity: | Quality Scoring:
| | | | Mean (SEM) values shows in Figure 1. | Population similar: No
| | | | Symptom scores improved for drug treatments (A+P and D groups) compared to placebo. Significant treatment effect on day 1, P = 0.037, but not days 2 and 3. | Intervention(s) described: Yes
| Interventions: Allergic rhinitis patients randomized to one of following treatments during 3-day training period: | | rhinorrhea, nasal congestion, sneezing, mouth-breathing, itchy nose/throat, and tearing or red eyes graded daily on 5-point scale ranging from “absent” to “very severe, interfering with daily activities” | | Comorbidities described: No
| | Dropouts/withdrawals: 1 | | | Diagnosis by MD: Yes
| | | | | Objectively confirmed: No
| | No. of subjects at end: 67 with seasonal allergic rhinitis (see Notes); complete symptom score data on 59 patients | | | Outcome measures valid: No
| 1) Acrivastine 8 mg + pseudo-ephedrine 60 mg qid (A+P) (n = 22) | | | Placebo vs. A+P, P = 0.029 | Level of evidence: 2b
| | | | Placebo vs. D, P = 0.024 | Randomized: Yes
| | | | | Allocation concealed: Not described
| | | | 2) Performance on memory tests (training phase): Not abstracted
| 2) Diphenhydramine 50 mg qid (D) (n = 24) | Inclusion criteria: Documented medical treatment for seasonal allergic rhinitis over the prior 2 years; diary symptom score ≥ 9 prior to treatment | | | Double-blind: Yes
| | | | | Blinding adequate: No
| | | 2) Performance on memory tests (training phase) | 3) Performance on learning tests (training and examination phases): Not abstracted | Dropouts described: Yes
| 3) Placebo (n = 22) | | | | Intention-to-treat: No
| In all three groups, treatment was started the evening before the first of three evening training sessions and continued for 3 days. At the end of the 3-day training period, all allergic rhinitis patients were treated with acrivastine + pseudo-ephedrine, as above, for 14 days, after which they returned for examination phase.
| | Exclusion criteria: Severe mental of physical disorders; alcohol or drug abuse; chronic medication use; drug hypersensitivity | 3) Performance on learning tests (training and examination phases) | | Notes:
| | | | | Study also completed by 28 normal controls with no history of allergic rhinitis, matched for age and intelligence.
| | Age: Overall mean 20.0 (SD 2.3), range 16–25
| | | | | Study designed primarily to test performance on a didactic computer simulation. Patients randomized to separate treatments during 3-day training phase at start of trial. After training period, all allergic rhinitis patients treated with acrivastine + pseudo-ephedrine for 14 days preceding the examination phase.
| | Control 20.2 (SD 2.6)
| | Acrivastine + pseudophedrine 20.0 (2.7)
| | Placebo 19.8 (2.0)
| | Diphenhydramine 20.1 (1.7)
| Duration of study treatment: | Sex:
| 17 days+, as follows: 2-hour introduction phase, 3-day training phase, 14-day interval, and 1-hour examination phase | Control 10 M/18 F
| | Acrivastine + Pseudophedrine: 13 M/9 F
| | Placebo 7 M/15 F | | | Examination lasted approximately 1 hour and was designed to assess retention of knowledge acquired during training phase and measure group differences in performance attributable to the combined effects of allergies and treatment during the training period.
| | Diphenhydramine 14 M/10 F
| No mention of rescue med | Race: NR
| No pre-trial washout period described | Other:
| Dates: April - August 1993, Dutch pollen season
| Location: The Netherlands
| Setting: Academic center
| Type(s) of providers: NR; authors from psychiatry, neuropsychology, and psychopharmacology departments
Williams, Hull, McSorley, et al., 1996 | Design: RCT, parallel-group, randomization stratified to assure uniform sex distribution | No. of subjects at start: 676 | 1) Patient-assessed symptom severity: runny nose; sneezing; itchy nose/throat; tearing, itching, or redness of eyes; and nasal congestion graded twice each day (upon arising and at bedtime) on scale of 0 (absent) to 5 (very severe) | 1) Patient-assessed symptom severity: | Quality Scoring:
| | | | Mean diary symptom scores days 1–14: | Population similar: Yes
| | Dropouts/withdrawals: None reported | | Combination 8.5 | Intervention(s) described: Yes
| | | | Acrivastine 9.8 | Comorbidities described: No
| Interventions: | | | Pseudoephedrine 10.8 | Diagnosis by MD: Yes
| 1) Acrivastine 8 mg + pseudoephedrine 60 mg, combined in a single capsule, four times per day (n = 202–3) | No. of subjects at end: 676 | | Placebo 11.3 | Objectively confirmed: Yes
| | | | P < 0.001 for combination compared to other 3 treatment groups | Outcome measures valid: No
| | Inclusion criteria: Age ≥ 18; positive skin test reaction to mountain cedar; 2-year history of symptoms | | | Level of evidence: 1b
| | | | | Randomized: Yes
| | | | Mean nasal congestion scores days 1–14:
| 2) Acrivastine 8 mg four times per day (n = 202–3)
| | | | Combination 2.3 | Double-blind: Yes
| | Exclusion criteria: Nasal obstruction (turbinates, septal deviation); vasomotor rhinitis; contraindication to study medications; pregnant, lactating, or not on acceptable form of contraception; use of meds known to effect response to study drug within specified times based on drug half-life | 2) Investigator global assessment of efficacy | Acrivastine 2.7 | Blinding adequate: Yes
| 3) Pseudoephedrine 60 mg four times per day (n = 202–3) | | | Pseudoephedrine 2.6 | Dropouts described: yes
| | | | Placebo 2.9 | Intention-to-treat: Yes
| | | 3) Adverse events: spontaneous reports of AEs evaluated | P < 0.001 for combination compared to acrivastine
| 4) Placebo four times per day (n = 68)
| | | | | Note: Precise numbers of patients in active treatment groups not reported (all 202 or 203).
| | | | Mean allergy symptom scores days 1–14:
| Duration of study treatment: 2 weeks
| | | | Combination 6.2
| | | | Acrivastine 7.1
| No mention of rescue med | | | Pseudoephedrine 8.2
| | Age: Mean 36–37, range 18–76 | | Placebo 8.4
| No pre-trial washout period described; individuals taking antihistamines, decongest-ants, MAOIs, cromolyn sodium, or corticosteroids within specified times prior to study (based on half-lives of respective drugs) were excluded | | | P < 0.001 for combination compared to pseudoephedrine
| | Sex: 367 F, 309 M
| | Race: 81–91% white per group | | 2) Investigator global assessment of efficacy: Not abstracted
| | Other: | | 3) Adverse events:
| | | | 12 types of AEs, total number not reported. Most common in combination group relative to placebo group were dry mouth (8%), insomnia (7%), somnolence (7%), and headache (6%).
| Dates: NR (discussion states season lasts from Christmas through February)
| Location: South central Texas
| Setting: 6 outpatient centers
| Type(s) of providers: NR
Wilson, Dempsey, Sims, et al., 2000 | Design: RCT, parallel-group | No. of subjects at start: 40 | 1) Patient-assessed symptom severity: runny nose, blocked/stuffy nose, itchy nose, sneezing, itchy eyes, watery eyes, red eyes, and tickly throat graded twice each day on scale of 0 (no symptoms) to 3 (maximal symptoms) | 1) Patient-assessed symptom severity: | Quality Scoring:
| | | | Total symptom score mean (SEM) after 4 weeks: | Population similar: Yes
| Interventions: | Dropouts/withdrawals: 2 withdrew during placebo run-in phase prior to randomization | | | Intervention(s) described: Yes
| 1) Cetirizine 10 mg + mometasone furoate nasal spray 200 (g (two squirts in each nostril), once daily (n = 14) | | | Cetirizine 4.3 (1.4) ** | Comorbidities described: No
| | | | Cetirizine + mometasone 2.1 (1.1) *** | Diagnosis by MD: Yes
| | | | Cetirizine + montelukast 5.5 (1.2) ** | Objectively confirmed: Yes
| | No. of subjects at end: 38 | | ** P < 0.01 vs. run-in, ***P < 0.001 vs. run-in | Outcome measures valid: No
| | | | | Level of evidence: 1b
| | Inclusion criteria: Symptomatic seasonal allergic rhinitis; positive skin to at least 1 pollen extract | | | Randomized: Yes
| 2) Cetirizine 10 mg + montelukast 10 mg, once daily (n = 11) | | | Cetirizine significantly improved all symptoms at 4 weeks except eye symptoms. Cetirizine + mometasone significantly improved all symptoms at 4 weeks. Cetirizine + montelukast significant improved total, nasal, and eye symptoms only at 4 weeks. | Allocation concealed: Not described
| | | 2) Patient-assessed impact of symptoms on daily activities: graded twice per day on scale of 0 (no interference with daily activity) to 10 (maximal interference with daily activity)
| | | | | Double-blind: No
| | Exclusion criteria: None specified | | | Blinding adequate: Not applicable
| 3) Cetirizine 10 mg + placebo, once daily (n = 13)
| | Age: Mean 30 (SEM 1.4), range 16–65 | | | Dropouts described: Yes
| | | | | Intention-to-treat: Yes
| Duration of study treatment: 4 weeks
| | Sex: 26 F, 12 M | | 2) Patient-assessed impact of symptoms on daily activities:
| | | | | Notes:
| No mention of rescue med | Race: NR | 3) Nasal peak inspiratory flow | Daily activity score after 4 weeks | Double-dummy blinding technique employed.
| | | | Cetirizine 1.1 (0.4) **
| Trial preceded by placebo run-in period, lasting a minimum of 1 week, during which usual medications were suspended | Other: | | Cetirizine + mometasone 0.5 (0.3) ***
| | | | Cetirizine + montelukast 1.8 (0.5) | Pollen levels measured daily during trial.
| | | | ** P < 0.01 vs. run-in, ***P < 0.001 vs. run-in
| | | | | No data on adverse events.
| Dates: June-July 1998 | | | Daily activity not improved significantly in cetirizine + montelukast group.
| Location: Scotland
| | | | 3) Nasal peak inspiratory flow: Not abstracted
| Setting: Outpatient medical school
| Type(s) of providers:
| Allergy specialist

† Quality scoring criteria were as follows:

Population similar: Was the study population described and reasonably similar to an adult working US population? (Yes [described and similar], No [described, but not similar], Not adequately described)

Intervention(s) described: Were the intervention protocols referenced or described in sufficient detail to replicate? (Yes, No)

Comorbidities described: Was the presence of comorbid asthma (or other upper respiratory conditions) described in the study population? (Yes, No)

Diagnosis by MD: Was the diagnosis of allergic rhinitis based on physician diagnosis? (Yes, No, Not applicable [asthma patients only])

Objectively confirmed: If physician-diagnosed, was the diagnosis supported by objective evidence of allergy (e.g., skin prick or serum IgE antibody testing)? (Yes, No, Not applicable)

Outcome measures valid: Were the main outcomes of interest to us measured in a way that has been demonstrated empirically to be valid and reliable (e.g., using a standardized scale such the RQLQ or SF-36)? (Yes, No, Not adequately described)

Level of evidence: Based on Oxford Center for Evidence-Based Medicine Levels of Evidence (1a, 1b, 1c, 2a, 2b, 2c, 3a, 3b, 4, 5)

Randomized: Was the study described as “randomized”? (Yes, No)

Allocation concealed: If the method for concealing allocation from the investigators was described, was it adequate (table of random numbers, computer-generated, coin tossing, etc.) or inadequate (alternating, date of birth, hospital number, etc.)? (Not described, Yes [described and adequate], No [described, but inadequate])

Double-blind: Was the study described as “double-blind”? (Yes, No)

Blinding adequate: If the method of double-blinding was described, was it adequate (e.g., identical placebo, active placebo, injection vs. tablet with double dummy) or inadequate (e.g., tablet vs. injection with no double dummy)? (Not described, Yes [described and adequate], No [described, but inadequate])

Dropouts described: Did the study describe dropouts and withdrawals so that all patients entering the trial could be accounted for? (Yes, No)

Intention-to-treat: Was the analysis performed according to the intention-to-treat principle? (Yes, No, Can't determine)

Evidence Table 5. Clinician Specialty Differences

Study | Design and Interventions | Patient Population | Outcomes Reported | Results | | | | Quality Score^†^/Notes
Brydon, 1993 | Design: Prospective before-after comparison | No. of subjects at start: 53 | 1) GP visits | 1) Of 23 patients with positive skin tests, GP visits dropped 71% (p < 0.001) after consultation with the nurse practitioner. | | | | Quality Scoring:
| | | | | | | | Population similar: Yes
| | Dropouts/withdrawals: 14 | 2) Number of prescriptions written | | | | | Intervention(s) described: No
| Intervention(s): Consultation with allergy nurse practitioner | | | | | | | Comorbidities described: No
| | No. of subjects at end: 39 | | | | | | Diagnosis by MD: Yes
| | | | 2) Of 23 patients with skin positive skin tests, number of scripts dropped 39% (p < 0.001) in the 9 months after consultation with the nurse practitioner. | | | | Objectively confirmed: Yes
| Duration of study treatment: | Inclusion criteria: Referred to nurse practitioner for allergy consultation | | | | | | Outcome measures valid: No
| 9 months prior to consultation and 9 months after | | | | | | | Level of evidence: 4
| Dates: 11/90-3/91 | Exclusion criteria: NR | | | | | | Notes:
| | | | | | | | High dropout rate (25%).
| Location: UK | Age: Median 38 yrs
| | | | | | | | Article implies that nurse practitioners spend more time with allergy sufferers and better educate them, resulting in better management of allergic rhinitis and decreased GP utilization.
| Setting: Patients referred for consultation by general practitioners (GPs) | Sex: 44% female
| | Race: NR
| Type(s) of providers: GPs, nurse practitioners
Camilleri, 1991 | Design: Case series, survey | No. of subjects at start: NR | 1) Duration of steroid use | 1) Mean duration 4.8 months; only 12% used nasal steroid spray for < 4 weeks | | | | Quality Scoring:
| | | 2) Mean dose per month | | | | | Population similar: Yes
| Intervention(s): None | Dropouts/withdrawals: NR | 3) Reported symptoms | | | | | Intervention(s) described: No
| | | 4) Mean standardized total course steroid dose, calculated based on equivalent budesonide dose | 2) Mean 12 mg (range 4.3 – 30.9 mg) | | | | Comorbidities described: No
| Duration of study treatment: | No. of subjects at end: 60 | | 56.5% used recommended dose | | | | Diagnosis by MD: Yes
| NA | | | 15% more than recommended dose | | | | Objectively confirmed: No
| | Inclusion criteria: Referred to otolaryngologist rhinitis clinic for the first fine; report previous failed nasal steroid treatment | | 28.5% less than recommended dose | | | | Outcome measures valid: No
| Dates: NR | | | | | | | Level of evidence: 4
| | | | 3) Reported symptoms
| Location: Glasgow, UK | | | Blocked | 51%
| | | | Catarrh | 27% | | | Notes:
| Setting: Rhinitis clinic | Exclusion criteria: NR | | Drip | 12% | | | Author concluded that no more than 29% of treatment failures could be attributed to lack of patient education.
| | | | Sneeze | 5%
| Type(s) of providers: | Age: Mean 27 years(range 14–68 years) | | Loss of smell | 5%
| Otolaryngologist
| | | | 4) Mean 61 mg (range 2 – 228 mg); median 36 mg (equivalent to 4 spray canisters)
| | Sex: 52% female
| | Race: NR
| | 80% confirmed to have allergic or
Demoly, Allaert Lecasble, et al., 2002 | Design: Survey | No. of subjects at start: | 1) Duration of symptoms at consultation | 1) Current episode 19.6 ± 40.4 days | | | | Quality Scoring:
| | 3026 patients | | | | | | Population similar: Yes
| Intervention(s): None | 1321 physicians | | 2) Past history | | | | Intervention(s) described: No
| | | | None 15.3% | | | | Comorbidities described: No
| Duration of study treatment: NA | Dropouts/withdrawals: NA | 2) Past allergy consultation | 55.5% identified allergen | | | | Diagnosis by MD: Yes
| | | | 42.2% had previous allergy testing | | | | Objectively confirmed: No
| | No. of subjects at end: NA | | 44% previously treated | | | | Outcome measures valid: No
| Dates: May 2000 | | 3) Patient-reported impairments | | | | | Level of evidence: 4
| | Inclusion criteria: First 4 patients consulting physician for intermittent allergic rhinitis during study period. | | 3) Patient-reported impairments
| Location: France | | | 79.2% Occupational impairment
| | | 4) Specialist consultation | 91.8% impaired ADL | | | | Notes:
| Setting: General medical practices throughout France
| | | | 4) Consultation of specialist for 10.3%
| | Exclusion criteria: Patient previously enrolled in a clinical trial or another epidemiological survey. | 5) Treatments prescribed | 78.8% allergologist
| Type(s) of providers: GPs | | | 23.2% ENT specialist
| | | | 11.8% pulmonologist
| | | 6) Predictors of sick leave based on multivariable analysis of patients ordered sick leave (n=137) versus not.
| | | | 5) Treatments prescribed
| | Age: Mean 36.5 ± 13.6 yrs | | Oral antihistamines | 92.4%
| | | | Topical corticosteroids | 45.2%
| | Sex: 47.5% female | | Antiallergic eyedrops | 32.2%
| | | | Topical antihistamines | 16.8%
| | Race: NR | | Local vasoconstrictors | 8.7%
| | | 7) Patient assessment of information/ education needs/ plans | Systemic corticosteroid | 11.7%
| | | | Two or more meds | 74.4%
| | | | Sick leave ordered in 4.6% for 5.7 ± 4.8d
| | | | 6) Predictors of ordering sick leave
| | | | 1^st^ episode p<0.001)
| | | | impaired work p<0.001
| | | | impaired personal life p<0.02
| | | | sleeping difficulty p<0.05
| | | | 7) 79% considered information form physician adequate and easy to understand
| | | | 58.2% wanted more advice
| | | | 94.6% from family doctor
| | | | 13.3% books and magazines
| | | | 11.6% pharmacist
| | | | 54.7% completely adherent to treatment
Francillon, Burnand, Frei, et al., 1995 | Design: Survey | No. of subjects at start: NR | 1) Hay fever score | 1) Hay fever scores not associated with socioprofessional status, referral pattern, age, sex, duration of symptoms or geographic locations. | | | | Quality Scoring:
| | | | | | | | Population similar: Not adequately described
| Intervention(s): NA | Dropouts/withdrawals: NR | 2) Reason for referral
| | | | | | | | Intervention(s) described: Not applicable
| Duration of study treatment: | No. of subjects at end: 126
| NA | | | 2) 30% referred by a physician. Reason for referral because of patients reported symptom severity (63%), or they were looking for a specialist skill (37%). Of those looking for a specialist, 24% wanted optimal treatment, 23% wanted a specific and accurate diagnosis. | | | | Comorbidities described: Yes
| | Inclusion criteria: Referral to clinic and willingness to complete survey | | | | | | Diagnosis by MD: Yes
| Dates: 6–8/92 | | | | | | | Objectively confirmed: No
| | | | | | | | Outcome measures valid: No
| Location: Switzerland | | | | | | | Level of evidence: 4
| | Exclusion criteria: Chief complaint related primarily to asthma or allergic conditions other than hay fever
| Setting: Allergy clinics
| | | | | | | | Note: No data on whether specialist care offers benefits to patients with allergic rhinitis
| Type(s) of providers: GP, allergist
| | Age: Adults (age > 16)
| | Sex: 50% female
| | Race: Italian and French
Gani, Pozzi, Crivellaro, et al., 2001 | Design: RCT | No. of subjects at start: 101 | 1) Compliance rate | 1) Dropout/noncompliance rate | | | | Quality Scoring:
| | | | | A | B | C | Population similar: Yes
| Intervention(s): Patient education adjunct to nasal glucocorticoid spray. | Dropouts/withdrawals: 6 | 2) Nasal symptoms | Dropouts | 4 | 0 | 2 | Intervention(s) described: Yes
| | | | Noncompliant | 9 | 3 | 4 | Comorbidities described: Yes
| | No. of subjects at end: 95 | | Total | 13 | 3 | 6 | Diagnosis by MD: Yes
| 1) written drug information from manufacturer (package insert) | | 3) Ocular symptoms | P=0.001 (A vs. B+C) | | | | Objectively confirmed: Yes
| | Inclusion criteria: 2 year history of SAR solely due to pollens; positive skin test; positive RAST. Referred to nurse practitioner for allergy consultation | | | | | | Outcome measures valid: No
| | | 4) Respiratory symptoms (cough, wheezing, tightness) | 2) Nasal symptoms | | | | Level of evidence: 2b
| 2) training on use of nasal spray and simplified written information | | | Group A | 62.6 ± 51 | | | Randomized: Yes
| | | | Group B | 64.7 ± 50 | | | Allocation concealed : Not described
| | | | Group C | 54.1 ± 62
| 3) detailed lesson on nature of disease | | 4) Drug consumption for symptom control | P=NS | | | | Double-blind: No
| | Exclusion criteria: Sensitization to cat dander, mites or mold; anatomical abnormalities of upper respiratory airways; previous or ongoing SIT; chronic systemic corticosteroid treatment. | | | | | | Blinding adequate: NA
| | | | 3) Ocular symptoms | | | | Dropouts described: Yes
| All patients received regular therapy with mometasone furoate nasal spray (2 puffs per nostril q.i.d. = 200 mcg/d) | | | Group A | 51.3 ± 52.8 | | | Intention-to-treat: No
| | | | Group B | 46.0 ± 52
| | | | Group C | 42.6 ± 55
| | | | P=0.02 | | | | Notes:
| Dates: NR | Age: Mean 30 yrs | | 4) Respiratory symptoms
| | | | Group A | 16.2 ± 24
| Location: Genoa, Italy | Sex: 39% female | | Group B | 11.7 ± 20
| | | | Group C | 6.0 ± 15
| Setting: Allergy clinic | Race: NR | | P=0.02 (A vs. C)
| Type(s) of providers: | 32 patients also had mild asthma and were stratified into 3 treatment groups | | 1) Drug consumption for sx control Oral antihistamines (tablets taken)
| Allergists
| | | | Group A | 8.3 ± 15
| | | | Group B | 4 ± 11.3
| | | | Group C | 1.3 ± 6.1
| | | | P=0.08 (A vs. C)
| | | | 6) Inhaled albuterol (at least one dose)
| | | | Group A | 6(23.8%)
| | | | Group B | 2(5.7%)
| | | | Group C | 0
| | | | P=0.05 (A vs. B+C); P=0.005 (A vs. C)
| | | | 7) Any drug (at least one dose)
| | | | Group A | 13(50%)
| | | | Group B | 12(34%)
| | | | Group C | 5(14.7%)
| | | | P=0.02 (A vs. B+C); P=0.003 (A vs. C)
Lane, Pine, and Pillsbury, 2001 | Design: Case series | No. of subjects at start: 3,329 | 1) Positive skin test responses, defined as 3 or more 2+ reactions or 1 or more 3+ reactions | 1) 2,653 (79.7%) had positive skin test responses. | | | | Quality Scoring:
| | | | | | | | Population similar: Yes
| Intervention(s): Allergy skin testing by intradermal skin end point titration (SET) with a panel of aeroallergens diluted serially in 5-fold decreasing concentrations of the following antigens: Epidermals, mold mix, Trichophyton, Candida, and Epidermophyton species, cotton, house dust mixture (w/o mite antigens, mite (Der f 1), ragweed, weed mix, grass mix, tree mix, and fescue. | Dropouts/withdrawals: NR | | | | | | Intervention(s) described: Not applicable
| | | | 2) 2,008 (75.7%) patients underwent immunotherapy
| | No. of subjects at end: NA | | | | | | Comorbidities described: No
| | | 2) Proportion of patients with positive skin test response who underwent immunotherapy | | | | | Diagnosis by MD: Yes
| | Inclusion criteria: Referral to clinic for allergy skin testing | | 3) Among patients undergoing immunotherapy, improvement was 3.9 on a 1- to 5-point scale. Patients with no improvement in nasal congestion symptoms had an average rating of 3.57, significantly lower than all patients (p = 0.015). | | | | Objectively confirmed: Yes
| | | | | | | | Outcome measures valid: No
| | | | | | | | Level of evidence: 4
| | Exclusion criteria: None
| | | 3) Self-rated effectiveness of immunotherapy
| | Age: 45.2 ± 14.5 years
| | Sex: 58% female | 4) Proportion of current IT patients who underwent nasal or sinus surgery
| | | | 4) A survey of 275 patients currently undergoing immunotherapy showed that 84 (30.5%) had a history of nasal or sinus surgery, either before IT (35.6%), after IT (57.8%) or during IT (6%). Nasal congestion was the symptom most often reported to be improved with surgery (74.3%). Surgical procedures (131 procedures in 72 patients) included septoplasty (59 patients), reduction of inferior turbinates (38 patients) or endoscopic sinus surgery (34 patients), with 54% of patients having more than one procedure. The most frequent combination was septoplasty and reduction of inferior turbinates (n = 18). Mean self-reported effectiveness of IT was not significantly different between patients who had and had not undergone surgery.
| | Race: NR
| Duration of study treatment:
| NA
| Dates: 1979-1999
| Location: Chapel Hill, NC
| Setting: Allergy clinic at academic medical center
| Type(s) of providers:
| Otolaryngologist, allergy nurses
Scadding, Richards, and Price, 2000 | Design: Population-based survey | No. of subjects at start: NR | 1) Consultation distribution | 1) GPs were the main point of contact for education and treatment: | | | | Quality Scoring:
| | | | | | | | Population similar: Yes
| | Dropouts/withdrawals: NR | | 54% of patients consulted GPs | | | | Intervention(s) described: Not applicable
| Intervention(s): NA | | 2) Prevalence of seasonal allergic rhinitis | 27% consulted pharmacists
| | No. of subjects at end: 2139 | | 7% a health food consultant | | | | Comorbidities described: Yes
| Duration of study treatment: | | | 2% a specialist | | | | Diagnosis by MD: No
| NA | Inclusion criteria: Adults listed in the UK electoral register followed by telephone contact; screening criteria not listed | 3) Symptoms | | | | | Objectively confirmed: Not applicable
| | | | 2) Prevalence of seasonal allergic rhinitis:
| Dates: Grass pollen season | | 4) Satisfaction with treatment | | | | | Outcome measures valid: No
| | | | 15% overall | | | | Level of evidence: 1b
| Location: Southern England | | | 23% 16–34 age group
| | Exclusion criteria: NR | | 13% 35–54 age group
| Setting: Community | | | 8% 55+ age group | | | | Note: Does not really provide any information between health care providers other than the aforementioned distribution regarding consultation.
| | Age: 16–65+ years
| Type(s) of providers: NA | | | 3) Symptoms (seasonal allergic rhinitis [SAR] vs. perennial allergic rhinitis [PAR]):
| | Sex: 42% M, 58% F
| | Race: NR | | Symptom | | SAR | PAR
| | | | Sneezing | | 78% | 65%
| | | | Runny nose | | 64% | 59%
| | | | Itchy eyes | | 52% | 31%
| | | | Watery eyes | | 42% | 33%
| | | | Itchy nose | | 41% | 38%
| | | | Headache | | 25% | 41%
| | | | Wheeze | | 15% | 25%
| | | | Blocked nose | | 37% | 46%
| | | | Blocked sinuses | | 37% | 21%
| | | | Sore nose | | 18% | 10%
| | | | 4) Satisfaction with treatment:
| | | | Level of Satisfaction | All | SAR | PAR
| | | | Very | 32% | 17% | 34%
| | | | Reasonably | 28% | 36% | 27%
| | | | Some | 14% | 18% | 12%
| | | | Not | 3% | 10% | 2%
| | | | Not applicable | 24% | 19% | 25%
White, Smith, Baker, et al., 1998 | Design: Postal survey (cohort) | No. of subjects at start: 846 | 1) Usage pattern of the antihistamine and steroid spray by the patient in relation to overall control of symptoms | 1) 54% of patients reported partial or poor control of their symptoms. | | | | Quality Scoring:
| | | | | | | | Population similar: Yes
| | Dropouts/withdrawals: 219 | | | | | | Intervention(s) described: No
| Intervention(s): | | | 69.4% of these were not taking their meds appropriately. | | | | Comorbidities described: No
| 1) Nonsedating antihistamine | No. of subjects at end: 627 (74.1%) | | | | | | Diagnosis by MD: Yes
| | | | | | | | Objectively confirmed: No
| 2) Steroid nasal spray | | | 30.6% of patients were taking their meds appropriately, but did not have full control of their symptoms. | | | | Outcome measures valid: No
| | Inclusion criteria: Identified as having been prescribed a non-sedating antihistamine and a nasal steroid spray by GP | | | | | | Level of evidence: 2b
| Duration of study treatment:
| NR
| | | | At least 15% of the 54% of patients would be suitable for immunotherapy by a specialist. | | | | Note: The article indicates that 54% of the patients seen at the GP clinics are partially/poorly controlled with the medication and dosing regimen they were using. The authors suggest that better control of the symptoms would be achieved with referral to a specialist for immunotherapy but offer no data to support this conclusion.
| Dates: 1994-95
| | Exclusion criteria: NR
| Location: UK
| | Age: 32.8 years ± 13.3
| Setting: Patients selected from GP practices
| | Sex: 54.9% female
| Type(s) of providers: GPs | Race: NR

† Quality scoring criteria were as follows:

Population similar: Was the study population described and reasonably similar to an adult working US population? (Yes [described and similar], No [described, but not similar], Not adequately described)

Intervention(s) described: Were the intervention protocols referenced or described in sufficient detail to replicate? (Yes, No)

Comorbidities described: Was the presence of comorbid asthma (or other upper respiratory conditions) described in the study population? (Yes, No)

Diagnosis by MD: Was the diagnosis of allergic rhinitis based on physician diagnosis? (Yes, No, Not applicable [asthma patients only])

Objectively confirmed: If physician-diagnosed, was the diagnosis supported by objective evidence of allergy (e.g., skin prick or serum IgE antibody testing)? (Yes, No, Not applicable)

Outcome measures valid: Were the main outcomes of interest to us measured in a way that has been demonstrated empirically to be valid and reliable (e.g., using a standardized scale such the RQLQ or SF-36)? (Yes, No, Not adequately described)

Level of evidence: Based on Oxford Center for Evidence-Based Medicine Levels of Evidence (1a, 1b, 1c, 2a, 2b, 2c, 3a, 3b, 4, 5)

Evidence Table 6. Racial and Ethnic Variation

Study | Design and Interventions | Patient Population | Outcomes Reported | Results | Quality Score†/Notes
Fagan, Scheff, Hryhorczuk, et al., 2001 | Design: Cross-sectional, population-based survey | Inclusion criteria: Schoolchildren in grades 7 through 12 | 1) Prevalence - unadjusted | 1) Unadjusted prevalence: | Quality Scoring:
| | | | Rhinitis (lifetime) - 36.3% | Population similar: No
| | | | Rhinitis (12 months) - 31.9% | Intervention(s) described: Not applicable
| Assessment method: Self-administered survey | Sample size: 2044 | 2) Prevalence - adjusted for age, gender, family history of asthma, active smoking and exposure to dampness in past 12 months | Hay fever - 22.4%
| | | | | Comorbidities described: Yes
| | Age: 7^th^ to 12^th^ graders | | 2) Adjusted prevalence African-American vs. other: | Diagnosis by MD: No
| Definitions: | | | | Objectively confirmed: Not applicable
| Rhinitis - sneezing or a runny or blocked nose not associated with a cold or the flu | Sex: 1034 males; 1010 females | | Current rhinitis - Odds ratio 1.0 (95% CI 0.68–1.47)
| | | | | Outcome measures valid: No
| | Race: 1551 white; 332 Hispanic; 163 African-American; 154 other or not reported | | Hay fever - Odds ratio 1.18 (95% CI 0.78–1.78) | Level of evidence: 1b
| | | 3) Functional impairment defined as “interferes with daily activities”
| Hay fever - “yes” response to the question, “Have you ever had hay fever?” | | | 3) Rhinitis functional impairment: | Notes:
| | | | Not at all - 79.9%
| | | | Little - 15.8%
| | | | Moderate - 3.6%
| Response rate: 90% | | | A lot 0.7%
| Dates: 1993 | | | African-Americans were significantly more likely to report functional impairment.
| Location: Illinois, USA
Lebowitz, Cassell, and McCarroll, 1972 | Design: Prospective incidence study of minor illnesses | No. of subjects at start: 448 families | 1) Illness episodes (person days) | 1) Illness episodes: Out of 61,893 person-days of illness, 4255 (6.9%) were due to rhinitis | Quality Scoring:
| | | | | Population similar: No
| | | | | Intervention(s) described: Not applicable
| | Dropouts/withdrawals: NR | 2) Illness duration (mean)
| Assessment method: Weekly interview, using standardized questions to assess 14 symptoms | | | 2) Illness duration: | Comorbidities described: No
| | No. of subjects at end: NR | 3) Illness incidence by sex, age, and race | Average duration of rhinitis was 7.4 days | Diagnosis by MD: No
| | | | | Objectively confirmed: Not applicable
| | Inclusion criteria: Volunteers from a 2-stage cluster sample | | 3) Incidence of rhinitis per person year:
| | | | White - 0.7 per person year | Outcome measures valid: No
| Definitions: | | | Black - 0.4 per person year | Level of evidence: 1b
| Rhinitis - “yes” response to “Did you have a stuffy or runny nose…” that was not associated with a common cold? | Average follow-up: 45 weeks; 1168 person-years of observation | | Puerto Rican - 0.3 per person year
| | | | | Notes:
| | Age: NR | | | No adjustments for age differences in race comparison.
| | Sex: NR
| Dates: 1962-1965
| | Race: NR | | | Follow-up rate is unclear.
| Location: New York City, USA
| | Other:
Lower, Henry, Mandik, et al., 1993 | Design: Retrospective cohort study | No. of subjects: 315 | 1) Non-adherence - patients who had discontinued immunotherapy for ≥ 6 months (presumably prior to completing the full 2- to 4-year course of treatment) | 1) Non-adherence: 138 (44%) | Quality Scoring:
| | | | | Population similar: No
| | Inclusion criteria: Allergic rhinitis, asthma, or atopic dermatitis; computerized medical records; immunotherapy treatment based on specific allergens identified by skin testing, begun at least 1 year prior to study start | | 2) Reasons for non-adherence: | Intervention(s) described: Yes
| Intervention: Immunotherapy given weekly for up to 8 months, then maintenance doses every 2 to 4 weeks for 2 to 4 years | | | Inconvenient: 17 | Comorbidities described: Yes
| | | | Symptoms not decreased: 15 | Diagnosis by MD: Yes
| | | | Symptoms improved: 14 | Objectively confirmed: Yes
| | | | Changed clinic: 14 | Outcome measures valid: No
| | | | Child refused: 9 | Level of evidence: 2b
| | | | Local reaction: 6
| Dates: NR | | 2) Reasons for non-adherence - response to open-ended question administered by telephone | Financial burden: 6
| | Exclusion criteria: None | | Other: 7 | Notes:
| Location: Pittsburgh, USA | | | Could not contact to determine: 50
| | Age: “Pediatric population” (range, 5–18 years)
| Setting: University-affiliated allergy clinic | | | 3) Non-adherence factors:
| | | 3) Factors associated with non-adherence, including gender, race, and type of health insurance | Non-white race and non-private insurance were associated with non-adherence.
| | Sex: 190 male; 125 female
| Type(s) of providers: Allergy specialists
| | Race: 254 white; 59 non-white
| | Other: 52 allergic rhinitis with asthma; 34 allergic rhinitis with atopic dermatitis
Strachan, Sibbald, Weiland, et al., 1997 | Design: International survey (prospective cohort) | No. of subjects 721,601 | 1) Prevalence - reported as a range and by percentiles for the 155 centers | 1) Prevalence: | Quality Scoring:
| | | | Rhinitis (lifetime): ranged from 2.0% to 80.5% | Population similar: No
| | Response rate: 149 of 155 centers achieved response rates of ≥ 80% in the 13- to 14-year-old groups; 89 of 91 centers achieved response rates of ≥ 70% in the 6- to 7-year-old group | | | Intervention(s) described: Not applicable
| Definitions: | | | Rhinitis (12 months): ranged from 1.5% to 66.6%
| Rhinitis - “yes” response to question, “Have you ever had a problem with sneezing or a runny or blocked nose, when you did not have a cold or the flu?” | | | | Comorbidities described: No
| | | | Hay fever (lifetime): ranged from 0% to 54.4% | Diagnosis by MD: No
| | | | | Objectively confirmed: Not applicable
| | | | | Outcome measures valid: No
| | Inclusion criteria: School enrollment and appropriate age or grade level | | | Level of evidence: 1b
| Hay fever - “yes” response to question, “Have you ever had hay fever?”
| | | | | Notes:
| | Age: 6- to 7- (257,800) and 13- to 14-year-olds (463,801)
| Assessment: Questionnaire (self- or parent-completed)
| | Sex: NR
| Dates: NR | Race: NR
| Location: 155 centers in 56 countries | Other:
| setting: Schools selected randomly within each participating center
Turkeltaub and Gergen, 1991 | Design: Population-based survey | No. of subjects: 12,742 | 1) Prevalence, weighted for the sampling design, reported separately for whites and blacks | 1) Prevalence (whites, blacks) Chronic rhinitis: 20.4% (SE 0.5); 19.2% (SE 1.2), p = ns | Quality Scoring:
| | | | | Population similar: Yes
| | Inclusion criteria: None | | | Intervention(s) described: Not applicable
| Definitions: | | | Allergic rhinitis: 9.8% (SE 0.5); 8.1% (SE 0.9), p = ns
| Chronic rhinitis - no physician's diagnosis of hay fever, but frequent nasal and/or eye symptoms that did not vary by both season and pollen during the past 12 months, not counting colds or the flu | Exclusion criteria: None | | | Comorbidities described: ??
| | | 2) Prevalence, weighted for sampling design, and adjusted for age, sex, smoking, poverty level and urban/rural residence | Allergic rhinitis without asthma: 7.8% (SE 0.4); 5.1 (SE 0.6), p < 0.01 | Diagnosis by MD: No
| | Age: Range, 12–74 years | | | Objectively confirmed: Not applicable
| | | | Allergic rhinitis with asthma: 2.0% (SE 0.2); 3.1% (SE 0.5), p < 0.05
| | Sex: 6,174 males; 6,568 females | | | Outcome measures valid: No
| | | | | Level of evidence: 1b
| | Race: 11,260 white (88%); 1,482 Black
| | | | 2) Adjusted prevalence:(whites, blacks) Chronic rhinitis: 20.4% (SE 0.5); 18.8% (SE 1.2), p = ns
| | | | | Notes:
| Allergic rhinits-physician diagnosis of hay fever or frequent nasal and/or eye symptoms that varied by both season and pollen during the past 12 months, not counting colds or the flu
| | | | Allergic rhinitis: 10.0% (SE 0.5); 8.4% (SE 1,1), p = ns
| | | | Allergic rhinitis without asthma: 7.9% (SE 0.4); 5.3 (SE 0.8), p < 0.01
| | | | Allergic rhinitis with asthma: 2.0% (SE 0.2); 3.1% (SE 0.6), p = ns
| Assessments: Interviews using structured questionnaires
| Response rate: 73.1%
| Dates: 1976-1980
| Location: USA
| Setting: Community-based

† Quality scoring criteria were as follows:

Population similar: Was the study population described and reasonably similar to an adult working US population? (Yes [described and similar], No [described, but not similar], Not adequately described)

Intervention(s) described: Were the intervention protocols referenced or described in sufficient detail to replicate? (Yes, No)

Comorbidities described: Was the presence of comorbid asthma (or other upper respiratory conditions) described in the study population? (Yes, No)

Diagnosis by MD: Was the diagnosis of allergic rhinitis based on physician diagnosis? (Yes, No, Not applicable [asthma patients only])

Objectively confirmed: If physician-diagnosed, was the diagnosis supported by objective evidence of allergy (e.g., skin prick or serum IgE antibody testing)? (Yes, No, Not applicable)

Outcome measures valid: Were the main outcomes of interest to us measured in a way that has been demonstrated empirically to be valid and reliable (e.g., using a standardized scale such the RQLQ or SF-36)? (Yes, No, Not adequately described)

Level of evidence: Based on Oxford Center for Evidence-Based Medicine Levels of Evidence (1a, 1b, 1c, 2a, 2b, 2c, 3a, 3b, 4, 5)