# Bibliography

Aabel S. No beneficial effect of isopathic prophylactic treatment for birch pollen allergy during a low-pollen season: a double-blind, placebo-controlled clinical trial of homeopathic Betula 30c. Br Homeopath J. 2000;89(4):169-73. [pmid: 11055773].
Aabel S. Prophylactic and acute treatment with the homeopathic medicine, Betula 30c for birch pollen allergy: a double-blind, randomized, placebo-controlled study of consistency of VAS responses. Br Homeopath J. 2001;90(2):73-8. [pmid: 11341460].
Aabel S, Laerum E, Dolvik S, et al. Is homeopathic ‘immunotherapy” effective? A double-blind, placebo-controlled trial with the isopathic remedy Betula 30c for patients with birch pollen allergy. Br Homeopath J. 2000;89(4):161-8. [pmid: 11055772].
Aalbers R, Kauffman H F, Groen H, et al. The effect of nedocromil sodium on the early and late reaction and allergen-induced bronchial hyperresponsiveness. J Allergy Clin Immunol. 1991;87(5):993-1001. [pmid: 1851191].
Aaronson D W. Side effects of rhinitis medications. J Allergy Clin Immunol. 1998;101(2 II):S379-S382. [pmid: 9500733].
Abd-El-Al A M, Bayoumy A M, Abou Salem E A. A study on Demodex folliculorum in rosacea. J Egyptian Soc Parasitol. 1997;27(1):183-95.
Abelson MB, Lanier RQ. The added benefit of local Patanol therapy when combined with systemic Claritin for the inhibition of ocular itching in the conjunctival antigen challenge model. Acta Ophthalmol Scand Suppl 1999;(228):53–6.
Aberg N. Asthma and allergic rhinitis in Swedish conscripts. Clin Exp Allergy. 1989;19(1):59-63. [pmid: 2784709].
Aberg N, Hesselmar B, Aberg B, et al. Increase of asthma, allergic rhinitis and eczema in Swedish schoolchildren between 1979 and 1991. Clin Exp Allergy. 1995;25(9):815-9. [pmid: 8564719].
Abramson M, Puy R, Weiner J. Immunotherapy in asthma: an updated systematic review. [Review]. Allergy. 1999;54(10):1022-41. [pmid: 10536881].
Abramson M J, Puy R M, Weiner J M. Is allergen immunotherapy effective in asthma? A meta-analysis of randomized controlled trials. Am J Respir Crit Care Med. 1995;151(4):969-74. [pmid: 7697274].
Acero S, Tabar A I, Alvarez M J, et al. Occupational asthma and food allergy due to carmine. Allergy Eur J Allergy Clin Immunol. 1998;53(9):897-901.
Adelroth E, Rak S, Haahtela T, et al. Recombinant humanized mAb-E25, an anti-IgE mAb, in birch pollen-induced seasonal allergic rhinitis. J Allergy Clin Immunol. 2000;106(2):253-9. [pmid: 10932067].
Adelsberg B R. Sedation and performance issues in the treatment of allergic conditions. [Review]. Arch Intern Med. 1997;157(5):494-500. [pmid: 9066452].
Adkins J C, Brogden R N. Zafirlukast: A review of its pharmacology and therapeutic potential in the management of asthma. Drugs. 1998;55(1):121-44. [pmid: 9463793].
Adkinson N F. Immunotherapy for allergic rhinitis. N Engl J Med. 1999;341:522-4. [pmid: 10441610].
Agostini J V, Leo-Summers L S, Inouye S K. Cognitive and other adverse effects of diphenhydramine use in hospitalized older patients. Arch Intern Med. 2001;161(17):2091-7. [pmid: 11570937].
Agrawal D K. Pharmacology and clinical efficacy of desloratadine as an anti-allergic and anti-inflammatory drug. Expert Opin Invest Drugs. 2001;10(3):547-60.
Ahman M, Holmstrom M, Ingelman-Sundberg H. Inflammatory markers in nasal lavage fluid from industrial arts teachers. Am J Ind Med. 1995;28(4):541-50. [pmid: 8533794].
Akaho E, Runion H I, Inoue K. American and Japanese drug distribution and information systems in 1994 and a proposed system for improved pharmaceutical care. Drug Inf J. 1999;33(2):487-508.
Akcakaya N, Hassanzadeh A, Camcioglu Y, et al. Local and systemic reactions during immunotherapy with adsorbed extracts of house dust mite in children. Ann Allergy Asthma Immunol. 2000;85(4):317-21. [pmid: 11061476].
Akmanlar N, Altintas D U, Guneser K S, et al. Comparison of conventional and rush immunotherapy with der PI in childhood respiratory allergy. Allergol Immunopathol (Madr). 2000;28(4):213-8. [pmid: 11022267].
Al Frayh A R, Shakoor Z, Gad El Rab M O, et al. Increased prevalence of asthma in Saudi Arabia. Ann Allergy Asthma Immunol. 2001;86(3):292-6. [pmid: 11289327].
Al-Shammari S A, Khoja T A, Al-Ansary L A, et al. Care of asthmatic patients in primary health care centers. Ann Saudi Med. 1996;16(1):24-8. [pmid: 17372397].
Alam R, Dejarnatt A, Stafford S, et al. Selective inhibition of the cutaneous late but not immediate allergic response to antigens by misoprostol, a PGE analog. Results of a double-blind, placebo-controlled randomized study. Am Rev Respir Dis. 1993;148(4 Pt 1):1066-70. [pmid: 8214926].
Alldred A. Etanercept in rheumatoid arthritis. Expert Opin Pharmacother. 2001;2(7):1137-48. [pmid: 11583065].
Allsup S J, Gosney M, Regan M, et al. Side effects of influenza vaccination in healthy older people: A randomised single-blind placebo-controlled trial. Gerontology. 2001;47(6):311-4. [pmid: 11721144].
Althaus M A, Pichler W J. Nasal application of a gel formulation of N-acetyl-aspartyl glutamic acid (NAAGA) compared with placebo and disodium cromoglycate in the symptomatic treatment of pollinosis. Allergy Eur J Allergy Clin Immunol. 1994;49(3):184-8.
Altman D G, Bland J M. Absence of evidence is not evidence of absence. BMJ. 1995;311(7003):485. [pmid: 7647644].
Alvarez-Cuesta E, Cuesta-Herranz J, Puyana-Ruiz J, et al. Monoclonal antibody-standardized cat extract immunotherapy: Risk-benefit effects from a double-blind placebo study. J Allergy Clin Immunol. 1994;93(3):556-66. [pmid: 8151058].
Alvarez-Cuesta E, Gonzelez-Mancebo E. Immunotherapy in bronchial asthma. Curr Opin Pulm Med. 2000;6(1):50-4. [pmid: 10608426].
Alves B, Sheikh A, Hurwitz B, et al. Allergen injection immunotherapy for seasonal allergic rhinitis (Protocol for a Cochrane Review). In: The Cochrane Library, Issue 1, 2002. Oxford: Update Software.
American Academy of Allergy, Asthma & Immunology. The allergy report. Milwaukee, WI: American Academy of Allergy, Asthma & Immunology, Inc.; 2000.
Andersen N H, Jeppesen F, Schioler T, et al. Treatment of hay fever with sodium cromoglycate, hyposensitization, or a combination. Allergy. 1987;42(5):343-51. [pmid: 3115130].
Anderson E R, Murphy M P, Weymuller E A Jr. Clinimetric evaluation of the Sinonasal Outcome Test-16. Otolaryngol Head Neck Surg. 1999;121(6):702-7. [pmid: 10580223].
Anderson H R, Pottier A C, Strachan D P. Asthma from birth to age 23: incidence and relation to prior and concurrent atopic disease. Thorax. 1992;47(7):537-42. [pmid: 1412098].
Andersson M, Berglund R, Greiff L, et al. A comparison of budesonide nasal dry powder with fluticasone propionate aqueous nasal spray in patients with perennial allergic rhinitis. Rhinology. 1995;33(1):18-21. [pmid: 7784789].
Andersson M, Rimmer J, Salome C, et al. Dual symptomatic and exudative nasal responses are not characteristics of perennial allergic rhinitis. Acta Oto-Laryngol. 2001;121(3):407-13.
Andre C, Vatrinet C, Galvain S, et al. Safety of sublingual-swallow immunotherapy in children and adults. Int Arch Allergy Immunol. 2000;121(3):229-34. [pmid: 10729782].
Andri L, Senna G, Andri G, et al. Local nasal immunotherapy for birch allergic rhinitis with extract in powder form. Clin Exp Allergy. 1995;25(11):1092-9. [pmid: 8581842].
Andri L, Senna G, Betteli C, et al. Local nasal immunotherapy with extract in powder form is effective and safe in grass pollen rhinitis: a double-blind study. J Allergy Clin Immunol. 1996;97(1 Pt 1):34-41. [pmid: 8568135].
Andri L, Senna G, Betteli C, et al. Local nasal immunotherapy for Dermatophagoides-induced rhinitis: efficacy of a powder extract. J Allergy Clin Immunol. 1993;91(5):987-96. [pmid: 8491949].
Andri L, Senna G E, Betteli C, et al. Local nasal immunotherapy in allergic rhinitis to Parietaria. A double-blind controlled study. Allergy. 1992;47(4 Pt 1):318-23. [pmid: 1443452].
Andri L, Senna GE, Betteli C, et al. Combined treatment of allergic rhinitis with terfenadine and nimesulide, a non-steroidal antiinflammatory drug. Allerg Immunol (Paris) 1992;24(8):313–4, 317–9.
Ankier S I, Warrington S J. A double-blind placebo-controlled study of the efficacy and tolerability of ebastine against hayfever in general practice patients. J Intern Med. 1989;226(6):453-8. [pmid: 2577377].
Anonymous. A trial of house dust mite extract in bronchial asthma. Mite Allergy Subcommittee of the Research Committee of the British Thoracic Association. Br J Dis Chest 1979;73(3):260–70.
Anonymous. Regulatory control and standardization of allergenic extracts. Clinical studies with “standardized” extracts. Arbeiten Aus Dem Paul-Ehrlich-Institut, Dem Georg-Speyer-Haus Und Dem Ferdinand-Blum-Institut Zu Frankfurt A.M. 1985;(79):279–309.
Anonymous. Astemizole - Another non-sedating antihistamine. Med Lett Drugs Ther 1989;31(791):43–4.
Anonymous. A large-scale, office-based study evaluates the use of a new class of non-sedating antihistamines. A report from CEN. J Am Board Fam Pract 1990;3(4):241–52.
Anonymous. Intranasal triamcinolone for allergic rhinitis. Med Lett Drugs Ther 1991;33(859):116–7.
Anonymous. English physicians favor extended role for pharmacists. Am J Hosp Pharm 1992;49(11):2648, 2651.
Anonymous. Entex pse tabs. Pharmindex 1992;34(9):7.
Anonymous. Safety of terfenadine and astemizole. Med Lett Drugs Ther 1992;34(863):9–10.
Anonymous. Tritan tabs. Pharmindex 1992;34(9):6.
Anonymous. Information your patient can use: A directional study. Part I. Immunol Allergy Pract. 1993. 15(9–10):303–6.
Anonymous. Itraconazole. Med Lett Drugs Ther 1993;35(888):7–10.
Anonymous. Loratadine - A new antihistamine. Med Lett Drugs Ther 1993;35(902):71–2.
Anonymous. Acrivastine/pseudoephedrine (Semprex-D) for seasonal allergic rhinitis. Med Lett Drugs Ther 1994;36(930):78–80.
Anonymous. Cisapride for nocturnal heartburn. Med Lett Drugs Ther 1994;36(915):11–3.
Anonymous. Intranasal budesonide for allergic rhinitis. Med Lett Drugs Ther 1994;36(926):63–4.
Anonymous. Ophthalmic levocabastine for allergic conjunctivitis. Med Lett Drugs Ther 1994;36(920):35–6.
Anonymous. Oral pilocarpine for xerostomia. Med Lett Drugs Ther 1994;36(929):76.
Anonymous. Claritin. Formulary 1995;30(12):745.
Anonymous. Fluticasone propionate nasal spray for allergic rhinitis. Med Lett Drugs Ther 1995;37(940):5–6.
Anonymous. Antihistamine cleared. P T 1996;21(3):111.
Anonymous. Cetirizine - A new antihistamine. Med Lett Drugs Ther 1996;38(970):21–3.
Anonymous. Fexofenadine. Med Lett Drugs Ther 1996;38(986):95–6.
Anonymous. Ipratropium bromide nasal spray available. Female Patient Ob Gyn Ed 1996;21(5):83.
Anonymous. Once-daily formulation for allergy drug approved. P T 1996;21(11):582.
Anonymous. Azelastine for seasonal allergic rhinitis. Am Fam Phys 1997;55(7):2541.
Anonymous. Azelastine nasal spray for allergic rhinitis. Med Lett Drugs Ther 1997;39(1000):45–7.
Anonymous. Ceclor CD. Formulary 1997;32(2):119.
Anonymous. Claritin reditabs. Formulary 1997;32(4):333.
Anonymous. Flomax: Alpha-adrenergic blocker for BPH. Formulary 1997;32(7):659–60.
Anonymous. Mibefradil release expands calcium-channel-blocker choices. Am J Health-Syst Pharm 1997;54(18):2033.
Anonymous. Pulmozyme. Formulary 1997;32(2):114.
Anonymous. Budesonide turbuhaler for asthma. Med Lett Drugs Ther 1998;40(1018):15–6.
Anonymous. Executive summary. Allergy Eur J Allergy Clin Immunol Suppl 1998;53(41):7–31.
Anonymous. Irbesartan: How does it stack up against others of its class? Drugs Ther Perspect 1998;11(5):1–5.
Anonymous. Mizolastine expands the choice of second-generation antihistamines for allergic rhinitis. Drugs Ther Perspect 1998;12(9):1–6.
Anonymous. Rhinitis. Ann Allergy Asthma Immunol 1998;80(4):287.
Anonymous. Treatment of childhood allergic rhinitis is less than optimal. Drugs Ther Perspect 1998;12(2):5–9.
Anonymous. Allergic factors associated with the development of asthma and the influence of cetirizine in a double-blind, randomised, placebo-controlled trial: first results of ETAC. Early Treatment of the Atopic Child. Pediatr Allergy Immunol 1998;9(3):116–24.
Anonymous. Aventis. Formulary 1999;34(10 Suppl):19–27.
Anonymous. Concluding points. Round Table Ser R Soc Med 1999;67:65.
Anonymous. Infusion reactions associated with the therapeutic use of monoclonal antibodies in the treatment of malignancy. Cancer Metastasis Rev 1999;18(4):465–71.
Anonymous. Johnson and Johnson (A focus on Ortho-McNeil and Janssen). Formulary 1999;34(10 Suppl):51–5.
Anonymous. Natural selection: Exploring alternative remedies. Occup Health 1999;51(12):30–1.
Anonymous. New preparation of terfenadine, without cardiotoxicity. Can Fam Phys 1999;45:2073–81.
Anonymous. Sinus woes cost billions to treat each year: bad situation gets worse. Case Manage Advisor 1999;10(12):190, 196.
Anonymous. Cevimeline (Evoxac) for dry mouth. Med Lett Drugs Ther 2000;42(1084):70.
Anonymous. CME Quiz. Am J Manag Care 2000;6(1 Suppl):S19–S20.
Anonymous. Drugs for prevention and treatment of postmenopausal osteoporosis. Med Lett Drugs Ther 2000;42(1090):97–100.
Anonymous. Fexofenadine a first-line option for seasonal allergic rhinitis and chronic idiopathic urticaria. Drugs Ther Perspect 2000;16(8):1–5.
Anonymous. New drugs for allergic conjunctivitis. Med Lett Drugs Ther 2000;42(1077):39–46.
Anonymous. Approval for Schering-Plough drug. Manuf Chem 2001;72(2):8.
Anonymous. AstraZeneca opens new Pound Sterling45m high tech r&d site. Manuf Chem 2001;72(11):12.
Anonymous. Aventis increases Allegra production. Manuf Chem 2001;72(4):12.
Anonymous. Nebulized budesonide for asthma in children. Med Lett Drugs Ther 2001;43(1096):6–7.
Anonymous. Thunderstorms and asthma excerbations. Med Today 2001;2(7):10.
Anonymous. Budesonide (Entocort EC) for Crohn's disease. Med Lett Drugs Ther 2002;44(1122):6–8.
Antonicelli L, Bilò M B, Pucci S, et al. Efficacy of an air-cleaning device equipped with a high efficiency particulate air filter in house dust mite respiratory allergy. Allergy. 1991;46(8):594-600. [pmid: 1789401].
Ariano R, Kroon A M, Augeri G, et al. Long-term treatment with allergoid immunotherapy with Parietaria. Clinical and immunologic effects in a randomized, controlled trial. Allergy. 1999;54(4):313-9. [pmid: 10371089].
Ariano R, Panzani R C, Chiapella M, et al. Local immunotherapy of seasonal allergic rhinitis in children due to Parietaria officinalis pollen: A preliminary report. Pediatr Asthma Allergy Immunol. 1993;7(4):227-37.
Ariano R, Panzani R C, Chiapella M, et al. Local intranasal immunotherapy with allergen in powder in atopic patients sensitive to Parietaria officinalis pollen. J Investig Allergol Clin Immunol. 1995;5(3):126-32.
Ariano R, Panzani R C, Saraga J. New clinical data and therapeutic prospects in Cupressaceae pollen allergy. Allerg Immunol (Paris). 2000;32(3):135-8. [pmcid: 267442]. [pmid: 10815250].
Arlian L G, Morgan M S. Serum antibody to Sarcoptes scabiei and house dust mite prior to and during infestation with S. scabiei. Vet Parasitol. 2000;90(4):315-26. [pmid: 10856817].
Arruda L K, Platts-Mills T A, Longbottom J L, et al. Aspergillus fumigatus: identification of 16, 18, and 45 kd antigens recognized by human IgG and IgE antibodies and murine monoclonal antibodies. J Allergy Clin Immunol. 1992;89(6):1166-76. [pmid: 1607551].
Arvidsson M B, Löwhagen O, Rak S. Effect of 2-year placebo-controlled immunotherapy on airway symptoms and medication in patients with birch pollen allergy. J Allergy Clin Immunol. 2002;109(5):777-83. [pmid: 11994699].
Aschan G. Decongestion of nasal mucous membranes by oral medication in acute rhinitis. A rhinomanometric study to demonstrate synergism between antihistamines and adrenergic substance. Acta Otolaryngol (Stockh). 1974;77(6):433-8. [pmid: 4600134].
Asher B F, Seidman M, Snyderman C. Complementary and alternative medicine in otolaryngology. Laryngoscope. 2001;111(8):1383-9. [pmid: 11568573].
Asher M I, Keil U, Anderson H R, et al. International Study of Asthma and Allergies in Childhood (ISAAC): rationale and methods. Eur Respir J. 1995;8(3):483-91. [pmid: 7789502].
Assa'ad A, Lierl M. Effect of acellular pertussis vaccine on the development of allergic sensitization to environmental allergens in adults. J Allergy Clin Immunol. 2000;105(1 Pt 1):170-5. [pmid: 10629468].
Astarita C, Scala G, Sproviero S, et al. Effects of enzyme-potentiated desensitization in the treatment of pollinosis: a double-blind placebo-controlled trial. J Investig Allergol Clin Immunol. 1996;6(4):248-55.
Aversa A, Fabbri A. New oral agents for erectile dysfunction: What is changing in our practice?. Asian J Androl. 2001;3(3):175-9. [pmid: 11561186].
Babu K S, Arshad S H, Holgate S T. Anti-IgE treatment: An update. Allergy Eur J Allergy Clin Immunol. 2001;56(12):1121-8.
Babu K S, Salvi S S. Aspirin and asthma. Chest. 2000;118(5):1470-6. [pmid: 11083703].
Bachert C I. Importance of quality of life in patients with seasonal allergic rhinitis. Rev Fr Allergol Immunol Clin. 2000;40(1):74-7.
Backhouse C I. Intra-nasal flunisolide in the treatment of allergic rhinitis in general practice. Curr Med Res Opin. 1979;6(1):14-9. [pmid: 378554].
Backhouse C I, Finnamore V P, Gosden C W. Treatment of seasonal allergic rhinitis with flunisolide and terfenadine. J Int Med Res. 1986;14(1):35-41. [pmid: 3082694].
Bagenstose S E, Bernstein J A. Treatment of chronic rhinitis by an allergy specialist improves quality of life outcomes. Ann Allergy Asthma Immunol. 1999;83(6 Pt 1):524-8. [pmid: 10619343].
Bahceciler N N, Isik U, Barlan I B, et al. Efficacy of sublingual immunotherapy in children with asthma and rhinitis: a double-blind, placebo-controlled study. Pediatr Pulmonol. 2001;32(1):49-55. [pmid: 11416876].
Bahir A, Goldberg A, Mekori Y A, et al. Continuous avoidance measures with or without acaricide in dust mite-allergic asthmatic children. Ann Allergy Asthma Immunol. 1997;78(5):506-12. [pmid: 9164365].
Baiardini I, Pasquali M, Giardini A, et al. Quality of life in respiratory allergy. [Review]. Allergy Asthma Proc. 2001;22(3):177-81. [pmid: 11424880].
Bailey D A, Gilleran L G, Merchant P G. Waivers for disqualifying medical conditions in U.S. Naval Aviation personnel. Aviat Space Environ Med. 1995;66(5):401-7. [pmid: 7619031].
Baker S B. The dilemma of anesthetizing the child with an upper respiratory tract infection. Semin Anesth. 1992;11(4):265-73.
Baldwin C M, Bell I R, O'Rourke M K, et al. The association of respiratory problems in a community sample with self-reported chemical intolerance. Eur J Epidemiol. 1997;13(5):547-52. [pmid: 9258567].
Balkissoon R, Shusterman D J. Occupational upper airway disorders. Semin Respir Crit Care Med. 1999;20(6):569-80.
Banks D E, Shah A A, Lopez M, et al. Chest illnesses and the decline of FEV1 in steelworkers. J Occup Environ Med. 1999;41(12):1085-90. [pmid: 10609229].
Banz K, Schwicker D, Thomas A M. Economic evaluation of immunoprophylaxis in children with recurrent ear, nose and throat infections. Pharmacoeconomics. 1994;6(5):464-77. [pmid: 10155274].
Baraldi E, Azzolin N M, Carra S, et al. Effect of topical steroids on nasal nitric oxide production in children with perennial allergic rhinitis: a pilot study. Respir Med. 1998;92(3):558-61. [pmid: 9692122].
Baraniuk J M, Meltzer E O, Spector S L. Impact of allergic rhinitis and related airway disorders. J Respir Dis. 1996;17(Suppl):511-23.
Bardana E J Jr. Occupational asthma and related respiratory disorders. Dis Mon. 1995;41(3):145-90.
Bardare M, Zani G, Novembre E, et al. Local nasal immunotherapy with a powder extract for grass pollen induced rhinitis in pediatric ages: a controlled study. J Investig Allergol Clin Immunol. 1996;6(6):359-63.
Barnes C, Tuck J, Simon S, et al. Allergenic materials in the house dust of allergy clinic patients. Ann Allergy Asthma Immunol. 2001;86(5):517-23. [pmid: 11379802].
Baroody F M. Developments in the drug treatment of allergic rhinitis. Curr Opin Otolaryngol Head Neck Surg. 1998;6(1):6-17.
Barrett J, Dunkin J W, Shelton M. Examination of the NHANES data set: pets, wheezing, and allergy symptoms. South Online J Nurs Res. 2001;2(1):1-11.
Barth D, Hair J A, Kunkle B N, et al. Efficacy of eprinomectin against mange mites in cattle. Am J Vet Res. 1997;58(11):1257-9. [pmid: 9361888].
Bascom R. Environmental factors and respiratory hypersensitivity: the Americas. Toxicol Letters. 1996;86(23):115-30.
Basnyet D, Basnyet J. Allergies understood: conventional and complementary approaches. Positive Health. 2000;56:19-22.
Bast G. WAO invites Member Societies to host GLORIA(TM) program. Allergy Clin Immunol Int. 2001;13(4):182.
Baur X. New aspects of isocyanate asthma. Lung. 1990;168(Suppl):606-13. [pmid: 2117170].
Baur X, Chen Z, Marczynski B. Respiratory diseases caused by occupational exposure to 1,5-naphthalene-diisocyanate (NDI): Results of workplace-related challenge tests and antibody analyses. Am J Ind Med. 2001;39(4):369-72. [pmid: 11323786].
Beck H I, Korsgaard J. Atopic dermatitis and house dust mites. Br J Dermatol. 1989;120(2):245-51. [pmid: 2923797].
Becker A. Clinical evidence with montelukast in the management of chronic childhood asthma. Drugs. 2000;59(Suppl 1):29-34. [pmid: 10741880].
Becker A. Leukotriene receptor antagonists: efficacy and safety in children with asthma. Pediatr Pulmonol. 2000;30(2):183-6. [pmid: 10922144].
Beckman D B, Grammer L C. Pharmacotherapy to prevent the complications of allergic rhinitis. [Review]. Allergy Asthma Proc. 1999;20(4):215-23. [pmid: 10476319].
Belchi-Hernandez J, Mora-Gonzalez A, Iniesta-Perez J. Baker's asthma caused by Saccharomyces cerevisiae in dry powder form. J Allergy Clin Immunol. 1996;97(1 I):131-4. [pmid: 8568127].
Bellanti J A, Wallerstedt D B. Allergic rhinitis update: epidemiology and natural history. [Review]. Allergy Asthma Proc. 2000;21(6):367-70. [pmid: 11191103].
Bellussi L, Passali D. Treatment of upper airways inflammation with nimesulide. Drugs. 1993;46(Suppl 1):107-10. [pmid: 7506146].
Benincasa C, Lloyd R S. Evaluation of fluticasone propionate aqueous nasal spray taken alone and in combination with cetirizine in the prophylactic treatment of seasonal allergic rhinitis. Drug Invest. 1994;8(4):225-33.
Benninger M S, Sedory Holzer S E, Lau J. Diagnosis and treatment of uncomplicated acute bacterial rhinosinusitis: summary of the Agency for Health Care Policy and Research evidence-based report. Otolaryngol Head Neck Surg. 2000;122(1):1-7. [pmid: 10629474].
Benninger M S, Senior B A. The development of the Rhinosinusitis Disability Index. Arch Otolaryngol Head Neck Surg. 1997;123(11):1175-9. [pmid: 9366696].
Bentley S. Performance in students with seasonal allergy. J Int Med Res. 1980;8(3):221-3. [pmid: 7389990].
Berdeaux G, Hervie C, Smajda C, et al. Parental quality of life and recurrent ENT infections in their children: development of a questionnaire. Rhinitis Survey Group. Qual Life Res. 1998;7(6):501-12. [pmid: 9737140].
Berdeaux G, Lafuma A, Perruchet A M, et al. Cost effectiveness of immunoprophylaxis in the prevention of recurrent infectious rhinitis in adults. Pharmacoeconomics. 1998;14(3):313-22. [pmid: 10186469].
Berger I, Argaman Z, Schwartz S B, et al. Efficacy of corticosteroids in acute bronchiolitis: short-term and long-term follow-up. Pediatr Pulmonol. 1998;26(3):162-6. [pmid: 9773910].
Berger W E, Fineman S M, Lieberman P, et al. Double-blind trials of azelastine nasal spray monotherapy versus combination therapy with loratadine tablets and beclomethasone nasal spray in patients with seasonal allergic rhinitis. Rhinitis Study Groups. Ann Allergy Asthma Immunol. 1999;82(6):535-41. [pmid: 10400480].
Bergmann R L, Edenharter G, Bergmann K E, et al. Socioeconomic status is a risk factor for allergy in parents but not in their children. Clin Exp Allergy. 2000;30(12):1740-5. [pmid: 11122212].
Bergqvist A, Jacobson J, Harris S. A double blind randomized study of the treatment of endometriosis with nafarelin or nafarelin plus norethisterone. Gynecol Endocrinol. 1997;11(3):187-94. [pmid: 9209899].
Berman B A, Ross R N. Antihistamines and the management of allergic rhinitis in the workplace. Adv Ther. 1996;13(2):95-102.
Bernstein D I. Desloratadine: A viewpoint. Drugs. 2001;61(6):797.
Bernstein D I, Schoenwetter W F, Nathan R A, et al. Efficacy and safety of fexofenadine hydrochloride for treatment of seasonal allergic rhinitis. Ann Allergy Asthma Immunol. 1997;79(5):443-8. [pmid: 9396979].
Bernstein I L, Tennenbaum J, Georgakis N, et al. Fraction A: a new immunotherapeutic approach for ragweed pollinosis. Int Arch Allergy Appl Immunol. 1976;50(2):181-91. [pmid: 1107233].
Bernstein J A. Cost-benefit analysis for allergen immunotherapy. Immunol Allergy Clin North Am. 2000;20(3):593-608.
Bertoni M, Cosmi F, Bianchi I, et al. Clinical efficacy and tolerability of a steady dosage schedule of local nasal immunotherapy. Results of preseasonal treatment in grass pollen rhinitis. Ann Allergy Asthma Immunol. 1999;82(1):47-51. [pmid: 9988206].
Bertrand B, Jamart J, Marchal J L, et al. Cetirizine and pseudoephedrine retard alone and in combination in the treatment of perennial allergic rhinitis: a double-blind multicentre study. Rhinology. 1996;34(2):91-6. [pmid: 8876070].
Besag F M C, Dulac O, Alving J, et al. Long-term safety and efficacy of lamotrigine (Lamictal(R)) in paediatric patients with epilepsy. Seizure. 1997;6(1):51-6. [pmid: 9061824].
Beyzarov E P. Eye relief: New ophthalmic product promises to bring fast relief to allergic conjunctivitis sufferers. Drug Topics. 2000;144(13):15.
Biostat. Comprehensive Meta-analysis [computer program]. Version 1.25. Englewood, NJ: Biostat; 1999.
Black H R, Sollins J S, Garofalo J L. The addition of doxazosin to the therapeutic regimen of hypertensive patients inadequately controlled with other antihypertensive medications: A randomized, placebo-controlled study. Am J Hypertens. 2000;13(5 I):468-74. [pmid: 10826396].
Black P N, Blasi F, Jenkins C R, et al. Trial of roxithromycin in subjects with asthma and serological evidence of infection with Chlamydia pneumoniae. Am J Respir Crit Care Med. 2001;164(4):536-41. [pmid: 11520711].
Blainey A D, Phillips M J, Ollier S, et al. Hyposensitization with a tyrosine adsorbed extract of Dermatophagoides pteronyssinus in adults with perennial rhinitis. A controlled clinical trial. Allergy. 1984;39(7):521-8. [pmid: 6388401].
Blair H. Natural history of childhood asthma. 20-year follow-up. Arch Dis Child. 1977;52(8):613-9. [pmid: 921306].
Blair H, Viner A S. A double blind trial of a 2% solution of sodium cromoglycate in perennial rhinitis. Clin Allergy. 1975;5(2):139-43. [pmid: 806396].
Blaiss M S. How to determine the cost-effectiveness of available allergic rhinitis treatments. Drug Benefit Trends. 1998;10:32-6.
Blaiss M S. Quality of life in allergic rhinitis. [Review]. Ann Allergy Asthma Immunol. 1999;83(5):449-54. [pmid: 10582730].
Blaiss M S. Cognitive, social, and economic costs of allergic rhinitis. [Review]. Allergy Asthma Proc. 2000;21(1):7-13. [pmid: 10748946].
Blanc P D, Trupin L, Earnest G, et al. Alternative therapies among adults with a reported diagnosis of asthma or rhinosinusitis: data from a population-based survey. Chest. 2001;120(5):1461-7. [pmid: 11713120].
Blanc P D, Trupin L, Eisner M, et al. The work impact of asthma and rhinitis: findings from a population-based survey. J Clin Epidemiol. 2001;54(6):610-8. [pmid: 11377122].
Blomqvist A M, Axelsson I G K, Danielsson D, et al. Atopic allergy to chloramine-T and the demonstration of specific IgE antibodies by the radioallergosorbent test. Int Arch Occup Environ Health. 1991;63(5):363-5. [pmid: 1765415].
Blose J S, Adams K F Jr, Patterson J H. Torsemide: A pyridine-sulfonylurea loop diuretic. Ann Pharmacother. 1995;29(4):396-402. [pmid: 7633019].
Blumenthal M N, Schwartz R H, Kaiser H. Nedocromil sodium 2% ophthalmic solution for the treatment of ragweed pollen seasonal allergic conjunctivitis. Ocul Immunol Inflamm. 2000;8(3):159-67. [pmid: 11120577].
Bødtger U, Poulsen L K, Jacobi H H, et al. The safety and efficacy of subcutaneous birch pollen immunotherapy -- a one-year, randomised, double-blind, placebo-controlled study. Allergy. 2002;57:297-305. [pmid: 11906359].
Bolhaar S T H P, Van Ginkel C J W. Occupational allergy to cyclamen. Allergy Eur J Allergy Clin Immunol. 2000;55(4):411-2.
Bonifazi F, Bilo M B. Efficacy of specific immunotherapy in allergic asthma: myth or reality?. Allergy. 1997;52(7):698-710. [pmid: 9265984].
Boonsawat W, Salome C M, Woolcock A J. Effect of allergen inhalation on the maximal response plateau of the dose-response curve to methacholine. Am Rev Respir Dis. 1992;146(3):565-9. [pmid: 1519829].
Bousquet J. Allergic rhinitis: Review of guidelines. Rev Fr Allergol Immunol Clin. 1998;38(10):938-41.
Bousquet J. Allergy - A global problem. Allergy Clin Immunol Int. 2000;12(4):141-2.
Bousquet J. Allergic rhinitis as a global health problem. Allergy Clin Immunol Int. 2001;13(4):137.
Bousquet J, Bullinger M, Fayol C, et al. Assessment of quality of life in patients with perennial allergic rhinitis with the French version of the SF-36 Health Status Questionnaire. J Allergy Clin Immunol. 1994;94(2 Pt 1):182-8. [pmid: 8064070].
Bousquet J, Chanal I, Murrieta M, et al. Lack of subsensitivity to mizolastine over 8-week treatment. Allergy. 1996;51(4):251-6. [pmid: 8792922].
Bousquet J, Davies R J. Chairmen's introduction. Clin Exp Allergy Suppl. 1998;28(6):1.
Bousquet J, Demoly P, Michel F B. Specific immunotherapy in rhinitis and asthma. Ann Allergy Asthma Immunol. 2001;87(1 Suppl):38-42. [pmid: 11476474].
Bousquet J, Duchateau J, Pignat J C, et al. Improvement of quality of life by treatment with cetirizine in patients with perennial allergic rhinitis as determined by a French version of the SF-36 questionnaire. J Allergy Clin Immunol. 1996;98(2):309-16. [pmid: 8757208].
Bousquet J, Frank E, Soussana M, et al. Double-blind, placebo-controlled immunotherapy with a high-molecular-weight, formalinized allergoid in grass pollen allergy. Int Arch Allergy Appl Immunol. 1987;82(34):550-2. [pmid: 3553031].
Bousquet J, Hejjaoui A, Skassa-Brociek W, et al. Double-blind, placebo-controlled immunotherapy with mixed grass-pollen allergoids. I. Rush immunotherapy with allergoids and standardized orchard grass-pollen extract. J Allergy Clin Immunol. 1987;80(4):591-8. [pmid: 3668124].
Bousquet J, Hejjaoui A, Soussana M, et al. Double-blind, placebo-controlled immunotherapy with mixed grass-pollen allergoids. IV. Comparison of the safety and efficacy of two dosages of a high-molecular-weight allergoid. J Allergy Clin Immunol. 1990;85(2):490-7. [pmid: 2406327].
Bousquet J, Lockey R, Malling H J. Allergen immunotherapy: therapeutic vaccines for allergic diseases. A WHO position paper. [Review]. J Allergy Clin Immunol. 1998;102(4 Pt 1):558-62. [pmid: 9802362].
Bousquet J, Lockey R, Malling H J, et al. Allergen immunotherapy: therapeutic vaccines for allergic diseases. World Health Organization. American Academy of Allergy, Asthma and Immunology. [Review]. Ann Allergy Asthma Immunol. 1998;81(5 Pt 1):401-5. [pmid: 9860031].
Bousquet J, Lockey R F, Malling H J. Preface: Allergen immunotherapy: Therapeutic vaccines for allergic diseases. Allergy Eur J Allergy Clin Immunol Suppl. 1998;53(44):1-42.
Bousquet J, Maasch H J, Hejjaoui A, et al. Double-blind, placebo-controlled immunotherapy with mixed grass-pollen allergoids. III. Efficacy and safety of unfractionated and high-molecular-weight preparations in rhinoconjunctivitis and asthma. J Allergy Clin Immunol. 1989;84(4 Pt 1):546-56. [pmid: 2677092].
Bousquet J, Scheinmann P, Guinnepain M T, et al. Sublingual-swallow immunotherapy (SLIT) in patients with asthma due to house-dust mites: a double-blind, placebo-controlled study. Allergy. 1999;54(3):249-60. [pmid: 10321561].
Bousquet J, van Cauwenberge P, Khaltaev N, et al. Allergic rhinitis and its impact on asthma (ARIA). J Allergy Clin Immunol. 2001;108:S147-336. [pmid: 11707753].
Bowler S D, Mitchell C A, Miles J. House dust control and asthma: a placebo-control trial of cleaning air filtration. Ann Allergy. 1985;55(3):498-500. [pmid: 4037436].
Boyce E G, Umland E M. Sildenafil citrate: A therapeutic update. Clin Ther. 2001;23(1):2-23. [pmid: 11219477].
Bramer S L, Suri A. Inhibition of CYP2D6 by quinidine and its effects on the metabolism of cilostazol. Clin Pharmacokinet. 1999;37(Suppl 2):41-51. [pmid: 10702886].
Branco-Ferreira M, dos Santos M C, Palma-Carlos M L, et al. Antihistamines and serum adhesion molecule levels. Allergi Immunol (Paris). 2001;33(6):233-6. [pmcid: 275431].
Braun J J, Alabert J P, Michel F B, et al. Adjunct effect of loratadine in the treatment of acute sinusitis in patients with allergic rhinitis. Allergy. 1997;52(6):650-5. [pmid: 9226059].
Breitenbach J M, Ferreira F, Jilek A, et al. Biological and immunological importance of Bet v 1 isoforms. Adv Exp Med Biol. 1996;409:117-26. [pmid: 9095231].
Bridi A A, Rehbein S, Carvalho L A, et al. Efficacy of ivermectin in a controlled release formulation against Psoroptes ovis (Hering, 1838) gervais, 1841 (Acari: Psoroptidae) on sheep. Vet Parasitol. 1998;78(3):215-21. [pmid: 9760063].
Brigden M L. A practical workup for eosinophilia: You can investigate the most likely causes right in your office. Postgrad Med. 1999;105(3):193-210. [pmid: 10086043].
Briggs A H, O'Brien B J. The death of cost-minimization analysis? [Review]. Health Econ. 2001;10(2):179-84. [pmid: 11252048].
Brisman J, Jarvholm B, Lillienberg L. Exposure-response relations for self reported asthma and rhinitis in bakers. Occup Environ Med. 2000;57(5):335-40. [pmid: 10769299].
Broder I, Higgins M W, Mathews K P, et al. Epidemiology of asthma and allergic rhinitis in a total community, Tecumseh, Michigan. 3. Second survey of the community. J Allergy Clin Immunol. 1974;53(3):127-38. [pmid: 4813888].
Brogden R N, McTavish D. Budesonide. An updated review of its pharmacological properties, and therapeutic efficacy in asthma and rhinitis. Drugs. 1992;44(3):375-407. [pmid: 1382936].
Bronsky E, Boggs P, Findlay S, et al. Comparative efficacy and safety of a once-daily loratadine-pseudoephedrine combination versus its components alone and placebo in the management of seasonal allergic rhinitis. J Allergy Clin Immunol. 1995;96(2):139-47. [pmid: 7636050].
Bronsky E A, Druce H, Findlay S R, et al. A clinical trial of ipratropium bromide nasal spray in patients with perennial nonallergic rhinitis. J Allergy Clin Immunol. 1995;95(5 II):1117-22. [pmid: 7751528].
Brooks C D, Francom S F, Peel B G, et al. Spectrum of seasonal allergic rhinitis symptom relief with topical corticoid and oral antihistamine given singly or in combination. Am J Rhinol. 1996;10(3):193-9.
Brooks C D, Karl K J. Hay fever treatment with combined antihistamine and cyclooxygenase-inhibiting drugs. J Allergy Clin Immunol. 1988;81(6):1110-7. [pmid: 2897986].
Brooks C D, Nelson A, Parzyck R, et al. Protective effect of hydroxyzine and phenylpropanolamine in the challenged allergic nose. Ann Allergy. 1981;47(5 Pt 1):316-9. [pmid: 7316247].
Brown CS, Parker NG, Stegbauer CC. Managing allergic rhinitis. Nurse Pract 1999;24:107–8, 110–1, 115–7, 120.
Brown C W, Hawkins L. Allergy prevalence and causal factors in the domestic environment: results of a random population survey in the United Kingdom. Ann Allergy Asthma Immunol. 1999;83(3):240-4. [pmid: 10507270].
Brown H M, Merrett T G. Effectiveness of an acaricide in management of house dust mite allergy. Ann Allergy. 1991;67(1):25-31. [pmid: 1859037].
Bruce C A, Norman P S, Rosenthal R R, et al. The role of ragweed pollen in autumnal asthma. J Allergy Clin Immunol. 1977;59(6):449-59. [pmid: 68044].
Bruce H. Rhinitis. Prim Care Clin Off Pract. 1990;17(2):309-22.
Brunet C, Bedard P M, Lavoie A, et al. Allergic rhinitis to ragweed pollen. I. Reassessment of the effects of immunotherapy on cellular and humoral responses. J Allergy Clin Immunol. 1992;89(1 Pt 1):76-86. [pmid: 1370510].
Brunet C, Bedard P M, Lavoie A, et al. Allergic rhinitis to ragweed pollen. II. Modulation of histamine-releasing factor production by specific immunotherapy. J Allergy Clin Immunol. 1992;89(1 Pt 1):87-94. [pmid: 1370511].
Brunton S. Allergic rhinitis: breaking the cycle of disease and treatment. Fam Pract Recertification 1997;19(9):14–6, 23–6, 29–32.
Bryant D H, Burns M W, Lazarus L. The correlation between skin tests, bronchial provocation tests and the serum level of IgE specific for common allergens in patients with asthma. Clin Allergy. 1975;5(2):145-57. [pmid: 1139766].
Brydon M. The effectiveness of a peripatetic allergy nurse practitioner service in managing atopic allergy in general practice--a pilot study. Clin Exp Allergy. 1993;23(12):1037-44. [pmid: 10779298].
Buchanan DJ, Hillis A, Williams PN. A double blind controlled trial of Bencard house dust mite (Migen) hyposensitisation in Zambian asthmatics. Med J Zambia 1980-1981;15(1):14–6.
Buckman R, Lewith G. What does homoeopathy do - and how?. BMJ. 1994;309(6947):103-6. [pmid: 8038642].
Bukstein D A, Biondi R M, Blumenthal M M, et al. Tilarin in combination with astemizole. Allergy. 1996;51(28 Suppl):20-7. [pmid: 8651473].
Bumsted R M. Cryotherapy for chronic vasomotor rhinitis: Technique and patient selection for improved results. Laryngoscope. 1984;94(4):539-44. [pmid: 6708699].
Buntinx F, Van Krunkelsven P, Morabia A, et al. Antibiotics for the common cold. Lancet. 1996;348(9029):754-5. [pmid: 8806309].
Burney P, Malmberg E, Chinn S, et al. The distribution of total and specific serum IgE in the European Community Respiratory Health Survey. J Allergy Clin Immunol. 1997;99(3):314-22. [pmid: 9058686].
Burr M L, Dean B V, Butland B K, et al. Prevention of mite infestation of bedding by means of an impregnated sheet. A randomized controlled trial. Allergy. 1988;43(4):299-302. [pmid: 3291634].
Burr M L, Dean B V, Merrett T G, et al. Effects of anti-mite measures on children with mite-sensitive asthma: a controlled trial. Thorax. 1980;35(7):506-12. [pmid: 7001667].
Burr M L, Miskelly F G, Butland B K, et al. Environmental factors and symptoms in infants at high risk of allergy. J Epidemiol Community Health. 1989;43(2):125-32. [pmid: 2687426].
Burr M L, Neale E, Dean B V, et al. Effect of a change to mite-free bedding on children with mite-sensitive asthma: a controlled trial. Thorax. 1980;35(7):513-4. [pmid: 7001668].
Burr M L, St Leger A S, Neale E. Anti-mite measurements in mite-sensitive adult asthma. A controlled trial. Lancet. 1976;1(7955):333-5. [pmid: 54740].
Burris J F, Davidov M E, Jenkins P, et al. Comparison of the antihypertensive effects of betaxolol and chlorthalidone as monotherapy and in combination. Arch Intern Med. 1989;149(11):2437-41. [pmid: 2684073].
Burtin B, Duchateau J, Pignat J C, et al. Further improvement of quality of life by cetirizine in perennial allergic rhinitis as a function of treatment duration. J Investig Allergol Clin Immunol. 2000;10(2):66-70.
Burton W N, Conti D J, Chen C Y, et al. The impact of allergies and allergy treatment on worker productivity. J Occup Environ Med. 2001;43(1):64-71. [pmid: 11201771].
Busse W, Janssens M, Eisen G. A multicenter, double-blind, randomized, placebo-controlled trial comparing the efficacy and tolerability of levocabastine-oxymetazoline nasal spray with levocabastine and oxymetazoline alone in the symptomatic treatment of seasonal allergic rhinitis. Am J Rhinol. 1996;10(2):105-11.
Butterfield J H, Gleich G J, Yunginger J W, et al. Immunotherapy with short ragweed fraction A:D-glutamic acid:D-lysine polymer in ragweed hay fever. J Allergy Clin Immunol. 1981;67(4):272-8. [pmid: 6970763].
Butz A M, Larson E, Fosarelli P, et al. Occurrence of infectious symptoms in children in day care homes. Am J Infect Control. 1990;18(6):347-53. [pmid: 2285172].
Caffarelli C, Sensi L G, Marcucci F, et al. Preseasonal local allergoid immunotherapy to grass pollen in children: a double-blind, placebo-controlled, randomized trial. Allergy. 2000;55(12):1142-7. [pmid: 11117271].
Calhoun K H. Chronic rhinosinusitis: Cost-effective work-up, guidelines for treatment. Consultant. 1997;37(12):3112-22.
Call R S, Smith T F, Morris E, et al. Risk factors for asthma in inner city children. J Pediatr. 1992;121(6):862-6. [pmid: 1447646].
Call R S, Ward G, Jackson S, et al. Investigating severe and fatal asthma. J Allergy Clin Immunol. 1994;94(6 Pt 1):1065-72. [pmid: 7798539].
Camilleri A E. Information leaflets in the rhinitis clinic?. J Laryngol Otol. 1991;105(4):282-4. [pmid: 2026941].
Campbell F, Jones K. Feather vs. non-feather bedding for asthma (Cochrane Review). In: the Cochrane Library, Issue 4, 2001, Oxford: Update Software, 2001.
Canady R G, Platts-Mills T, Murphy A, et al. Vital capacity reservoir and online measurement of childhood nitrosopnea are linearly related. Clinical implications. Am J Respir Crit Care Med. 1999;159(1):311-4. [pmid: 9872855].
Cantani A, Arcese G, Lucenti P, et al. A three-year prospective study of specific immunotherapy to inhalant allergens: Evidence of safety and efficacy in 300 children with allergic asthma. J Investig Allergol Clin Immunol. 1997;7(2):90-7.
Canter D, Frank G J, Knapp L E, et al. Quinapril and hydrochlorothiazide combination for control of hypertension: Assessment by factorial design. J Hum Hypertens. 1994;8(3):155-62. [pmid: 8006914].
Caramia G, Franceschini F, Cimarelli Z A, et al. The efficacy of E.P.D., a new immunotherapy, in the treatment of allergic diseases in children. Allerg Immunol (Paris). 1996;28(9):308-10. [pmcid: 267442]. [pmid: 8986246].
Cariski AT. Cilostazol: A novel treatment option in intermittent claudication. Int J Clin Pract Suppl 2001;-(119):11–8.
Carlsen K H, Kramer J, Fagertun H E, et al. Loratadine and terfenadine in perennial allergic rhinitis. Treatment of nonresponders to the one drug with the other drug. Allergy. 1993;48(6):431-6. [pmid: 8238798].
Carosso A, Ruffino C, Bugiani M. The effect of birth season on pollenosis. Ann Allergy. 1986;56(4):300-3. [pmid: 3963521].
Carpenter L L, McDougle C J, Epperson C N, et al. A risk-benefit assessment of drugs used in the management of obsessive-compulsive disorder. Drug Saf. 1996;15(2):116-34. [pmid: 8884163].
Carsons S. A review and update of Sjogren's syndrome: Manifestations, diagnosis, and treatment. Am J Manag Care. 2001;7(14 Suppl):S433-S443. [pmid: 11605978].
Carswell F, Birmingham K, Oliver J, et al. The respiratory effects of reduction of mite allergen in the bedrooms of asthmatic children—a double-blind controlled trial. Clin Exp Allergy. 1996;26(4):386-96. [pmid: 8732235].
Carswell F, Oliver J, Weeks J. Do mite avoidance measures affect mite and cat airborne allergens?. Clin Exp Allergy. 1999;29(2):193-200. [pmid: 10051723].
Carswell F, Robinson D W, Oliver J, et al. House dust mites in Bristol. Clin Allergy. 1982;12(6):533-45. [pmid: 7151267].
Carter M C, Perzanowski M S, Raymond A, et al. Home intervention in the treatment of asthma among inner-city children. J Allergy Clin Immunol. 2001;108(5):732-7. [pmid: 11692097].
Casale T B. Anti-immunoglobulin E (omalizumab) therapy in seasonal allergic rhinitis. Am J Respir Crit Care Med. 2001;164(8 II):S18-S21. [pmid: 11704613].
Casale T B. Experience with monoclonal antibodies in allergic mediated disease: Seasonal allergic rhinitis. J Allergy Clin Immunol. 2001;108(2 Suppl):S84-S88. [pmid: 11498678].
Casale T B, Bernstein I L, Busse W W, et al. Use of an anti-IgE humanized monoclonal antibody in ragweed-induced allergic rhinitis. J Allergy Clin Immunol. 1997;100(1):110-21. [pmid: 9257795].
Casale T B, Condemi J, LaForce C, et al. Effect of Omalizumab on symptoms of seasonal allergic rhinitis: a randomized controlled trial. JAMA. 2001;286:2956-67. [pmid: 11743836].
Casanovas M, Guerra F, Moreno C, et al. Double-blind, placebo-controlled clinical trial of preseasonal treatment with allergenic extracts of Olea europaea pollen administered sublingually. J Investig Allergol Clin Immunol. 1994;4(6):305-14.
Casiano R R. Treatment of acute and chronic rhinosinusitis. Semin Respir Infect. 2000;15(3):216-26. [pmid: 11052422].
Castelain M, Birnbaum J, Castelain P Y, et al. Patch test reactions to mite antigens: a GERDA multicentre study. Groupe d'Etudes et de Recherches en Dermato-Allergie. Contact Dermatitis. 1993;29(5):246-50. [pmid: 8112063].
Centers for Disease Control and Prevention, National Center for Health Statistics. Current estimates from the National Health Interview Survey, 1996. Vital and Health Statistics, Series 10, No. 200. DHHS Publication No. (PHS) 99–1528. Hyattsville, MD: US Department of Health and Human Services. October 1999.
Cereghino J J, Biton V, Abou-Khalil B, et al. Levetiracetam for partial seizures: results of a double-blind, randomized clinical trial. Neurology. 2000;55(2):236-42. [pmid: 10908898].
Chan-Yeung M, Ferguson A, Chan H, et al. Umbilical cord blood mononuclear cell proliferative response to house dust mite does not predict the development of allergic rhinitis and asthma. J Allergy Clin Immunol. 1999;104(2 Pt 1):317-21. [pmid: 10452751].
Chan-Yeung M, Manfreda J, Dimich-Ward H, et al. A randomized controlled study on the effectiveness of a multifaceted intervention program in the primary prevention of asthma in high-risk infants. Arch Pediatr Adolesc Med. 2000;154(7):657-63. [pmid: 10891016].
Chan-Yeung M, Manfreda J, Dimich-Ward H, et al. Mite and cat allergen levels in homes and severity of asthma. Am J Respir Crit Care Med. 1995;152(6 Pt 1):1805-11. [pmid: 8520740].
Chang J H, Becker A, Ferguson A, et al. Effect of application of benzyl benzoate on house dust mite allergen levels. Ann Allergy Asthma Immunol. 1996;77(3):187-90. [pmid: 8814042].
Chang M Y, Hogan A D, Rakes G P, et al. Salivary cotinine levels in children presenting with wheezing to an emergency department. Pediatr Pulmonol. 2000;29(4):257-63. [pmid: 10738012].
Chapman J, Girardeau C, O'Coneell E J. We have made progress but there is still work to be done. Ann Allergy Asthma Immunol. 2000;85(3):159. [pmid: 11030267].
Chapman J A. How relevant are pollen and mold spore counts to clinical practice?. Ann Allergy Asthma Immunol. 2000;84(5):467-8. [pmid: 10830995].
Chapman M D, Heymann P W, Wilkins S R, et al. Monoclonal immunoassays for major dust mite (Dermatophagoides) allergens, Der p I and Der f I, and quantitative analysis of the allergen content of mite and house dust extracts. J Allergy Clin Immunol. 1987;80(2):184-94. [pmid: 3611539].
Chapman M D, Platts-Mills T A, Gabriel M, et al. Antibody response following prolonged hyposensitization with Dermatophagoides pteronyssinus extract. Int Arch Allergy Appl Immunol. 1980;61(4):431-40. [pmid: 7364496].
Chapman M D, Pollart S M, Luczynska C M, et al. Hidden allergic factors in the etiology of asthma. [Review]. Chest. 1988;94(1):185-90. [pmid: 3289835].
Chapman M D, Rowntree S, Mitchell E B, et al. Quantitative assessments of IgG and IgE antibodies to inhalant allergens in patients with atopic dermatitis. J Allergy Clin Immunol. 1983;72(1):27-33. [pmid: 6853930].
Charman C. Clinical evidence: atopic eczema. [Review]. BMJ. 1999;318(7198):1600-4. [pmid: 10364122].
Charpin D, Kleisbauer J P, Lanteaume A, et al. Asthma and allergy to house-dust mites in populations living in high altitudes. Chest. 1988;93(4):758-61. [pmid: 3258228].
Chatterjee S. Immunotherapeutic strategies to combat allergic respiratory diseases. Indian J Pharmacol. 2001;33(4):293.
Chen C C, Hsieh K H. Effects of Microstop-treated anti-mite bedding on children with mite-sensitive asthma. Acta Paed Sin. 1996;37(6):420-7.
Chen JL. Failure of desensitization in the management of vancomycin hypersensitivity. [Abstract]. ASHP Midyear Clin Mtg 1993;28:P-443(D).
Chesnut I C H, Silverman S, Andriano K, et al. A randomized trial of nasal spray salmon calcitonin in postmenopausal women with established osteoporosis: The prevent recurrence of osteoporotic fractures study. Am J Med. 2000;109(4):267-76. [pmid: 10996576].
Chew F T, Goh D Y, Lee B W. Effects of an acaricide on mite allergen levels in the homes of asthmatic children. Acta Paediatr Japonica. 1996;38(5):483-8.
Chinn S. A simple method for converting an odds ratio to effect size for use in meta-analysis. Stat Med. 2000;19(22):3127-31. [pmid: 11113947].
Chinn S, Jarvis D, Luczynska C, et al. Individual allergens as risk factors for bronchial responsiveness in young adults. Thorax. 1998;53(8):662-7. [pmid: 9828852].
Chowdhury I, Chatterjee B. The immunological and clinical effects of immunotherapy in patients suffering from house dust allergy. Ann Agric Environ Med. 1999;6(2):91-7. [pmid: 10607989].
Chowgule R V, Shetye V M, Parmar J R, et al. Prevalence of respiratory symptoms, bronchial hyperreactivity, and asthma in a megacity. Results of the European community respiratory health survey in Mumbai (Bombay). Am J Respir Crit Care Med. 1998;158(2):547-54. [pmid: 9700134].
Cicutto LC, Chapman KR. Approaches to unresponsive asthma. Drug Benefit Trends 2001;13(6):34–6, 55–60.
Cipolla C, Lugo G, Sassi C, et al. A new risk of occupational disease: Allergic asthma and rhinoconjunctivitis in persons working with beneficial arthropods. Int Arch Occup Environ Health. 1996;68(2):133-5. [pmid: 8720284].
Ciprandi G. Relationships between allergic diseases: Conjunctivitis, rhinitis and asthma. Drug News Perspect. 1997;10(5):317-20.
Ciprandi G, Cosentino C, Milanese M, et al. Fexofenadine reduces nasal congestion in perennial allergic rhinitis. Allergy Eur J Allergy Clin Immunol. 2001;56(11):1068-70.
Ciprandi G, Pronzato C, Ricca V, et al. Loratadine treatment of rhinitis due to pollen allergy reduces epithelial ICAM-1 expression. Clin Exp Allergy. 1997;27(10):1175-83. [pmid: 9383258].
Ciprandi G, Ricca V, Tosca M, et al. Continuous antihistamine treatment controls allergic inflammation and reduces respiratory morbidity in children with mite allergy. Allergy. 1999;54(4):358-65. [pmid: 10371095].
Ciprandi G, Tosca M, Passalacqua G, et al. Long-term cetirizine treatment reduces allergic symptoms and drug prescriptions in children with mite allergy. Ann Allergy Asthma Immunol. 2001;87(3):222-6. [pmid: 11570619].
Ciprandi G, Tosca M, Ricca V, et al. Cetirizine treatment of rhinitis in children with pollen allergy: Evidence of its antiallergic activity. Clin Exp Allergy. 1997;27(10):1160-6. [pmid: 9383256].
Cirla A M, Sforza N, Roffi G P, et al. Preseasonal intranasal immunotherapy in birch-alder allergic rhinitis. A double-blind study. Allergy. 1996;51(5):299-305. [pmid: 8836333].
Clavel R, Bousquet J, Andre C. Clinical efficacy of sublingual-swallow immunotherapy: a double-blind, placebo-controlled trial of a standardized five-grass-pollen extract in rhinitis. Allergy. 1998;53(5):493-8. [pmid: 9636808].
Cleophas T J M, Tavenier P. Clinical trials in chronic diseases. J Clin Pharmacol. 1995;35(6):594-8. [pmid: 7665719].
Clerico D M. Sources and effects of indoor air pollution, including sick building syndrome. Curr Opin Otolaryngol Head Neck Surg. 1996;4(1):44-9.
Cloosterman S G, Bijl-Hofland I D, van Herwaarden C L, et al. A placebo-controlled clinical trial of regular monotherapy with short-acting and long-acting beta(2)-agonists in allergic asthmatic patients. Chest. 2001;119(5):1306-15. [pmid: 11348933].
Cloosterman S G, Hofland I D, Lukassen H G, et al. House dust mite avoidance measures improve peak flow and symptoms in patients with allergy but without asthma: a possible delay in the manifestation of clinical asthma?. J Allergy Clin Immunol. 1997;100(3):313-9. [pmid: 9314342].
Cloosterman S G, Schermer T R, Bijl-Hofland I D, et al. Effects of house dust mite avoidance measures on Der p 1 concentrations and clinical condition of mild adult house dust mite-allergic asthmatic patients, using no inhaled steroids. Clin Exp Allergy. 1999;29(10):1336-46. [pmid: 10520054].
Cloud M L, Enas G C, Kemp J, et al. A specific LTD4/LTE4-receptor antagonist improves pulmonary function in patients with mild, chronic asthma. Am Rev Respir Dis. 1989;140(5):1336-9. [pmid: 2554766].
Clover A. Patient benefit survey: Tunbridge Wells Homoeopathic Hospital 1997. Br Homeopath J. 2000;89(Suppl 1):S45.
Cockburn I M, Bailit H L, Berndt E R, et al. Loss of work productivity due to illness and medical treatment. J Occup Environ Med. 1999a;41(11):948-53. [pmid: 10570499].
Cockburn I M, Bailit H L, Berndt E R, et al. Costing out care: when antihistamines go to work. Bus Health. 1999b;17(3):49-50. [pmid: 10387170].
Cockcroft D W, Cuff M T, Tarlo S M, et al. Allergen injection therapy with glutaraldehyde-modified—ragweed pollen-tyrosine adsorbate. A double-blind trial. J Allergy Clin Immunol. 1977;60(1):56-62. [pmid: 406299].
Coffman D A, Jenkins M. Intranasal betamethasone valerate in seasonal rhinitis. Practitioner. 1975;215(1289):665-8. [pmid: 665].
Cohen J. Statistical power analysis for the behavioral sciences. Hillsdale, NJ: L. Erlbaum Associates; 1988.
Cohen L. Indoor air quality a major public-health issue, workshop told. Can Med Assoc J. 1995;153(1):92-3. [pmid: 7796382].
Cohen S G, King J R. Skin tests: A historic trail. Immunol Allergy Clin North Am. 2001;21(2):191-249.
Colberg K, Hettich M, Sigmund R, et al. The efficacy and tolerability of an 8-day administration of intravenous and oral meloxicam: A comparison with intramuscular and oral diclofenac in patients with acute lumbago. Curr Med Res Opin. 1995;13(7):363-77. [pmid: 8862936].
Colgan R, Powers J H. Appropriate antimicrobial prescribing: Approaches that limit antibiotic resistance. Am Fam Phys. 2001;64(6):999-1004.
Collard Ph, Rodenstein D O. Nasal continuous positive airway pressure for sleep apnoea. Eur Respir Monogr. 1998;3(10):179-204.
Colloff M J. House dust mite control with Acarosan—an extreme test?. Clin Exp Allergy. 1992;22(7):657-8. [pmid: 1504885].
Colloff M J, Lever R S, McSharry C. A controlled trial of house dust mite eradication using natamycin in homes of patients with atopic dermatitis: effect on clinical status and mite populations. Br J Dermatol. 1989;121(2):199-208. [pmid: 2673323].
Compston J E. Pharmacological interventions for post-menopausal osteoporosis: An evidence-based approach. Rheumatology (UK). 2000;39(12):1309-12. [pmcid: 128936].
Comstock G W, Stone R W, Tonascia J A, et al. Respiratory survey findings as predictors of disability from respiratory diseases. Am Rev Respir Dis. 1981;124(4):367-71. [pmid: 7294499].
Conde H D J, Palma A J L, Delgado R J, et al. Comparison of azelastine nasal spray and oral ebastine in treating seasonal allergic rhinitis. Curr Med Res Opin. 1995;13(6):299-304. [pmid: 8829888].
Condemi J, Schulz R, Lim J. Triamcinolone acetonide aqueous nasal spray versus loratadine in seasonal allergic rhinitis: efficacy and quality of life. Ann Allergy Asthma Immunol. 2000;84(5):533-8. [pmid: 10831008].
Cook PR, Farias C. The safety of allergen immunotherapy: a literature review. [Review]. Ear Nose Throat J 1998;77(5):378–9, 383–8.
Cools M, Van Bever H P, Weyler J J, et al. Long-term effects of specific immunotherapy, administered during childhood, in asthmatic patients allergic to either house-dust mite or to both house-dust mite and grass pollen. Allergy. 2000;55(1):69-73. [pmid: 10696859].
Cooper C, Srakkestad J A, Radowicki S, et al. Matrix delivery transdermal 17beta-estradiol for the prevention of bone loss in postmenopausal women. Osteoporosis Int. 1999;9(4):358-66.
Cooper N K. A cheaper preparation of disodium cromoglycate in the treatment of allergic rhinitis. J R Army Med Corps. 1989;135(1):34. [pmid: 2494325].
Cooper P J, Darbyshire J, Nunn A J, et al. A controlled trial of oral hyposensitization in pollen asthma and rhinitis in children. Clin Allergy. 1984;14(6):541-50. [pmid: 6391735].
Corey J P, Kemker B J, Branca J T, et al. Health status in allergic rhinitis. Otolaryngol Head Neck Surg. 2000;122(5):681-5. [pmid: 10793346].
Corne J, Djukanovic R, Thomas L, et al. The effect of intravenous administration of a chimeric anti-IgE antibody on serum IgE levels in atopic subjects: efficacy, safety, and pharmacokinetics. J Clin Invest. 1997;99(5):879-87. [pmid: 9062345].
Cornere M, Fitzharris P, Douglas R. Immunotherapy: practical guide to administration. New Ethicals. 1999;2:67-72.
Corrado O J, Pastorello E, Ollier S, et al. A double-blind study of hyposensitization with an alginate conjugated extract of D. pteronyssinus (Conjuvac) in patients with perennial rhinitis. 1. Clinical aspects. Allergy. 1989;44(2):108-15. [pmid: 2655491].
Corren J. Allergic rhinitis and asthma: How important is the link?. J Allergy Clin Immunol. 1997;99(2):S781-S786. [pmid: 9042071].
Corren J. The impact of allergic rhinitis on bronchial asthma. J Allergy Clin Immunol. 1998;101(2 II):S352-S356. [pmid: 9500726].
Corren J, Harris A G, Aaronson D, et al. Efficacy and safety of loratadine plus pseudoephedrine in patients with seasonal allergic rhinitis and mild asthma. [erratum appears in J Allergy Clin Immunol 1998 Jun;101(6 Pt 1):792]. J Allergy Clin Immunol. 1997;100(6 Pt 1):781-8. [pmid: 9438487].
Cote J, Cartier A, Robichaud P, et al. Influence of asthma education on asthma severity, quality of life and environmental control. Can Respir J. 2000;7(5):395-400. [pmid: 11058207].
Craig-McFeely P M, Acharya N V, Shakir S A W. Evaluation of the safety of fexofenadine from experience gained in general practice use in England in 1997. Eur J Clin Pharmacol. 2001;57(4):313-20. [pmid: 11549210].
Craig T, Sawyer A M, Fornadley J A. Use of immunotherapy in a primary care office. Am Fam Physician. 1998;57(8):1888-94. [pmid: 9575326].
Crane J, Ellis I, Siebers R, et al. A pilot study of the effect of mechanical ventilation and heat exchange on house-dust mites and Der p 1 in New Zealand homes. Allergy. 1998;53(8):755-62. [pmid: 9722224].
Crater S E, Peters E J, Martin M L, et al. Expired nitric oxide and airway obstruction in asthma patients with an acute exacerbation. Am J Respir Crit Care Med. 1999;159(3):806-11. [pmid: 10051254].
Crater S E, Peters E J, Phillips C D, et al. Prospective analysis of CT of the sinuses in acute asthma. AJR Am J Roentgenol. 1999;173(1):127-31. [pmid: 10397112].
Creticos P S. Immunotherapy with allergens. J Am Med Assoc. 1992;268(20):2834-9.
Creticos P S, Reed C E, Norman P S, et al. Ragweed immunotherapy in adult asthma. N Engl J Med. 1996;334(8):501-6. [pmid: 8559203].
Criner G J, Brennan K, Travaline J M, et al. Efficacy and compliance with noninvasive positive pressure ventilation in patients with chronic respiratory failure. Chest. 1999;116(3):667-75. [pmid: 10492269].
Crobach M, Hermans J, Kaptein A, et al. Nasal smear eosinophilia for the diagnosis of allergic rhinitis and eosinophilic non-allergic rhinitis. Scand J Prim Health Care. 1996;14(2):116-21. [pmid: 8792506].
Crobach M J J, Hermans J, Kaptein A A, et al. The diagnosis of allergic rhinitis: How to combine the medical history with the results of radioallergosorbent tests and skin prick tests. Scand J Prim Health Care. 1998;16(1):30-6. [pmid: 9612876].
Cross S. Mould spores: the unusual suspects in hay fever. Community Nurse. 1997;3(4):25-6. [pmid: 9451141].
Cross S, Buck S, Hubbard J. ABC of allergies: Allergy in general practice. BMJ. 1998;316(7144):1584-7. [pmid: 9596600].
Crown WH. Productivity measurement in pharmaceutical studies. Drug Benefit Trends 2000;12(2):5BH-8BH.
Crystal-Peters J, Crown W H, Goetzel R Z, et al. The cost of productivity losses associated with allergic rhinitis. Am J Manag Care. 2000;6(3):373-8. [pmid: 10977437].
Crystal-Peters J, Neslusan C, Crown W H, et al. Treating allergic rhinitis in patients with comorbid asthma: The risk of asthma-related hospitalizations and emergency department visits. J Allergy Clin Immunol. 2002;109(1 Pt 1):57-62. [pmid: 11799366].
Cuffel B, Wamboldt M, Borish L, et al. Economic consequences of comorbid depression, anxiety, and allergic rhinitis. Psychosomatics. 1999;40(6):491-6. [pmid: 10581977].
Cunningham J M, Chiu E J, Landgraf J M, et al. The health impact of chronic recurrent rhinosinusitis in children. Arch Otolaryngol Head Neck Surg. 2000;126(11):1363-8. [pmid: 11074834].
Curtis V A, Kerwin R W. A risk-benefit assessment of risperidone in schizophrenia. Drug Saf. 1995;12(2):139-45. [pmid: 7539272].
Custovic A, Simpson B M, Simpson A, et al. Manchester Asthma and Allergy Study: low-allergen environment can be achieved and maintained during pregnancy and in early life. J Allergy Clin Immunol. 2000;105(2 Pt 1):252-8. [pmid: 10669844].
Custovic A, Taggart S C, Francis H C, et al. Exposure to house dust mite allergens and the clinical activity of asthma. J Allergy Clin Immunol. 1996;98(1):64-72. [pmid: 8765819].
Custovic A, Woodcock A. Clinical effects of allergen avoidance. [Review]. Clin Rev Allergy Immunol. 2000;18(3):397-419. [pmid: 10981266].
Cuthbert O D, Jeffrey I G, McNeill H B, et al. Barn allergy among Scottish farmers. Clin Allergy. 1984;14(2):197-206. [pmid: 6705183].
Cvitanovic S, Zekan L, Capkun V, et al. Specific hyposensitization in patients allergic to Parietaria officinalis pollen allergen. J Investig Allergol Clin Immunol. 1994;4(6):283-90.
D'Amato G, Liccardi G, Russo M, et al. Measurement of serum levels of eosinophil cationic protein to monitor patients with seasonal respiratory allergy induced by Parietaria pollen (treated and untreated with specific immunotherapy). Allergy. 1996;51(4):245-50. [pmid: 8792921].
D'Amato G, Lobefalo G, Liccardi G, et al. A double-blind, placebo-controlled trial of local nasal immunotherapy in allergic rhinitis to Parietaria pollen. Clin Exp Allergy. 1995;25(2):141-8. [pmid: 7750006].
D'Souza M F, Pepys J, Wells I D, et al. Hyposensitization with Dermatophagoides pteronyssinus in house dust allergy: a controlled study of clinical and immunological effects. Clin Allergy. 1973;3(2):177-93. [pmid: 4131252].
Damm M, Jungehulsing M, Eckel H E, et al. Effects of systemic steroid treatment in chronic polypoid rhinosinusitis evaluated with magnetic resonance imaging. Otolaryngol Head Neck Surg. 1999;120(4):517-23. [pmid: 10187944].
Davies B H. Epidemiology of building-associated illness. Immunol Allergy Clin North Am. 1994;14(3):483-93.
Davies R. The health economics of quality of life. Eur Respir Rev. 1997;7(47):303-6.
Davis K L, Powchik P. Tacrine. Lancet. 1995;345(8950):625-30. [pmid: 7534856].
De Alarcon A, Walsh E E, Carper H T, et al. Detection of IgA and IgG but not IgE antibody to respiratory syncytial virus in nasal washes and sera from infants with wheezing. J Pediatr. 2001;138(3):311-7. [pmid: 11241035].
de Andrade A D, Charpin D, Birnbaum J, et al. Indoor allergen levels in day nurseries. J Allergy Clin Immunol. 1995;95(6):1158-63. [pmid: 7797783].
De Blay F, Sanchez J, Platts-Mills T, et al. [Metrology of airborne particles carrying the principal air allergens]. [French]. Rev Mal Respir. 1995;12(4):343-52. [pmid: 7481046].
de Bock G H, Reijneveld S A, van Houwelingen J C, et al. Multiattribute utility scores for predicting family physicians' decisions regarding sinusitis. Med Decis Making. 1999;19(1):58-65. [pmid: 9917021].
de Graaf-in't Veld C, Garrelds I M, van Toorenenbergen A W, et al. Nasal responsiveness to allergen and histamine in patients with perennial rhinitis with and without a late phase response. Thorax. 1997;52(2):143-8. [pmid: 9059474].
de Graaf-in't Veld T, Garrelds I M, van Toorenenbergen A W, et al. Effect of topical levocabastine on nasal response to allergen challenge and nasal hyperreactivity in perennial rhinitis. Ann Allergy Asthma Immunol. 1995;75(3):261-6. [pmid: 7552929].
de Graaf-in't Veld T, Koenders S, Garrelds I M, et al. The relationships between nasal hyperreactivity, quality of life, and nasal symptoms in patients with perennial allergic rhinitis. J Allergy Clin Immunol. 1996;98(3):508-13. [pmid: 8828527].
De Zotti R, Molinari S, Larese F, et al. Pre-employment screening among trainee bakers. Occup Environ Med. 1995;52(4):279-83. [pmid: 7795745].
Dekkers C P M, Beker J A, Thjodleifsson B, et al. Comparison of rabeprazole 20 mg vs. omeprazole 20 mg in the treatment of active gastric ulcer - A European multicentre study. Aliment Pharmacol Ther. 1998;12(8):789-95. [pmid: 9726393].
Demoly P, Allaert F - A, Lecasble M, et al. ERASM, a pharmacoepidemiologic survey on management of intermittent allergic rhinitis in every day general medical practice in France. Allergy. 2002;57:546-54. [pmid: 12028122].
Denman A M, Cornthwaite D. Control of house dust mite antigen in bedding. Lancet. 1990;335(8696):1038. [pmid: 1970089].
Derebery M J, Berliner K I. Allergy and health-related quality of life. Otolaryngol Head Neck Surg. 2000;123(4):393-9. [pmid: 11020174].
Desrosiers M Y, Salas-Prato M. Treatment of chronic rhinosinusitis refractory to other treatments with topical antibiotic therapy delivered by means of a large-particle nebulizer: results of a controlled trial. Otolaryngol Head Neck Surg. 2001;125(3):265-9. [pmid: 11555764].
Deuell B, Arruda L K, Hayden M L, et al. Trichophyton tonsurans allergen. I. Characterization of a protein that causes immediate but not delayed hypersensitivity. J Immunol. 1991;147(1):96-101. [pmid: 1711086].
Devlin J, David T J, Stanton R H. Elemental diet for refractory atopic eczema. Arch Dis Child. 1991;66(1):93-9. [pmid: 1994860].
Dharmage S C, Abramson M, Raven J, et al. Why do only some of the young adults with bronchial hyperreactivity wheeze?. J Asthma. 1998;35(5):391-9. [pmid: 9734346].
Di Stanislao C, Di Berardino L, Bianchi I, et al. A double-blind, placebo-controlled study of preventive immunotherapy with E.P.D., in the treatment of seasonal allergic disease. Allerg Immunol (Paris). 1997;29(2):39-42. [pmcid: 267442]. [pmid: 9084819].
Diamant Z, Fokkens W J. Leukotriene receptor antagonists: Clinical potential in allergic rhinitis. Rhinology. 2001;39(4):187-90. [pmid: 11826686].
Diamant Z, Timmers M C, van der Veen H, et al. Effect of inhaled heparin on allergen-induced early and late asthmatic responses in patients with atopic asthma. Am J Respir Crit Care Med. 1996;153(6 Pt 1):1790-5. [pmid: 8665036].
Diamond L, Gerson K, Cato A, et al. An evaluation of triprolidine and pseudoephedrine in the treatment of allergic rhinitis. Ann Allergy. 1981;47(2):87-91. [pmid: 7258744].
Dietemann A, Bessot J C, Hoyet C, et al. A double-blind, placebo controlled trial of solidified benzyl benzoate applied in dwellings of asthmatic patients sensitive to mites: clinical efficacy and effect on mite allergens. J Allergy Clin Immunol. 1993;91(3):738-46. [pmid: 8454796].
DiGioacchino M, Cavallucci E, Verna N, et al. Allergens in occupational allergy. Prevention and management. Int J Immunopathol Pharmacol. 2000;13(3):163-8.
Dockery D W, Speizer F E, Stram D O, et al. Effects of inhalable particles on respiratory health of children. Am Rev Respir Dis. 1989;139(3):587-94. [pmid: 2923355].
Dockhorn R, Aaronson D, Bronsky E, et al. Ipratropium bromide nasal spray 0.03% and beclomethasone nasal spray alone and in combination for the treatment of rhinorrhea in perennial rhinitis. Ann Allergy Asthma Immunol. 1999;82(4):349-59. [pmid: 10227333].
Dockhorn R J, Williams B O, Sanders R L. Efficacy of acrivastine with pseudoephedrine in treatment of allergic rhinitis due to ragweed. Ann Allergy Asthma Immunol. 1996;76(2):204-8. [pmid: 8595542].
Dolor R J, Witsell D L, Hellkamp A S, et al. Comparison of cefuroxime with or without intranasal fluticasone for the treatment of rhinosinusitis. The CAFFS Trial: a randomized controlled trial. JAMA. 2001;286(24):3097-105. [pmid: 11754675].
Dolz I, Martinez-Cocera C, Bartolome J M, et al. A double-blind, placebo-controlled study of immunotherapy with grass-pollen extract Alutard SQ during a 3-year period with initial rush immunotherapy. Allergy. 1996;51(7):489-500. [pmid: 8863926].
Donahue J G, Greineder D K, Connor-Lacke L, et al. Utilization and cost of immunotherapy for allergic asthma and rhinitis. Ann Allergy Asthma Immunol. 1999;82(4):339-47. [pmid: 10227332].
Donovan J P, Buckeridge D L, Briscoe M P, et al. Efficacy of immunotherapy to ragweed antigen tested by controlled antigen exposure. Ann Allergy Asthma Immunol. 1996;77(1):74-80. [pmid: 8705641].
Dooms-Goossens A. Sensitisation to corticosteroids: Consequences for anti-inflammatory therapy. Drug Saf. 1995;13(2):123-9. [pmid: 7576263].
Dorward A J, Colloff M J, MacKay N S, et al. Effect of house dust mite avoidance measures on adult atopic asthma. Thorax. 1988;43(2):98-102. [pmid: 3353895].
Dorward A J, Waclawski E, Kerr J W. A comparison of the clinical and immunological effects of an alum-precipitated five-grass extract with a conjugated two-grass extract in the desensitization of hay fever. Clin Allergy. 1984;14(6):561-70. [pmid: 6391736].
Douglass J A, Thien F C K, O'Hehir R E. Immunoteraphy in asthma. Thorax. 1997;52(Suppl 3):S22-S29. [pmid: 9381422].
Dreborg S, Sjogren I, Eriksson N E, et al. Selection of patients for biological standardization as exemplified by standardization of mugwort, goosefoot and English plantain pollen allergen extracts/preparations. Allergy Eur J Allergy Clin Immunol. 1987;42(7):485-95.
Drettner B. Why does research in rhinology matter?. J Laryngol Otol. 1984;98(12):1193-205. [pmid: 6392458].
Drouin M A, Yang W H, Horak F, et al. Adding loratadine to topical nasal steroid therapy improves moderately severe seasonal allergic rhinoconjunctivitis. Adv Ther. 1995;12(6):340-9.
Druce H M, Spector S L, Fireman P, et al. Double-blind study of intranasal ipratropium bromide in nonallergic perennial rhinitis. Ann Allergy. 1992;69(1):53-60. [pmid: 1385682].
Duarte C, Baehre M, Gharakhanian S, et al. Treatment of severe seasonal rhinoconjunctivitis by a combination of azelastine nasal spray and eye drops: a double-blind, double-placebo study. J Investig Allergol Clin Immunol. 2001;11(1):34-40.
DuBuske L M. Introduction: Risk management in asthma and allergic diseases. J Allergy Clin Immunol. 1996;98(6 III):S289-S290. [pmid: 8977539].
DuBuske L M. Appropriate and inappropriate use of immunotherapy. Ann Allergy Asthma Immunol. 2001;87(1 Suppl):56-67. [pmid: 11476478].
Duff A L, Pomeranz E S, Gelber L E, et al. Risk factors for acute wheezing in infants and children: viruses, passive smoke, and IgE antibodies to inhalant allergens. Pediatrics. 1993;92(4):535-40. [pmid: 8414823].
Dunlop G. Management of patients with rhinitis. Med Today. 2001;2(10):61-7.
Durham S R, Kay A B, Hamid Q. Changes in allergic inflammation associated with successful immunotherapy. [Review]. Int Arch Allergy Immunol. 1995;107(13):282-4. [pmid: 7613151].
Durham S R, Varney V, Gaga M, et al. Immunotherapy and allergic inflammation. Clin Exp Allergy. 1991;21(Suppl 1):206-10. [pmid: 2032147].
Durham S R, Walker S. Immunotherapy for hayfever. Chem Immunol. 2000;78:199-208. [pmid: 12847731].
Durham S R, Walker S M, Varga E M, et al. Long-term clinical efficacy of grass-pollen immunotherapy. N Engl J Med. 1999;341(7):468-75. [pmid: 10441602].
Durr D G, Desrosiers M Y, Dassa C. Quality of life in patients with rhinosinusitis. J Otolaryngol. 1999;28(2):108-11. [pmid: 10212880].
Dykewicz MS. Primary care update: brief summaries for clinical practice. Rhinitis update: a guide to treatment. Consultant 1999;39(5):1446, 1448–50.
Dykewicz M S. Rhinitis update: A guide to diagnosis. Consultant. 1999;39(4):1253-5.
Dykewicz M S, Fineman S. Diagnosis and management of rhinitis: Parameter documents of the Joint Task Force on Practice Parameters in Allergy, Asthma, and Immunology: Preface. Joint Task Force on Practice Parameters in Allergy, Asthma, and Immunology, representing the American Academy of Allergy, Asthma and Immunology, the American College of Allergy, Asthma and Immunology, and the Joint Council of Allergy, Asthma and Immunology. Ann Allergy Asthma Immunol. 1998;81(5 II):vi.
Dykewicz M S, Fineman S. Executive Summary of Joint Task Force practice parameters on diagnosis and management of rhinitis. Ann Allergy Asthma Immunol. 1998;81(5 Pt 2):463-8. [pmid: 9860024].
Dykewicz M S, Fineman S, Nicklas R, et al. Joint Task Force algorithm and annotations for diagnosis and management of rhinitis. Ann Allergy Asthma Immunol. 1998;81(5 Pt 2):469-73. [pmid: 9860025].
Dykewicz M S, Fineman S, Skoner D P. Joint Task Force summary statements on diagnosis and management of rhinitis. Ann Allergy Asthma Immunol. 1998;81(5 Pt 2):474-7. [pmid: 9860026].
Easthope S, Jarvis B. Omalizumab. Drugs. 2001;61(2):253-60. [pmid: 11270941].
Eccles R. Nasal airflow in health and disease. Acta Oto-Laryngol. 2000;120(5):580-95.
Edsbacker S, Sachar, Pena. Budesonide capsules: Scientific basis. Drugs Today. 2000;36(Suppl G):9-23.
Eggleston P A. Urban children and asthma: Morbidity and mortality. Immunol Allergy Clin North Am. 1998;18(1):75-84.
Ehnert B, Lau-Schadendorf S, Weber A, et al. Reducing domestic exposure to dust mite allergen reduces bronchial hyperreactivity in sensitive children with asthma. J Allergy Clin Immunol. 1992;90(1):135-8. [pmid: 1629503].
el-Azazy O M. Camel tick (Acari:Ixodidae) control with pour-on application of flumethrin. Vet Parasitol. 1996;67(34):281-4. [pmid: 9017876].
el-Dahr J M, Fink R, Selden R, et al. Development of immune responses to Aspergillus at an early age in children with cystic fibrosis. Am J Respir Crit Care Med. 1994;150(6 Pt 1):1513-8. [pmid: 7952609].
Eldridge M W, Peden D B. Allergen provocation augments endotoxin-induced nasal inflammation in subjects with atopic asthma. J Allergy Clin Immunol. 2000;105(3):475-81. [pmid: 10719296].
Ellis A K, Day J H, Lundie M J. Impact on quality of life during an allergen challenge research trial. Ann Allergy Asthma Immunol. 1999;83(1):33-9. [pmid: 10437814].
Ellis A K, Rafeiro E, Day J H. Quality of life indices may be predictive of placebo and medication response to treatment for allergic rhinitis. Ann Allergy Asthma Immunol. 2001;86(4):393-6. [pmid: 11345281].
Elmogy M, Fayed H, Marzok H, et al. Oral ivermectin in the treatment of scabies. Int J Dermatol. 1999;38(12):926-8. [pmid: 10632775].
Emanuel I A, Shah S B. Chronic rhinosinusitis: allergy and sinus computed tomography relationships. Otolaryngol Head Neck Surg. 2000;123(6):687-91. [pmid: 11112958].
Endicott N A. Chronic fatigue syndrome in psychiatric patients: lifetime and premorbid personal history of physical health. Psychosom Med. 1998;60(6):744-51. [pmid: 9847035].
Englender M. Nasal laser mucotomy (L-mucotomy) of the interior turbinates. J Laryngol Otol. 1995;109(4):296-9. [pmid: 7782683].
Engvall K, Norrby C, Norback D. Asthma symptoms in relation to building dampness and odour in older multifamily houses in Stockholm. Int J Tuberculosis Lung Dis. 2001;5(5):468-77.
Enright P L, McClelland R L, Newman A B, et al. Underdiagnosis and undertreatment of asthma in the elderly. Cardiovascular Health Study Research Group. Chest. 1999;116(3):603-13. [pmid: 10492260].
Eriksson N E, Ahlstedt S, Lövhagen O. Immunotherapy in spring-time hay fever. A clinical and immunological study comparing two different treatment extract compositions. Allergy. 1979;34(4):233-47. [pmid: 92897].
Escudero A I, Sanchez-Guerrero I M, Mora A M, et al. Cost-effectiveness of various methods of diagnosing hypersensitivity to Alternaria. Allergol Immunopathol (Madr). 1993;21(4):153-7. [pmid: 8237720].
Euba R, Chalder T, Wallace P, et al. Self-reported allergy-related symptoms and psychological morbidity in primary care. Int J Psychiatry Med. 1997;27(1):47-56. [pmid: 9565713].
European Agency for Evaluation of Medicinal Products. Committee for Proprietary Medicinal Products European Public Assessment Report (EPAR): Neoclarityn. 2001. Available at: http://www.eudra.org/humandocs/humans/epar/neoclarityn/neoclarityn.htm. Accessed August 31, 2002.
Ewan P W, Alexander M M, Snape C, et al. Effective hyposensitization in allergic rhinitis using a potent partially purified extract of house dust mite. Clin Allergy. 1988;18(5):501-8. [pmid: 3069238].
Eysink P E D, Bindels P J E, Huisman J S, et al. Development of specific immunoglobulin E in coughing toddlers: A medical records review of symptoms in general practice. Pediatr Allergy Immunol. 2001;12(3):133-41. [pmid: 11473678].
Fagan J K, Scheff P A, Hryhorczuk D, et al. Prevalence of asthma and other allergic diseases in an adolescent population: association with gender and race. Ann Allergy Asthma Immunol. 2001;86(2):177-84. [pmid: 11258687].
Fahlbusch B, Hornung D, Heinrich J, et al. Quantification of group 5 grass pollen allergens in house dust. Clin Exp Allergy. 2000;30(11):1645-52. [pmid: 11069575].
Fakhri Z I, Erwa H H. Skin test survey in castor bean allergic working population in Eastern Sudan, with frequency response of first dilutions giving skin reactions. J Soc Occup Med. 1988;38(4):128-33. [pmid: 2976861].
Falk J E, Juto J E, Stridh G, et al. Dose-response study of formaldehyde on nasal mucosa swelling. A study on residents with nasal distress at home. Am J Rhinol. 1994;8(3):143-6.
Falliers C J, Redding M A. Controlled comparison of anew antihistamine-decongestant combination to its individual components. Ann Allergy. 1980;45(2):75-80. [pmid: 6157338].
Fanales-Belasio E, Ciofalo A, Zambetti G, et al. Intranasal immunotherapy with Dermatophagoides extract: in vivo and in vitro results of a double-blind placebo-controlled trial. Rhinology. 1995;33(3):126-31. [pmid: 8560161].
Farooqi I S, Hopkin J M. Early childhood infection and atopic disorder. Thorax. 1998;53(11):927-32. [pmid: 10193389].
Fasce L, Ciprandi G, Pronzato C, et al. Cetirizine reduces ICAM-I on epithelial cells during nasal minimal persistent inflammation in asymptomatic children with mite-allergic asthma. Int Arch Allergy Immunol. 1996;109(3):272-6. [pmid: 8620097].
Fawcett I V. Allergen immunotherapy and avoidance. Prim Care Clinics in Office Practice. 1998;25(4):869-83.
Fearby S, Frew A J. Hunting the magic bullet in immunotherapy: New forms of old treatment or something completely different?. Clin Exp Allergy. 2001;31(7):969-74. [pmid: 11467985].
Fell P, Brostoff J. A single dose desensitization for summer hay fever. Results of a double blind study-1988. Eur J Clin Pharmacol. 1990;38(1):77-9. [pmid: 2328752].
Fell WR, Mabry RL, Mabry CS. Quality of life analysis of patients undergoing immunotherapy for allergic rhinitis. Ear Nose Throat J 1997;76(8):528–32, 534–6.
Feo F, Martinez J, Martinez A, et al. Occupational allergy in saffron workers. Allergy Eur J Allergy Clin Immunol. 1997;52(6):633-41.
Ferguson BJ. Allergic rhinitis: options for pharmacotherapy and immunotherapy. Postgrad Med 1997;101(5):117–20, 123–6, 131.
Ferguson B J. Options for pharmacotherapy and immunotherapy. Postgrad Med. 1997;101(5):117-31. [pmid: 9158611].
Ferguson B J. What role do systemic corticosteroids, immunotherapy, and antifungal drugs play in the therapy of allergic fungal rhinosinusitis?. Arch Otolaryngol Head Neck Surg. 1998;124(10):1174-8. [pmid: 9776199].
Ferguson B J. Cost-effective pharmacotherapy for allergic rhinitis. [Review]. Otolaryngol Clin North Am. 1998;31(1):91-110. [pmid: 9530680].
Ferguson B J, Blom H M, Mulder P. Is cigarette smoke exposure a confounder in the evaluation or efficacy of nasal steroid sprays in nonallergic, noninfectious perennial rhinitis? (multiple letters). J Allergy Clin Immunol. 1998;102(1):155-6. [pmid: 9679865].
Filipiak B, Heinrich J, Schafer T, et al. Farming, rural lifestyle and atopy in adults from southern germany - Results from the MONICA/KORA study Augsburg. Clin Exp Allergy. 2001;31(12):1829-38. [pmid: 11737033].
Filon F L, Bosco A, Fiorito A, et al. Latex symptoms and sensitisation in health care workers. Int Arch Occup Environ Health. 2001;74(3):219-23. [pmid: 11355297].
Finn A F Jr, Aaronson D, Korenblat P, et al. Ipratropium bromide nasal spray 0.03% provides additional relief from rhinorrhea when combined with terfenadine in perennial rhinitis patients; a randomized, double-blind, active-controlled trial. Am J Rhinol. 1998;12(6):441-9. [pmid: 9883302].
Finn R. John Bostock, hay fever, and the mechanism of allergy. Lancet. 1992;340(8833):1453-5. [pmid: 1360571].
Fireman P. Treatment of allergic rhinitis: effect on occupation productivity and work force costs. [Review]. Allergy Asthma Proc. 1997;18(2):63-7. [pmid: 9134061].
Fireman P. Treatment strategies designed to minimize medical complications of allergic rhinitis. [erratum appears in Am J Rhinol 1997 May-Jun;11(3):217]. [Review]. Am J Rhinol. 1997;11(2):95-102. [pmid: 9129750].
Fireman P. Therapeutic approaches to allergic rhinitis: Treating the child. J Allergy Clin Immunol. 2000;105(6 II):S616-S621. [pmid: 10856167].
Fokkens W J. Who should treat patients with seasonal allergic rhinitis?. Allergy. 2002;57:469-71. [pmid: 12028110].
Fontana V J, Holt L E, Mainland D. Effectiveness of hyposensitization therapy in ragweed hay-fever in children. JAMA. 1966;195(12):985-92. [pmid: 5952104].
Forbes A B, Pitt S R, Baggott D G, et al. A review of the use of a controlled-release formulation of ivermectin in the treatment and prophylaxis of Psoroptes ovis infestations in sheep. [Review]. Vet Parasitol. 1999;83(34):319-26. [pmid: 10423013].
Ford A W, Platts-Mills T A. Standardized extracts, dust mite, and other arthropods (inhalants). [Review]. Clin Rev Allergy. 1987;5(1):49-73. [pmid: 2435397].
Ford A W, Rawle F C, Lind P, et al. Standardization of Dermatophagoides pteronyssinus: assessment of potency and allergen content in ten coded extracts. Int Arch Allergy Appl Immunol. 1985;76(1):58-67. [pmid: 3967933].
Foresi A. A comparison of the clinical efficacy and safety of intranasal fluticasone propionate and antihistamines in the treatment of rhinitis. Allergy Eur J Allergy Clin Immunol Suppl. 2000;55(62):12-4.
Fornadley J A, Corey J P, Osguthorpe J D, et al. Allergic rhinitis: clinical practice guideline. Committee on Practice Standards, American Academy of Otolaryngic Allergy. Otolaryngol Head Neck Surg. 1996;115(1):115-22. [pmid: 8758640].
Forray C, Noble S A. Subtype selective alpha1-adrenoceptor antagonists for the treatment of benign prostatic hyperplasia. Expert Opin Invest Drugs. 1999;8(12):2073-94.
Francillon C, Burnand B, Frei P, et al. Referral pattern to the allergist for hay fever in a health-care system with open access to specialists. Allergy. 1995;50(12):959-63. [pmid: 8834824].
Frankland A W. House dust mites and allergy. [Review]. Arch Dis Child. 1972;47(253):327-9. [pmid: 4556161].
Frankland A W. Practice of allergy in the United Kingdom. Ann Allergy. 1993;71(4):335-7. [pmid: 8214795].
Frankum B. Management of hay fever. New Ethicals 1998;1:55, 57–9.
Frederick J M, Warner J O, Jessop W J, et al. Effect of a bed covering system in children with asthma and house dust mite hypersensitivity. Eur Respir J. 1997;10(2):361-6. [pmid: 9042633].
Freebairn A J E, Last A T J, Illidge T M. Trastuzumab: Designer drug or fashionable fad?. Clin Oncol. 2001;13(6):427-33.
Freedman S O. First-line treatment of hay fever: What is the best option?. Can Med Assoc J. 1997;156(8):1141-3. [pmid: 9141984].
Frenz D A. Foundational readings concerning pollen for allergists and aerobiologists. Ann Allergy Asthma Immunol. 2000;84(3):320-2. [pmid: 10752916].
Frew A J, Smith H E. Sublingual immunotherapy. J Allergy Clin Immunol. 2001;107(3):441-4. [pmid: 11240942].
Friedmann P S. The role of dust mite antigen sensitization and atopic dermatitis: Editorial. Clin Exp Allergy. 1999;29(7):869-72. [pmid: 10383586].
Friedmann P S, Tan B B. Mite elimination--clinical effect on eczema. Allergy. 1998;53(48 Suppl):97-100. [pmid: 10096818].
Fritschi L, DeKlerk N, Sim M, et al. Respiratory morbidity and exposure to bauxite, alumina and caustic mist in alumina refineries. J Occup Health. 2001;43(5):231-7.
Frostad A B, Grimmer O, Sandvik L, et al. Hyposensitization. Comparing a purified (refined) allergen preparation and a crude aqueous extract from timothy pollen. Allergy. 1980;35(2):81-95. [pmid: 7386802].
Frostad A B, Grimmer O, Sandvik L, et al. Clinical effects of hyposensitization using a purified allergen preparation from Timothy pollen as compared to crude aqueous extracts from Timothy pollen and a four-grass pollen mixture respectively. Clin Allergy. 1983;13(4):337-57. [pmid: 6136346].
Furin M J, Norman P S, Creticos P S, et al. Immunotherapy decreases antigen-induced eosinophil cell migration into the nasal cavity. J Allergy Clin Immunol. 1991;88(1):27-32. [pmid: 2071783].
Gabriel M, Ng H K, Allan W G, et al. Study of prolonged hyposensitization with D. pteronyssinus extract in allergic rhinitis. Clin Allergy. 1977;7(4):325-39. [pmid: 589769].
Gaddie J, Skinner C, Palmer K N. Hyposensitisation with house dust mite vaccine in bronchial asthma. BMJ. 1976;2(6035):561-2. [pmid: 786429].
Gaglani B, Borish L, Bartelson B L, et al. Nasal immunotherapy in weed-induced allergic rhinitis. Ann Allergy Asthma Immunol. 1997;79(3):259-65. [pmid: 9305235].
Gaig P, Enrique E, Garcia-Ortega P, et al. Asthma, mite sensitization, and sleeping in bunks. Ann Allergy Asthma Immunol. 1999;82(6):531-3. [pmid: 10400479].
Galant S, Berger W, Gillman S, et al. Prevalence of sensitization to aeroallergens in California patients with respiratory allergy. Ann Allergy Asthma Immunol. 1998;81(3):203-10. [pmid: 9759795].
Galant S P, Wilkinson R. Clinical prescribing of allergic rhinitis medication in the preschool and young school-age child: What are the options?. Biodrugs. 2001;15(7):453-63. [pmid: 11520256].
Gani F, Pozzi E, Crivellaro M A, et al. The role of patient training in the management of seasonal rhinitis and asthma: clinical implications. Allergy. 2001;56:65-8. [pmid: 11167354].
Garrelds I M, de Graaf-in't Veld T, Nahori M - A, et al. Interleukin-5 and eosinophil cationic protein in nasal lavages of rhinitis patients. Eur J Pharmacol. 1995;275(3):295-300. [pmid: 7768298].
Garrelds I M, van Amsterdam J G, de Graaf-in't Veld C, et al. Nitric oxide metabolites in nasal lavage fluid of patients with house dust mite allergy. Thorax. 1995;50(3):275-9. [pmid: 7660342].
Gautrin D, Ghezzo H, Infante-Rivard C, et al. Natural history of sensitization, symptoms and occupational diseases in apprentices exposed to laboratory animals. Eur Respir J. 2001;17(5):904-8. [pmid: 11488324].
Gawchik S M, Lim J. Comparison of intranasal triamcinolone acetonide with oral loratadine in the treatment of seasonal ragweed-induced allergic rhinitis. Am J Manag Care. 1997;3(7):1052-8. [pmid: 10173369].
Gebhart F. Allergy care: Pharmacists assuming a wider role. Drug Topics. 1999;143(11 Suppl):23s-6s.
Gelber L E, Seltzer L H, Bouzoukis J K, et al. Sensitization and exposure to indoor allergens as risk factors for asthma among patients presenting to hospital. Am Rev Respir Dis. 1993;147(3):573-8. [pmid: 8442589].
Geller-Bernstein C, Pibourdin J M, Dornelas A, et al. Efficacy of the acaricide: acardust for the prevention of asthma and rhinitis due to dust mite allergy, in children. Allerg Immunol (Paris). 1995;27(5):147-54. [pmcid: 267442]. [pmid: 7662102].
Gendeh B S, Murad S, Razi A M, et al. Skin prick test reactivity to foods in adult Malaysians with rhinitis. Otolaryngol Head Neck Surg. 2000;122(5):758-62. [pmid: 10793361].
Gentile D A, Skoner D P. The relationship between airway hyperreactivity (AHR) and sodium, potassium adenosine triphosphatase (Na+,K+ ATPase) enzyme inhibition. J Allergy Clin Immunol. 1997;99(3):367-73. [pmid: 9058693].
Georgitis J W, Banov C, Boggs P B, et al. Ipratropium bromide nasal spray in non-allergic rhinitis: efficacy, nasal cytological response and patient evaluation on quality of life. Clin Exp Allergy. 1994;24(11):1049-55. [pmid: 7874603].
Georgitis J W, Meltzer E O, Kaliner M, et al. Onset-of-action for antihistamine and decongestant combinations during an outdoor challenge. Ann Allergy Asthma Immunol. 2000;84(4):451-9. [pmid: 10795655].
Georgitis J W, Reisman R E, Clayton W F, et al. Local intranasal immunotherapy for grass-allergic rhinitis. J Allergy Clin Immunol. 1983;71(1 Pt 1):71-6. [pmid: 6337198].
Giannarini L, Maggi E. Decrease of allergen-specific T-cell response induced by local nasal immunotherapy. Clin Exp Allergy. 1998;28(4):404-12. [pmid: 9641566].
Gibbons M D, Gunn C G, Niwas S, et al. Cost analysis of computer-aided endoscopic sinus surgery. Am J Rhinol. 2001;15(2):71-5. [pmid: 11345156].
Giembycz M A. Cilomilast: A second generation phosphodiesterase 4 inhibitor for asthma and chronic obstructive pulmonary disease. Expert Opin Invest Drugs. 2001;10(7):1361-79.
Gill P, Dowell A C, Neal R D, et al. Evidence based general practice: A retrospective study of interventions in one training practice. BMJ. 1996;312(7034):819-21. [pmid: 8608291].
Gillies D R, Littlewood J M, Sarsfield J K. Controlled trial of house dust mite avoidance in children with mild to moderate asthma. Clin Allergy. 1987;17(2):105-11. [pmid: 3581459].
Gilmore T M, Alexander B H, Mueller B A, et al. Occupational injuries and medication use. Am J Industrial Med. 1996;30(2):234-9.
Giovane A L, Bardare M, Passalacqua G, et al. A three-year double-blind placebo-controlled study with specific oral immunotherapy to Dermatophagoides: evidence of safety and efficacy in paediatric patients. Clin Exp Allergy. 1994;24(1):53-9. [pmid: 8156447].
Girard J P, el-Habib G, Granjard P. Treatment of hay fever by Allerglobuline: a randomized double-blind study. Clin Allergy. 1988;18(4):393-400. [pmid: 3416419].
Gleich G J, Zimmermann E M, Henderson L L, et al. Effect of immunotherapy on immunoglobulin E and immunoglobulin G antibodies to ragweed antigens: a six-year prospective study. J Allergy Clin Immunol. 1982;70(4):261-71. [pmid: 6811645].
Gliklich R E, Metson R. Techniques for outcomes research in chronic sinusitis. Laryngoscope. 1995;105(4 Pt 1):387-90. [pmid: 7715384].
Glover D, Norris T, Bryson S, et al. Loratadine post-marketing surveillance by general practice computer network. Pharm Med. 1992;6(2):87-97.
Godard P H, Chanez P, Redier H, et al. New therapeutical approaches in the treatment of asthma. Ann New York Acad Sci. 1994;725:367-77. [pmid: 8031008].
Godfrey R C. Asthma and IgE levels in rural and urban communities of The Gambia. Clin Allergy. 1975;5(2):201-7. [pmid: 1139767].
Goetzel RZ, Ozminkowski RJ, Del Rosso G, et al. Are drugs a cost or an investment? Bus Health 2000;18(6):39–42, 45.
Gold D R, Burge H A, Carey V, et al. Predictors of repeated wheeze in the first year of life: the relative roles of cockroach, birth weight, acute lower respiratory illness, and maternal smoking. Am J Respir Crit Care Med. 1999;160(1):227-36. [pmid: 10390405].
Gold M R, Franks P, McCoy K I, et al. Toward consistency in cost-utility analyses: using national measures to create condition-specific values. Med Care. 1998;36(6):778-92. [pmid: 9630120].
Golden S, Teets S J, Lehman E B, et al. Effect of topical nasal azelastine on the symptoms of rhinitis, sleep, and daytime somnolence in perennial allergic rhinitis. Ann Allergy Asthma Immunol. 2000;85(1):53-7. [pmid: 10923605].
Gordon B R. Immunotherapy basics. Otolaryngol Head Neck Surg. 1995;113(5):597-602. [pmid: 7478650].
Gosepath J, Schaefer D, Amedee R G, et al. Individual monitoring of aspirin desensitization. Arch Otolaryngol Head Neck Surg. 2001;127(3):316-21. [pmid: 11255478].
Gossel TA. Back to school health issues. US Pharm 1993;18(9):20, 22, 26, 28, 30.
Gotfried M. Relationship between rhinosinusitis and asthma: Is there a link?. Infect Med. 1998;15(Suppl C):67-73.
Gotzsche P C, Hammarquist C, Burr M. House dust mite control measures in the management of asthma: meta-analysis. BMJ. 1998;317(7166):1105-10. [pmcid: 28691]. [pmid: 9784442].
Gøtzsche PC, Johansen HK, Hammarquist C, et al. House dust mite control measures for asthma (Cochrane Review). In: The Cochrane Library, Issue 2, 2001. Oxford: Update Software.
Goudie A C, Evans N A, Gration K A, et al. Doramectin--a potent novel endectocide. Vet Parasitol. 1993;49(1):5-15. [pmid: 8236738].
Gozalo R F, Estrada R J L, Martin H S, et al. Patient satisfaction and allergen immunotherapy. J Investig Allergol Clin Immunol. 1999;9(2):101-5.
Graf P, Enerdal J, Hallen H. Ten days' use of oxymetazoline nasal spray with or without benzalkonium chloride in patients with vasomotor rhinitis. Arch Otolaryngol Head Neck Surg. 1999;125(10):1128-32. [pmid: 10522506].
Graf P, Hallen H, Juto J E. Benzalkonium chloride in a decongestant nasal spray aggravates rhinitis medicamentosa in healthy volunteers. Clin Exp Allergy. 1995;25(5):395-400. [pmid: 7553241].
Grammer L C, Shaughnessey M A, Shaughnessy J J, et al. Asthma as a variable in a study of immunotherapy for allergic rhinitis. J Allergy Clin Immunol. 1984;73(5 Pt 1):557-60. [pmid: 6715723].
Grammer L C, Shaughnessy M A, Bernhard M I, et al. The safety and activity of polymerized ragweed: a double-blind, placebo-controlled trial in 81 patients with ragweed rhinitis. J Allergy Clin Immunol. 1987;80(2):177-83. [pmid: 3301986].
Grammer L C, Shaughnessy M A, Henderson J, et al. A clinical and immunologic study of workers with trimellitic-anhydride- induced immunologic lung disease after transfer to low exposure jobs. Am Rev Respir Dis. 1993;148(1):54-7. [pmid: 8317814].
Grammer L C, Shaughnessy M A, Shaughnessy J J, et al. Allergenicity, immunogenicity, and safety of immunotherapy with various molecular weight ranges of polymerized ragweed. J Allergy Clin Immunol. 1985;76(2 Pt 1):195-200. [pmid: 4019951].
Grammer L C, Shaughnessy M A, Suszko I M, et al. A double-blind histamine placebo-controlled trial of polymerized whole grass for immunotherapy of grass allergy. J Allergy Clin Immunol. 1983;72(5 Pt 1):448-53. [pmid: 6355247].
Grammer L C, Zeiss C R, Suszko I M, et al. A double-blind, placebo-controlled trial of polymerized whole ragweed for immunotherapy of ragweed allergy. J Allergy Clin Immunol. 1982;69(6):494-9. [pmid: 7042799].
Grant A C, Roter E P. Circadian sneezing. Neurology. 1994;44(3 I):369-75. [pmid: 8145900].
Grant J A, Nicodemus C F, Findlay S R, et al. Cetirizine in patients with seasonal rhinitis and concomitant asthma: Prospective, randomized, placebo-controlled trial. J Allergy Clin Immunol. 1995;95(5 I):923-32. [pmid: 7751511].
Green R J, Potter P, Plit M, et al. The South African allergic rhinitis working group and allergic rhinitis. S Afr Med J. 1998;88(11):1366-7. [pmid: 9861936].
Greenbaum J, Hainer S, Sussman G. Letter to the editor. Can J Allergy Clin Immunol. 1999;4(1):6.
Gregory C, Cifaldi M, Tanner L A. Targeted intervention programs: creating a customized practice model to improve the treatment of allergic rhinitis in a managed care population. Am J Manag Care. 1999;5(4):485-96. [pmid: 10387387].
Grembiale R D, Camporota L, Naty S, et al. Effects of specific immunotherapy in allergic rhinitic individuals with bronchial hyperresponsiveness. Am J Respir Crit Care Med. 2000;162(6):2048-52. [pmid: 11112112].
Grewar J, MacDonald T M. Hay fever symptoms and over-the-counter remedies: A community pharmacy study. Int J Pharm Pract. 1998;6(1):22-9.
Griffith CJ. Allergic rhinitis: practical guide to diagnosis and management… recertification series. Phys Assistant 1994;18(7):19–21, 24–6, 29–30 passim.
Groholt E K, Stigum H, Nordhagen R, et al. Children with chronic health conditions in the Nordic countries in 1996 - Influence of socio-economic factors. Ambul Child Health. 2001;7(34):177-89.
Gronneberg R, Strandberg K, Stalenheim G, et al. Equivalent inhibition by terbutaline of anti-human IgE skin responses in atopic and non-atopic subjects. Allergy. 1985;40(1):27-35. [pmid: 2579597].
Grosclaude M, Mees K, Pinelli M E, et al. Cetirizine and pseudoephedrine retard, given alone or in combination, in patients with seasonal allergic rhinitis. Rhinology. 1997;35(2):67-73. [pmid: 9299654].
Gross N J. Allergy to laboratory animals: Epidemiologic, clinical, and physiologic aspects, and a trial of cromolyn in its management. J Allergy Clin Immunol. 1980;66(2):158-65. [pmid: 6772703].
Grupp-Phelan J, Lozano P, Fishman P. Health care utilization and cost in children with asthma and selected comorbidities. J Asthma. 2001;38(4):363-73. [pmid: 11456390].
Guarderas J C. Rhinitis and sinusitis: Office management. Mayo Clin Proc. 1996;71(9):882-8. [pmid: 8790266].
Guez S, Vatrinet C, Fadel R, et al. House-dust-mite sublingual-swallow immunotherapy (SLIT) in perennial rhinitis: a double-blind, placebo-controlled study. Allergy. 2000;55(4):369-75. [pmid: 10782522].
Gunasekara N S, Noble S. Isosorbide 5-mononitrate. A review of a sustained-release formulation (Imdur(R)) in stable angina pectoris. Drugs. 1999;57(2):261-77. [pmid: 10188765].
Gunter M J. The role of the ECHO model in outcomes research and clinical practice improvement. Am J Manag Care. 1999;5(4 Suppl):S217-24. [pmid: 10387542].
Gupta S K. Treating allergies: A perspective in family practice. J Indian Med Assoc. 2000;98(3):132-3. [pmid: 11016173].
Gutgesell C, Heise S, Seubert S, et al. Double-blind placebo-controlled house dust mite control measures in adult patients with atopic dermatitis. Br J Dermatol. 2001;145(1):70-4. [pmid: 11453909].
Haahtela T, Jaakonmaki I. Relationship of allergen-specific IgE antibodies, skin prick tests and allergic disorders in unselected adolescents. Allergy. 1981;36(4):251-6. [pmid: 6172046].
Haahtela T, Wihl J A, Munch E, et al. Hyposensitization in hay fever with grass pollen extracts: a three-year study comparing a dialysed alum adsorbed extract with allpyral. Ann Allergy. 1984;52(5):355-62. [pmid: 6721260].
Haas N, Sterry W. The use of ELM to monitor the success of antiscabietic treatment. Epiluminescence light microscopy. Arch Dermatol. 2001;137(12):1656-7. [pmid: 11735726].
Hadley J A. Evaluation and management of allergic rhinitis. Med Clin North Am. 1999;83(1):13-25. [pmid: 9927957].
Hadley J A, Schaefer S D. Clinical evaluation of rhinosinusitis: History and physical examination. Otolaryngol Head Neck Surg. 1997;117(3 II Suppl):S8-S11. [pmid: 9334783].
Hajat S, Haines A, Atkinson R W, et al. Association between air pollution and daily consultations with general practitioners for allergic rhinitis in London, United Kingdom. Am J Epidemiol. 2001;153(7):704-14. [pmid: 11282799].
Halken S, Niklassen U, Hansen L G, et al. Encasing of mattresses in children with asthma and house dust mite allergy. [Abstract]. J Allergy Clin Immunol. 1997;99:S320.
Haller V, Williams G. Diving candidates as they present for fitness to dive assessment: Diving medicine case studies Part 1. S Pac Underw Med Soc J. 2001;31(3):157-62.
Hamilton R G, Chapman M D, Platts-Mills T A E, et al. House dust aeroallergen measurements in clinical practice: A guide to allergen-free home and work environments. Immunol Allergy Pract. 1992;14(3):96-112.
Hansell A, Hollowell J, Nichols T, et al. Use of the General Practice Research Database (GPRD) for respiratory epidemiology: A comparison with the 4th Morbidity Survey in General Practice (MSGP4). Thorax. 1999;54(5):413-9. [pmid: 10212105].
Harkness P, Brown P, Fowler S, et al. A national audit of sinus surgery. Results of the Royal College of Surgeons of England comparative audit of ENT surgery. Clin Otolaryngol. 1997;22(2):147-51. [pmid: 9160929].
Harper J I, Ahmed I, Barclay G, et al. Cyclosporin for severe childhood atopic dermatitis: Short course versus continuous therapy. Br J Dermatol. 2000;142(1):52-8. [pmid: 10651694].
Harrelson G L. Theme introduction. Athl Ther Today. 2001;6(5):5.
Harvey R P, Comer C, Sanders B, et al. Model for outcomes assessment of antihistamine use for seasonal allergic rhinitis. J Allergy Clin Immunol. 1996;97(6):1233-41. [pmid: 8648018].
Harving H, Korsgaard J, Dahl R. House-dust mite exposure reduction in specially designed, mechanically ventilated “healthy” homes. Allergy. 1994;49(9):713-8. [pmid: 7695059].
Hauschildt P, Molhave L, Kjaergaard S K. Reactions of healthy persons and persons suffering from allergic rhinitis when exposed to office dust. Scand J Work Environ Health. 1999;25(5):442-9. [pmid: 10569465].
Hayden F G, Diamond L, Wood P B, et al. Effectiveness and safety of intranasal ipratropium bromide in common colds. A randomized, double-blind, placebo-controlled trial. Ann Intern Med. 1996;125(2):89-97. [pmid: 8678385].
Hayden M L, Perzanowski M, Matheson L, et al. Dust mite allergen avoidance in the treatment of hospitalized children with asthma. Ann Allergy Asthma Immunol. 1997;79(5):437-42. [pmid: 9396978].
Heald A E, Pieper C F, Schiffman S S. Taste and smell complaints in HIV-infected patients. AIDS. 1998;12(13):1667-74. [pmid: 9764787].
Hedlin G, Wille S, Browaldh L, et al. Immunotherapy in children with allergic asthma: effect on bronchial hyperreactivity and pharmacotherapy. J Allergy Clin Immunol. 1999;103(4):609-14. [pmid: 10200009].
Hedman J, Kaprio J, Poussa T, et al. Prevalence of asthma, aspirin intolerance, nasal polyposis and chronic obstructive pulmonary disease in a population-based study. Int J Epidemiol. 1999;28(4):717-22. [pmid: 10480701].
Heikkinen T, Ruohola A, Ruuskanen O, et al. Intranasally administered immunoglobulin for the prevention of rhinitis in children. Pediatr Infect Dis J. 1998;17(5):367-72. [pmid: 9613647].
Hellriegel E T, Arora S, Nelson M, et al. Steady-state pharmacokinetics and tolerability of modafinil given alone or in combination with methylphenidate in healthy volunteers. J Clin Pharmacol. 2001;41(8):895-904. [pmid: 11504278].
Henauer S, Seppey M, Huguenot C, et al. Effects of terfenadine and pseudoephedrine, alone and in combination in a nasal provocation test and in perennial rhinitis. Eur J Clin Pharmacol. 1991;41(4):321-4. [pmid: 1804647].
Hendeles L. Cetirizine: A new antihistamine with minimal sedation. Pharmacotherapy. 1996;16(5 I):967-8. [pmid: 8888096].
Hendrix S, Zeiss C R, Levitz D, et al. Polymerized whole ragweed: A two-year follow-up of patients treated with an improved method of immunotherapy. J Allergy Clin Immunol. 1980;65(1):57-60. [pmid: 7350204].
Hendrix S G, Patterson R, Zeiss C R, et al. A multi-institutional trial of polymerized whole ragweed for immunotherapy of ragweed allergy. J Allergy Clin Immunol. 1980;66(6):486-94. [pmid: 7000872].
Hendrix W C, Arruda L K, Platts-Mills T A, et al. Aspergillus epidural abscess and cord compression in a patient with aspergilloma and empyema. Survival and response to high dose systemic amphotericin therapy. [Review]. Am Rev Respir Dis. 1992;145(6):1483-6. [pmid: 1596022].
Hennessy S, Strom B L. Nonsedating antihistamines should be preferred over sedating antihistamines in patients who drive. Ann Intern Med. 2000;132(5):405-7. [pmid: 10691592].
Henriksen A H, Holmen T L, Bjermer L. Sensitization and exposure to pet allergens in asthmatics versus non-asthmatics with allergic rhinitis. Respir Med. 2001;95(2):122-9. [pmid: 11217908].
Herman D, Garay R, Le Gal M. A randomized double-blind placebo controlled study of azelastine nasal spray in children with perennial rhinitis. Int J Pediatr Otorhinolaryngol. 1997;39(1):1-8. [pmid: 9051434].
Hessel P A, Herbert F A, Melenka L S, et al. Lung health in sawmill workers exposed to pine and spruce. Chest. 1995;108(3):642-6. [pmid: 7656610].
Heymann P W, Rakes G P, Hogan A D, et al. Assessment of eosinophils, viruses and IgE antibody in wheezing infants and children. Int Arch Allergy Immunol. 1995;107(13):380-2. [pmid: 7613182].
Hide D W, Matthews S, Matthews L, et al. Effect of allergen avoidance in infancy on allergic manifestations at age two years. J Allergy Clin Immunol. 1994;93(5):842-6. [pmid: 8182225].
Hide D W, Matthews S, Tariq S, et al. Allergen avoidance in infancy and allergy at 4 years of age. Allergy. 1996;51(2):89-93. [pmid: 8738513].
Higgins K M, Davidian M, Chew G, et al. The effect of serial dilution error on calibration inference in immunoassay. Biometrics. 1998;54(1):19-32. [pmid: 9544505].
Hikal A H, Hikal E M. Cousenling tips for the top OTCs. Drug Topics. 1997;141(12):62-71.
Hill D, Ayra A, Solieri A, et al. Survey of computed tomography scanning and endoscopic sinus surgery in a group of district general hospitals in south Essex. J Laryngol Otol. 2001;115(1):26-30. [pmid: 11233617].
Hill D J, Hosking C S. The cow milk allergy complex: Overlapping disease profiles in infancy. Eur J Clin Nutr. 1995;49(Suppl 1):S1-S12. [pmid: 8647057].
Hill D J, Smart I J, Hosking C S. Specific cellular and humoral immunity in children with grass pollen asthma. Clin Allergy. 1982;12(1):83-9. [pmid: 7067069].
Hilliquin P, Allanore Y, Coste J, et al. Reduced incidence and prevalence of atopy in rheumatoid arthritis. Results of a case-control study. Rheumatology (UK). 2000;39(9):1020-6. [pmcid: 128936].
Hindmarch I, Riedel W J. Editorial. Hum Psychopharmacol. 1998;13(Suppl 2):S47-S48.
Hirsch S R, Kalbfleisch J H, Cohen S H. Comparison of Rinkel injection therapy with standard immunotherapy. J Allergy Clin Immunol. 1982;70(3):183-90. [pmid: 7108070].
Hirsch S R, Kalbfleisch J H, Golbert T M, et al. Rinkel injection therapy: a multicenter controlled study. J Allergy Clin Immunol. 1981;68(2):133-55. [pmid: 7019293].
Hirsck T, Sahn M, Leupold W. Double-blind placebo-controlled study of sublingual immunotherapy with house dust mite extract (D.Pt.) in children. Pediatr Allergy Immunol. 1997;8(1):21-7.
Hirvonen M R, Ruotsalainen M, Roponen M, et al. Nitric oxide and proinflammatory cytokines in nasal lavage fluid associated with symptoms and exposure to moldy building microbes. Am J Respir Crit Care Med. 1999;160(6):1943-6. [pmid: 10588610].
Ho T M, Yit Y H, Husain M. Development of an enzyme-linked immunosorbent assay for detection of IgE antibodies specific to Dermatophagoides pteronyssinus. Asian Pac J Allergy Immunol. 1988;6(2):103-6. [pmid: 3146256].
Hollingsworth HM. Allergic rhinoconjunctivitis: current therapy. Hospital Pract 1996;31(6):61–2, 65–7, 71–2 passim.
Hollingworth P, de Vere Tyndall A, Ansell B M, et al. Intensive immunosuppression versus prednisolone in the treatment of connective tissue diseases. Ann Rheum Dis. 1982;41(6):557-62. [pmid: 6128961].
Holm L, Ohman S, Bengtsson A, et al. Effectiveness of occlusive bedding in the treatment of atopic dermatitis--a placebo-controlled trial of 12 months' duration. Allergy. 2001;56(2):152-8. [pmid: 11167376].
Holt G R. The interface of otolaryngology with occupational medicine. Curr Opin Otolaryngol Head Neck Surg. 1996;4(1):59-61.
Honda K, Ooki K, Makishima K. Topical applications of trichloroacetic acid as therapy for nasal allergy. Eur Arch Oto-Rhino-Laryngol. 1994;251(Suppl 1):S65-S67.
Honig P K, Cantilena L R. Polypharmacy. Pharmacokinetic perspectives. Clin Pharmacokinet. 1994;26(2):85-90. [pmid: 8162659].
Hoover G E, Newman L J, Platts-Mills T A, et al. Chronic sinusitis: risk factors for extensive disease. J Allergy Clin Immunol. 1997;100(2):185-91. [pmid: 9275139].
Hopper J L, Jenkins M A, Carlin J B, et al. Increase in the self-reported prevalence of asthma and hay fever in adults over the last generation: a matched parent-offspring study. Austr J Publ Health. 1995;19(2):120-4.
Horak F, Jager S, Berger U, et al. Controlled exposure to mite allergen for a dose-finding of dimethindene maleate (DMM). Agents & Actions 1994;41:Spec No: C124–6.
Horak F, Jager S, Toth J, et al. Efficacy and tolerability of astemizole-D and loratadine-D during prolonged, controlled allergen challenge in the Vienna Challenge Chamber. Arzneim-Forsch Drug Res. 1996;46(11):1077-81. [pmid: 8955868].
Horak F, Stubner P, Berger U E, et al. Immunotherapy with sublingual birch pollen extract. A short-term double-blind placebo study. J Investig Allergol Clin Immunol. 1998;8(3):165-71.
Horak F, Stubner U P. New trends in allergic rhinitis. Allergy Clin Immunol Int. 1998;10(3):81-7.
Horak F, Toth J, Marks B, et al. Efficacy and safety relative to placebo of an oral formulation of cetirizine and sustained-release pseudoephedrine in the management of nasal congestion. Allergy. 1998;53(9):849-56. [pmid: 9788685].
Hordijk G J, Antvelink J B, Luwema R A. Sublingual immunotherapy with a standardised grass pollen extract; a double-blind placebo-controlled study. Allergol Immunopathol (Madr). 1998;26(5):234-40. [pmid: 9885731].
Horst M, Hejjaoui A, Horst V, et al. Double-blind, placebo-controlled rush immunotherapy with a standardized Alternaria extract. J Allergy Clin Immunol. 1990;85(2):460-72. [pmid: 2406323].
Howard KB, Bowers BW, Cook CK, et al. Intranasal fluticasone, loratadine tablets, and their use in combination: An evaluation of economic and humanistic outcomes. Drug Benefit Trends 2001;13(10):45–6, 48, 51–2.
Howarth P. The development of guidelines for allergic rhinitis. Rev Fr Allergol Immunol Clin. 2001;41(1):116-20.
Howland W C, Hampel F C, Martin B G, et al. The efficacy of fluticasone propionate aqueous nasal spray for allergic rhinitis and its relationship to topical effects. Clin Ther. 1996;18(6):1106-17. [pmid: 9001827].
Htut T, Higenbottam T W, Gill G W, et al. Eradication of house dust mite from homes of atopic asthmatic subjects: a double-blind trial. J Allergy Clin Immunol. 2001;107(1):55-60. [pmid: 11149991].
Huang S L, Lin K C, Pan W H. Dietary factors associated with physician-diagnosed asthma and allergic rhinitis in teenagers: Analyses of the first Nutrition and Health Survey in Taiwan. Clin Exp Allergy. 2001;31(2):259-64. [pmid: 11251627].
Huang S W. The effects of an air cleaner in the homes of children with perennial allergic rhinitis. Pediatr Asthma Allergy Immunol. 1993;7(2):111-7.
Hudmon K S, Corelli R L, Kroon L A, et al. Reducing pulmonary disease: The pharmacist's role in smoking cessation. J Pharm Pract. 2001;14(2):143-59.
Huerter J V Jr. Functional endoscopic sinus surgery and allergy. Otolaryngol Clin North Am. 1992;25(1):231-8. [pmid: 1549385].
Hueston W J, Eberlein C, Johnson D, et al. Criteria used by clinicians to differentiate sinusitis from viral upper respiratory tract infection. J Fam Pract. 1998;46(6):487-92. [pmid: 9638113].
Hungin A P S, Gunn S D, Bate C M, et al. A comparison of the efficacy of omeprazole 20 mg once daily with ranitidine 150 mg bd in the relief of symptomatic gastro-oesophageal reflux disease in general practice. Br J Clin Res. 1993;4:73-88.
Hunskaar S, Fosse R T. Allergy to laboratory mice and rats: A review of its prevention management, and treatment. Lab Anim. 1993;27(3):206-21. [pmid: 8366665].
Hunt J F, Erwin E, Palmer L, et al. Expression and activity of pH-regulatory glutaminase in the human airway epithelium. Am J Respir Crit Care Med. 2002;165(1):101-7. [pmid: 11779738].
Hunt J F, Fang K, Malik R, et al. Endogenous airway acidification. Implications for asthma pathophysiology. Am J Respir Crit Care Med. 2000;161(3 Pt 1):694-9. [pmid: 10712309].
Huss K, Salerno M, Huss R W. Computer-assisted reinforcement of instruction: effects on adherence in adult atopic asthmatics. Res Nurs Health. 1991;14(4):259-67. [pmid: 1891611].
Huss R W, Huss K, Squire E N, et al. Mite allergen control with acaricide fails. J Allergy Clin Immunol. 1994;94(1):27-32. [pmid: 8027495].
Huttin C, Andral J. How the reimbursement system may influence physicians' decisions results from focus groups interviews in France. Health Policy. 2000;54(2):67-86. [pmid: 11094264].
Hyndman S J, Vickers L M, Htut T, et al. A randomized trial of dehumidification in the control of house dust mite. Clin Exp Allergy. 2000;30(8):1172-80. [pmid: 10931126].
Ige O M, Onadeko O B. Respiratory symptoms and ventilatory function of the sawmillers in Ibadan, Nigeria. Afr J Med Medical Sci. 2000;29(2):101-4.
Iliopoulos O, Proud D, Adkinson N F, et al. Effects of immunotherapy on the early, late, and rechallenge nasal reaction to provocation with allergen: changes in inflammatory mediators and cells. J Allergy Clin Immunol. 1991;87(4):855-66. [pmid: 2013680].
Illum P, Meistrup-Larsen U, Moesner J, et al. Disodium cromoglycate (Lomudal) in the treatment of hay fever. Acta Allergol. 1973;28(5):416-24. [pmid: 4150611].
Iloeje U H, Redlich C A. Indoor air pollution: An update for the clinician. Clin Pulm Med. 2000;7(3):128-33.
Ingram J M, Rakes G P, Hoover G E, et al. Eosinophil cationic protein in serum and nasal washes from wheezing infants and children. J Pediatr. 1995;127(4):558-64. [pmid: 7562276].
Institute for Clinical Systems Improvement. Rhinitis. Bloomington: MN: Institute for Clinical Systems Improvement, 2000.
Iribarren C, Friedman G D, Klatsky A L, et al. Exposure to environmental tobacco smoke: association with personal characteristics and self reported health conditions. J Epidemiol Community Health. 2001;55(10):721-8. [pmid: 11553655].
Irons J S, Pruzansky J J, Patterson R. Allergy grand rounds: immunotherapy: mechanisms of action suggested by measurements of immunologic and cellular parameters. J Allergy Clin Immunol. 1975;56:64-77. [pmid: 48527].
Ishizuka T, Furuya Y. Influence of meals and night shifts on health. J Med Syst. 1993;17(34):201-6. [pmid: 8254265].
Iskandar N M, Naguib M B. Chlamydia trachomatis: An underestimated cause for rhinitis in neonates. Int J Pediatr Otorhinolaryngol. 1998;42(3):233-7. [pmid: 9466226].
Israel E. Leukotrienes and rhinitis. Clin Exp Allergy Suppl Rev. 2001;1(2):160-2.
Ito H, Nakamura Y, Takagi S, et al. Effects of azelastine on the level of serum interleukin-4 and soluble CD23 antigen in the treatment of nasal allergy. Arzneimittelforschung. 1998;48(12):1143-7. [pmid: 9893928].
Iversen M, Korsgaard J, Hallas T, et al. Mite allergy and exposure to storage mites and house dust mites in farmers. Clin Exp Allergy. 1990;20(2):211-9. [pmid: 2357620].
Jaakkola J J K, Heinonen O P. Shared office space and the risk of the common cold. Eur J Epidemiol. 1995;11(2):213-6. [pmid: 7672078].
Jaakkola J J K, Miettinen P. Type of ventilation system in office buildings and sick building syndrome. Am J Epidemiol. 1995;141(8):755-65. [pmid: 7709918].
Jackson-Menaldi C A, Dzul A I, Holland R W. Allergies and vocal fold edema: A preliminary report. J Voice. 1999;13(1):113-22. [pmid: 10223679].
Jahnsen F L, Lund-Johansen F, Dunne J F, et al. Experimentally induced recruitment of plasmacytoid (CD123SUPhigh) dendritic cells in human nasal allergy. J Immunol. 2000;165(7):4062-8. [pmid: 11034417].
Janda P, Sroka R, Tauber S, et al. Diode laser treatment of hyperplastic inferior nasal turbinates. Lasers Surg Med. 2000;27(2):129-39. [pmid: 10960819].
Janson C, Chinn S, Jarvis D, et al. Effect of passive smoking on respiratory symptoms, bronchial responsiveness, lung function, and total serum IgE in the European Community Respiratory Health Survey: A cross-sectional study. Lancet. 2001;358(9299):2103-9. [pmid: 11784622].
Järvinen K A J, Pirilä V, Björksten F, et al. Unsuitability of bakery work for a person with atopy: A study of 234 bakery workers. Ann Allergy. 1979;42(3):192-5. [pmid: 426330].
Jarvis D, Chinn S, Luczynska C, et al. The association of family size with atopy and atopic disease. Clin Exp Allergy. 1997;27(3):240-5. [pmid: 9088649].
Jeebhay M F, Lopata A L, Robins T G. Seafood processing in South Africa: A study of working practices, occupational health services and allergic health problems in the industry. Occup Med. 2000;50(6):406-13.
Jen A, Baroody F, de Tineo M, et al. As-needed use of fluticasone propionate nasal spray reduces symptoms of seasonal allergic rhinitis. J Allergy Clin Immunol. 2000;105(4):732-8. [pmid: 10756223].
Jirapongsananuruk O, Malainual N, Sangsupawanich P, et al. Partial mattress encasing significantly reduces house dust mite antigen on bed sheet surface: a controlled trial. Ann Allergy Asthma Immunol. 2000;84(3):305-10. [pmid: 10752914].
Jirapongsananuruk O, Vichyanond P. Nasal cytology in the diagnosis of allergic rhinitis in children. Ann Allergy Asthma Immunol. 1998;80(2):165-70. [pmid: 9494449].
Johansson S G O. Visions for the IAACI. Allergy Clin Immunol Int. 2000;12(5):249.
Joint Task Force on Practice Parameters. Practice parameters for allergen immunotherapy. Joint Task Force on Practice Parameters, representing the American Academy of Allergy, Asthma and Immunology, the American College of Allergy, Asthma and Immunology, and the Joint Council of Allergy, Asthma and Immunology. J Allergy Clin Immunol. 1996;98(6 Pt 1):1001-11. [pmid: 8977497].
Joint Task Force on Practice Parameters in Allergy, Asthma and Immunology. Diagnosis and management of rhinitis: complete guidelines of the Joint Task Force on Practice Parameters in Allergy, Asthma and Immunology. Joint Task Force on Practice Parameters in Allergy, Asthma and Immunology, representing the American Academy of Allergy, Asthma and Immunology; the American College of Allergy, Asthma and Immunology; and the Joint Council of Allergy, Asthma and Immunology. Ann Allergy Asthma Immunol. 1998;81(5 Pt 2):478-518. [pmid: 9860027].
Jones H S. Allergic rhinitis: A study on the prescribing preferences in general practice. Br J Clin Pract. 1989;43(1):30-2. [pmid: 2480154].
Jones N S. Nasal manifestations of rheumatic diseases. Ann Rheum Dis. 1999;58(10):589-90. [pmid: 10491354].
Jones N S, Carney A S, Davis A. The prevalence of allergic rhinosinusitis: A review. J Laryngol Otol. 1998;112(11):1019-30. [pmid: 10197137].
Jones R C M, Hughes C R, Wright D, et al. Early house moves, indoor air, heating methods and asthma. Respir Med. 1999;93(12):919-22. [pmid: 10653056].
Jooma O F, Weinberg E G, Berman D, et al. Accumulation of house-dust mite (Der-p-1) levels on mattress covers. S Afr Med J. 1995;85(10):1002-5. [pmid: 8596961].
Jordan J A, Mabry R L. Geriatric rhinitis: What it is, and how to treat it. Geriatrics. 1998;53(6):76-84. [pmid: 9634108].
Juliusson S, Bende M. Effect of systemically administered Hinf 1- and Hinf 2-receptor antagonists on nasal blood flow as measured with laser Doppler flowmetry in a provoked allergic reaction. Rhinology. 1996;34(1):24-7. [pmid: 8739864].
Jüni P, Witschi A, Bloch R, et al. The hazards of scoring the quality of clinical trials for meta-analysis. JAMA. 1999;282(11):1054-60. [pmid: 10493204].
Juniper E. Rhinitis and quality of life. Rev Fr Allergol Immunol Clin. 2001;41(1):111-5.
Juniper E F. Rhinitis and quality of life. Eur Respir Rev. 1997;7(47):300-2.
Juniper E F. Measuring health-related quality of life in rhinitis. [Review]. J Allergy Clin Immunol. 1997;99(2):S742-9. [pmid: 9042066].
Juniper E F. Quality of life in adults and children with asthma and rhinitis. [Review]. Allergy. 1997;52(10):971-7. [pmid: 9360747].
Juniper E F. Impact of upper respiratory allergic diseases on quality of life. J Allergy Clin Immunol. 1998;101(2 II):S386-S391. [pmid: 9500735].
Juniper E F. Rhinitis management: the patient's perspective. Clin Exp Allergy. 1998;28(Suppl 6):34-8. [pmid: 9988433].
Juniper E F, Guyatt G H. Development and testing of a new measure of health status for clinical trials in rhinoconjunctivitis. Clin Exp Allergy. 1991;21(1):77-83. [pmid: 2021881].
Juniper E F, Guyatt G H, Andersson B, et al. Comparison of powder and aerosolized budesonide in perennial rhinitis: validation of rhinitis quality of life questionnaire. Ann Allergy. 1993;70(3):225-30. [pmid: 8452318].
Juniper E F, Guyatt G H, Archer B, et al. Aqueous beclomethasone dipropionate in the treatment of ragweed pollen-induced rhinitis: further exploration of “as needed” use. J Allergy Clin Immunol. 1993;92(1 Pt 1):66-72. [pmid: 8335858].
Juniper E F, Guyatt G H, Dolovich J. Assessment of quality of life in adolescents with allergic rhinoconjunctivitis: development and testing of a questionnaire for clinical trials. J Allergy Clin Immunol. 1994;93(2):413-23. [pmid: 8120268].
Juniper E F, Guyatt G H, Ferrie P J, et al. First-line treatment of seasonal (ragweed) rhinoconjunctivitis. A randomized management trial comparing a nasal steroid spray and a nonsedating antihistamine. Can Med Assoc J. 1997;156(8):1123-31. [pmid: 9141982].
Juniper E F, Guyatt G H, Ferrie P J, et al. Sodium cromoglycate eye drops: Regular versus ‘as needed’ use in the treatment of seasonal allergic conjunctivitis. J Allergy Clin Immunol. 1994;94(1):36-43. [pmid: 8027497].
Juniper E F, Guyatt G H, Griffith L E, et al. Interpretation of rhinoconjunctivitis quality of life questionnaire data. J Allergy Clin Immunol. 1996;98(4):843-5. [pmid: 8876562].
Juniper E F, Howland W C, Roberts N B, et al. Measuring quality of life in children with rhinoconjunctivitis. J Allergy Clin Immunol. 1998;101(2 Pt 1):163-70. [pmid: 9500748].
Juniper E F, Kline P A, Hargreave F E, et al. Comparison of beclomethasone dipropionate aqueous nasal spray, astemizole, and the combination in the prophylactic treatment of ragweed pollen-induced rhinoconjunctivitis. J Allergy Clin Immunol. 1989;83(3):627-33. [pmid: 2494249].
Juniper E F, Kline P A, Ramsdale E H, et al. Comparison of the efficacy and side effects of aqueous steroid nasal spray (budesonide) and allergen-injection therapy (Pollinex-R) in the treatment of seasonal allergic rhinoconjunctivitis. J Allergy Clin Immunol. 1990;85(3):606-11. [pmid: 2107241].
Juniper EF, Ponte CD, Shapiro GG. Drug spotlight: the newer antihistamines. Patient Care 1996;30(7):34–8, 39–42, 47–8.
Juniper E F, Thompson A K, Ferrie P J, et al. Validation of the standardized version of the Rhinoconjunctivitis Quality of Life Questionnaire. J Allergy Clin Immunol. 1999;104(2 Pt 1):364-9. [pmid: 10452758].
Juniper E F, Thompson A K, Ferrie P J, et al. Development and validation of the mini Rhinoconjunctivitis Quality of Life Questionnaire. Clin Exp Allergy. 2000;30(1):132-40. [pmid: 10606940].
Juniper E F, Willms D G, Guyatt G H, et al. Aqueous beclomethasone dipropionate nasal spray in the treatment of seasonal (ragweed) rhinitis. Can Med Assoc J. 1992;147(6):887-92. [pmid: 1525732].
Kagi MK, Wuthrich B. Different methods of local allergen-specific immunotherapy. Allergy 57:379–88.
Kaiser H B, Findlay S R, Georgitis J W, et al. Long-term treatment of perennial allergic rhinitis with ipratropium bromide nasal spray 0.06%. J Allergy Clin Immunol. 1995;95(5 II):1128-32. [pmid: 7751529].
Kaiser HB, Kaliner MA, Nelson HS. Who needs allergy testing? Patient Care 1997;31(14):169–72, 175, 179–83.
Kalayci O, Saraclar Y, Adalioglu G, et al. The effect of cetirizine on sulfidoleukotriene production by blood leukocytes in children with allergic rhinitis. Allergy. 1995;50(12):964-9. [pmid: 8834825].
Kaliner M. Allergy care in the next millennium: Guidelines for the specialty. J Allergy Clin Immunol. 1997;99(6 I Suppl):729-34. [pmid: 9215237].
Kaliner M A, Osguthorpe J D, Fireman P, et al. Sinusitis: bench to bedside. Current findings, future directions. [erratum appears in J Allergy Clin Immunol 1997 Oct;100(4):510]. [Review]. J Allergy Clin Immunol. 1997;99(6 Pt 3):S829-48. [pmid: 9212027].
Kalra S, Crank P, Hepworth J, et al. Absence of seasonal variation in concentrations of the house dust mite allergen Der p1 in south Manchester homes. Thorax. 1992;47(11):928-31. [pmid: 1465750].
Kammermeyer J K, Rajtora D W, Anuras J, et al. Clinical evaluation of intranasal topical flunisolide therapy in allergic rhinitis. J Allergy Clin Immunol. 1977;59(4):287-93. [pmid: 14982].
Kanerva L, Vanhanen M. Occupational allergic contact urticaria and rhinoconjunctivitis from a detergent protease. Contact Dermatitis. 2001;45(1):49-51. [pmid: 11422276].
Kanga J F. Dornase alfa therapy in cystic fibrosis: Who should get it?. Chest. 1996;110(4):871-2. [pmid: 8874235].
Kanthawatana S, Maturim W, Fooanan S, et al. Skin prick reaction and nasal provocation response in diagnosis of nasal allergy to the house dust mite. Ann Allergy Asthma Immunol. 1997;79(5):427-30. [pmid: 9396976].
Kao N L. Costs of rhinitis and asthma. Ann Allergy Asthma Immunol. 1995;74(5):448. [pmid: 7749978].
Kaplan A P. Visions for the World Allergy Organization. Allergy Clin Immunol Int. 2001;13(2):71.
Karlberg B E, Lins L E, Hermansson K. Efficacy and safety of telmisartan, a selective ATinf 1 receptor antagonist, compared with enalapril in elderly patients with primary hypertension. J Hypertens. 1999;17(2):293-302. [pmid: 10067800].
Kaszuba S M, Baroody F M, deTineo M, et al. Superiority of an intranasal corticosteroid compared with an oral antihistamine in the as-needed treatment of seasonal allergic rhinitis. Arch Intern Med. 2001;161(21):2581-7. [pmid: 11718589].
Katelaris C H. Successful immunotherapy. A partnership between consultant and general practitioner. [Review]. Aust Fam Physician. 1998;27(8):687-92. [pmid: 9735486].
Katelaris C H. Showcasing Australia. Allergy Clin Immunol Int. 2000;12(5):189-90.
Katelaris C H, Carrozzi F M, Burke T V, et al. A springtime olympics demands special consideration for allergic athletes. J Allergy Clin Immunol. 2000;106(2):260-6. [pmid: 10932068].
Katz R M. Treating the student with seasonal allergic rhinitis. Pediatr Asthma Allergy Immunol. 1996;10(3):93-100.
Katzenstein L. Allergies: nothing to sneeze at. Am Health Fitness Body Mind. 1993;12(4):44-9.
Kaufman H S, Roth H L. Hyposensitization with alum precipitated extracts in atopic dermatitis: a placebo-controlled study. Ann Allergy. 1974;32(6):321-30. [pmid: 4597822].
Kay A B. Allergy and allergic diseases. Part 2. New Engl J Med. 2001;344:109-13. [pmid: 11150362].
Kay A B. Allergy and allergic diseases. First of two parts. [Review]. N Engl J Med. 2001;344(1):30-7. [pmid: 11136958].
Kay A B, Holgate S T. Good allergy practice. Clin Exp Allergy. 1995;25(7):579.
Kay G G. The effects of antihistamines on cognition and performance. J Allergy Clin Immunol. 2000;105(6 II):S622-S627. [pmid: 10856168].
Keith P K, Haddon J, Birch S. A cost-benefit analysis using a willingness-to-pay questionnaire of intranasal budesonide for seasonal allergic rhinitis. Rhinocort Study Group. Ann Allergy Asthma Immunol. 2000;84(1):55-62. [pmid: 10674566].
Kelso J M, Jones R T, Tellez R, et al. Oral allergy syndrome successfully treated with pollen immunotherapy. Ann Allergy Asthma Immunol. 1995;74(5):391-6. [pmid: 7749969].
Kelso J M, Sodhi N, Gosselin V A, et al. Diagnostic performance characteristics of the standard Phadebas RAST, modified RAST, and pharmacia CAP system versus skin testing. Ann Allergy. 1991;67(5):511-4. [pmid: 1958005].
Kemker B J, Corey J P, Branca J, et al. Development of the Allergy Outcome Survey for allergic rhinitis. Otolaryngol Head Neck Surg. 1999;121(5):603-5. [pmid: 10547479].
Kenner D. European botanic therapies, part III: The use of essential oils in clinical practice. Am J Acupunct. 1998;26(23):105-15.
Kerkhof M, Droste J H, de Monchy J G, et al. Distribution of total serum IgE and specific IgE to common aeroallergens by sex and age, and their relationship to each other in a random sample of the Dutch general population aged 20–70 years. Dutch ECRHS Group, European Community Respiratory Health Study. Allergy. 1996;51(11):770-6. [pmid: 8947333].
Keslin MH, Jarrell CM, Gregory C. Diagnosis and treatment of allergic rhinitis: primary care in an integrated health system setting. Am J Manag Care 1999;5(4 Suppl):S248–56; quiz S257–8.
Kessler R C, Almeida D M, Berglund P, et al. Pollen and mold exposure impairs the work performance of employees with allergic rhinitis. Ann Allergy Asthma Immunol. 2001;87(10):289-95. [pmid: 11686420].
Kettis L A, Isacson D, Eriksson C. Assessment of the appropriateness of extemporaneous preparations prescribed in Swedish primary care. Int J Pharm Pract. 1996;4(2):117-22.
Kifuji K, McCullough J, Ownby D R. Relationship between dust mite allergen and human IgA in house dust samples. Ann Allergy. 1993;70(3):219-24. [pmid: 8452317].
Kilpelainen M, Koskenvuo M, Helenius H, et al. Wood stove heating, asthma and allergies. Respir Med. 2001;95(11):911-6. [pmid: 11716206].
Kim Y, Suzuki K, Kitao S, et al. Clinical review of nasal allergy due to fungus. Acta Oto-Laryngol Supplement. 1996;525:105-7.
Kim Y K, Park H W, Park H S, et al. Sensitivity to citrus red mite and the development of asthma. Ann Allergy Asthma Immunol. 2000;85(6 Pt 1):483-8. [pmid: 11152170].
Kimura Y, Kanazawa Y, Kida K, et al. A study of atopic dermatitis in elementary school children in Hirosaki City, Aomori Prefecture, Japan. Environ Health Prev Med. 1998;3(3):141-5.
King HC. Allergy testing by primary care physicians. Postgrad Med 1990;87(4):137–40, 143.
Kiviloog J. Variability of bronchial reactivity to exercise and metacholine in bronchial asthma. Scand J Respir Dis. 1973;54(6):359-68. [pmid: 4773705].
Kivity S, Sade K, Abu-Arisha F, et al. Epidemiology of bronchial asthma and chronic rhinitis in schoolchildren of different ethnic origins from two neighboring towns in Israel. Pediatr Pulmonol. 2001;32(3):217-21. [pmid: 11536451].
Kjellman M. Treatment of children with perennial rhinitis with brompheniraminemaleate and phenylpropanolaminehydrochloride (lunerin mite). Acta Allergol. 1975;30(1):48-57. [pmid: 1098353].
Kjellman N I, Lanner A. Hyposensitization in childhood hay fever. A comparison of refined and whole timothy extracts. Allergy. 1980;35(4):323-34. [pmid: 6108724].
Klein GL, Timerman V. Pharmacologic and nonpharmacologic treatment of allergic rhinitis. Phys Assistant 1993;17(5):52–6, 59–60, 62 passim.
Klein G L, Ziering R W. Allergy tips of the month: For physicians. Immunol Allergy Pract. 1993;15(7):210-1.
Klimek L, Wolf H, Mewes T, et al. The effect of short-term immunotherapy with molecular standardized grass and rye allergens on eosinophil cationic protein and tryptase in nasal secretions. J Allergy Clin Immunol. 1999;103(1 Pt 1):47-53. [pmid: 9893184].
Klossek J M, Laliberte F, Laliberte M F, et al. Local safety of intranasal triamcinolone acetonide: Clinical and histological aspects of nasal mucosa in the long term treatment of perennial allergic rhinitis. Rhinology. 2001;39(1):17-22. [pmid: 11340690].
Kniest F M, Wolfs B J, Vos H, et al. Mechanisms and patient compliance of dust-mite avoidance regimens in dwellings of mite-allergic rhinitic patients. Clin Exp Allergy. 1992;22(7):681-9. [pmid: 1504890].
Kniest F M, Young E, Van Praag M C, et al. Clinical evaluation of a double-blind dust-mite avoidance trial with mite-allergic rhinitic patients. Clin Exp Allergy. 1991;21(1):39-47. [pmid: 2021877].
Knight A. The role of levocabastine in the treatment of allergic rhinoconjunctivitis. Br J Clin Pract. 1994;48(3):139-43. [pmid: 7913336].
Knight A, Underdown B J, Demanuele F, et al. Disodium cromoglycate in ragweed-allergic rhinitis. J Allergy Clin Immunol. 1976;58(2):278-83. [pmid: 7585].
Kobayashi R H, Kiechel I F, Kobayashi A L D, et al. Topical nasal sprays: Treatment of allergic rhinitis. Am Fam Phys. 1994;50(1):151-7.
Koch B, Oparil S, Stimpel M. Co-administration of an ACE-inhibitor (moexipril) and hormonal replacement therapy in postmenopausal women. J Hum Hypertens. 1999;13(5):337-42. [pmid: 10376852].
Kogan H. Hayfever: A modern condition. Occup Health. 1993;45(5):166-8.
Kolbeck K G, Ehnhage A, Juto J E, et al. Airway reactivity and exhaled NO following swine dust exposure in healthy volunteers. Respir Med. 2000;94(11):1065-72. [pmid: 11127493].
Konno A, Yamakoshi T, Terada N, et al. Mode of action of a topical steroid on immediate phase reaction after antigen challenge and nonspecific nasal hyperreactivity in nasal allergy. Int Arch Allergy Immunol. 1994;103(1):79-87. [pmid: 8260854].
Kooistra J B, Pasch R, Reed C E. The effects of air cleaners on hay fever symptoms in air-conditioned homes. J Allergy Clin Immunol. 1978;61(5):315-9. [pmid: 346629].
Kopferschmitt-Kubler M C, Couchot A, Pauli G. Evaluation of the effect of oral cetirizine on antigen-induced immediate asthmatic response. Ann Allergy. 1990;65(6):501-3. [pmid: 1979472].
Korsgaard J. Preventive measures in hose-dust allergy. Am Rev Respir Dis. 1982;125(1):80-4. [pmid: 7065513].
Korsgaard J. Preventive measures in mite asthma. A controlled trial. Allergy. 1983;38(2):93-102. [pmid: 6342456].
Korsgaard J. Mite asthma and residency. A case-control study on the impact of exposure to house-dust mites in dwellings. Am Rev Respir Dis. 1983;128(2):231-5. [pmid: 6881682].
Kort H S, Schober G, Koren L G, et al. Mould-devouring mites differ in guanine excretion from dust-eating Acari, a possible error source in mite allergen exposure studies. Clin Exp Allergy. 1997;27(8):921-5. [pmid: 9291290].
Koskinen O M, Husman T M, Meklin T M, et al. The relationship between moisture or mould observations in houses and the state of health of their occupants. Eur Respir J. 1999;14(6):1363-7. [pmid: 10624768].
Kotwani A, Puri R, Gupta U. Efficacy of nimesulide alone and in combination with cetirizine in acute allergic rhinitis. J Assoc Physicians India. 2001;49:518-22. [pmid: 11361264].
Kozma C M, Sadik M K, Watrous M L. Economic outcomes for the treatment of allergic rhinitis. [Review]. Pharmacoeconomics. 1996;10(1):4-13. [pmid: 10172730].
Kozma C M, Schulz R M, Sclar D A, et al. A comparison of costs and efficacy of intranasal fluticasone propionate and terfenadine tablets for seasonal allergic rhinitis. Clin Ther. 1996;18(2):334-46. [pmid: 8733993].
Krause H F, Squillace S P, Mabry R L, et al. Antihistamines and decongestants. Otolaryngol Head Neck Surg. 1992;107(6 I):835-40. [pmid: 1281916].
Kray K T, Squire E N, Tipton W R, et al. Cromolyn sodium in seasonal allergic conjunctivitis. J Allergy Clin Immunol. 1985;76(4):623-7. [pmid: 3932499].
Kremer B, Klimek L, Bullinger M, et al. Generic or disease-specific quality of life scales to characterize health status in allergic rhinitis?. Allergy. 2001;56:957-63. [pmid: 11576074].
Kreuser E D, Kuchler T, Zwingers T, et al. A multicenter prospective randomized trial with assessment of quality of life in patients with metastatic colorectal carcinoma comparing interferon alpha-2b and folinic acid as modulators of 5-fluorouracil. Onkologie. 1994;17(1):78-84.
Kristensen O. A prospective study of the development of hand eczema in an automobile manufacturing industry. Contact Dermatitis. 1992;26(5):341-5. [pmid: 1395598].
Kroidl R F, Göbel D, Balzer D, et al. Clinical effects of benzyl benzoate in the prevention of house-dust-mite allergy. Results of a prospective, double-blind, multicenter study. Allergy. 1998;53(4):435-40. [pmid: 9574889].
Krouse J H. Computed tomography stage, allergy testing, and quality of life in patients with sinusitis. Otolaryngol Head Neck Surg. 2000;123(4):389-92. [pmid: 11020173].
Krouse J H, Krouse H J. Patient use of traditional and complementary therapies in treating rhinosinusitis before consulting an otolaryngologist. Laryngoscope. 1999;109(8):1223-7. [pmid: 10443823].
Krouse J H, Krouse H J. Efficacy of immunotherapy based on skin end-point titration. Otolaryngol Head Neck Surg. 2000;123(3):183-7. [pmid: 10964288].
Kujala V M, Reijula K E. Glove-related rhinopathy among hospital personnel. Am J Ind Med. 1996;30(2):164-70. [pmid: 8844046].
Kuna P, Alam R, Kuzminska B, et al. The effect of preseasonal immunotherapy on the production of histamine-releasing factor (HRF) by mononuclear cells from patients with seasonal asthma: results of a double-blind, placebo-controlled, randomized study. J Allergy Clin Immunol. 1989;83(4):816-24. [pmid: 2468702].
Kuo H W, Jian G J, Chen C L, et al. White blood cell count as an indicator of formaldehyde exposure. Bull Environ Contam Toxicol. 1997;59(2):261-7. [pmid: 9211697].
Kupa A. Allergic rhinitis and immunotherapy. Med J Aust. 1992;157(1):9-11. [pmid: 1640909].
Kusunoki T, Hosoi S, Asai K, et al. Relationships between atopy and lung function: Results from a sample of one hundred medical students in Japan. Ann Allergy Asthma Immunol. 1999;83(4):343-7. [pmid: 10541428].
La Rosa M, Ranno C, Andre C, et al. Double-blind placebo-controlled evaluation of sublingual-swallow immunotherapy with standardized Parietaria judaica extract in children with allergic rhinoconjunctivitis. J Allergy Clin Immunol. 1999;104(2 Pt 1):425-32. [pmid: 10452766].
Lack G. Pediatric allergic rhinitis and comorbid disorders. [Review]. J Allergy Clin Immunol. 2001;108(1 Suppl):S9-15. [pmid: 11449201].
Lale A M, Mason J D T, Jones N S. Mucociliary transport and its assessment: A review. Clin Otolaryngol Allied Sci. 1998;23(5):388-96. [pmid: 9800073].
Lamb H M, Culy C R, Faulds D. Inhaled fluticasone propionate: A pharmacoeconomic review of its use in the management of asthma. Pharmacoeconomics. 2000;18(5):487-510. [pmid: 11151402].
Lander F, Meyer H W, Norn S. Serum IgE specific to indoor moulds, measured by basophil histamine release, is associated with building-related symptoms in damp buildings. Inflamm Res. 2001;50(4):227-31. [pmid: 11392611].
Lane A P, Pine H S, Pillsbury H C III. Allergy testing and immunotherapy in an academic otolaryngology practice: a 20-year review. Otolaryngol Head Neck Surg. 2001;124(1):9-15. [pmid: 11228445].
Lang D M, Visintainer P F, Howland W C, et al. Survey of the extent and nature of care for adults and older adults by allergy/immunology practitioners. Ann Allergy Asthma Immunol. 2000;85(2):106-10. [pmid: 10982216].
Lanier B Q, Gross R D, Marks B B, et al. Olopatadine ophthalmic solution adjunctive to loratadine compared with loratadine alone in patients with active seasonal allergic conjunctivitis symptoms. Ann Allergy Asthma Immunol. 2001;86(6):641-8. [pmid: 11428736].
Lanphear B P, Kahn R S, Berger O, et al. Contribution of residential exposures to asthma in US children and adolescents. Pediatrics. 2001;107(6):E98. [pmid: 11389296].
Lasley M V. Allergic disease prevention and risk factor identification. Immunol Allergy Clin North Am. 1999;19(1):149-59.
Lau S K, Wei W I, Van Hasselt C A, et al. A clinical comparison of budesonide nasal aerosol, terfenadine and a combined therapy of budesonide and oxymetazoline in adult patients with perennial rhinitis. Asian Pac J Allergy Immunol. 1990;8(2):109-15. [pmid: 1709020].
Leaderer B P, Samet J M. Passive smoking and adults: New evidence for adverse effects. Am J Respir Crit Care Med. 1994;150(5 I):1216-8. [pmid: 7952542].
Leaver-Dunn D, Robinson J B, Laubenthal J. Assessment of respiratory conditions in athletes. Athl Ther Today. 2000;5(6):14-9.
Lebacq E Jr, Gline J P, Joue P, et al. Exploratory study of the decongestive effect of Rhinopront syrup in adults and in children with acute rhinitis. Clin Trials Meta-Analyis. 1994;29(23):113-24.
Lebowitz M D, Cassell E J, McCarroll J. Health and the urban environment. XI. The incidence and burden of minor illness in a healthy population: methods, symptoms, and incidence. Am Rev Respir Dis. 1972;106(6):824-34. [pmid: 4641217].
Ledford DK, Lockey RF. Allergic rhinitis: offering relief this season… second in a series of two articles. J Respir Dis 1998;19(8):647–50, 659–60, 662 passim.
Lee J, Cummins G, Okamoto L. A descriptive analysis of the use and cost of new-generation antihistamines in the treatment of allergic rhinitis: a retrospective database analysis. Am J Manag Care. 2001;7(4 Suppl):S103-12. [pmid: 11392821].
Lee J T, Shy C M. Respiratory function as measured by peak expiratory flow rate and PM10: six communities study. J Expo Anal Environ Epidemiol. 1999;9(4):293-9. [pmid: 10489154].
Lee M. Tamsulosin for the treatment of benign prostatic hypertrophy. Ann Pharmacother. 2000;34(2):188-99. [pmid: 10676828].
Lee M, Cho S, Park H, et al. Citrus red mite (Panonychus citri) is a common sensitizing allergen among children living around citrus orchards. Ann Allergy Asthma Immunol. 2000;85(3):200-4. [pmid: 11030274].
Lees L J. A trial of house dust mite adsorbed on tyrosine in general practice. Br J Clin Pract. 1974;28(10):343-46. [pmid: 4613367].
Leickly F E, Sears-Ewald D, Ownby D R. A comparative cost-effectiveness study of two treatment modalities for ragweed hay fever. Am J Rhinol. 1989;3(2):99-104.
Leino M, Montan P, Nja F. A double-blind group comparative study of ophthalmic sodium cromoglycate, 2% four times daily and 4% twice daily, in the treatment of seasonal allergic conjunctivitis. Allergy Eur J Allergy Clin Immunol. 1994;49(3):147-51.
Leong K P, Chan S P, Tang C Y, et al. Quality of life of patients with perennial allergic rhinitis: preliminary validation of the Rhinoconjunctivitis Quality of Life Questionnaire in Singapore. Asian Pac J Allergy Immunol. 1999;17(3):163-7. [pmid: 10697254].
Leopold D. A perplexing olfactory loss. Arch Otolaryngol Head Neck Surg. 2000;126(6):803. [pmid: 10872026].
Leopold D, Ferguson B J, Piccirillo J F. Outcomes assessment. Otolaryngol Head Neck Surg. 1997;117(3 II Suppl):S58-S68. [pmid: 9334790].
Leroyer C, Malo J L, Girard D, et al. Chronic rhinitis in workers at risk of reactive airways dysfunction syndrome due to exposure to chlorine. Occup Environ Med. 1999;56(5):334-8. [pmid: 10472308].
Leung R, Lam C W, Chan A, et al. Indoor environment of residential homes in Hong Kong--relevance to asthma and allergic disease. Clin Exp Allergy. 1998;28(5):585-90. [pmid: 9645595].
Levien T, Baker D E. Reviews of fexofenadine and nicotine nasal spray. Hosp Pharm. 1997;32(5):694-721.
Levien T, Baker D E. Tamulosin hydrochloride and samarium-153 lexidronam injection. Hosp Pharm. 1998;33(1):75-96.
Levine B. Effect of eprosartan and enalapril in the treatment of black hypertensive patients: Subgroup analysis of a 26-week, double-blind, multicentre study. Curr Med Res Opin. 1999;15(1):25-32. [pmid: 10216808].
Lewis S A, Weiss S T, Platts-Mills T A, et al. Association of specific allergen sensitization with socioeconomic factors and allergic disease in a population of Boston women. J Allergy Clin Immunol. 2001;107(4):615-22. [pmid: 11295648].
Leynadier F, Banoun L, Dollois B, et al. Immunotherapy with a calcium phosphate-adsorbed five-grass-pollen extract in seasonal rhinoconjunctivitis: a double-blind, placebo-controlled study. Clin Exp Allergy. 2001;31(7):988-96. [pmid: 11467988].
Leynadier F, Herman D, Vervloet D, et al. Specific immunotherapy with a standardized latex extract versus placebo in allergic healthcare workers. J Allergy Clin Immunol. 2000;106(3):585-90. [pmid: 10984382].
Leynaert B, Neukirch C, Liard R, et al. Quality of life in allergic rhinitis and asthma. A population-based study of young adults. Am J Respir Crit Care Med. 2000;162(4 Pt 1):1391-6. [pmid: 11029350].
Li J T. Grass-pollen immunotherapy for 3 to 4 years was still effective 3 years after being discontinued… commentary on Durham SR, Walker SM, Varga E, et al. Long-term clinical efficacy of grass-pollen immunotherapy. N Engl J Med1999 Aug 12;341:468–75. ACP Journal Club. 2000;132(2):65.
Li J T. Asthma and allergy: A four-article symposium. Postgrad Med. 2001;109(5):43.
Li J T C, Andrist D, Bamlet W R, et al. Accuracy of patient prediction of allergy skin test results. Ann Allergy Asthma Immunol. 2000;85(5):382-4. [pmid: 11101180].
Liao E, Leahy M, Cummins G. The costs of nonsedating antihistamine therapy for allergic rhinitis in managed care: an updated analysis. Am J Manag Care. 2001;7(15 Suppl):S459-68. [pmid: 11680261].
Lichtenstein L M, Ishizaka K, Norman P S, et al. IgE antibody measurements in ragweed hay fever. Relationship to clinical severity and the results of immunotherapy. J Clin Invest. 1973;52(2):472-82. [pmcid: 302277]. [pmid: 4119162].
Lichtenstein L M, Norman P S, Winken-Werder W L, et al. In vitro studies of human ragweed allergy. Changes in cellular and humoral activity associated with specific desensitization. J Clin Invest. 1966;45:1126-36. [pmcid: 292785]. [pmid: 16695914].
Lichtenstein L M, Norman P S, Winkenwerder W L. Clinical and in vitro studies on the role of immunotherapy in ragweed hay fever. Am J Med. 1968;44(4):514-24. [pmid: 4171086].
Lichtenstein L M, Norman P S, Winkenwerder W L. A single year of immunotherapy for ragweed hay fever. Immunologic and clinical studies. Ann Intern Med. 1971;75(5):663-71. [pmid: 4107763].
Lieberman P. American Academy of Asthma, Allergy and Immunology - 55th Annual Meeting: 26 February - 3 March 1999, Orlando, FL, USA. Idrugs. 1999;2(5):405-9. [pmid: 16155841].
Lieberman P. American Academy of Asthma, Allergy and Immunology - 56th annual meeting: 3–8 March 2000, San Diego, CA, USA. Curr Opin Anti-Inflammatory Immunomodulatory Invest Drugs. 2000;2(2):153-9.
Lin R Y, Nahal A, Lee M, et al. Changes in nasal leukocytes and epithelial cells associated with topical beclomethasone treatment. Ann Allergy Asthma Immunol. 2000;84(6):618-22. [pmid: 10875491].
Linneberg A, Nielsen N H, Madsen F, et al. Secular trends of allergic asthma in Danish adults. The Copenhagen Allergy Study. Respir Med. 2001;95(4):258-64. [pmid: 11316107].
Lipiec A, Jurkiewicz D, Rapiejko P. Mould hypersensitivity in allergic rhinitis patients. Int Rev Allergol Clin Immunol. 2000;6(2):57-62.
Lipold A G. Six ideas to boost employee productivity. Bus Health. 2001;19(9):26-30. [pmid: 11642055].
Lipworth B J. Emerging role of antileukotriene therapy in allergic rhinitis. Clin Exp Allergy. 2001;31(12):1813-21. [pmid: 11737031].
Littorin M, Truedsson L, Welinder H, et al. Acute respiratory disorder, rhinoconjunctivitis and fever associated with the pyrolysis of polyurethane derived from diphenylmethane diisocyanate. Scand J Work Environ Health. 1994;20(3):216-22. [pmid: 7973495].
Liu C M, Hsu M - C. Clinical evaluation of azelastine nasal spray versus terfenadine in the treatment of allergic rhinitis. J Taiwan Otolaryngol Head Neck Surg. 1999;34(6):471-8.
Liu J T, Hammitt J K, Wang J D, et al. Mother's willingness to pay for her own and her child's health: a contingent valuation study in Taiwan. Health Econ. 2000;9(4):319-26. [pmid: 10862075].
LoBuono C. Eliminating allergy triggers. Patient Care 2000;34(7):107–9, 120–1.
Lockey R F. Building- and home-related complaints and illnesses: Summary statement. J Allergy Clin Immunol. 1994;94(2 II Suppl):423-4.
Lockey R F. “ARIA”: Global guidelines and new forms of allergen immunotherapy. J Allergy Clin Immunol. 2001;108(4):497-9. [pmid: 11590370].
Lockey R F, Widlitz M D, Mitchell D Q, et al. Comparative study of cetirizine and terfenadine versus placebo in the symptomatic management of seasonal allergic rhinitis. Ann Allergy Asthma Immunol. 1996;76(5):448-54. [pmid: 8630719].
Lombardero M, Heymann P W, Platts-Mills T A, et al. Conformational stability of B cell epitopes on group I and group II Dermatophagoides spp. allergens. Effect of thermal and chemical denaturation on the binding of murine IgG and human IgE antibodies. J Immunol. 1990;144(4):1353-60. [pmid: 1689351].
Lombardi C, Gargioni S, Melchiorre A, et al. Safety of sublingual immunotherapy with monomeric allergoid in adults: Multicenter post-marketing surveillance study. Allergy Eur J Allergy Clin Immunol. 2001;56(10):989-92.
Lombardi E, Stein R T, Wright A L, et al. The relation between physician-diagnosed sinusitis, asthma, and skin test reactivity to allergens in 8-year-old children. Pediatr Pulmonol. 1996;22(3):141-6. [pmid: 8893251].
Long A, McFadden C, DeVine D, et al. Management of allergic and nonallergic rhinitis. Evidence Report/Technology Assessment No. 54 (Prepared by New England Medical Center Evidence-based Practice Center under Contract No. 290-97-0019). AHRQ Publication No. 02-E024. Rockville, MD: Agency for Healthcare Research and Quality. May 2002.
Long L, Soeken K, Ernst E. Herbal medicines for the treatment of osteoarthritis: A systematic review. Rheumatology (UK). 2001;40(7):779-93. [pmcid: 128936].
Lonneux J F, Losson B. Field efficacy of injectable and pour-on moxidectin in cattle naturally infested with Psoroptes ovis (Acarina: Psoroptidae). Vet Parasitol. 1992;45(12):147-52. [pmid: 1485416].
Lonneux J F, Nguyen T Q, Delhez M, et al. Antibody response after treatment in cattle infected with Psoroptes ovis. Res Vet Sci. 1997;63(1):57-60. [pmid: 9368957].
Lorette G, Giannetti A, Pereira R S, et al. One-year treatment of chronic urticaria with mizolastine: Efficacy and safety. J Eur Acad Dermatol Venereol. 2000;14(2):83-90. [pmid: 10972091].
Losson B, Lonneux J F. Field efficacy of injectable moxidectin in cattle naturally infested with Chorioptes bovis and Sarcoptes scabiei. Vet Parasitol. 1993;51(12):113-21. [pmid: 8128574].
Lovering A M. Counting the cost of rhinosinusitis. Round Table Ser R Soc Med. 1999;67:51-8.
Lowe F. Alpha-1-adrenoceptor blockade in the treatment of benign prostatic hyperplasia. Prostate Cancer Prostatic Dis. 1999;2(3):110-9. [pmid: 12496820].
Lowell F C, Franklin W. A double-blind study of the effectiveness and specificity of injecton therapy in ragweed hay fever. N Engl J Med. 1965;273(13):675-9. [pmid: 5318212].
Lowenthal D T, Flannery M, Mader S L, et al. Benign prostatic hyperplasia: Maximizing treatment with alpha blockers. Geriatrics. 1998;53(10 Suppl 2):S4-S26. [pmid: 9789482].
Lower T, Henry J, Mandik L, et al. Compliance with allergen immunotherapy. Ann Allergy. 1993;70(6):480-2. [pmid: 8507043].
Luczynska C, Sterne J, Bond J, et al. Indoor factors associated with concentrations of house dust mite allergen, Der p 1, in a random sample of houses in Norwich, UK. Clin Exp Allergy. 1998;28(10):1201-9. [pmid: 9824386].
Lum L C, Lum L M, Lum L C. Medications in the allergy/asthma office. Immunol Allergy Clin North Am. 1999;19(1):101-27.
Lund V. Summary of discussion. Round Table Ser R Soc Med. 1999;67:59-63.
Lund V J. Health related quality of life in sinonasal disease. Rhinology. 2001;39(4):182-6. [pmid: 11826685].
Lundback B. Epidemiology of rhinitis and asthma. [Review]. Clin Exp Allergy 1998;(Suppl 2):3–10.
Lundberg L, Isacson D. The impact of over-the-counter availability of nasal sprays on sales, prescribing, and physician visits. Scand J Prim Health Care. 1999;17(1):41-5. [pmid: 10229992].
Lundblad F P. House dust mite allergy in an office building. Appl Occup Environ Hyg. 1991;6(2):94-6.
Lundblad L, Sipila P, Farstad T, et al. Mometasone furoate nasal spray in the treatment of perennial non-allergic rhinitis: a Nordic, multicenter, randomized, double-blind, placebo-controlled study. Acta Oto-Laryngol. 2001;121(4):505-9.
Lurie A, Nadel J A, Roisman G, et al. Role of neutral endopeptidase and kininase II on substance P-induced increase in nasal obstruction in patients with allergic rhinitis. Am J Respir Crit Care Med. 1994;149(1):113-7. [pmid: 7509244].
Lusk R P, Stankiewicz J A. Pediatric rhinosinusitis. Otolaryngol Head Neck Surg. 1997;117(3 II Suppl):S53-S57. [pmid: 9334789].
Lutsky I I, Neuman I. Laboratory animal dander allergy: I. An occupational disease. Ann Allergy. 1975;35(4):201-5. [pmid: 1238037].
Lynoe N, Svensson T. Doctors' attitudes towards empirical data -- a comparative study. Scand J Soc Med. 1997;25(3):210-6. [pmid: 9360279].
M'Raihi L, Charpin D, Thibaudon M, et al. Bronchial challenge to house dust can induce immediate bronchoconstriction in allergic asthmatic patients. Ann Allergy. 1990;65(6):485-8. [pmid: 2256579].
Mabry R L, Mabry C S. Allergic fungal rhinosinusitis: experience with immunotherapy. Arch Otolaryngol Head Neck Surg. 1998;124(10):1178. [pmid: 9776200].
Macchia L, Caiaffa M F, Di Felice G, et al. Changes in skin reactivity, specific IgE and IgG levels after one year of immunotherapy in olive pollinosis. Allergy. 1991;46(6):410-8. [pmid: 1957991].
Machiels J J, Buche M, Somville M A, et al. Complexes of grass pollen allergens and specific antibodies reduce allergic symptoms and inhibit the seasonal increase of IgE antibody. Clin Exp Allergy. 1990;20(6):653-60. [pmid: 2083405].
Machiels J J, Somville M A, Jacquemin M G, et al. Allergen-antibody complexes can efficiently prevent seasonal rhinitis and asthma in grass pollen hypersensitive patients. Allergen-antibody complex immunotherapy. Allergy. 1991;46(5):335-48. [pmid: 1928657].
Mackay I S, Durham S R. ABC of allergies. Perennial rhinitis. BMJ. 1998;316(7135):917-20. [pmid: 9552846].
Mackay I S, Durham S R. Perennial rhinitis. BMJ. 1998;316:917-20. [pmid: 9552846].
Mackowiak J I. The health and economic impact of rhinitis. Am J Manag Care. 1997;3:S8-S18. [pmid: 10180342].
Mackowiak J I, Stempel D A. Nasal steroids lead to superior outcomes in rhinitis: an outcomes monitoring pilot study in an HMO. [Abstract]. Ann Allergy Asthma Immunol. 1997;78:155.
Maderazo E G, Albano S D. Granulocyte migration abnormality in patients suffering from seasonal allergic rhinitis: failure of treatment with cimetidine. Int Arch Allergy Appl Immunol. 1984;74(3):211-5. [pmid: 6724715].
Mahe C, Chevret S. Analysis of recurrent failure times data: Should the baseline hazard be stratified?. Stat Med. 2001;20(24):3807-15. [pmid: 11782035].
Mahmoudi M, Gershwin M E. Sick building syndrome. III. Stachybotrys chartarum. J Asthma. 2000;37(2):191-8. [pmid: 10805208].
Maini R, St C E W, Breedveld F, et al. Infliximab (chimeric anti-tumour necrosis factor alpha monoclonal antibody) versus placebo in rheumatoid arthritis patients receiving concomitant methotrexate: A randomised phase III trial. Lancet. 1999;354(9194):1932-9. [pmid: 10622295].
Maini R N, Breedveld F C, Kalden J R, et al. Therapeutic efficacy of multiple intravenous infusions of anti-tumor necrosis factor monoclonal antibody combined with low-dose weekly methotrexate in rheumatoid arthritis. Arthritis Rheum. 1998;41(9):1552-63. [pmid: 9751087].
Majani G, Baiardini I, Giardini A, et al. Health-related quality of life assessment in young adults with seasonal allergic rhinitis. Allergy. 2001;56(4):313-7. [pmid: 11284798].
Malling H J. Practical immunotherapy. Rev Esp Alergol Inmunol Clin. 1996;11(Spec Iss 1):55-62.
Malling H J. Indications and contraindications for allergen-specific immunotherapy. Allergy Clin Immunol Int. 1998;10(3):76-80.
Malmberg H, Holopainen E, Grahne B, et al. Astemizole in the treatment of hay fever. Allergy Eur J Allergy Clin Immunol. 1983;38(4):227-31.
Malo J L, Chan-Yeung M. Current reviews of allergy and clinical immunology: Occupational asthma. J Allergy Clin Immunol. 2001;108(3):317-28. [pmid: 11544449].
Malone D C, Lawson K A, Smith D H, et al. A cost of illness study of allergic rhinitis in the United States. J Allergy Clin Immunol. 1997;99(1 Pt 1):22-7. [pmid: 9003207].
Mamikoglu B, Corey J. Safety of antihistamine therapy. Curr Opin Otolaryngol Head Neck Surg. 1998;6(1):75-9.
Manjra A, Berman D, Toerien A, et al. The effects of a single treatment of an acaricide, Acarosan, and a detergent, Metsan, on Der p 1 allergen levels in the carpets and mattresses of asthmatic children. S Afr Med J. 1994;84(5):278-80. [pmid: 7809773].
Mann K V, Crowe S J P, Tietze K J. Nonsedating histamine Hinf 1-receptor antagonists. Clin Pharm. 1989;8(5):331-44. [pmid: 2568212].
Manor O, Matthews S, Power C. Self-rated health and limiting longstanding illness: inter-relationships with morbidity in early adulthood. Int J Epidemiol. 2001;30(3):600-7. [pmid: 11416091].
Mansour M, Lanphear B P, Hornung R, et al. A side-by-side comparison of sampling methods for settled, indoor allergens. Environ Res. 2001;87(1):37-46. [pmid: 11534963].
Mao S J, Kluge K, Squillace S J. Apolipoprotein A-II can incorporate into plasma very low density lipoproteins. FEBS Lett. 1981;132(2):289-92. [pmid: 6795063].
Marchesani F, Cecarini L, Pela R, et al. Causes of chronic persistent cough in adult patients: The results of a systematic management protocol. Monaldi Arch Chest Dis. 1998;53(5):510-4. [pmid: 9861809].
Marinella M A. Rhinosinusitis possibly caused by Pasteurella multocida. Infect Dis Clin Pract. 1996;5(3):208-9.
Marini A, Agosti M, Motta G, et al. Effects of a dietary and environmental prevention programme on the incidence of allergic symptoms in high atopic risk infants: three years' follow-up. Acta Paediatr Suppl. 1996;414:1-21. [pmid: 8831855].
Marks G B. House dust mite exposure as a risk factor for asthma: benefits of avoidance. [Review]. Allergy. 1998;53(48 Suppl):108-14. [pmid: 10096821].
Marks G B, Tovey E R, Green W, et al. House dust mite allergen avoidance: a randomized controlled trial of surface chemical treatment and encasement of bedding. Clin Exp Allergy. 1994;24(11):1078-83. [pmid: 7677828].
Marks G B, Tovey E R, Green W, et al. The effect of changes in house dust mite allergen exposure on the severity of asthma. Clin Exp Allergy. 1995;25(2):114-8. [pmid: 7750002].
Marks G B, Tovey E R, Peat J K, et al. Variability and repeatability of house dust mite allergen measurement: implications for study design and interpretation. Clin Exp Allergy. 1995;25(12):1190-7. [pmid: 8821299].
Marogna M, Tiri A, Riva G. Clinical practice improvement program for immunotherapy of respiratory allergic diseases. Int J Immunopathol Pharmacol. 2001;14(2):93-101. [pmid: 12604024].
Marques Rezende R, Dos Santos A C, Anselmo-Lima W T, et al. Computed tomography for the evaluation of children with chronic rhinosinusitis: Proposal of a reduced examination and comparison with the standard examination. Int J Pediatr Otorhinolaryngol. 2000;55(1):11-5. [pmid: 10996230].
Marsa L. Making a case for easier access to allergy drugs. Los Angeles Times, (Health):S1, S6, 2001 Apr 9.
Marsland T W, Newton W P. Do antihistamines impair school performance in children?. J Fam Pract. 2001;50(9):738. [pmid: 11674900].
Martin I R, Henwood J L, Wilson F, et al. House dust mite and cat allergen levels in domestic dwellings in Christchurch. New Zealand Med J. 1997;110(1046):229-31. [pmid: 9236806].
Martinati L C, Boner A L. Optimum treatment of allergic rhinitis in children. Biodrugs. 1997;8(5):348-59. [pmid: 18020525].
Mason J, Reynolds R, Rao N. The systemic safety of fexofenadine HCl. Clin Exp Allergy Suppl. 1999;29(3):163-70.
Massey D G, Fournier-Massey G, James R H. Minimizing acarians and house dust in the tropics. Ann Allergy. 1993;71(5):439-44. [pmid: 8250349].
Massey D G, Furumizo R T, Fournier-Massey G, et al. House dust mites in university dormitories. Ann Allergy. 1988;61(3):229-32. [pmid: 3415054].
Maunsell K, Wraith D G, Hughes A M. Hyposensitisation in mite asthma. Lancet. 1971;1(7706):967-8. [pmid: 4102290].
Mazzaglia G, Greco S, Lando C, et al. Adult acute respiratory tract infections in Sicily: Pattern of antibiotic drug prescription in primary care. J Antimicrob Chemother. 1998;41(2):259-66. [pmid: 9533469].
McAllen M K. Hyposensitisation in grass pollen hay fever. A double blind trial of alumn precipitated pollen extract and depot emulsion pollen extract compared with placebo injections. Acta Allergol. 1969;24(6):421-31. [pmid: 4910693].
McAllen M K, Assem E S, Maunsell K. House-dust mite asthma. Results of challenge tests on five criteria with Dermatophagoides pteronyssinus. BMJ. 1970;2(708):501-4. [pmid: 4987898].
McAuley D F, McGovern V, Dick P T, et al. Churg-Strauss syndrome associated with leukotriene receptor antagonists. Ulster Med J. 2001;70(2):152-4. [pmid: 11795768].
McClellan K, Jarvis B. Desloratadine. Drugs. 2001;61(6):789-96. [pmid: 11398910].
McClennen W, Wilson T. Felodipine extended release versus conventional diuretic therapy for the treatment of systolic hypertension in elderly patients. Clin Invest Med. 1998;21(3):142-50. [pmid: 9627768].
McEwen L M, Birtwistle S, Kay A B, et al. Immunotherapy. BMJ. 1991;302(6775):530-1.
McFadden EA, Gungor A, Ng B, et al. Loratadine/pseudoephedrine for nasal symptoms in seasonal allergic rhinitis: a double-blind, placebo-controlled study. Ear Nose Throat J 2000;79(4):254, 257–8, 260 passim.
McHugh S M, Ewan P W. Reduction of increased serum neutrophil chemotactic activity following effective hyposensitization in house dust mite allergy. Clin Exp Allergy. 1989;19(3):327-34. [pmid: 2660970].
McHugh S M, Ewan P W. A clinical index: a new method to assess efficacy of allergen immunotherapy. Allergy. 1992;47(2 Pt 1):115-20. [pmid: 1632479].
McHugh S M, Lavelle B, Kemeny D M, et al. A placebo-controlled trial of immunotherapy with two extracts of Dermatophagoides pteronyssinus in allergic rhinitis, comparing clinical outcome with changes in antigen-specific IgE, IgG, and IgG subclasses. J Allergy Clin Immunol. 1990;86(4 Pt 1):521-31. [pmid: 1699985].
McKeever T M, Lewis S A, Smith C, et al. Siblings, multiple births, and the incidence of allergic disease: A birth cohort study using the West Midlands general practice research database. Thorax. 2001;56(10):758-62. [pmid: 11562513].
McLarty MR, Whittman L, Lawrence DB. Comparison of first generation antihistamines and cetirizine using an allergic rhinitis quality of life questionnaire. [Abstract]. ASHP Midyear Clin Mtg 1997;32:P-198E.
McMenamin P. Costs of hay fever in the United States in 1990. Ann Allergy. 1994;73(1):35-9. [pmid: 8030800].
McSherry J. Rhinosinusitis in primary care: What can guidelines achieve?. Round Table Ser R Soc Med. 1999;67:45-9.
McWhorter W P. Allergy and risk of cancer. A prospective study using NHANESI followup data. Cancer. 1988;62(2):451-5. [pmid: 3383143].
Mead M. Allergic rhinitis. Practice Nurse. 1997;13(9):556-7.
Medleau L, Willemse T. Efficacy of daily amitraz on generalised demodicosis in dogs. J Small Animal Pract. 1995;36(1):3-6.
Medrala W, Wolanczyk-Medrala A, Wrzyszcz M, et al. The influence of the first course of immunotherapy in patients with pollinosis on sulfidoleukotriene release from peripheral blood leukocytes. Int Rev Allergol Clin Immunol. 1999;5(1):13-6.
Meggs W J. Rads and ruds - The toxic induction of asthma and rhinitis. J Toxicol Clin Toxicol. 1994;32(5):487-501. [pmid: 7932908].
Mehta S B, Smith J M. Nasal hyposensitization and hay fever. Clin Allergy. 1975;5(3):279-84. [pmid: 1102147].
Mellerup M T, Hahn G W, Poulsen L K, et al. Safety of allergen-specific immunotherapy. Relation between dosage regimen, allergen extract, disease and systemic side-effects during induction treatment. Clin Exp Allergy. 2000;30(10):1423-9. [pmid: 10998019].
Meltzer E O. An overview of current pharmacotherapy in perennial rhinitis. J Allergy Clin Immunol. 1995;95(5 II):1097-110. [pmid: 7538519].
Meltzer E O. Allergy and clinical immunology. J Allergy Clin Immunol. 1997;99(6 II Suppl):S807.
Meltzer E O. The prevalence and medical and economic impact of allergic rhinitis in the United States. Introduction. J Allergy Clin Immunol. 1997;99(6 Pt 2):S807.
Meltzer E O. Clinical and antiinflammatory effects of intranasal budesonide aqueous pump spray in the treatment of perennial allergic rhinitis. Ann Allergy Asthma Immunol. 1998;81(2):128-34. [pmid: 9723557].
Meltzer E O. Role for cysteinyl leukotriene receptor antagonist therapy in asthma and their potential role in allergic rhinitis based on the concept of ‘one linked airway disease’. Ann Allergy Asthma Immunol. 2000;84(2):176-87. [pmid: 10719774].
Meltzer E O. Quality of life in adults and children with allergic rhinitis. [Review]. J Allergy Clin Immunol. 2001;108(1 Suppl):S45-53. [pmid: 11449206].
Meltzer E O, Casale T B, Nathan R A, et al. Once-daily fexofenadine HCl improves quality of life and reduces work and activity impairment in patients with seasonal allergic rhinitis. Ann Allergy Asthma Immunol. 1999;83(4):311-7. [pmid: 10541423].
Meltzer E O, Ehrlich P M. Step approach to the clinical management of allergic rhinitis: prescription and over the counter therapeutic reference summary. Manag Care Interface. 1999;12:70-7. [pmid: 11184274].
Meltzer E O, Grant J A. Impact of cetirizine on the burden of allergic rhinitis. [Review]. Ann Allergy Asthma Immunol. 1999;83(5):455-63. [pmid: 10582731].
Meltzer E O, Malmstrom K, Lu S, et al. Concomitant montelukast and loratadine as treatment for seasonal allergic rhinitis: a randomized, placebo-controlled clinical trial. J Allergy Clin Immunol. 2000;105(5):917-22. [pmid: 10808172].
Meltzer E O, Orgel H A, Biondi R, et al. Ipratropium nasal spray in children with perennial rhinitis. Ann Allergy Asthma Immunol. 1997;78(5):485-91. [pmid: 9164362].
Meltzer E O, Orgel H A, Bronsky E A, et al. Ipratropium bromide aqueous nasal spray for patients with perennial allergic rhinitis: a study of its effect on their symptoms, quality of life, and nasal cytology. J Allergy Clin Immunol. 1992;90(2):242-9. [pmid: 1386857].
Meltzer E O, Tyrell R J, Rich D, et al. A pharmacologic continuum in the treatment of rhinorrhea: the clinician as economist. [Review]. J Allergy Clin Immunol. 1995;95(5 Pt 2):1147-52. [pmid: 7538521].
Meran A, Morse J, Gibbs T G. A cross-over comparison of acrivastine, pseudoephedrine and their combination in seasonal allergic rhinitis. Rhinology. 1990;28(1):33-40. [pmid: 1970907].
Merget R, Heger M, Globisch A, et al. Quantitative bronchial challenge tests with wheat flour dust administered by spinhaler: comparison with aqueous wheat flour extract inhalation. J Allergy Clin Immunol. 1997;100(2):199-207. [pmid: 9275141].
Metintas S, Metintas M, Kalyoncu C, et al. Prevalence of asthma and other allergic diseases in primary schoolchildren of Eskisehir (Turkey). Allergy Clin Immunol Int. 2001;13(6):250-5.
Metlzer I O, Nathan R A, Selner J C, et al. Quality of life and rhinitic symptoms: Results of a nationwide survey with the SF-36 and RQLQ questionnaires. J Allergy Clin Immunol. 1997;99:S815-9.
Metso T, Bjorksten F, Kilpio K, et al. Serum myeloperoxidase and sick building syndrome. Lancet. 1993;342(8863):113-4. [pmid: 8100878].
Metson R, Cosenza M, Gliklich R E, et al. The role of image-guidance systems for head and neck surgery. Arch Otolaryngol Head Neck Surg. 1999;125(10):1100-4. [pmid: 10522501].
Metson R B, Gliklich R E. Clinical outcomes in patients with chronic sinusitis. Laryngoscope. 2000;110(3 Pt 3):24-8. [pmid: 10718411].
Metzger W J, Patterson R, Seiss C R, et al. Comparison of polymerized and unpolymerized antigen E for immunotherapy of ragweed allergy. New Engl J Med. 1976;295:1160-64. [pmid: 824555].
Meyer H W, Larsen F O, Jacobi H H, et al. Sick building syndrome: Association of symptoms with serum IgE specific to fungi. Inflamm Res. 1998;47(Suppl 1):S9-S10. [pmid: 9561392].
Miadonna A, Cottini M, Milazzo N, et al. In vivo and ex vivo inhibitory effects of loratadine on histamine release in patients with allergic rhinitis. Allergy. 1998;53(12):1183-8. [pmid: 9930595].
Miesen W M A J, DeMonchy J G R, Dubois A E J. Anaphylaxis on skin exposure to grass. Allergy Eur J Allergy Clin Immunol. 2001;56(8):799.
Mihrshahi S, Peat J K, Webb K, et al. The childhood asthma prevention study (CAPS): design and research protocol of a randomized trial for the primary prevention of asthma. Controlled Clinical Trials. 2001;22(3):333-54. [pmid: 11384793].
Miles V H, Fischer P R, Freij B J, et al. Variations in the treatment of common infections (multiple letters). Pediatr Infect Dis J. 1997;16(8):826-7. [pmid: 9271053].
Milgrom H, Biondi R, Georgitis J W, et al. Comparison of ipratropium bromide 0.03% with beclomethasone dipropionate in the treatment of perennial rhinitis in children. Ann Allergy Asthma Immunol. 1999;83(2):105-11. [pmid: 10480582].
Miller A C, Tees E C. A metabolizable adjuvant: clinical trial of grass pollen-tyrosine adsorbate. Clin Allergy. 1974;4(1):49-55. [pmid: 4824572].
Milosevic D N, Janosevic L J B, Janosevic S B. Intradermal tests with vasomotor agents perennial non-allergic rhinitis. Acta Oto-Rhino-Laryngol Belg. 2000;54(4):465-71.
Minatre D, Baker D E, Blanch M C, et al. Reviews of interferon-beta (preliminary evaluation) and loratadine. Hosp Pharm. 1993;28(11):1118-24.
Mischler T W, O'Brien W M, Rugloski R J, et al. Multiclinic trial with glutaraldehyde modified tyrosine adsorbed ragweed pollen immunotherapy (Pollinex). Curr Therap Res. 1981;29:745-56.
Mitchell E A, Elliott R B. Controlled trial of an electrostatic precipitator in childhood asthma. Lancet. 1980;2(8194):559-61. [pmid: 6106739].
Mitchell T N, Sander J W. Levetiracetam: A new antiepileptic drug for the adjunctive therapy of chronic epilepsy. Drugs Today. 2001;37(10):665-73. [pmid: 12738964].
Moffett L M. Allergic rhinitis: new guidelines for the millennium. Nebraska Mortar Pestle. 2000;64:16-9.
Moher D, Cook D J, Jadad A R, et al. Assessing the quality of randomised trials: current issues and future directions. Int J Tech Assess Health Care. 1996;12(2):195-208.
Moher D, Schulz K F, Altman D, et al. The CONSORT statement: revised recommendations for improving the quality of reports of parallel-group randomized trials. [Review]. JAMA. 2001;285(15):1987-91. [pmid: 11308435].
Moller C. Pediatric peculiarities of immunotherapy. Rev Esp Alergol Inmunol Clin. 1996;11(Spec Iss 1):35-8.
Möller C, Dreborg S, Ferdousi H A, et al. Pollen immunotherapy reduces the development of asthma in children with seasonal rhinoconjunctivitis (the PAT-study). J Allergy Clin Immunol. 2002;109(2):251-6. [pmid: 11842293].
Moller C, Dreborg S, Lanner A, et al. Oral immunotherapy of children with rhinoconjunctivitis due to birch pollen allergy. A double blind study. Allergy. 1986;41(4):271-9. [pmid: 3530030].
Moller C, Mygind N. Nasal blockage in children with non-infectious rhinitis: Consequences and treatment. Allergy Eur J Allergy Clin Immunol Suppl. 1997;52(40):45-51.
Mollet J A, Vailes L D, Avner D B, et al. Evaluation of German cockroach (Orthoptera:Blattellidae) allergen and seasonal variation in low-income housing. J Med Entomol. 1997;34(3):307-11. [pmid: 9151495].
Monfrecola G, Masturzo E, Riccardo A M, et al. Solar urticaria: a report on 57 cases. Am J Contact Dermat. 2000;11(2):89-94. [pmid: 10908176].
Moon C A L, Davey A. The efficacy and residual effects of trazodone (150 mg nocte) and mianserin in the treatment of depressed general practice patients. Psychopharmacology. 1988;95(Suppl):S7-S13. [pmid: 3133716].
Moon J S, Choi S O. Environmental controls in reducing house dust mites and nasal symptoms in patients with allergic rhinitis. Yonsei Med J. 1999;40(3):238-43. [pmid: 10412335].
Moreland L W. Soluble tumor necrosis factor receptor (p75) fusion protein (Enbrel) as a therapy for rheumatoid arthritis. Rheum Dis Clin North Am. 1998;24(3):579-91. [pmid: 9710888].
Mori S, Fujieda S, Sunaga H, et al. Expression of platelet-derived endothelial cell growth factor and vascularity in the nasal mucosa from allergic rhinitis. Clin Exp Allergy. 2000;30(11):1637-44. [pmid: 11069574].
Moriguchi H, Matsumoto M, Nishimoto Y, et al. The development of a pollen information system for the improvement of QOL. J Med Investig. 2001;48(34):198-209. [pmid: 11694960].
Mortimer M J, Kay J, Gawkrodger D J, et al. The prevalence of headache and migraine in atopic children: An epidemiological study in general practice. Headache. 1993;33(8):427-31. [pmid: 8262782].
Mortz C G, Lauritsen J M, Bindslev-Jensen C, et al. Prevalence of atopic dermatitis, asthma, allergic rhinitis, and hand and contact dermatitis in adolescents. The Odense adolescence cohort study on atopic diseases and dermatitis. Br J Dermatol. 2001;144(3):523-32. [pmid: 11260009].
Mosbech H. Who will benefit from hyposensitization? Predictive parameters in house dust mite allergic asthmatics. Allergy. 1990;45(3):209-12. [pmid: 2327561].
Mosbech H, Dirksen A, Dreborg S, et al. Hyposensitization in asthmatics with mPEG-modified and unmodified house dust mite extract. IV. Occurrence and prediction of side effects. Allergy. 1990;45(2):142-50. [pmid: 2316824].
Mosbech H, Dreborg S, Madsen F, et al. High dose grass pollen tablets used for hyposensitization in hay fever patients. A one-year double blind placebo-controlled study. Allergy. 1987;42(6):451-5. [pmid: 3310717].
Mosbech H, Osterballe O. Does the effect of immunotherapy last after termination of treatment? Follow-up study in patients with grass pollen rhinitis. Allergy. 1988;43(7):523-9. [pmid: 3148282].
Moscato G, Galdi E, Scibilia J, et al. Occupational asthma, rhinitis and urticaria due to piperacillin sodium in a pharmaceutical worker. Eur Respir J. 1995;8(3):467-9. [pmid: 7789496].
Moss M H, Bush R K. Patient selection and administration of aeroallergen vaccines. Immunol Allergy Clin North Am. 2000;20(3):533-52.
Motta G, Passali D, De Vincentiis I, et al. A multicenter trial of specific local nasal immunotherapy. Laryngoscope. 2000;110(1):132-9. [pmid: 10646729].
Moverare R, Rak S, Elfman L. Allergen-specific increase in interleukin (IL)-4 and IL-5 secretion from peripheral blood mononuclear cells during birch-pollen immunotherapy. Allergy. 1998;53(3):275-81. [pmid: 9542607].
Moverare R, Vesterinen E, Metso T, et al. Pollen-specific rush immunotherapy: clinical efficacy and effects on antibody concentrations. Ann Allergy Asthma Immunol. 2001;86(3):337-42. [pmid: 11289336].
Muirhead G J, Wulff M B, Fielding A, et al. Pharmacokinetic interactions between sildenafil and saquinavir/ritonavir. Br J Clin Pharmacol. 2000;50(2):99-107. [pmid: 10930961].
Muncer S J. Control of house dust mite in managing asthma. Power dressing is important in meta-analysis. BMJ. 1999;318(7187):871. [pmid: 10223799].
Mungan D, Misirligil Z, Gurbuz L. Comparison of the efficacy of subcutaneous and sublingual immunotherapy in mite-sensitive patients with rhinitis and asthma--a placebo controlled study. Ann Allergy Asthma Immunol. 1999;82(5):485-90. [pmid: 10353581].
Munir A K, Einarsson R, Dreborg S K. Vacuum cleaning decreases the levels of mite allergens in house dust. Pediatr Allergy Immunol. 1993;4(3):136-43. [pmid: 8220802].
Munoz Lejarazu D, Bernaola G, Fernandez E, et al. Seasonal versus perennial immunotherapy: evaluation after three years of treatment. J Investig Allergol Clin Immunol. 1993;3(4):210-6.
Munro C S, Levell N J, Shuster S, et al. Maintenance treatment with cyclosporin in atopic eczema. Br J Dermatol. 1994;130(3):376-80. [pmid: 8148281].
Muro M D, Tabar A I, Lizaso M T, et al. Cluster versus conventional immunotherapy in patients allergic to Dermatophagoides pteronyssinus: a controlled study of in vivo and in vitro parameters. J Investig Allergol Clin Immunol. 1999;9(3):146-54.
Murphy A W, Platts-Mills T A, Lobo M, et al. Respiratory nitric oxide levels in experimental human influenza. Chest. 1998;114(2):452-6. [pmid: 9726729].
Murphy III EE, Slavin RG. Occupational rhinitis: when to suspect, what to do: does the problem originate or simply worsen at work? J Respir Dis 2001;22(6):347–50, 352.
Murray A B, Ferguson A C. Dust-free bedrooms in the treatment of asthmatic children with house dust or house dust mite allergy: a controlled trial. Pediatrics. 1983;71(3):418-22. [pmid: 6338475].
Musk A W, deKlerk N H, Beach J R, et al. Respiratory symptoms and lung function in alumina refinery employees. Occup Environ Med. 2000;57(4):279-83. [pmid: 10810116].
Mygind N. Clinical investigation of allergic rhinitis and allied conditions. [Review]. Allergy. 1979;34(4):195-208. [pmid: 391092].
Mygind N. Introduction. Rhinology. 2000;38(Suppl 16):2.
Mygind N. Nasal inflammation and anti-inflammatory treatment. Semantics or clinical reality?. Rhinology. 2001;39(2):61-5. [pmid: 11486439].
Naclerio R, Solomon W. Rhinitis and inhalant allergens. [Review]. JAMA. 1997;278(22):1842-8. [pmid: 9396645].
Naclerio R M. Allergic rhinitis. [Review]. New Engl J Med. 1991;325(12):860-9. [pmid: 1875971].
Naclerio R M. Dose-dependent effects of intranasal steroids: How relevant?. Ann Allergy Asthma Immunol. 2000;85(4):248-9. [pmid: 11061465].
Naclerio R M, Baroody F M. Response of nasal mucosa to histamine or methacholine challenge: use of a quantitative method to examine the modulatory effects of atropine and ipratropium bromide. J Allergy Clin Immunol. 1992;90(6 Pt 2):1051-4. [pmid: 1460207].
Naclerio R M, deTineo M L, Baroody F M. Ragweed allergic rhinitis and the paranasal sinuses. A computed tomographic study. Arch Otolaryngol Head Neck Surg. 1997;123(2):193-6. [pmid: 9046288].
Naclerio R M, Proud D, Moylan B, et al. A double-blind study of the discontinuation of ragweed immunotherapy. J Allergy Clin Immunol. 1997;100(3):293-300. [pmid: 9314339].
Nagata M, Yamamoto H, Tabe K, et al. Effect of rush immunotherapy in house-dust-mite (HDM)-sensitive adult bronchial asthma: changes in in vivo and in vitro responses to HDM. Intern Med. 1993;32(9):702-9. [pmid: 8142674].
Nagy G. The use of Paxirasol in clinical practice. [Review]. Ther Hung. 1993;41(3):100-6. [pmid: 8202865].
Nalebuff D J. Use of RAST screening in clinical allergy: a cost-effective approach to patient care. Ear Nose Throat J. 1985;64(3):107-21. [pmid: 3920041].
Nascimento Silva M G, Naspitz C K, Sole D. Evaluation of quality of life in children and teenagers with allergic rhinitis: adaptation and validation of the Rhinoconjunctivitis Quality of Life Questionnaire (RQLQ). Allergol Immunopathol. 2001;29(4):111-9.
Nash DB, Sullivan SD, Mackowiak J. Optimizing quality of care and cost effectiveness in treating allergic rhinitis in a managed care setting. Am J Manag Care 2000;6(1 Suppl):S3–15; quiz S19–20.
Naspitz C K, Rizzo M C, Fernandez-Caldas E, et al. Environmental control in childhood asthma. Pediatr Pulmonol Suppl. 1995;11:47-8. [pmid: 7547342].
Nathan R A, Meltzer E O, Seiner J C, et al. Prevalence of allergic rhinitis in the United States. J Allergy Clin Immunol. 1997;99:S808-14.
National Heart Lung and Blood Institute. Practical guide for the diagnosis and management of asthma. NIH Publication No. 97–4053. Rockville, MD: National Institutes of Health, 1997.
National Institute of Allergy and Infectious Diseases, National Institutes of Health. Allergy statistics. NIAID Fact Sheet. Bethesda, MD: National Institute of Allergy and Infectious Diseases. January 2002.
National Institutes of Health. Fighting seasonal allergies. NIH Word on Health. Bethesda, MD: National Institutes of Health. June 2002.
Nayak A S, Philip G, Lu S, et al. Efficacy and tolerability of montelukast alone or in combination with loratadine in seasonal allergic rhinitis: a multicenter, randomized, double-blind, placebo-controlled trial performed in the fall. Ann Allergy Asthma Immunol. 2002;88(6):592-600. [pmid: 12086367].
Negrini A C, Troise C, Voltolini S, et al. Oral antihistamine/decongestant treatment compared with intranasal corticosteroids in seasonal allergic rhinitis. Clin Exp Allergy. 1995;25(1):60-5. [pmid: 7537170].
Nelson H S, Areson J, Reisman R. A prospective assessment of the remote practice of allergy: comparison of the diagnosis of allergic disease and the recommendations for allergen immunotherapy by board-certified allergists and a laboratory performing in vitro assays. J Allergy Clin Immunol. 1993;92(3):380-6. [pmid: 8360388].
Nelson H S, Hirsch S R, Ohman J L Jr, et al. Recommendations for the use of residential air-cleaning devices in the treatment of allergic respiratory diseases. J Allergy Clin Immunol. 1988;82(4):661-9. [pmid: 3171006].
Nelson H S, Oppenheimer J, Vatsia G A, et al. A double-blind, placebo-controlled evaluation of sublingual immunotherapy with standardized cat extract. J Allergy Clin Immunol. 1993;92(2):229-36. [pmid: 8349933].
Neri M, Spanevello A. Chronic bronchial asthma from challenge to treatment: Epidemiology and social impact. Thorax. 2000;55(Suppl 2):S57-S58. [pmid: 10992561].
Neutel J M, Smith D H G, Reilly P A. The efficacy and safety of telmisartan compared to enalapril in patients with severe hypertension. Int J Clin Pract. 1999;53(3):175-8. [pmid: 10665127].
Newill C A, Evans R III, Khoury M J. Preemployment screening for allergy to laboratory animals: Epidemiologic evaluation of its potential usefulness. J Occup Med. 1986;28(11):1158-64. [pmid: 3783284].
Newton D A. Sinusitis in children and adolescents. Prim Care Clin Off Pract. 1996;23(4):701-17.
Newton D A, Maberley D J, Wilson R. House dust mite hyposensitization. Br J Dis Chest. 1978;72(1):21-8. [pmid: 341952].
Ng T P, Tan W C. Epidemiology of chronic (perennial) rhinitis in Singapore: prevalence estimates, demographic variation and clinical allergic presentation. Ann Acad Med Singapore. 1994;23(1):83-8. [pmid: 8185279].
Nickel J C. Long-term implications of medical therapy on benign prostatic hyperplasia end points. Urology. 1998;51(4 Suppl A):50-7. [pmid: 9586597].
Nickelsen J A, Goldstein S, Mueller U, et al. Local intranasal immunotherapy for ragweed allergic rhinitis. II. Immunologic response. J Allergy Clin Immunol. 1981;68(1):41-5. [pmid: 6972401].
Nickelsen J A, Goldstein S, Mueller U, et al. Local intranasal immunotherapy for ragweed allergic rhinitis. I. Clinical response. J Allergy Clin Immunol. 1981;68(1):33-40. [pmid: 7240598].
Niehaus M D, Gwaltney M J Jr, Hendley J O, et al. Lactoferrin and eosinophilic cationic protein in nasal secretions of patients with experimental rhinovirus colds, natural colds, and presumed acute community-acquired bacterial sinusitis. J Clin Microbiol. 2000;38(8):3100-2. [pmcid: 87198]. [pmid: 10921988].
Nielsen L, Johnsen C R, Mosbech H, et al. Antihistamine premedication in specific cluster immunotherapy: a double-blind, placebo-controlled study. J Allergy Clin Immunol. 1996;97(6):1207-13. [pmid: 8648014].
Nielsen L P, Mygind N, Dahl R. Intranasal corticosteroids for allergic rhinitis: Superior relief. Drugs. 2001;61(11):1563-79. [pmid: 11577794].
Nieters A, Brems S, Becker N. Cross-sectional study on cytokine polymorphisms, cytokine production after T-cell stimulation and clinical parameters in a random sample of a German population. Hum Genet. 2001;108(3):241-8. [pmid: 11354638].
Nightingale C H. Treating allergic rhinitis with second-generation antihistamines. Pharmacotherapy. 1996;16(5 I):905-14. [pmid: 8888086].
Nikkels A F, Henry F, Pierard G E. Allergic reactions to decorative skin paintings. J Eur Acad Dermatol Venereol. 2001;15(2):140-2. [pmid: 11495521].
Nimmagadda SR, Evans R 3rd. Allergy: etiology and epidemiology. [Review]. Pediatr Rev 1999;20(4):111–5; quiz 116.
Nishioka G J, Barbero G J, Konig P, et al. Symptom outcome after functional endoscopic sinus surgery in patients with cystic fibrosis: a prospective study. Otolaryngol Head Neck Surg. 1995;113(4):440-5. [pmid: 7567018].
Nishioka K, Yasueda H, Saito H. Preventive effect of bedding encasement with microfine fibers on mite sensitization. J Allergy Clin Immunol. 1998;101(1 Pt 1):28-32. [pmid: 9449497].
Niven R M, Pickering C A C. Is atopy and smoking important in the workplace?. Occup Med. 1999;49(3):197-200.
Nolen T M. Sedative effects of antihistamines: safety, performance, learning, and quality of life. [Review]. Clin Ther. 1997;19(1):39-55. [pmid: 9083707].
Norback D, Bjornsson E, Janson C, et al. Asthmatic symptoms and volatile organic compounds, formaldehyde, and carbon dioxide in dwellings. Occup Environ Med. 1995;52(6):388-95. [pmid: 7627316].
Nordstrom K, Norback D, Akselsson R. Influence of indoor air quality and personal factors on the sick building syndrome (SBS) in Swedish geriatric hospitals. Occup Environ Med. 1995;52(3):170-6. [pmid: 7735389].
Norman P. Desloratadine Sepracor. Curr Opin Anti-Inflammatory Immunomodulatory Invest Drugs. 2000;2(2):117-26.
Norman P S. A review of immunotherapy. [Review]. Allergy. 1978;33(2):62-70. [pmid: 80138].
Norman P S. Allergic rhinitis: combined therapy improves control. Consultant. 1991;31(8):25-9.
Norman P S, Lichtenstein L M, Kagey-Sobotka A, et al. Controlled evaluation of allergoid in the immunotherapy of ragweed hay fever. J Allergy Clin Immunol. 1982;70(4):248-60. [pmid: 6181113].
Norris P G, Schofield O, Camp R D. A study of the role of house dust mite in atopic dermatitis. Br J Dermatol. 1988;118(3):435-40. [pmid: 3281704].
Numata T, Hanazawa T, Konno A, et al. Comparative role of peptide leukotrienes and histamine in the development of nasal mucosal swelling in nasal allergy. Ann Otol Rhinol Laryngol. 1999;108(5):467-73. [pmid: 10335708].
Nunes C, Ladeira S. Double-blind study of cetirizine and loratadine versus placebo in patients with allergic rhinitis. J Investig Allergol Clin Immunol. 2000;10(1):20-3.
Nutting C M, Page S R. Iatrogenic Cushing's syndrome due to nasal betamethasone: A problem not to be sniffed at! Postgrad Med J. 1995;71(834):231-2. [pmid: 7784285].
Nuutinen J, Holopainen E, Malmberg H, et al. Terfenadine with or without phenylpropanolamine in the treatment of seasonal allergic rhinitis. Clin Exp Allergy. 1989;19(6):603-8. [pmid: 2574626].
O'Hollaren M T. Update in allergy and immunology. JK Pract. 1999;6(4):333-7.
Ogino S, Irifune M, Harada T, et al. Nasal allergy in medical students. Rhinology. 1990;28(3):163-8. [pmid: 2251466].
Ogino S, Kawashima K, Nibu M, et al. Comparison of multiple-antigen simultaneous test and CAP systems for diagnosis of nasal allergy. ORL: J Oto-Rhino-Laryngol Related Spec. 1995;57(4):210-3.
Ohashi Y, Nakai Y, Ohno Y, et al. Natural course of serum-specific immunoglobulin E and immunoglobulin G4 for a span of eight years in untreated patients with perennial allergic rhinitis. Laryngoscope. 1997;107(3):382-5. [pmid: 9121318].
Ohashi Y, Nakai Y, Tanaka A, et al. Immunotherapy decreases seasonal rise in serum-soluble CD23 in seasonal allergic rhinitis. Laryngoscope. 1998;108(5):706-11. [pmid: 9591550].
Ohashi Y, Nakai Y, Tanaka A, et al. Serologic study of the working mechanisms of immunotherapy for children with perennial allergic rhinitis. Arch Otolaryngol Head Neck Surg. 1998;124(12):1337-46. [pmid: 9865756].
Ohashi Y, Tanaka A, Kakinoki Y, et al. Effect of immunotherapy on seasonal changes in serum-specific IgE and IgG4 in patients with pollen allergic rhinitis. Laryngoscope. 1997;107(9):1270-5. [pmid: 9292616].
Ohashi Y, Tanaka A, Nakai Y. Decrease of serum levels of soluble CD23 during immunotherapy in patients with perennial allergic rhinitis. Ann Otol Rhinol Laryngol. 1999;108(2 part 1):193-200. [pmid: 10030240].
Ohman J L Jr. Allergen immunotherapy: Review of efficacy and current practice. Med Clin North Am. 1992;76(4):977-91. [pmid: 1614242].
Oldham G, Platts-Mills T A, Chalmers D M, et al. A quantitative method for measuring in vitro synthesis of IgA and IgG by human rectal mucosa: studies on normal controls and patients with hypogammaglobulinaemia. Immunology. 1979;37(3):661-8. [pmid: 500122].
Oliveira C A A, Sole D, Naspitz C K, et al. Improvement of bronchial hyperresponsiveness in asthmatic children treated for concomitant sinusitis. Ann Allergy Asthma Immunol. 1997;79(1):70-4. [pmid: 9236504].
Olivieri M, Mohaddes Zadeh M R, Talamini G, et al. Local nasal immunotherapy and bronchial hyperreactivity in seasonal allergic rhinitis: an observational pilot study. J Investig Allergol Clin Immunol. 2000;10(5):300-4.
Olsen O T, Frolund L, Heinig J, et al. A double-blind, randomized study investigating the efficacy and specificity of immunotherapy with Artemisia vulgaris or Phleum pratense/betula verrucosa. Allergol Immunopathol (Madr). 1995;23(2):73-8. [pmid: 8526170].
Omenaas E, Bakke P, Eide G E, et al. Serum house-dust-mite antibodies and reduced FEV1 in adults of a Norwegian community. Am J Respir Crit Care Med. 1995;152(4 Pt 1):1158-63. [pmid: 7551364].
Omenaas E, Bakke P, Eide G E, et al. Serum house dust mite antibodies: predictor of increased bronchial responsiveness in adults of a community. Eur Respir J. 1996;9(5):919-25. [pmid: 8793452].
Ortolani C, Pastorello E A, Incorvaia C, et al. A double-blind, placebo-controlled study of immunotherapy with an alginate-conjugated extract of Parietaria judaica in patients with Parietaria hay fever. Allergy. 1994;49(1):13-21. [pmid: 8198235].
Orzano A J, Eaton L, Cody R P. The otitis media repeater - A 9-year family practice experience with children and adults. Dis Manage Clin Outcomes. 1998;1(6):218-23.
Osguthorpe JD. Turf battles diminish the credibility of all allergists. Ear Nose Throat J 1988;67(8):554, 556.
Osterballe O. Immunotherapy in hay fever with two major allergens 19, 25 and partially purified extract of timothy grass pollen. A controlled double blind study. In vivo variables, season I. Allergy. 1980;35(6):473-89. [pmid: 7008640].
Osterballe O. Nasal and skin sensitivity during immunotherapy with two major allergens 19, 25 and partially purified extract of timothy grass pollen. Allergy. 1982;37(3):169-77. [pmid: 6814282].
Osterballe O. Immunotherapy with grass pollen major allergens. Allergy. 1982;37(6):379-88. [pmid: 7137533].
Osterballe O. Side effects during immunotherapy with purified grass pollen extracts. Allergy. 1982;37(8):553-62. [pmid: 7181051].
Osterballe O, Egeskjold E M, Johansen A S, et al. Anti-IgG antibodies during immunotherapy with purified grass pollen extracts. Allergy. 1982;37(3):209-16. [pmid: 6182816].
Osterballe O, Lowenstein H, Norn S, et al. Immunotherapy with grass pollen major allergens. Immunological results from a prospective 3-year double blind study. Allergy. 1982;37(7):491-501. [pmid: 7181048].
Owen G O, Canter R J, Robinson A. Snoring, apnoea and ENT symptoms in the paediatric community. Clin Otolaryngol Allied Sci. 1996;21(2):130-4. [pmid: 8735397].
Owen S, Morganstern M, Hepworth J, et al. Control of house dust mite antigen in bedding. Lancet. 1990;335(8686):396-7. [pmid: 1968126].
Owerbach J, Winters B, Villella W. Pharmacist selection of allergy medication based on patient response to trial regimens. Am J Hosp Pharm. 1981;38(6):856-8. [pmid: 7246558].
Oxford Centre for Evidence-based Medicine. Levels of evidence. May 2001. Produced by Phillips B, Ball C, Sackett D, et al., since November 1998. Available at: http://163.1.96.10/docs/levels.html#levels. Accessed May 30, 2002.
Paddon D. Intranasal corticosteroids in allergic rhinitis. Paper did not include all data on adverse effects. BMJ. 1999;318(7194):1350. [pmid: 10323829].
Paggiaro P L, Dente F L, Morelli M C, et al. Postallergen inhaled budesonide reduces late asthmatic response and inhibits the associated increase of airway responsiveness to methacholine in asthmatics. Am J Respir Crit Care Med. 1994;149(6):1447-51. [pmid: 8004297].
Pajno G B, Morabito L, Barberio G, et al. Clinical and immunologic effects of long-term sublingual immunotherapy in asthmatic children sensitized to mites: a double-blind, placebo-controlled study. Allergy. 2000;55(9):842-9. [pmid: 11003448].
Palczynski C, Walusiak J, Hanke W, et al. Natural rubber-latex immediate hypersensitivity in surgeons. A cross-sectional study. Int Rev Allergol Clin Immunol. 2000;6(1):15-9.
Panda N K, Mann S B. Comparative efficacy and safety of terfenadine with pseudoephedrine and terfenadine alone in allergic rhinitis. Otolaryngol Head Neck Surg. 1998;118(2):253-5. [pmid: 9482562].
Pariente P D, LePen C, Los F, et al. Quality-of-life outcomes and the use of antihistamines in a French national population-based sample of patients with perennial rhinitis. Pharmacoeconomics. 1997;12(5):585-95. [pmid: 10174325].
Parikh A, Scadding G K. Seasonal allergic rhinitis. BMJ. 1997;314:1392-5. [pmid: 9161315].
Parker W A, Whisman B A, Apaliski S J, et al. The relationships between late cutaneous responses and specific antibody responses with outcome of immunotherapy for seasonal allergic rhinitis. J Allergy Clin Immunol. 1989;84(5 Pt 1):667-77. [pmid: 2809024].
Passalacqua G, Albano M, Fregonese L, et al. Randomised controlled trial of local allergoid immunotherapy on allergic inflammation in mite-induced rhinoconjunctivitis. Lancet. 1998;351(9103):629-32. [pmid: 9500318].
Passalacqua G, Albano M, Pronzato C, et al. Long-term follow-up of nasal immunotherapy to Parietaria: clinical and local immunological effects. Clin Exp Allergy. 1997;27(8):904-8. [pmid: 9291287].
Passalacqua G, Albano M, Ruffoni S, et al. Nasal immunotherapy to Parietaria: evidence of reduction of local allergic inflammation. Am J Respir Crit Care Med. 1995;152(2):461-6. [pmid: 7633693].
Passalacqua G, Canonica G W. Allergen-specific sublingual immunotherapy for respiratory allergy. Biodrugs. 2001;15(8):509-19. [pmid: 11543692].
Passalacqua G, Venturi S, Zoccali P, et al. Oral and sublingual immunotherapy: General aspects and critical considerations. Wien Med Wochenschr. 1999;149(1415):433-7. [pmid: 10584288].
Pastorello E A, Ortolani C, Incorvaia C, et al. A double-blind study of hyposensitization with an alginate-conjugated extract of Dermatophagoides pteronyssinus (Conjuvac) in patients with perennial rhinitis. II. Immunological aspects. Allergy. 1990;45(7):505-14. [pmid: 2252161].
Pastorello E A, Pravettoni V, Incorvaia C, et al. Clinical and immunological effects of immunotherapy with alum-absorbed grass allergoid in grass-pollen-induced hay fever. Allergy. 1992;47(4 Pt 1):281-90. [pmid: 1443446].
Patchett K, Lewis S, Crane J, et al. Cat allergen (Fel d 1) levels on school children's clothing and in primary school classrooms in Wellington, New Zealand. J Allergy Clin Immunol. 1997;100(6 Pt 1):755-9. [pmid: 9438482].
Patterson R. The role of immunotherapy in respiratory allergic diseases. J Allergy Clin Immunol. 1998;101(2 II):S403-S404. [pmid: 9500739].
Patterson R, Harris K E, Grammer L C, et al. Potential effect of the administration of substance P and allergen therapy on immunoglobulin E-mediated allergic reactions in human subjects. J Lab Clin Med. 1999;133(2):189-99. [pmid: 9989771].
Pauley T R, Magee M J, Cury J D. Pharmacist-managed, physician-directed asthma management program reduces emergency department visits. Ann Pharmacother. 1995;29(1):5-9. [pmid: 7711346].
Pawankar R. Anti-lgE treatment in allergic disease. Allergy Clin Immunol Int. 2001;13(1):4-10.
Payton K B, Hebert J, Clarke K D. Assessing and treating rhinitis. A pratical guide for Canadian physicians. Can Med Assoc J. 1994;151(4 Suppl):1-27. [pmid: 8055409].
Pearce N, Douwes J, Beasley R. Is allergen exposure the major primary cause of asthma? [Review]. Thorax. 2000;55(5):424-31. [pmid: 10770825].
Peat J K, Tovey E, Gray E J, et al. Asthma severity and morbidity in a population sample of Sydney schoolchildren: Part II--Importance of house dust mite allergens. Austral NZ J Med. 1994;24(3):270-6.
Peat J K, Tovey E, Mellis C M, et al. Importance of house dust mite and Alternaria allergens in childhood asthma: an epidemiological study in two climatic regions of Australia. Clin Exp Allergy. 1993;23(10):812-20. [pmid: 10780887].
Peat J K, Tovey E, Toelle B G, et al. House dust mite allergens. A major risk factor for childhood asthma in Australia. Am J Respir Crit Care Med. 1996;153(1):141-6. [pmid: 8542107].
Peckham C, Butler N. A national study of asthma in childhood. J Epidemiol Community Health. 1978;32(2):79-85. [pmid: 681590].
Pecoud A, Nicod L, Badan M, et al. Effects of one-year hyposensitization in allergic rhinitis. Comparison of two house dust mite extracts. Allergy. 1990;45(5):386-92. [pmid: 2378442].
Peden D B. The use of nasal lavage for objective measurement of irritant-induced nasal inflammation. Regul Toxicol Pharmacol. 1996;24(1 II):S76-S78. [pmid: 8921560].
Peden D B, Setzer R W, Devlin R B. Ozone exposure has both a priming effect on allergen-induced responses and an intrinsic inflammatory action in the nasal airways of perennially allergic asthmatics. Am J Respir Crit Care Med. 1995;151(5):1336-45. [pmid: 7735583].
Pedersen P A, Weeke E R. Allergic rhinitis in Danish general practice. Prevalence and consultation rates. Allergy. 1981;36(6):375-9. [pmid: 7316106].
Pedersen P A, Weeke E R. Asthma and allergic rhinitis in the same patients. Allergy. 1983;38(1):25-9. [pmid: 6837893].
Pedersen S. Introduction. J Allergy Clin Immunol. 2001;108(1 Suppl):S1. [pmid: 11449199].
Pedinoff A J. Approaches to the treatment of seasonal allergic rhinitis. South Med J. 1996;89(12):1130-9. [pmid: 8969344].
Pegelow K O, Belin L, Broman P, et al. Immunotherapy with alginate-conjugated and alum-precipitated grass pollen extracts in patients with allergic rhinoconjunctivitis. Allergy. 1984;39(4):275-90. [pmid: 6731753].
Peggs J F, Shimp L A, Opdycke R A C. Antihistamines: The old and the new. Am Fam Phys. 1995;52(2):593-600.
Pelikan Z, de Vries K. Effects of some drugs applied topically to the nasal mucosa before nasal provocation tests with allergen. Acta Allergol. 1974;29(5):337-53. [pmid: 4154695].
Pence H L, Mitchell D Q, Greely R L, et al. Immunotherapy for mountain cedar pollinosis. A double-blind controlled study. J Allergy Clin Immunol. 1976;58(1 Pt 1):39-50. [pmid: 780406].
Peng Z K, Naclerio R M, Norman P S, et al. Quantitative IgE- and IgG-subclass responses during and after long-term ragweed immunotherapy. J Allergy Clin Immunol. 1992;89(2):519-29. [pmid: 1740582].
Peroni D G, Piacentini G L, Martinati L C, et al. Double-blind trial of house-dust mite immunotherapy in asthmatic children resident at high altitude. Allergy. 1995;50(11):925-30. [pmid: 8748726].
Persi L, Demoly P, Harris A G, et al. Comparison between nasal provocation tests and skin tests in patients treated with loratadine and cetirizine. J Allergy Clin Immunol. 1999;103(4):591-4. [pmid: 10200006].
Persky V, Coover L, Hernandez E, et al. Chicago community-based asthma intervention trial: feasibility of delivering peer education in an inner-city population. Chest. 1999;116(4 Suppl 1):216S-23S. [pmid: 10532497].
Perzanowski M S, Ronmark E, Nold B, et al. Relevance of allergens from cats and dogs to asthma in the northernmost province of Sweden: schools as a major site of exposure. J Allergy Clin Immunol. 1999;103(6):1018-24. [pmid: 10359880].
Perzanowski M S, Sporik R, Squillace S P, et al. Association of sensitization to Alternaria allergens with asthma among school-age children. J Allergy Clin Immunol. 1998;101(5):626-32. [pmid: 9600499].
Pescollderungg L, Peroni D, Locatelli F, et al. Determination of serum eosinophil cationic protein, eosinophil count, and total IgE in children with different severities of atopic diseases. Pediatr Asthma Allergy Immunol. 2000;14(2):109-18.
Petersson G. Allergy practice and the otolaryngologist. Curr Opin Otolaryngol Head Neck Surg. 1995;3(3):218-23.
Philip G, Togias A. Allergic rhinitis: up-to-date strategies for management. J Respir Dis 1999;20(9):580–2, 585–8.
Philip G, Togias A G. Allergic rhinitis: today's approach to treatment. J Respir Dis. 1995;16(4):367-72.
Piacentini G L, Peroni D G, Sette L, et al. Inhibition of different dosages of oxatomide or placebo on skin prick test and nasal allergen provocation. J Allergy Clin Immunol. 1991;88(2):218-25. [pmid: 1679065].
Pichler C E, Helbling A, Pichler W J. Three years of specific immunotherapy with house-dust-mite extracts in patients with rhinitis and asthma: significant improvement of allergen-specific parameters and of nonspecific bronchial hyperreactivity. Allergy. 2001;56(4):301-6. [pmid: 11284796].
Pichler C E, Marquardsen A, Sparholt S, et al. Specific immunotherapy with Dermatophagoides pteronyssinus and D. farinae results in decreased bronchial hyperreactivity. Allergy. 1997;52(3):274-83. [pmid: 9140517].
Pickard B H. Nasal disease in relation to fitness of a pilot. Aviat Space Environ Med. 1984;55(5):429-30. [pmid: 6732702].
Pieckova E, Jesenska Z. Microscopic fungi in dwellings and their health implications in humans. Ann Agric Environ Med. 1999;6(1):1-11. [pmid: 10384209].
Pien L C. The role of allergy evaluation and immunotherapy in asthma. Clin Pulm Med. 1995;2(3):165-71.
Pigatto P D, Bigardi A S, Valsecchi R H, et al. Mite patch testing in atopic eczema: a search for correct concentration. Australasian J Dermatol. 1997;38(4):231-2.
Pirhonen I, Nevalainen A, Husman T, et al. Home dampness, moulds and their influence on respiratory infections and symptoms in adults in Finland. Eur Respir J. 1996;9(12):2618-22. [pmid: 8980978].
Pitten F A, Scholler M, Kruger U, et al. Filamentous fungi and yeasts on mattresses covered with different encasings. Eur J Dermatol. 2001;11(6):534-7. [pmid: 11701403].
Pizzi L T, Biskupiak J E. Patient compliance and its impact on treatment outcomes. Dis Manage Health Outcomes. 1999;6(5):269-78.
Platts-Mills T A. Allergens and asthma. [Review]. Allergy Proc. 1990;11(6):269-71. [pmid: 2292373].
Platts-Mills T A, Chapman M D. Dust mites: immunology, allergic disease, and environmental control. [erratum appears in J Allergy Clin Immunol 1988 Nov;82(5 Pt 1):841.]. [Review]. J Allergy Clin Immunol. 1987;80(6):755-75. [pmid: 3320157].
Platts-Mills T A, Chapman M D, Marsh D G. Human immunoglobulin E and immunoglobulin G antibody responses to the “minor” ragweed allergen Ra3: correlation with skin tests and comparison with other allergens. J Allergy Clin Immunol. 1981;67(2):129-34. [pmid: 7451780].
Platts-Mills T A, Chapman M D, Wheatly L M. Control of house dust mite in managing asthma. Conclusions of meta-analysis are wrong. BMJ. 1999;318(7187):870-1. [pmid: 10223798].
Platts-Mills T A, Fiocco G P, Hayden M L, et al. Serum IgE antibodies to Trichophyton in patients with urticaria, angioedema, asthma, and rhinitis: development of a radioallergosorbent test. J Allergy Clin Immunol. 1987;79(1):40-5. [pmid: 3805546].
Platts-Mills T A, Mueller G A, Wheatley L M. Future directions for allergen immunotherapy. [Review]. J Allergy Clin Immunol. 1998;102(3):335-43. [pmid: 9768570].
Platts-Mills T A, Rawle F, Chapman M D. Problems in allergen standardization. [Review]. Clin Rev Allergy. 1985;3(3):271-90. [pmid: 2410091].
Platts-Mills T A, Sporik R, Ingram J M, et al. Dog and cat allergens and asthma among school children in Los Alamos, New Mexico, USA: altitude 7,200 feet. Int Arch Allergy Immunol. 1995;107(13):301-3. [pmid: 7613154].
Platts-Mills T A, Sporik R B, Chapman M D, et al. The role of domestic allergens. [Review]. Ciba Found Symp. 1997;206:173-89. [pmid: 9257012].
Platts-Mills T A, Sullivan T J, Kaliner M A. Allergy versus asthma as the focus of the subspecialty. J Allergy Clin Immunol. 1996;97(3):865-8. [pmid: 8613647].
Platts-Mills T A, Vaughan J W, Carter M C, et al. The role of intervention in established allergy: avoidance of indoor allergens in the treatment of chronic allergic disease. J Allergy Clin Immunol. 2000;106(5):787-804. [pmid: 11080699].
Platts-Mills T A, Woodfolk J A, Chapman M D, et al. Changing concepts of allergic disease: the attempt to keep up with real changes in lifestyles. [Review]. J Allergy Clin Immunol. 1996;98(6 Pt 3):S297-306. [pmid: 8977541].
Plavec D, Somogyi-Zalud E, Godnic-Cvar J. Nonspecific nasal responsiveness in workers occupationally exposed to respiratory irritants. Am J Ind Med. 1993;24(5):525-32. [pmid: 8266929].
Plosker G L, Faulds D. Troglitazone: A review of its use in the management of type 2 diabetes mellitus. Drugs. 1999;57(3):409-38. [pmid: 10193691].
Pollart S, Chapman M D, Platts-Mills T A. House dust mite and dust control. [Review]. Clin Rev Allergy. 1988;6(1):23-33. [pmid: 3289711].
Pollart S M, Chapman M D, Fiocco G P, et al. Epidemiology of acute asthma: IgE antibodies to common inhalant allergens as a risk factor for emergency room visits. J Allergy Clin Immunol. 1989;83(5):875-82. [pmid: 2715548].
Pollart S M, Chapman M D, Platts-Mills T A. House dust sensitivity and environmental control. [Review]. Prim Care. 1987;14(3):591-603. [pmid: 3313464].
Pollart S M, Mullins D E, Vailes L D, et al. Identification, quantitation, and purification of cockroach allergens using monoclonal antibodies. J Allergy Clin Immunol. 1991;87(2):511-21. [pmid: 1993811].
Pollart S M, Reid M J, Fling J A, et al. Epidemiology of emergency room asthma in northern California: association with IgE antibody to ryegrass pollen. J Allergy Clin Immunol. 1988;82(2):224-30. [pmid: 3261307].
Pollart S M, Smith T F, Morris E C, et al. Environmental exposure to cockroach allergens: analysis with monoclonal antibody-based enzyme immunoassays. J Allergy Clin Immunol. 1991;87(2):505-10. [pmid: 1993810].
Ponsonby A L, Glasgow N, Gatenby P, et al. The relationship between low level nitrogen dioxide exposure and child lung function after cold air challenge. Clin Exp Allergy. 2001;31(8):1205-12. [pmid: 11529889].
Por C P, Evans M F. Effective treatment for ragweed allergy: Nasal puffers or antihistamines?. Can Fam Phys. 1998;44:1625-6.
Pordy R C. Cilazapril plus hydrochlorothiazide: Improved efficacy without reduced safety in mild to moderate hypertension: A double-blind placebo-controlled multicenter study of factorial design. Cardiology. 1994;85(5):311-22. [pmid: 7850821].
Porst H, Rosen R, Padma-Nathan H, et al. The efficacy and tolerability of vardenafil, a new, oral, selective phosphodiesterase type 5 inhibitor, in patients with erectile dysfunction: The first at-home clinical trial. Int J Impotence Res. 2001;13(4):192-9.
Portnoy J M. Immunotherapy for inhalant allergies: Guidelines for why, when, and how to use this treatment. Postgrad Med. 2001;109(5):89-106. [pmid: 11381673].
Posey W C, Nelson H S. Controlled trials with four per cent cromolyn spray in seasonal allergic rhinitis. Clin Allergy. 1977;7(5):485-96. [pmid: 412612].
Pradalier A, Basset D, Claudel A, et al. Sublingual-swallow immunotherapy (SLIT) with a standardized five-grass-pollen extract (drops and sublingual tablets) versus placebo in seasonal rhinitis. Allergy. 1999;54(8):819-28. [pmid: 10485385].
Prasanna A, Murthy P S N. Vasomotor rhinitis and sphenopalatine ganglion block. J Pain Symptom Management. 1997;13(6):332-8.
Pratt C M, Mason J, Russell T, et al. Cardiovascular safety of fexofenadine HCl. Am J Cardiol. 1999;83(10):1451-4. [pmid: 10335761].
Prescott L M. Highlights of the 96th Annual Meeting of the American Society of Clinical Pharmacology and Therapeutics. P T. 1995;20(7):492-4.
Prevost M, Turenne Y, Moote D W, et al. Comparative study of SCH 434 and CTM-D in the treatment of seasonal allergic rhinitis. Clin Ther. 1994;16(1):50-6. [pmid: 7911402].
Puchner T C Jr, Fink J N. Occupational rhinitis. Immunol Allergy Clin North Am. 2000;20(2):303-22.
Pullerits T, Praks L, Ristioja V, et al. Comparison of a nasal glucocorticoid, antileukotriene, and a combination of antileukotriene and antihistamine in the treatment of seasonal allergic rhinitis. J Allergy Clin Immunol. 2002;109(6):949-55. [pmid: 12063523].
Pullerits T, Praks L, Sjostrand M, et al. An intranasal glucocorticoid inhibits the increase of specific IgE initiated during birch pollen season. J Allergy Clin Immunol. 1997;100(5):601-5. [pmid: 9389288].
Pullerits T, Praks L, Skoogh B E, et al. Randomized placebo-controlled study comparing a leukotriene receptor antagonist and a nasal glucocorticoid in seasonal allergic rhinitis. Am J Respir Crit Care Med. 1999;159(6):1814-8. [pmid: 10351924].
Purello-D'Ambrosio F, Gangemi S, Isola S, et al. Sublingual immunotherapy: a double-blind, placebo-controlled trial with Parietaria judaica extract standardized in mass units in patients with rhinoconjunctivitis, asthma, or both. Allergy. 1999;54(9):968-73. [pmid: 10505460].
Purello-D'Ambrosio F, Gangemi S, Merendino R A, et al. Comparative study between fluticasone propionate and cetirizine in the treatment of allergic rhinitis. Allergol Immunopathol. 1998;26(6):277-82.
Purello-D'Ambrosio F, Isola S, Ricciardi L, et al. A controlled study on the effectiveness of loratadine in combination with flunisolide in the treatment of nonallergic rhinitis with eosinophilia (NARES). Clin Exp Allergy. 1999;29(8):1143-7. [pmid: 10457120].
Purello-D'Ambrosio F, Ricciardi L, Isola S, et al. Rush sublingual immunotherapy in Parietaria allergic patients. [erratum appears in Allergol Immunopathol (Madr) 1996 Nov-Dec;24(6):262]. Allergol Immunopathol (Madr). 1996;24(4):146-51. [pmid: 8939269].
Purello D F, Tigano F, Gallesio M T, et al. Astemizole-D compared with triprolidine-D (Actifed(R)) for acute treatment of perennial allergic rhinitis. J Pharm Med. 1994;4(1):15-22.
Purohit A, Duvernelle C, Melac M, et al. Twenty-four hours of activity of cetirizine and fexofenadine in the skin. Ann Allergy Asthma Immunol. 2001;86(4):387-92. [pmid: 11345280].
Quirce S, Gomez M, Bombin C, et al. Glutaraldehyde-induced asthma. Allergy Eur J Allergy Clin Immunol. 1999;54(10):1121-2.
Rachelefsky G S. National guidelines needed to manage rhinitis and prevent complications. Ann Allergy Asthma Immunol. 1999;82(3):296-305. [pmid: 10094222].
Radcliffe M J, Lampe F C, Brostoff J. Allergen-specific low-dose immunotherapy in perennial allergic rhinitis: a double-blind placebo-controlled crossover study. J Investig Allergol Clin Immunol. 1996;6(4):242-7.
Radenne F, Lamblin C, Vandezande L M, et al. Quality of life in nasal polyposis. J Allergy Clin Immunol. 1999;104(1):79-84. [pmid: 10400843].
Radon K, Schottky A, Garz S, et al. Distribution of dust-mite allergens (Lep d 2, Der p 1, Der f 1, Der 2) in pig-farming environments and sensitization of the respective farmers. Allergy Eur J Allergy Clin Immunol. 2000;55(3):219-25.
Ragusa F V, Passalacqua G, Gambardella R, et al. Nonfatal systemic reactions to subcutaneous immunotherapy: a 10-year experience. J Investig Allergol Clin Immunol. 1997;7(3):151-4.
Rajakulasingam K, Polosa R, Lau L C, et al. The influence of terfenadine and ipratropium bromide alone and in combination on bradykinin-induced nasal symptoms and plasma protein leakage. Clin Exp Allergy. 1992;22(7):717-23. [pmid: 1387041].
Rak S, Hakanson L, Venge P. Immunotherapy abrogates the generation of eosinophil and neutrophil chemotactic activity during pollen season. J Allergy Clin Immunol. 1990;86(5):706-13. [pmid: 2229837].
Rak S, Heinrich C, Jacobsen L, et al. A double-blinded, comparative study of the effects of short preseason specific immunotherapy and topical steroids in patients with allergic rhinoconjunctivitis and asthma. J Allergy Clin Immunol. 2001;108(6):921-8. [pmid: 11742269].
Rakes G P, Arruda E, Ingram J M, et al. Rhinovirus and respiratory syncytial virus in wheezing children requiring emergency care. IgE and eosinophil analyses. Am J Respir Crit Care Med. 1999;159(3):785-90. [pmid: 10051251].
Ratner P H, Findlay S R, Hampel F Jr, et al. A double-blind, controlled trial to assess the safety and efficacy of azelastine nasal spray in seasonal allergic rhinitis. J Allergy Clin Immunol. 1994;94(5):818-25. [pmid: 7963150].
Ratner P H, van Bavel J H, Martin B G, et al. A comparison of the efficacy of fluticasone propionate aqueous nasal spray and loratadine, alone and in combination, for the treatment of seasonal allergic rhinitis. J Fam Pract. 1998;47(2):118-25. [pmid: 9722799].
Raulf-Heimsoth M, Wirtz C, Papenfuss F, et al. Nasal lavage mediator profile and cellular composition of nasal brushing material during latex challenge tests. Clin Exp Allergy. 2000;30(1):110-21. [pmid: 10606938].
Rawle F C, Mitchell E B, Platts-Mills T A. T cell responses to the major allergen from the house dust mite Dermatophagoides pteronyssinus, Antigen P1: comparison of patients with asthma, atopic dermatitis, and perennial rhinitis. J Immunol. 1984;133(1):195-201. [pmid: 6609976].
Ray N F, Baraniuk J N, Thamer M, et al. Direct expenditures for the treatment of allergic rhinoconjunctivitis in 1996, including the contributions of related airway illnesses. J Allergy Clin Immunol. 1999;103(3 Pt 1):401-7. [pmid: 10069872].
Ray N F, Baraniuk J N, Thamer M, et al. Healthcare expenditures for sinusitis in 1996: contributions of asthma, rhinitis, and other airway disorders. J Allergy Clin Immunol. 1999;103(3 Pt 1):408-14. [pmid: 10069873].
Rebmann H, Weber A K, Focke I, et al. Does benzyl benzoate prevent colonization of new mattresses by mites? A prospective study. Allergy. 1996;51(12):876-82. [pmid: 9020414].
Reed C E. Measurement of airborne antigens. J Allergy Clin Immunol. 1982;70(1):38-40. [pmid: 7086001].
Reed C E. Introduction: New insights into allergic rhinitis: Quality of life, associated airway diseases, and antihistamine potency. J Allergy Clin Immunol. 1997;99(2):S740-S741.
Reichenberg K, Broberg A G. Quality of life in childhood asthma: Use of the paediatric asthma quality of life questionnaire in a swedish sample of children 7 to 9 years old. Acta Paediatr. 2000;89(8):989-95. [pmid: 10976845].
Reichmuth D. Allergic rhinitis. Drugs Today. 2001;37(5):283-309. [pmid: 12768218].
Reid M J. Complicating features of asthma. Pediatr Clin North Am. 1992;39(6):1327-42. [pmid: 1437322].
Reid M J, Moss R B, Hsu Y P, et al. Seasonal asthma in northern California: allergic causes and efficacy of immunotherapy. J Allergy Clin Immunol. 1986;78(4 Pt 1):590-600. [pmid: 3771951].
Reilly D, Taylor M A, Beattie N G, et al. Is evidence for homoeopathy reproducible?. Lancet. 1994;344(8937):1601-6. [pmid: 7983994].
Reilly M C, Tanner A, Meltzer E O. Work, classroom and activity impairment instruments: validation studies in allergic rhinitis. Clin Drug Invest. 1996;11:278-88.
Reilly M C, Zbrozek A S, Dukes E M. The validity and reproducibility of a work productivity and activity impairment instrument. Pharmacoeconomics. 1993;4(5):353-65. [pmid: 10146874].
Reinstein J A. Self-medication: Editorial. Int Pharm. J. 1999;13(1):2-3.
Reisacher W R, Finn D G, Stern J, et al. Manifestations of AIDS in the head and neck. South Med J. 1999;92(7):684-97. [pmid: 10414477].
Reiser J, Ingram D, Mitchell E B, et al. House dust mite allergen levels and an anti-mite mattress spray (natamycin) in the treatment of childhood asthma. Clin Exp Allergy. 1990;20(5):561-7. [pmid: 2253088].
Reisman RE. Allergic rhinitis: update on your therapeutic choices. Consultant 1996;36(9):1899–901, 1905–6.
Reisman R E, Mauriello P M, Davis G B, et al. A double-blind study of the effectiveness of a high-efficiency particulate air (HEPA) filter in the treatment of patients with perennial allergic rhinitis and asthma. J Allergy Clin Immunol. 1990;85(6):1050-7. [pmid: 2191991].
Retailliau H F, Storch G A, Curtis A C, et al. The epidemiology of influenza B in a rural setting in 1977. Am J Epidemiol. 1979;109(6):639-49. [pmid: 110144].
Retzow A, Althaus M, DeMey C, et al. Study on the interaction of the dopamine agonist alpha-dihydroergocryptine with the pharmacokinetics of digoxin. Arzneim. -Forsch Drug Res. 2000;50(7):591-6.
Revicki D A, Leidy N K, Brennan-Diemer F, et al. Development and preliminary validation of the multiattribute Rhinitis Symptom Utility Index. Qual Life Res. 1998;7(8):693-702. [pmid: 10097618].
Rheinstein P H. Significant FDA approvals in 1994. Am Fam Phys. 1995;51(4):888-90.
Ricard N, Kind P, Christian S, et al. Link between patient preferences and treatment outcomes in seasonal allergic rhinitis: an empiric investigation. Clin Ther. 1999;21(1):268-77. [pmid: 10090440].
Ricard N, Sauriol L, Christian S. The effect of seasonal allergic rhinitis in children on caregivers' lives: A pilot study. Pediatr Asthma Allergy Immunol. 2000;14(2):119-24.
Ricci G, Patrizi A, Specchia F, et al. Effect of house dust mite avoidance measures in children with atopic dermatitis. Br J Dermatol. 2000;143(2):379-84. [pmid: 10951149].
Rice D H. Endoscopic sinus surgery. Otolaryngol Head Neck Surg. 1994;111(1):100-10. [pmid: 8028915].
Richards S, Thornhill D, Roberts H, et al. How many people think they have hay fever, and what they do about it. Br J Gen Pract. 1992;42(360):284-6. [pmid: 1419261].
Risby E, Donnigan D, Nemeroff C B. Formulary considerations for treating psychiatric disorders: Schizophrenia. Formulary. 1997;32(2):142-55.
Rischitelli D G. A workers' compensation primer. Ann Allergy Asthma Immunol. 1999;83(6 II):614-7. [pmid: 10619331].
Rizzo M C, Arruda L K, Chapman M D, et al. IgG and IgE antibody responses to dust mite allergens among children with asthma in Brazil. Ann Allergy. 1993;71(2):152-8. [pmid: 8346869].
Roberts J. Examination and health history findings among children and youths, 6–17 years, United States. Vital Health Stat 1973;Ser.11(129):71 p.
Robertson A S, Burge P S, Hedge A, et al. Comparison of health problems related to work and environmental measurements in two office buildings with different ventilation systems. Br Med J Clin Res Ed. 1985;291(6492):373-6.
Robertson A S, Sherwood B P. Building sickness. Practitioner. 1985;229(1404):531-4. [pmid: 4022919].
Robinson D S. Allergen immunotherapy: Does it work and, if so, how and for how long?. Thorax. 2000;55(Suppl 1):S11-S14. [pmid: 10943632].
Rodriguez A, Trujillo M J, Herrero T, et al. Allergy to calcitonin. Allergy Eur J Allergy Clin Immunol. 2001;56(8):801.
Ronborg S M, Mosbech H, Johnsen C R, et al. Exposure chamber for allergen challenge. The development and validation of a new concept. Allergy. 1996;51(2):82-8. [pmid: 8738512].
Ronborg S M, Mosbech H, Poulsen L K. Exposure chamber for allergen challenge. A placebo-controlled, double-blind trial in house-dust-mite asthma. Allergy. 1997;52(8):821-8. [pmid: 9284981].
Ronborg S M, Poulsen L K, Skov P S, et al. Effect of two different types of vacuum cleaners on airborne Fel d 1 levels. Ann Allergy Asthma Immunol. 1999;82(3):307-10. [pmid: 10094223].
Rooklin AR, Gawchik SM. Allergic rhinitis -- it's that time again! Contemp Pediatr 1994;11(4):19–20, 23–6, 28 passim.
Root T S, Quan D J. Histamineinf 2-receptor antagonists do not prevent allergic reactions. J Pharm Technol. 1994;10(2):58-60.
Roquet A, Raud J, Hallden G, et al. Effects of loratadine on anti-IgE-induced inflammation, histamine release, and leukocyte recruitment in skin of atopics. Allergy. 1995;50(5):414-20. [pmid: 7573830].
Rose C. Bioaerosols. West J Med. 1994;160(6):566. [pmid: 8053183].
Rose G, Arlian L, Bernstein D, et al. Evaluation of household dust mite exposure and levels of specific IgE and IgG antibodies in asthmatic patients enrolled in a trial of immunotherapy. J Allergy Clin Immunol. 1996;97(5):1071-8. [pmid: 8626984].
Rosenfeld R M. Pilot study of outcomes in pediatric rhinosinusitis. Arch Otolaryngol Head Neck Surg. 1995;121(7):729-36. [pmid: 7598848].
Ross A M, Corden J M, Fleming D M. The role of oak pollen in hay fever consultations in general practice and the factors influencing patients' decisions to consult. Br J Gen Pract. 1996;46(409):451-5. [pmid: 8949322].
Ross A M, Fleming D M. Incidence of allergic rhinitis in general practice, 1981-92. BMJ. 1994;308(6933):897-900. [pmid: 8173372].
Ross R N. The costs of allergic rhinitis. Am J Manag Care. 1996;2:285-90.
Ross R N, Nelson H S, Finegold I. Effectiveness of specific immunotherapy in the treatment of allergic rhinitis: an analysis of randomized, prospective, single- or double-blind, placebo-controlled studies. Clin Ther. 2000;22(3):342-50. [pmid: 10963288].
Rossetti L, Barbieri P, Velati P, et al. The efficacy of the combination of I-moprolol and dipivefrin in reducing the intraocular pressure in primary open-angle glaucoma or in ocular hypertension. Graefe's Arch Clin Exp Ophthalmol. 1994;232(11):670-4. [pmid: 7843592].
Rossoff L J, Stempel D A. Cost-effective treatment of rhinitis: a managed care perspective. Am J Manag Care. 1997;3(Suppl 1):S1-28.
Rowley J A, Safwan B M. Obstructive sleep apnea: The latest treatment strategies. J Respir Dis. 2000;21(9):577-80.
Rowntree S, Cogswell J J, Platts-Mills T A, et al. Development of IgE and IgG antibodies to food and inhalant allergens in children at risk of allergic disease. Arch Dis Child. 1985;60(8):727-35. [pmid: 4037856].
Rowntree S, Mitchell E B, Platts-Mills T A. Assessment of skin reactivity and specific antibody to egg and milk proteins in patients with atopic dermatitis: comparison with responses to the house dust mite antigen. Int Arch Allergy Appl Immunol. 1986;79(2):132-9. [pmid: 3943914].
Rowntree S, Platts-Mills T A, Cogswell J J, et al. A subclass IgG4-specific antigen-binding radioimmunoassay (RIA): comparison between IgG and IgG4 antibodies to food and inhaled antigens in adult atopic dermatitis after desensitization treatment and during development of antibody responses in children. J Allergy Clin Immunol. 1987;80(4):622-30. [pmid: 3668126].
Royal College of Physicians, Royal College of Pathologists. Good allergy practice--standards of care for providers and purchasers of allergy services within the National Health Service. Clin Exp Allergy. 1995;25(7):586-95. [pmid: 8521176].
Rutishauser M, Pitzke P, Grevers G, et al. Use of a polyvalent bacterial lysate in patients with recurrent respiratory tract infections: Results of a prospective, placebo-controlled, randomized, double-blind study. Adv Ther. 1998;15(6):330-41. [pmid: 10351117].
Ryan D, Cross S. Rhinitis and allergy. Asthma Gen Pract. 2000;9(2 Suppl):S24-S26.
Sabbah A, Hassoun S, Le Sellin J, et al. A double-blind, placebo-controlled trial by the sublingual route of immunotherapy with a standardized grass pollen extract. Allergy. 1994;49(5):309-13. [pmid: 8092425].
Salmun L M, Gates D, Scharf M, et al. Loratadine versus cetirizine: assessment of somnolence and motivation during the workday. Clin Ther. 2000;22(5):573-82. [pmid: 10868555].
Santilli J, Nathan R, Glassheim J, et al. Patients receiving immunotherapy report it is effective as assessed by the rhinitis outcomes questionnaire (ROQ) in a private practice setting. Ann Allergy Asthma Immunol. 2001;86(2):219-21. [pmid: 11258693].
Santilli J, Nathan R, Glassheim J, et al. Validation of the rhinitis outcomes questionnaire (ROQ). Ann Allergy Asthma Immunol. 2001;86(2):222-5. [pmid: 11258694].
Santoni P, Perdona B, Read BH. Seasonal allergic rhinitis. Practitioner 1984;228(1391):460, 462.
Santos R, Cifaldi M, Gregory C, et al. Economic outcomes of a targeted intervention program: the costs of treating allergic rhinitis patients. Am J Manag Care. 1999;5(4 Suppl):S225-34. [pmid: 10387543].
Sapci T, Karavus A, Onmus H, et al. Impression cytology (IC) in clinical practice. Marmara Med J. 2000;13(2):75-81.
Saraclar Y, Sekerel B E, Kalayci O, et al. The effect of house dust mite specific immunotherapy on cysteinyl leukotriene production by blood leukocytes in subjects with perennial allergic rhinitis and asthma. J Investig Allergol Clin Immunol. 1998;8(2):98-104.
Scadding G. Diagnosis and management of rhinitis. CPD Bull Immunol Allergy. 2000;1(2):42-6.
Scadding G K. Could treating asthma help rhinitis? [Review]. Clin Exp Allergy. 1997;27(12):1387-93. [pmid: 9433933].
Scadding G K. Treating asthma: Don't forget the nose. Can J Allergy Clin Immunol. 1999;4(5):238-43.
Scadding G K, Richards D H, Price M J. Patient and physician perspectives on the impact and management of perennial and seasonal allergic rhinitis. Clin Otolaryngol Allied Sci. 2000;25(6):551-7. [pmid: 11122298].
Scalabrin D M, Bavbek S, Perzanowski M S, et al. Use of specific IgE in assessing the relevance of fungal and dust mite allergens to atopic dermatitis: a comparison with asthmatic and nonasthmatic control subjects. J Allergy Clin Immunol. 1999;104(6):1273-9. [pmid: 10589012].
Schädlich P K, Brecht J G. Economic evaluation of specific immunotherapy versus symptomatic treatment of allergic rhinitis in Germany. Pharmacoeconomics. 2000;17:37-52. [pmid: 10747764].
Schafheutle E I, Cantrill J A, Nicolson M, et al. Insights into the choice between self-medication and a doctor's prescription: A study of hay fever sufferers. Int J Pharm Pract. 1996;4(3):156-61.
Schapowal A. Petasites Study Group. Randomized controlled trial of butterbur and cetirizine for treating seasonal allergic rhinitis. BMJ. 2002;324:1-4. [pmid: 11777781].
Scherger J E. The spectrum of upper respiratory infections in family practice. Semin Fam Med. 1982;3(4):168-73.
Schmidt A, Adam S A, Kolloch R, et al. Antihypertensive effects of valsartan/hydrochlorothiazide combination in essential hypertension. Blood Press. 2001;10(4):230-7. [pmid: 11800062].
Schmidt B M W, Kusma M, Feuring M, et al. The phosphodiesterase 4 inhibitor roflumilast is effective in the treatment of allergic rhinitis. J Allergy Clin Immunol. 2001;108(4):530-6. [pmid: 11590377].
Schmidt J, Zalewski P, Olszewski J, et al. Histopathological verification of clinical indications to partial inferior turbinectomy. Rhinology. 2001;39(3):147-50. [pmid: 11721505].
Schneider L C, Lester M R. Atopic disease, rhinitis and conjunctivitis, and upper respiratory infections. [Review]. Curr Opin Pediatr. 1998;10(5):539-47. [pmid: 9818255].
Schnitzer T, Morton C, Coker S. Topical capsaicin therapy for osteoarthritis pain: Achieving a maintenance regimen. Semin Arthritis Rheum. 1994;23(Suppl 3):34-40.
Schofield M, Fleming S. Go with the flow - A review of the respiratory therapeutic area. Emerg Drugs. 2000;5(2):123-33.
Schwab I R. Nonsteroidal eye drops for ocular allergy. West J Med. 1994;161(6):594-5. [pmid: 7856163].
Schwartz R, Freij B J, Ziai M, et al. Antimicrobial prescribing for acute purulent rhinitis in children: A survey of pediatricians and family practitioners. Pediatr Infect Dis J. 1997;16(2):185-90. [pmid: 9041598].
Sears M R, Jones D T, Silva P A, et al. Asthma in seven year old children: a report from the Dunedin Multidisciplinary Child Development Study. N Z Med J. 1982;95(713):533-6. [pmid: 6957768].
Segura T, Casale T B. Allergic rhinitis: Basic pathophysiology and therapeutic strategies. Can J Allergy Clin Immunol. 1999;4(7):318-30.
Self T, Chafin C C. Drug therapy of allergic rhinitis. Am J Manag Care. 1999;5(9):1191-200.
Seltzer J M. Building-related illnesses. J Allergy Clin Immunol. 1994;94(2 II Suppl):351-62. [pmid: 8077589].
Senior B A, Glaze C, Benninger M S. Use of the Rhinosinusitis Disability Index (RSDI) in rhinologic disease. Am J Rhinol. 2001;15(1):15-20. [pmid: 11258649].
Sensi L G, Seri A, Siracusa A, et al. Allergic rhinitis in children: effects of flunisolide and disodium cromoglycate on nasal eosinophil cationic protein. Clin Exp Allergy. 1997;27(3):270-6. [pmid: 9088653].
Seppey M, Hausler R, Bruchez M, et al. Facial thermograpy - An assessment of cetirizine effects upon nasal provocation in rhinitis. Allergy Clin Immunol Int. 2000;12(5):232-9.
Serra H A, Alves O, Rizzo L F, et al. Loratadine-pseudoephedrine in children with allergic rhinitis, a controlled double-blind trial. Br J Clin Pharmacol. 1998;45(2):147-50. [pmid: 9491827].
Sette L, Comis A, Marcucci F, et al. Benzyl-benzoate foam: effects on mite allergens in mattress, serum and nasal secretory IgE to Dermatophagoides pteronyssinus, and bronchial hyperreactivity in children with allergic asthma. Pediatr Pulmonol. 1994;18(4):218-27. [pmid: 7838620].
Settipane G A. Allergic rhinitis--update. Otolaryngol Head Neck Surg. 1986;94(4):470-5. [pmid: 3086809].
Settipane R A. Complications of allergic rhinitis. [Review]. Allergy Asthma Proc. 1999;20(4):209-13. [pmid: 10476318].
Settipane R J, Hagy G W, Settipane G A. Long-term risk factors for developing asthma and allergic rhinitis: a 23-year follow-up study of college students. [Review]. Allergy Proc. 1994;15(1):21-5. [pmid: 8005452].
Shahar E, Lorber M. Prevalence of self-reported allergic conditions in an adult population in Israel. Isr Med Assoc J. 2001;3(3):190-3. [pmid: 11303377].
Shaikh W A. Ephedrine-saline nasal wash in allergic rhinitis. J Allergy Clin Immunol. 1995;96(5 Pt 1):597-600. [pmid: 7499675].
Shapiro G G, Wighton T G, Chinn T, et al. House dust mite avoidance for children with asthma in homes of low-income families. J Allergy Clin Immunol. 1999;103(6):1069-74. [pmid: 10359888].
Sharkey P, Portnoy J. Rush immunotherapy: experience with a one-day schedule. Ann Allergy Asthma Immunol. 1996;76(2):175-80. [pmid: 8595538].
Sheikh A, Hurwitz B. House dust mite avoidance measures for perennial allergic rhinitis (Cochrane Review). In: The Cochrane Library, Issue 1, 2002. Oxford: Update Software.
Shibasaki M, Noguchi E, Takeda K, et al. Distribution of IgE and IgG antibody levels against house dust mites in schoolchildren, and their relation with asthma. J Asthma. 1997;34(3):235-42. [pmid: 9168851].
Shirtcliffe P M, Easthope S E, Cheng S, et al. The effect of delipidated deglycolipidated (DDMV) and heat-killed Mycobacterium vaccae in asthma. Am J Respir Crit Care Med. 2001;163(6):1410-4. [pmid: 11371410].
Shusterman D, Murphy M A, Balmes J. The influence of sex, allergic rhinitis, and test system on nasal sensitivity to airborne irritants: a pilot study. Environ Health Perspectives. 2001;109(1):15-9.
Sibbald B, Kerry S, Strachan D P, et al. Patient characteristics associated with the labelling of asthma. Fam Pract. 1994;11(2):127-32. [pmid: 7958574].
Sibbald B, Rink E. Labelling of rhinitis and hayfever by doctors. Thorax. 1991;46(5):378-81. [pmid: 2068696].
Sienra-Monge J J, Gazca-Aguilar A, Del Rio-Navarro B. Double-blind comparison of cetirizine and loratadine in children ages 2 to 6 years with perennial allergic rhinitis. Am J Ther. 1999;6(3):149-55. [pmid: 10423657].
Sih T. News from the Interamerican Association of Pediatric Otorhinolaryngology II IAPO's Congress, Sao Paulo, Brazil, September 1997 presidential address: On pollution. Int J Pediatr Otorhinolaryngol. 1998;44(2):193-4. [pmid: 9725539].
Silva A L, Silva A B, Stankiewicz J A. Nasal obstruction in pregnancy. Prim Care Update Ob Gyns. 1995;2(1):37-44.
Silverman M, Turner-Warwick M. Exercise induced asthma: response to disodium cromoglycate in skin-test positive and skin-test negative subjects. Clin Allergy. 1972;2(2):137-42. [pmid: 4632180].
Silverman S L. Calcitonin. Am J Med Sci. 1997;313(1):13-6. [pmid: 9001161].
Silvers W S. The skier's nose: a model of cold-induced rhinorrhea. Ann Allergy. 1991;67(1):32-6. [pmid: 1859038].
Sim T C, Reece L M, Hilsmeier K A, et al. Secretion of chemokines and other cytokines in allergen-induced nasal responses: Inhibition by topical steroid treatment. Am J Respir Crit Care Med. 1995;152(3):927-33. [pmid: 7545059].
Simola M, Boss I, Holopainen E, et al. Astemizole in combination with pseudoephedrine in the treatment of seasonal allergic rhinitis. Rhinology. 1996;34(1):21-3. [pmid: 8739863].
Simons F E. Learning impairment and allergic rhinitis. [Review]. Allergy Asthma Proc. 1996;17(4):185-9. [pmid: 8871736].
Simons F E. The eternal triangle: benefit, risk, and cost of therapeutic agents. [Review]. Ann Allergy Asthma Immunol. 1996;77(5):337-40. [pmid: 8933770].
Simons F E, Imada M, Li Y, et al. Fel d 1 peptides: effect on skin tests and cytokine synthesis in cat-allergic human subjects. Int Immunol. 1996;8(12):1937-45. [pmid: 8982778].
Simons F E R. The eternal triangle: Benefit, risk, and cost of therapeutic agents. Ann Allergy Asthma Immunol. 1996;77(5):337-40. [pmid: 8933770].
Simpson K, Jarvis B. Fexofenadine: review of its use in the management of seasonal allergic rhinitis and chronic idiopathic urticaria. Drugs. 2000;59:301-21. [pmid: 10730552].
Simpson R J. Budesonide and terfenadine, separately and in combination, in the treatment of hay fever. Ann Allergy. 1994;73(6):497-502. [pmid: 7998664].
Sin A, Kose S, Terzioglu E, et al. Prevalence of atopy in young healthy population, in Izmir, Turkey. Allergol Immunopathol. 1997;25(2):80-4.
Singh S. Preparing your practice for the influenza season. Patient Care 2001;35(17):18–21, 25–6, 28 passim.
Sjostedt L, Willers S, Orbaek P, et al. A seven-year follow-up study of lung function and methacholine responsiveness in sensitized and non-sensitized workers handling laboratory animals. J Occup Environ Med. 1998;40(2):118-24. [pmid: 9503287].
Skoner D P. Control of allergic rhinitis with antihistamines may prevent the onset or recurrence of otitis media. Pediatr Asthma Allergy Immunol. 1997;11(4):193-205.
Skoner D P. Allergic rhinitis: definition, epidemiology, pathophysiology, detection, and diagnosis. [Review]. J Allergy Clin Immunol. 2001;108(1 Suppl):S2-8. [pmid: 11449200].
Skoner D P, Doyle W J, Boehm S, et al. Effect of terfenadine on nasal, eustachian tube, and pulmonary function after provocative intranasal histamine challenge. Ann Allergy. 1991;67(6):619-24. [pmid: 1750727].
Skoner D P, Hodgson M J, Doyle W J. Laser-printer rhinitis. New Engl J Med. 1990;322(18):1323. [pmid: 2325732].
Slavin R G. Occupational and allergic rhinitis: impact on worker productivity and safety. [Review]. Allergy Asthma Proc. 1998;19(5):277-84. [pmid: 9801741].
Slavin R G. Occupational rhinitis. Ann Allergy Asthma Immunol. 1999;83(6 part 2):597-601. [pmid: 10619328].
Slawson D C, Squillace S P, Franko J P. Throat culture to rule out GABHS. J Fam Pract. 1994;39(5):428. [pmid: 7964537].
Slunt J B, Taketomi E A, Platts-Mills T A. Human T-cell responses to Trichophyton tonsurans: inhibition using the serum free medium Aim V. Clin Exp Allergy. 1997;27(10):1184-92. [pmid: 9383259].
Sly R M. New guidelines for diagnosis and management of asthma. Ann Allergy Asthma Immunol. 1997;78(5):427-37. [pmid: 9164355].
Sly RM. Changing prevalence of allergic rhinitis and asthma. Ann Allergy Asthma Immunol 1999;82(3):233–48; quiz 248–52.
Smith A M, Yamaguchi H, Platts-Mills T A, et al. Prevalence of IgG anti-Der p 2 antibodies in children from high and low antigen exposure groups: relationship of IgG and subclass antibody responses to exposure and allergic symptoms. Clin Immunol Immunopathol. 1998;86(1):102-9. [pmid: 9434802].
Smith A P. Hyposensitization with Dermatophagoides pteronyssinus antigen: trial in asthma induced by house dust. BMJ. 1971;4(781):204-6. [pmid: 4940158].
Smith D. Self-reported glutaraldehyde symptoms: Are they an accurate predictor of workplace risk?. J Occup Health Saf Aust New Zealand. 2001;17(3):287-93.
Smith J M, Clegg R T, Cook N, et al. Intranasal beclomethasone diproprionate in allergic rhinitis. Br Med J. 1975;2(5965):255. [pmid: 1131575].
Smith J M, Pizarro Y A. Hyposensitization with extracts of Dermatophagoides pteronyssinus and house dust. Clin Allergy. 1972;2(3):281-3. [pmid: 4643787].
Smith L. Special considerations for the child with airway disease. [Review]. J Allergy Clin Immunol. 1998;101(2 Pt 2):S370-2. [pmid: 9500731].
Smith LJ. Diagnosis and treatment of allergic rhinitis [corrected][published erratum appears in Nurse Pract 1996 Jan-Feb;21(1):9]. Nurse Pract 1995;20(10):58, 60, 62 passim.
Smith M A. Norah Schuster student presentations. J R Soc Med. 1993;86(11):674-5.
Smolensky M. Knowledge and attitudes of American physicians and public about medical chronobiology and chronotherapeutics. Findings of two 1996 gallup surveys. Chronobiol Int. 1998;15(4):377-94. [pmid: 9706414].
Smolensky M H, Reinberg A, Labrecque G. Twenty-four hour pattern in symptom intensity of viral and allergic rhinitis: Treatment implications. J Allergy Clin Immunol. 1995;95(5 II):1084-96. [pmid: 7751526].
Snyman J R, Sommers D K, Van Wyk M, et al. The influence of betahistine on the dynamics of the cutaneous hypersensitivity reaction in patients with grass pollen allergy. Immunopharmacology. 1995;30(1):71-8. [pmid: 7591715].
Sonenthal K R, Grammer L C. Pulmonary reactions to chemicals in the workplace. Can J Allergy Clin Immunol. 2000;5(5):196-202.
Soto-Quiros M, Gutierrez I, Calvo N, et al. Allergen sensitization of asthmatic and nonasthmatic schoolchildren in Costa Rica. Allergy. 1998;53(12):1141-7. [pmid: 9930589].
Spaeth J, Klimek L, Mosges R. Sedation in allergic rhinitis is caused by the condition and not by antihistamine treatment. Allergy Eur J Allergy Clin Immunol. 1996;51(12):893-906.
Spafford C S, Grosser G S, Donatelle J R, et al. Contrast sensitivity differences between proficient and disabled readers using colored lenses. J Learn Disabil. 1995;28(4):240-52. [pmid: 7738436].
Spector S L. Overview of comorbid associations of allergic rhinitis. [Review]. J Allergy Clin Immunol. 1997;99(2):S773-80. [pmid: 9042070].
Spector S L, Bernstein I L, Li J T, et al. Parameters for the diagnosis and management of sinusitis. J Allergy Clin Immunol. 1998;102(6 Pt 2):S107-44. [pmid: 9847450].
Spector S L, Nicodemus C F, Corren J, et al. Comparison of the bronchodilatory effects of cetirizine, albuterol, and both together versus placebo in patients with mild-to-moderate asthma. J Allergy Clin Immunol. 1995;96(2):174-81. [pmid: 7636054].
Spencer C, Neales K. Minerva. BMJ. 2000;320(7234):590.
Spiewak R, Gora A, Horoch A, et al. Atopy, allergic diseases and work-related symptoms among students of agricultural schools: First results of the Lublin study. Ann Agric Environ Med. 2001;8(2):261-7. [pmid: 11748886].
Sporik R, Hill D J, Thompson P J, et al. The Melbourne House Dust Mite Study: long-term efficacy of house dust mite reduction strategies. J Allergy Clin Immunol. 1998;101(4 Pt 1):451-6. [pmid: 9564796].
Sporik R, Holgate S T, Platts-Mills T A, et al. Exposure to house-dust mite allergen (Der p I) and the development of asthma in childhood. A prospective study. N Engl J Med. 1990;323(8):502-7. [pmid: 2377175].
Sporik R, Ingram J M, Price W, et al. Association of asthma with serum IgE and skin test reactivity to allergens among children living at high altitude. Tickling the dragon's breath. Am J Respir Crit Care Med. 1995;151(5):1388-92. [pmid: 7735590].
Sporik R, Platts-Mills TA. Allergen exposure and the development of asthma. [Review]. Thorax 2001;56(Suppl 2):ii58–63.
Sporik R, Platts-Mills T A, Cogswell J J. Exposure to house dust mite allergen of children admitted to hospital with asthma. Clin Exp Allergy. 1993;23(9):740-6. [pmid: 10779304].
Sporik R, Squillace S P, Ingram J M, et al. Mite, cat, and cockroach exposure, allergen sensitisation, and asthma in children: a case-control study of three schools. Thorax. 1999;54(8):675-80. [pmid: 10413718].
Sporik R B, Arruda L K, Woodfolk J, et al. Environmental exposure to Aspergillus fumigatus allergen (Asp f I). Clin Exp Allergy. 1993;23(4):326-31. [pmid: 8319130].
Squillace S, Berggreen P, Jaffe P, et al. A normal initial colonoscopy after age 50 does not predict a polyp-free status for life. Am J Gastroenterol. 1994;89(8):1156-9. [pmid: 8053427].
Squillace S P. Environmental control. Otolaryngol Head Neck Surg. 1992;107(6 Pt 2):831-4. [pmid: 1470464].
Squillace S P. Immunotherapy in adult asthma. J Fam Pract. 1996;42(5):455. [pmid: 8642357].
Squillace S P. Indoor allergen avoidance: what really works?. J Respir Dis. 1999;20(1):13-6.
Squillace S P, Slawson D C. Guidelines for managing ankle injuries: the Ottawa ankle rules. J Fam Pract. 1994;39(6):593-4. [pmid: 7798866].
Squillace S P, Sporik R B, Rakes G, et al. Sensitization to dust mites as a dominant risk factor for asthma among adolescents living in central Virginia. Multiple regression analysis of a population-based study. Am J Respir Crit Care Med. 1997;156(6):1760-4. [pmid: 9412552].
Stahl E, van Rompay W, Wang E C, et al. Cost-effectiveness analysis of budesonide aqueous nasal spray and fluticasone propionate nasal spray in the treatment of perennial allergic rhinitis. Ann Allergy Asthma Immunol. 2000;84(4):397-402. [pmid: 10795647].
Starr M S, Weinstock M. Studies in pollen allergy. 3. The relationship between blocking antibody levels and symptomatic relief following hyposensitisation with allpyral in hay fever subjects. Int Arch Allergy Appl Immunol. 1970;38(5):514-21. [pmid: 4191851].
Stelmach I, Jerzynska J, Brzozowska A, et al. Double-blind, randomized, placebo-controlled trial of effect of nedocromil sodium on clinical and inflammatory parameters of asthma in children allergic to dust mite. Allergy. 2001;56(6):518-24. [pmid: 11421896].
Stempel D A. Intranasal corticosteroids for first-line treatment of allergic rhinitis: What's the evidence?. Formulary. 2001;36(4):276-93.
Stempel DA, Brunton S, Clanton M, et al. Issues in diagnosis and therapy. Am J Manag Care 1997;3(Suppl):S29–42, S47–8.
Stempel DA, Richardson M, Mackowiak J, et al. The health and economic impact of rhinitis. Am J Manag Care 1997;3(Suppl):S8–18, S47–8.
Stempel D A, Thomas M. Treatment of allergic rhinitis: an evidence-based evaluation of nasal corticosteroids versus nonsedating antihistamines. Am J Manag Care. 1998;4(1):89-96. [pmid: 10179909].
Stenberg B, Eriksson N, Hoog J, et al. The sick building syndrome (SBS) in office workers. A case-referent study of personal, psychosocial and building-related risk indicators. Int J Epidemiol. 1994;23(6):1190-7. [pmid: 7721522].
Stenberg B, Eriksson N, Mild K H, et al. Facial skin symptoms in visual display terminal (VDT) workers. A case-referent study of personal, psychosocial, building- and VDT-related risk indicators. Int J Epidemiol. 1995;24(4):796-803. [pmid: 8550278].
Sterk P J, Buist S A, Woolcock A J, et al. The message from the World Asthma Meeting. The Working Groups of the World Asthma Meeting, held in Barcelona, Spain, December 9–13, 1998. [Review]. Eur Respir J. 1999;14(6):1435-53. [pmid: 10624779].
Sterk P J, Leff A R, Pauwels R, et al. Panel discussion. Eur Respir Rev. 1999;9(65):21-2.
Stevens D A, Schwartz H J, Lee J Y, et al. A randomized trial of itraconazole in allergic bronchopulmonary aspergillosis. N Engl J Med. 2000;342(11):756-62. [pmid: 10717010].
Stevens L M, Lynm C, Glass R M. Seasonal allergic rhinitis. J Am Med Assoc. 2001;286(23):3038.
Stevenson L A, Gergen P J, Hoover D R, et al. Sociodemographic correlates of indoor allergan sensitivity among United States children. J Allergy Clin Immunol. 2001;108(5):747-53. [pmid: 11692099].
Stimpel M, Koch B, Weber M A. Comparison between moexipril and atenolol in obese postmenopausal women with hypertension. Maturitas. 1998;30(1):69-77. [pmid: 9819786].
Stone M, Ellis H. Dissecting room problem: Prevalence of latex allergy among medical students. Clin Anat. 1998;11(3):191-3. [pmid: 9579592].
Storms W, Meltzer E O, Nathan R A, et al. Allergic rhinitis: the patient's perspective. J Allergy Clin Immunol. 1997;99:S825-8.
Storms W, Meltzer E O, Nathan R A, et al. The economic impact of allergic rhinitis. J Allergy Clin Immunol. 1997;99:S820-4.
Storms W W. Risk-benefit assessment of fluticasone propionate in the treatment of asthma and allergic rhinitis. J Asthma. 1998;35(4):313-36. [pmid: 9669826].
Strachan D, Sibbald B, Weiland S, et al. Worldwide variations in prevalence of symptoms of allergic rhinoconjunctivitis in children: the International Study of Asthma and Allergies in Childhood (ISAAC). Ped Allergy Immunol. 1997;8(4):161-76.
Strachan D P. House dust mite allergen avoidance in asthma. Benefits unproved but not yet excluded. BMJ. 1998;317(7166):1096-7. [pmid: 9784440].
Strangert K. Respiratory illness in preschool children with different forms of day care. Pediatrics. 1976;57(2):191-6. [pmid: 1250654].
Stroup D F, Berlin J A, Morton S C, et al. Meta-analysis of observational studies in epidemiology: a proposal for reporting. Meta-analysis Of Observational Studies in Epidemiology (MOOSE) group. [Review]. JAMA. 2000;283(15):2008-12. [pmid: 10789670].
Stubner U P, Toth J, Marks B, et al. Efficacy and safety of an oral formulation of cetirizine and prolonged-release pseudoephedrine versus xylometazoline nasal spray in nasal congestion. Arzneimittelforschung. 2001;51(11):904-10. [pmid: 11765592].
Subiza J L, Subiza J, Barjau M C, et al. Inhibition of the seasonal IgE increase to Dactylis glomerata by daily sodium chloride nasal-sinus irrigation during the grass pollen season. J Allergy Clin Immunol. 1999;104(3 I):711-2. [pmid: 10482855].
Sullivan S D, Weiss K B. Health economics of asthma and rhinitis. II. Assessing the value of interventions. J Allergy Clin Immunol. 2001;107(2):203-10. [pmid: 11174182].
Sussman G L. Canadian Journal of Allergy and Clinical Immunology: Editorial. Can J Allergy Clin Immunol. 2000;5(3):96.
Sussman G L, Mason J, Compton D, et al. The efficacy and safety of fexofenadine HCl and pseudoephedrine, alone and in combination, in seasonal allergic rhinitis. J Allergy Clin Immunol. 1999;104(1):100-6. [pmid: 10400846].
Sussman G L, Moote D M, Danoff D, et al. Guidelines for the use of allergen immunotherapy. Can Med Assoc J. 1995;152(9):1413-9. [pmid: 7728690].
Sutherland M, Czarny D, Douglass J. Allergy in the airway. Aust Fam Physician. 1998;27(8):681-5. [pmid: 9735485].
Suzuki M, Kawauchi H, Mogi G. Clinical efficacy of an antiallergic drug on otitis media with effusion in association with allergic rhinitis. Auris Nasus Larynx. 1999;26(2):123-9. [pmid: 10214889].
Svensson C, Klementsson H, Andersson M, et al. Glucocorticoid-induced attenuation of mucosal exudation of fibrinogen and bradykinins in seasonal allergic rhinitis. Allergy Eur J Allergy Clin Immunol. 1994;49(3):177-83.
Swims M P. Potential terfenadine-fluoxetine interaction (2). Ann Pharmacother. 1993;27(11):1404-5. [pmid: 8286821].
Symington I S, O'Neill D, Kerr J W. Comparision of a glutaraldehyde-modified pollen--tyrosine adsorbate with an alum-precipitated pollen vaccine in the treatment of hay fever. Clin Allergy. 1977;7(2):189-94. [pmid: 872364].
Szekely G, Gorgenyi F. Postmarketing surveillance-one of the key issues in drug development. Ther Hung. 1992;40(4):147-53. [pmid: 1345020].
Tabar A I, Muro M D, Garcia B E, et al. Dermatophagoides pteronyssinus cluster immunotherapy. A controlled trial of safety and clinical efficacy. J Investig Allergol Clin Immunol. 1999;9(3):155-64.
Taccariello M, Parikh A, Darby Y, et al. Nasal douching as a valuable adjunct in the management of chronic rhinosinusitis. Rhinology. 1999;37(1):29-32. [pmid: 10229979].
Taivainen A I, Tukiainen H O, Terho E O, et al. Powered dust respirator helmets in the prevention of occupational asthma among farmers. Scand J Work Environ Health. 1998;24(6):503-7. [pmid: 9988093].
Tan B B, Weald D, Strickland I, et al. Double-blind controlled trial of effect of housedust-mite allergen avoidance on atopic dermatitis. Lancet. 1996;347(8993):15-8. [pmid: 8531541].
Tanner L A, Reilly M, Meltzer E O, et al. Effect of fexofenadine HCl on quality of life and work, classroom, and daily activity impairment in patients with seasonal allergic rhinitis. Am J Manag Care. 1999;5(4 Suppl):S235-47.
Tarchalska-Krynska B, Zawisza E. Effects of fusafungine on the cytologic picture of nose mucosal membranes in patients with acute upper respiratory tract infections: Multicenter study. Med Sci Monit. 1998;4(6):1036-9.
Tari M G, Mancino M, Ghezzi E, et al. Immunotherapy with an alum-adsorbed Parietaria-pollen allergoid: a 2-year, double-blind, placebo-controlled study. Allergy. 1997;52(1):65-74. [pmid: 9062631].
Tari M G, Mancino M, Madonna F, et al. Immunologic evaluation of 24 month course of sublingual immunotherapy. Allergol Immunopathol (Madr). 1994;22(5):209-16. [pmid: 7840022].
Tari M G, Mancino M, Monti G. Efficacy of sublingual immunotherapy in patients with rhinitis and asthma due to house dust mite. A double-blind study. Allergol Immunopathol (Madr). 1990;18(5):277-84. [pmid: 2097894].
Tari M G, Mancino M, Monti G. Immunotherapy by inhalation of allergen in powder in house dust allergic asthma--a double-blind study. J Investig Allergol Clin Immunol. 1992;2(2):59-67.
Tarlo S M, Cockcroft D W, Dolovich J, et al. Beclomethasone dipropionate aerosol in perennial rhinitis. J Allergy Clin Immunol. 1977;59(3):232-6. [pmid: 838992].
Tarlo S M, Sussman G L, Holness D L. Latex sensitivity in dental students and staff: A cross-sectional study. J Allergy Clin Immunol. 1997;99(3):396-401. [pmid: 9058696].
Taudorf E, Laursen L C, Djurup R, et al. Oral administration of grass pollen to hay fever patients. An efficacy study in oral hyposensitization. Allergy. 1985;40(5):321-35. [pmid: 3898904].
Taudorf E, Laursen L C, Lanner A, et al. Oral immunotherapy in birch pollen hay fever. J Allergy Clin Immunol. 1987;80(2):153-61. [pmid: 3301985].
Taudorf E, Weeke B. Orally administered grass pollen. Allergy. 1983;38(8):561-4. [pmid: 6362471].
Tay Y K, Khoo B P, Goh C L. The epidemiology of atopic dermatitis at a tertiary referral skin center in Singapore. Asian Pac J Allergy Immunol. 1999;17(3):137-41. [pmid: 10697251].
Taylor B, Broom B C. Atopy in medical students. Ann Allergy. 1981;47(3):197-9. [pmid: 7270992].
Taylor B, Sanders S S, Norman A P. A double blind controlled trial of house mite fortified house dust vaccine in childhood asthma. Clin Allergy. 1974;4(1):35-40. [pmid: 4596249].
Taylor G, Shivalkar P R. Local nasal desensitization in allergic rhinitis. Clin Allergy. 1972;2(2):125-36. [pmid: 4632179].
Taylor J, Suveges L. Got a minute? Timing the selection process during the puchase of cough, cold and allergic rhinitis products. Can Pharm J 1991;124(11):507–11, 526.
Taylor M A, Reilly D, Llewellyn-Jones R H, et al. Randomised controlled trial of homoeopathy versus placebo in perennial allergic rhinitis with overview of four trial series. BMJ. 2000;321(7259):471-6. [pmcid: 27460]. [pmid: 10948025].
Tee R D, Gordon D J, Lacey J, et al. Occupational allergy to the common house fly (Musca domestica): Use of immunologic response to identify atmospheric allergen. J Allergy Clin Immunol. 1985;76(6):826-31. [pmid: 4067132].
TePas E C, Umetsu D T. Immunotherapy of asthma and allergic diseases. Curr Opin Pediatr. 2000;12(6):574-8. [pmid: 11106278].
Terpstra S. Expectations of a citizen of the European Community concerning Brussels and the pollenosis of his grand children, children and himself: to 1993 and beyond. (Some considerations from a socio-economic point of view). Arb Paul Ehrlich Inst Bundesamt Sera Impfstoffe Frankf A M 1992;(85):25–38; discussion 38–40.
Testa B, Mesolella C, Mosti M R, et al. Changes in serum interferon-gamma, interleukin-4, and interleukin-12 cytokine levels in anti-histamine type 2-treated allergic rhinitis patients. Laryngoscope. 2001;111(2):236-9. [pmid: 11210867].
Testa B, Mesolella M, Testa D, et al. Glutathione in the upper respiratory tract. Ann Otol Rhinol Laryngol. 1995;104(2):117-9. [pmid: 7857012].
The SAS Institute. The SAS System for Windows [computer program]. Release 8.02. Cary, NC: The SAS Institute, Inc.; 2001.
Thiam D G, Tim C F, Hoon L S, et al. An evaluation of mattress encasings and high efficiency particulate filters on asthma control in the tropics. Asian Pac J Allergy Immunol. 1999;17(3):169-74. [pmid: 10697255].
Thomas D H V, Noyce P R. The interface between self medication and the NHS. BMJ. 1996;312(7032):688-91. [pmid: 8597739].
Thompson A K, Juniper E, Meltzer E O. Quality of life in patients with allergic rhinitis. [Review]. Ann Allergy Asthma Immunol. 2000;85(5):338-48. [pmid: 11101172].
Thornton Z. Are you on allergy alert? Chemist Druggist 1999;251(Mar Suppl):10, 12.
Tikkanen S, Kokkonen J, Juntti H, et al. Status of children with cow's milk allergy in infancy by 10 years of age. Acta Paediatr. 2000;89(10):1174-80. [pmid: 11083371].
Tinkelman D G, Bleecker E R, Ramsdell J, et al. Proventil HFA and ventolin have similar safety profiles during regular use. Chest. 1998;113(2):290-6. [pmid: 9498941].
Tobin M J. Asthma, airway biology, and allergic rhinitis in AJRCCM 2000. Am J Respir Crit Care Med. 2001;164(9):1559-80. [pmid: 11719293].
Tom C M, Kane M P. Management of toenail onychomycosis. Am J Health-Syst Pharm. 1999;56(9):865-71. [pmid: 10344609].
Tommel A B, Andre C, Frew A J, et al. Recent clinical and scientific evidences supporting sublingual immunotherapy. Allerg Immunol. 2001;33(5):199-201.
Trevino R J. Comparison of results of immunotherapy based on skin end-point titration, prick testing, and scratch testing. [erratum appears in Otolaryngol Head Neck Surg 1995 Mar;112(3):506]. Otolaryngol Head Neck Surg. 1994;111(5):550-2. [pmid: 7970790].
Trigg C J, Bennett J B, Tooley M, et al. A general practice based survey of bronchial hyperresponsiveness and its relation to symptoms, sex, age, atopy, and smoking. Thorax. 1990;45(11):866-72. [pmid: 2256016].
Triglia J M, Nicollas R. Nasal and sinus polyposis in children. Laryngoscope. 1997;107(7):963-6. [pmid: 9217140].
Tripathi A, Patterson R. Impact of allergic rhinitis treatment on quality of life. [Review]. Pharmacoeconomics. 2001;19(9):891-9. [pmid: 11700776].
Troise C, Bignardi D, Modena P, et al. Preventive symptomatic immunotherapy versus placebo in seasonal rhinitis due to grasses in children and to Parietaria in adult patients. Allerg Immunol (Paris). 2000;32(6):246-9. [pmcid: 267442]. [pmid: 10971859].
Troise C, Voltolini S, Canessa A, et al. Sublingual immunotherapy in Parietaria pollen-induced rhinitis: a double-blind study. J Investig Allergol Clin Immunol. 1995;5(1):25-30.
Trotter J P. The treatment of seasonal allergic rhinitis: cost implications of pharmacotherapy for managed care. Manag Care Interface. 2000;13(1):60-2. [pmid: 10747693].
Trotto N E. Asthma, rhinitis, sinusitis, urticaria. Patient Care. 1999;33(1):115-39.
Tsai L C, Tang R B, Hung M W, et al. Changes in the levels of house dust mite specific IgG4 during immunotherapy in asthmatic children. Clin Exp Allergy. 1991;21(3):367-72. [pmid: 1863900].
Tunnicliffe W S, Burge P S, Ayres J G. Effect of domestic concentrations of nitrogen dioxide on airway responses to inhaled allergen in asthmatic patients. Lancet. 1994;344(89398940):1733-6. [pmid: 7997002].
Tunnicliffe W S, Fletcher T J, Hammond K, et al. Sensitivity and exposure to indoor allergens in adults with differing asthma severity. Eur Respir J. 1999;13(3):654-9. [pmid: 10232442].
Tupker R A, de Monchy J G, Coenraads P J. House-dust mite hypersensitivity, eczema, and other nonpulmonary manifestations of allergy. [Review]. Allergy. 1998;53(48 Suppl):92-6. [pmid: 10096817].
Turkeltaub P C, Gergen P J. Prevalence of upper and lower respiratory conditions in the US population by social and environmental factors: data from the second National Health and Nutrition Examination Survey, 1976 to 1980 (NHANES II). Ann Allergy. 1991;67(2 Pt 1):147-54. [pmid: 1867453].
Turkeltaub P C, Norman P S, Crepea S. Treatment of ragweed hay fever with an intranasal spray containing fluinsolide, a new synthetic corticosteroid. J Allergy Clin Immunol. 1976;58(5):597-606. [pmid: 789436].
Turkeltaub P C, Norman P S, Johnson J D, et al. Treatment of seasonal and perennial rhinitis with intranasal flunisolide. Allergy. 1982;37(5):303-11. [pmid: 6812449].
Turner K J, Stewart G A, Woolcock A J, et al. Relationship between mite densities and the prevalence of asthma: comparative studies in two populations in the Eastern Highlands of Papua New Guinea. Clin Allergy. 1988;18(4):331-40. [pmid: 3416416].
Turner M W, Yalcin I, Soothill J F, et al. In vitro investigations in asthmatic children undergoing hyposensitization with tyrosine-adsorbed Dermatophagoides pteronyssinus antigen. Clin Allergy. 1984;14(3):221-31. [pmid: 6375891].
Turner P, Dear J, Scadding G, et al. Role of kinins in seasonal allergic rhinitis: icatibant, a bradykinin B2 receptor antagonist, abolishes the hyperresponsiveness and nasal eosinophilia induced by antigen. J Allergy Clin Immunol. 2001;107(1):105-13. [pmid: 11149999].
Ubel P A, Goold S. Recognizing bedside rationing: Clear cases and tough calls. Ann Intern Med. 1997;126(1):74-80. [pmid: 8992926].
Ulrik C S. Factors associated with increased bronchial responsiveness in adolescents and young adults: the importance of adjustment for prechallenge FEV1. J Allergy Clin Immunol. 1996;97(3):761-7. [pmid: 8613632].
Vailes L D, Perzanowski M S, Wheatley L M, et al. IgE and IgG antibody responses to recombinant Alt a 1 as a marker of sensitization to Alternaria in asthma and atopic dermatitis. Clin Exp Allergy. 2001;31(12):1891-5. [pmid: 11737041].
Valovirta E. Capacity of specific immunotherapy in prevention of allergic asthma in children: The preventive allergy treatment study (PAT). J Investig Allergol Clin Immunol. 1997;7(5):369-70.
Valovirta E. PAT--the Preventive Allergy Treatment Study design and preliminary results. Wien Med Wochenschr. 1999;149(1415):442-3. [pmid: 10584290].
van Agthoven M, Fokkens W J, van de Merwe J P, et al. Quality of life of patients with refractory chronic rhinosinusitis: effects of filgrastim treatment. Am J Rhinol. 2001;15(4):231-7. [pmid: 11554654].
Van Berge Henegouwen M T H, Van Driel H F, Kasteleijn-Nolst Trenite D G A. A patient diary as a tool to improve medicine compliance. Pharm World Sci. 1999;21(1):21-4. [pmid: 10214664].
Van Bever H P, Stevens W J. Effect of hyposensitization upon the immediate and late asthmatic reaction and upon histamine reactivity in patients allergic to house dust mite (Dermatophagoides pteronyssinus). Eur Respir J. 1992;5(3):318-22. [pmid: 1572445].
van Cauwenberge P. Management of rhinitis--the specialist's opinion. Clin Exp Allergy. 1998;28(Suppl 6):29-33. [pmid: 9988432].
Van Cauwenberge P. Intranasal steroids: Friends or foes? Brussels, Belgium July 4, 1999: Summary. Allergy Eur J Allergy Clin Immunol Suppl. 2000;55(62):24.
Van Cauwenberge P, Berdeaux G, Morineau A, et al. Use of diagnostic clusters to assess the economic consequences of rhinopharyngitis in children in Italy and France during the winter. Rhinitis Survey Group. Clin Ther. 1999;21(2):404-21. [pmid: 10211541].
Van Cauwenberge P, Juniper E F. Comparison of the efficacy, safety and quality of life provided by fexofenadine hydrochloride 120 mg, loratadine 10 mg and placebo administered once daily for the treatment of seasonal allergic rhinitis. Clin Exp Allergy. 2000;30(6):891-9. [pmid: 10848909].
van Cauwenberge P B. Epidemiology of common cold. Rhinology. 1985;23(4):273-82. [pmid: 4081523].
Van de Maele B. New strategy in the control of house dust mite allergy. Pharmatherapeutica. 1983;3(7):441-4. [pmid: 6608108].
van der Heide S, Kauffman H F, Dubois A E, et al. Allergen reduction measures in houses of allergic asthmatic patients: effects of air-cleaners and allergen-impermeable mattress covers. Eur Respir J. 1997;10(6):1217-23. [pmid: 9192919].
van der Heide S, Kauffman H F, Dubois A E, et al. Allergen-avoidance measures in homes of house-dust-mite-allergic asthmatic patients: effects of acaricides and mattress encasings. Allergy. 1997;52(9):921-7. [pmid: 9298177].
Van Der Veen M J, Jansen H M, Aalberse R C, et al. Der p 1 and Der p 2 induce less severe late asthmatic responses than native Dermatophagoides pteronyssinus extract after a similar early asthmatic response. Clin Exp Allergy. 2001;31(5):705-14. [pmid: 11422129].
Van Deusen M A, Angelini B L, Cordoro K M, et al. Efficacy and safety of oral immunotherapy with short ragweed extract. Ann Allergy Asthma Immunol. 1997;78(6):573-80. [pmid: 9207721].
Van Metre T E, Adkinson N F, Amodio F J, et al. A comparison of immunotherapy schedules for injection treatment of ragweed pollen hay fever. J Allergy Clin Immunol. 1982;69(2):181-93. [pmid: 7056949].
Van Metre T E, Adkinson N F Jr, Amodio F J, et al. A comparative study of the effectiveness of the Rinkel method and the current standard method of immunotherapy for ragweed pollen hay fever. J Allergy Clin Immunol. 1980;66(6):500-13. [pmid: 6159384].
Van Niekerk C H, De Wet J I. Efficacy of grass-maize pollen oral immunotherapy in patients with seasonal hay-fever: a double-blind study. Clin Allergy. 1987;17(6):507-13. [pmid: 3436031].
Van Wijk G R, Terreehorst I T, Mulder P G, et al. Intranasal capsaicin is lacking therapeutic effect in perennial allergic rhinitis to house dust mite. A placebo-controlled study. Clin Exp Allergy. 2000;30(12):1792-8. [pmid: 11122219].
Van Wijk R G. Perennial allergic rhinitis and nasal hyperreactivity. Am J Rhinol. 1998;12(1):33-5. [pmid: 9513657].
Vanhanen M, Tuomi T, Tiikkainen U, et al. Risk of enzyme allergy in the detergent industry. Occup Environ Med. 2000;57(2):121-5. [pmid: 10711280].
Varghese B T, Murthy P S N, Rajan R. Clinico-pathological correlation between allergic rhinitis and bronchial asthma. J Laryngol Otol. 2000;114(5):354-8. [pmid: 10912264].
Varney V A, Gaga M, Frew A J, et al. Usefulness of immunotherapy in patients with severe summer hay fever uncontrolled by antiallergic drugs. BMJ. 1991;302(6771):265-9. [pmid: 1998791].
Varney V A, Jacobson M R, Sudderick R M, et al. Immunohistology of the nasal mucosa following allergen-induced rhinitis. Identification of activated T lymphocytes, eosinophils, and neutrophils. Am Rev Respir Dis. 1992;146(1):170-6. [pmid: 1626799].
Vaughan J W, Platts-Mills T A. New approaches to environmental control. [Review]. Clin Rev Allergy Immunol. 2000;18(3):325-39. [pmid: 10981264].
Verberne A A P H, Frost C, Duiverman E J, et al. Addition of salmeterol versus doubling the dose of beclomethasone in children with asthma. Am J Respir Crit Care Med. 1998;158(1):213-9. [pmid: 9655732].
Verdiani P, Di Carlo S, Baronti A, et al. Effect of inhaled frusemide on the early response to antigen and subsequent change in airway reactivity in atopic patients. Thorax. 1990;45(5):377-81. [pmid: 2382243].
Verrall B, Muir D C, Wilson W M, et al. Laminar flow air cleaner bed attachment: a controlled trial. Ann Allergy. 1988;61(2):117-22. [pmid: 3041876].
Verstraeten J M, Verstraeten A F. Clinical evaluation of hyposensitization in allergic rhinitis: comparison of the results obtained with three different extracts. Material from a 3-year study. Ann Allergy. 1987;58(6):416-20. [pmid: 3592311].
Vervloet D, Charpin D, Birnbaum J. Extrinsic asthma and environmental allergens. [Review]. Allerg Immunol. 1991;23(7):281-3.
Vila L, Sanchez G, Ano M, et al. Risk factors for latex sensitization among health care workers. J Investig Allergol Clin Immunol. 1999;9(6):356-60.
Virant F S. Allergic rhinitis. Immunol Allergy Clin North Am. 2000;20(2):265-82.
Vogel G. New clues to asthma therapies. Science. 1997;276(5319):1643-6. [pmid: 9206826].
Voltolini S, Modena P, Minale P, et al. Sublingual immunotherapy in tree pollen allergy. Double-blind, placebo-controlled study with a biologically standardised extract of three pollens (alder, birch and hazel) administered by a rush schedule. Allergol Immunopathol. 2001;29(4):103-10.
Vourdas D, Syrigou E, Potamianou P, et al. Double-blind, placebo-controlled evaluation of sublingual immunotherapy with standardized olive pollen extract in pediatric patients with allergic rhinoconjunctivitis and mild asthma due to olive pollen sensitization. Allergy. 1998;53(7):662-72. [pmid: 9700035].
Vuurman E F P M, van Veggel L M A, Sanders R L, et al. Effects of Semprex-D and diphenhydramine on learning in young adults with seasonal allergic rhinitis. Ann Allergy Asthma Immunol. 1996;76(3):247-52. [pmid: 8634878].
Wagner R, Wendlberger U. Field efficacy of moxidectin in dogs and rabbits naturally infested with Sarcoptes spp., Demodex spp. and Psoroptes spp. mites. Vet Parasitol. 2000;93(2):149-58. [pmid: 11035233].
Walinder R, Norback D, Wieslander G, et al. Nasal patency and lavage biomarkers in relation to settled dust and cleaning routines in schools. Scand J Work Environ Health. 1999;25(2):137-43. [pmid: 10360469].
Walinder R, Norback D, Wieslander G, et al. Acoustic rhinometry and lavage biomarkers in relation to some building characteristics in Swedish schools. Indoor Air-Internat J Indoor Air Qual Climate. 2001;11(1):2-9.
Walinder R, Wieslander G, Norback D, et al. Influence of personal factors on nasal patency and lavage biomarkers in white-collar workers. Rhinology. 2000;38(3):130-5. [pmid: 11072659].
Walker C, Williams H, Phelan J. Allergic rhinitis history as a predictor of other future disqualifying otorhinolaryngological defects. Aviat Space Environ Med. 1998;69(10):952-6. [pmid: 9773895].
Walker S. The impact of allergic rhinitis on daily life. Practice Nurse 1999;18(2):100, 102, 104–5.
Walker S. Management of hayfever: A practical guide. Asthma J. 2001;6(2):106-8.
Walker S M, Pajno G B, Lima M T, et al. Grass pollen immunotherapy for seasonal rhinitis and asthma: a randomized, controlled trial. J Allergy Clin Immunol. 2001;107(1):87-93. [pmid: 11149996].
Walker S M, Varney V A, Gaga M, et al. Grass pollen immunotherapy: efficacy and safety during a 4-year follow-up study. Allergy. 1995;50(5):405-13. [pmid: 7573829].
Walpole O. Dusty answer. Occup Health. 2001;53(5):24-6.
Walshaw M J, Evans C C. Allergen avoidance in house dust mite sensitive adult asthma. Quarterly J Med. 1986;58(226):199-215.
Wang D, Smitz J, DeWaele M, et al. Effect of topical applications of budesonide and azelastine on nasal symptoms, eosinophil count and mediator release in atopic patients after nasal allergen challenge during the pollen season. Int Arch Allergy Immunol. 1997;114(2):185-92. [pmid: 9338613].
Warburton C J, Niven R M, Pickering C A, et al. Domiciliary air filtration units, symptoms and lung function in atopic asthmatics. Respir Med. 1994;88(10):771-6. [pmid: 7846339].
Ward A J, McKenniff M, Evans J M, et al. Theophylline--an immunomodulatory role in asthma?. Am Rev Respir Dis. 1993;147(3):518-23. [pmid: 8442581].
Ward G W Jr, Karlsson G, Rose G, et al. Trichophyton asthma: sensitisation of bronchi and upper airways to dermatophyte antigen. Lancet. 1989;1(8643):859-62. [pmid: 2564948].
Ward G W Jr, Woodfolk J A, Hayden M L, et al. Treatment of late-onset asthma with fluconazole. J Allergy Clin Immunol. 1999;104(3 Pt 1):541-6. [pmid: 10482825].
Warner J A, Frederick J M, Bryant T N, et al. Mechanical ventilation and high-efficiency vacuum cleaning: A combined strategy of mite and mite allergen reduction in the control of mite-sensitive asthma. J Allergy Clin Immunol. 2000;105(1 Pt 1):75-82. [pmid: 10629456].
Warner J A, Marchant J L, Warner J O. Double blind trial of ionisers in children with asthma sensitive to the house dust mite. Thorax. 1993;48(4):330-3. [pmid: 8511730].
Warner J O. Seasonal rhinoconjunctivitis and examinations: is this unfair discrimination?. Pediatr Allergy Immunol. 2000;11(3):129-30. [pmid: 10981521].
Wasserfallen J B, Gold K, Schulman K A, et al. Development and validation of a rhinoconjunctivitis and asthma symptom score for use as an outcome measure in clinical trials. J Allergy Clin Immunol. 1997;100(1):16-22. [pmid: 9257782].
Wasserfallen J B, Gold K, Schulman K A, et al. Item responsiveness of a rhinitis and asthma symptom score during a pollen season. J Asthma. 1999;36(5):459-65. [pmid: 10461935].
Wasserfallen J B, Leuenberger P, Pecoud A. Effect of cetirizine, a new H1 antihistamine, on the early and late allergic reactions in a bronchial provocation test with allergen. J Allergy Clin Immunol. 1993;91(6):1189-97. [pmid: 8099593].
Wasserman B. Allergic rhinitis and wellness opportunities. Manag Care Interface 2001;14(8):38–45, 50.
Watrous M L, Kozma C M, Reeder C E. Quality of life assessment in sufferers of rhinitis. [Abstract]. APhA Annual Meeting. 1994;141:43.
Watts R W, Perera Y S, Allsop J, et al. Immunological and purine enzyme studies on hyperuricaemic and normouricaemic patients with Down's syndrome. Clin Exp Immunol. 1979;36(3):355-63. [pmid: 158448].
Weeke E R. Epidemiology of allergic diseases in children. Rhinology. 1992;13(Suppl):5-12.
Weeks J, Oliver J, Birmingham K, et al. A combined approach to reduce mite allergen in the bedroom. Clin Exp Allergy. 1995;25(12):1179-83. [pmid: 8821297].
Weido A J, Reece L M, Alam R, et al. Intranasal fluticasone propionate inhibits recovery of chemokines and other cytokines in nasal secretions in allergen-induced rhinitis. Ann Allergy Asthma Immunol. 1996;77(5):407-15. [pmid: 8933780].
Weiland S K, Pless I B, Roghmann K J. Chronic illness and mental health problems in pediatric practice: Results from a survey of primary care providers. Pediatrics. 1992;89(3 Suppl):445-9. [pmid: 1741220].
Weiler J M, Bloomfield J R, Woodworth G G, et al. Effects of fexofenadine, diphenhydramine, and alcohol on driving performance. A randomized, placebo-controlled trial in the Iowa driving simulator. Ann Intern Med. 2000;132(5):354-63. [pmid: 10691585].
Weinblatt M E, Kremer J M, Bankhurst A D, et al. A trial of etanercept, a recombinant tumor necrosis factor receptor:Fc fusion protein, in patients with rheumatoid arthritis receiving methotrexate. New Engl J Med. 1999;340(4):253-9. [pmid: 9920948].
Weiner J M, Abramson M J, Puy R M. Intranasal corticosteroids versus oral H1 receptor antagonists in allergic rhinitis: systematic review of randomised controlled trials. BMJ. 1998;317(7173):1624-9. [pmcid: 28740]. [pmid: 9848901].
Weiser M, Gegenheimer L H, Klein P. A randomized equivalence trial comparing the efficacy and safety of Luffa comp.-Heel Nasal Spray with cromolyn sodium spray in the treatment of seasonal allergic rhinitis. Forsch Komplementarmed. 1999;6(3):142-8. [pmid: 10460983].
Weiss K B. Cost implications of upper respiratory allergic diseases. J Allergy Clin Immunol. 1998;101(2 II):S383-S385. [pmid: 9500734].
Weiss K B, Haus M, Iikura Y. Chapter 5: The costs of allergy and asthma and the potential benefit of prevention strategies. Allergy Clin Immunol Int. 2000;12(6):299-300.
Weiss K B, Sullivan S D. The health economics of asthma and rhinitis. I. Assessing the economic impact. [Review]. J Allergy Clin Immunol. 2001;107(1):3-8. [pmid: 11149982].
Weiss R J. Fluvastatin titrate-to-goal clinical practice study. Am J Ther. 1998;5(5):281-5. [pmid: 10099070].
Weiss S T, O'Connor G T, DeMolles D, et al. Indoor allergens and longitudinal FEV1 decline in older adults: the Normative Aging Study. J Allergy Clin Immunol. 1998;101(6 Pt 1):720-5. [pmid: 9648697].
Welch M J, Meltzer E O. Allergic rhinitis: a disease for all seasons. J Am Acad Phys Assistants. 1993;6(8):553-60.
Weldon D. Diagnosis and management of rhinitis. [Review]. Prim Care. 1998;25(4):831-48. [pmid: 9735122].
Welsh P W, Zimmermann E M, Yunginger J W, et al. Preseasonal intranasal immunotherapy with nebulized short ragweed extract. J Allergy Clin Immunol. 1981;67(3):237-42. [pmid: 7007474].
Wen T, Wang E, Shen S, et al. Allergenic potency of SMU-Df extract in comparison with VUS-Df extract; and diagnosis and immunotherapy for atopic dermatitis and rhinitis with SMU-Df extract in China. Arb Paul Ehrlich Inst Bundesamt Sera Impfstoffe Frankf A M 1992;(85):217–27.
Wessels F, Green R, Luyt D. Cost of therapy for allergic rhinitis. S Afr Med J. 1997;87(2):141-5. [pmid: 9107218].
Weyer A, Doinel C, Debbia M, et al. Grass pollen hyposensitization versus placebo therapy. II. Immunotherapy-induced changes in serum IgE and IgG levels. Allergy. 1981;36(5):319-28. [pmid: 7032342].
Weyer A, Donat N, L'Heritier C, et al. Grass pollen hyposensitization versus placebo therapy. I. Clinical effectiveness and methodological aspects of a pre-seasonal course of desensitization with a four-grass pollen extract. Allergy. 1981;36(5):309-17. [pmid: 7032341].
White P, Smith H, Baker N, et al. Symptom control in patients with hay fever in UK general practice: how well are we doing and is there a need for allergen immunotherapy?. Clin Exp Allergy. 1998;28(3):266-70. [pmid: 9543074].
Whyte K F, Flenley D C. House dust sensitivity and asthma. [Review]. Quarterly J Med. 1986;58(226):89-93.
Wickens K, Pearce N, Siebers R, et al. Indoor environment, atopy and the risk of the asthma in children in New Zealand. Pediatr Allergy Immunol. 1999;10(3):199-208. [pmid: 10565561].
Wiesenauer M, Heidl R. New approaches to treating pollenosis - A pilot study. Complement Ther Med. 1999;7(4):222-4. [pmid: 10709305].
Wihl J A, Ipsen H, Petersen B N, et al. Immunotherapy with partially purified and standardized tree pollen extracts. II. Results of skin prick tests and nasal provocation tests from a three-year double-blind study of patients treated with pollen extracts either of birch or combinations of alder, birch and hazel. Allergy. 1988;43(5):363-9. [pmid: 3046406].
Wilde M I, McTavish D. Tamsulosin. A review of its pharmacological properties and therapeutic potential in the management of symptomatic benign prostatic hyperplasia. Drugs. 1996;52(6):883-98. [pmid: 8957159].
Willes S R, Fitzgerald T K, Permutt T, et al. Acute respiratory response to prolonged, moderate levels of sidestream tobacco smoke. J Toxicol Environ Health. Part A. 1998;53(3):193-209.
Williams B O, Hull H, McSorley P, et al. Efficacy of acrivastine plus pseudoephedrine for symptomatic relief of seasonal allergic rhinitis due to mountain cedar. Ann Allergy Asthma Immunol. 1996;76(5):432-8. [pmid: 8630717].
Williams H C. Commentary. Evid. -Based Med. 2001;6(6):178.
Williamson L, Yudkin P, Livingstone R, et al. Hay fever treatment in general practice: A randomised controlled trial comparing standardised Western acupuncture with sham acupuncture. Acupunct Med. 1996;14(1):6-10.
Wilson A, Dempsey O J, Sims E J, et al. Evaluation of treatment response in patients with seasonal allergic rhinitis using domiciliary nasal peak inspiratory flow. Clin Exp Allergy. 2000;30(6):833-8. [pmid: 10848901].
Wilson A M, Orr L C, Sims E J, et al. Antiasthmatic effects of mediator blockade versus topical corticosteroids in allergic rhinitis and asthma. Am J Respir Crit Care Med. 2000;162(4 Pt 1):1297-301. [pmid: 11029334].
Wilson A M, Orr L C, Sims E J, et al. Effects of monotherapy with intra-nasal corticosteroid or combined oral histamine and leukotriene receptor antagonists in seasonal allergic rhinitis. Clin Exp Allergy. 2001;31(1):61-8. [pmid: 11167952].
Wilson A M, Sims E J, Orr L C, et al. Effects of topical corticosteroid and combined mediator blockade on domiciliary and laboratory measurements of nasal function in seasonal allergic rhinitis. Ann Allergy Asthma Immunol. 2001;87(4):344-9. [pmid: 11686428].
Wilson D R, Nouri-Aria K T, Walker S M, et al. Grass pollen immunotherapy: symptomatic improvement correlates with reductions in eosinophils and IL-5 mRNA expression in the nasal mucosa during the pollen season. J Allergy Clin Immunol. 2001;107(6):971-6. [pmid: 11398073].
Wilson DR, Torres Lima M, Durham SR. Sublingual immunotherapy for allergic rhinitis (Cochrane Protocol). In: The Cochrane Library, Issue 1, 2002, Oxford: Update Sofware, 2002.
Wilson R W. Cigarette smoking, disability days and respiratory conditions. J Occup Med. 1973;15(3):236-40. [pmid: 4693167].
Windom H H, Togias A. Rhinitis and asthma - Manifestations of one disease. Allergy Clin Immunol Int. 2001;13(4):154-61.
Winstead W, Barnett S N. Impact of endoscopic sinus surgery on global health perception: an outcomes study. Otolaryngol Head Neck Surg. 1998;119(5):486-91. [pmid: 9807074].
Winther L, Malling H J, Moseholm L, et al. Allergen-specific immunotherapy in birch- and grass-pollen-allergic rhinitis. I. Efficacy estimated by a model reducing the bias of annual differences in pollen counts. Allergy. 2000;55(9):818-26. [pmid: 11003445].
Wiseman L R, Benfield P. Intranasal fluticasone propionate. A reappraisal of its pharmacology and clinical efficacy in the treatment of rhinitis. [Review]. Drugs. 1997;53(5):885-907. [pmid: 9129872].
Witteman A M, Stapel S O, Perdok G J, et al. The relationship between RAST and skin test results in patients with asthma or rhinitis: A quantitative study with purified major allergens. J Allergy Clin Immunol. 1996;97(1 I):16-25. [pmid: 8568133].
Wittig H J, McLaughlin E T, Leifer K L, et al. Risk factors for the development of allergic disease: analysis of 2,190 patient records. Ann Allergy. 1978;41(2):84-8. [pmid: 686503].
Wober W, Diez Crespo C, Bahre M. Efficacy and tolerability of azelastine nasal spray in the treatment of allergic rhinitis: large scale experience in community practice. Curr Med Res Opin. 1997;13(10):617-26. [pmid: 9327196].
Wojnarowski C, Halmerbauer G, Mayatepek E, et al. Urinary leukotriene E(4), eosinophil protein X, and nasal eosinophil cationic protein are not associated with respiratory symptoms in 1-year-old children. Allergy. 2001;56(9):883-8. [pmid: 11551254].
Wolfe S P. ‘Prevention programmes’ - A dietetic minefield. Eur J Clin Nutr. 1995;49(Suppl 1):S92-S99. [pmid: 8647069].
Wong L, Hendeles L, Weinberger M. Pharmacologic prophylaxis of allergic rhinitis: relative efficacy of hydroxyzine and chlorpheniramine. J Allergy Clin Immunol. 1981;67(3):223-8. [pmid: 7007473].
Wong W M. Trastuzumab: Anti-HER2 antibody for treatment of metastatic breast cancer. Cancer Pract. 1999;7(1):48-50. [pmid: 9893005].
Wood R A, Johnson E F, Van Natta M L, et al. A placebo-controlled trial of a HEPA air cleaner in the treatment of cat allergy. Am J Respir Crit Care Med. 1998;158(1):115-20. [pmid: 9655716].
Wood S. Allergic rhinitis and hayfever. [Review]. Practitioner. 1992;236(1513):440-7. [pmid: 1360654].
Woodcock A, Custovic A. Allergen avoidance: does it work? [Review]. Brit Med Bull. 2000;56(4):1071-86. [pmid: 11359638].
Woodward C A, Boyle M H, Offord D R, et al. Correlates of children's use of physician and dentist services: Ontario child health study follow-up. Can J Public Health. 1993;84(2):103-6. [pmid: 8334600].
Worth J. Neo-natal sensitization to latex: A medical hypothesis. J Nutr Environ Med. 1999;9(4):305-12.
Wraith D G, Cunnington A M, Seymour W M. The role and allergenic importance of storage mites in house dust and other environments. Clin Allergy. 1979;9(6):545-61. [pmid: 519837].
Wray B B. In my opinion - Interview with the expert. Pediatr Asthma Allergy Immunol. 2001;15(1):55-7.
Wright A L, Holberg C J, Martinez F D, et al. Epidemiology of physician-diagnosed allergic rhinitis in childhood. Pediatrics. 1994;94(6 Pt 1):895-901. [pmid: 7971008].
Wüthrich B, Brignoli R, Canevascini M, et al. Epidemiological survey in hay fever patients: Symptom prevalence and severity and influence on patient management. Schweiz Med Wochenschr. 1998;128(5):139-43. [pmid: 9522418].
Yanase D J, David-Bajar K. The leukotriene antagonist montelukast as a therapeutic agent for atopic dermatitis. J Am Acad Dermatol. 2001;44(1):89-93. [pmid: 11148482].
Yang S H, Hong C Y, Yu C L. Decreased serum IgE level, decreased IFN-gamma and IL-5 but increased IL-10 production, and suppressed cyclooxygenase 2 mRNA expression in patients with perennial allergic rhinitis after treatment with a new mixed formula of Chinese herbs. Int Immunopharmacol. 2001;1(6):1173-82. [pmid: 11407311].
Yang W H, Dolovich J, Drouin M A, et al. Comparison of budesonide Turbuhaler with budesonide aqua in the treatment of seasonal allergic rhinitis. Rhinocort Study Group. Can Respir J. 1998;5(6):455-60. [pmid: 10070173].
Yang Y H, Lin Y T, Lu M Y, et al. A double-blind, placebo-controlled, and randomized study of loratadine (clarityne) syrup for the treatment of allergic rhinitis in children aged 3 to 12 years. Asian Pac J Allergy Immunol. 2001;19(3):171-5. [pmid: 11826911].
Yaniv E, Oppenheim D, Fuchs C. Chronic rhinitis in children. Int J Pediatr Otorhinolaryngol. 1992;23(1):51-7. [pmid: 1350576].
Yaniv E, Oppenheim D, Gatot A. Nasal histamine challenge: A method to predict the efficiency of antihistamine treatment. Am J Otolaryngol Head in seasonal pediatric allergy. J Investig Allergol Clin Immunol. 1999;9(5):305-13.
Zacharisen M C. Rhinitis in children, adolescents, the elderly, and pregnant women. Special considerations. Immunol Allergy Clin North Am. 2000;20(2):425-44.
Zeiger R S, Schatz M. Effect of allergist intervention on patient-centered and societal outcomes: allergists as leaders, innovators, and educators. [Review]. J Allergy Clin Immunol. 2000;106(6):995-1018. [pmid: 11112881].
Zenner H P, Baumgarten C, Rasp G, et al. Short-term immunotherapy: a prospective, randomized, double-blind, placebo-controlled multicenter study of molecular standardized grass and rye allergens in patients with grass pollen-induced allergic rhinitis. J Allergy Clin Immunol. 1997;100(1):23-9. [pmid: 9257783].
Zernike W, Corish T, Henderson S. An exploratory study from the patients' perspective of living with allergies. J Clin Nurs. 1997;6(5):371-7. [pmid: 9355471].
Neck Med Surg 1992;12(6):316–9.
Yawn B P, Yunginger J W, Wollan P C, et al. Allergic rhinitis in Rochester, Minnesota residents with asthma: frequency and impact on health care charges. J Allergy Clin Immunol. 1999;103(1 Pt 1):54-9. [pmid: 9893185].
Yelin E, Trupin L, Cisernas M, et al. A national study of medical care expenditures for respiratory conditions. Eur Respir J. 2002;19(3):414-21. [pmid: 11936516].
Yemaneberhan H, Bekele Z, Venn A, et al. Prevalence of wheeze and asthma and relation to atopy in urban and rural Ethiopia. Lancet. 1997;350(9071):85-90. [pmid: 9228959].
Yilmaz M, Bingol G, Altintas D, et al. Effect of SIT on quality of life. Allergy. 2000;55(3):302. [pmid: 10753028].
Yokota K, Johyama Y, Yamaguchi K. The relationship of airborne methyltetrahydrophthalic Anhydride concentrations to methyltetrahydrophthalic anhydride-induced symptoms. J Occup Health. 2001;43(4):201-4.
Young P. Asthma and allergies: an optimistic future. National Institutes of Health (NIH) Publication No. 80–388. Bethesda (MD): US Department of Health and Human Services, NIH, 1980.
Yuksel H, Tanac R, Gousseinov A, et al. Sublingual immunotherapy and influence on urinary leukotrienes in seasonal pediatric allergy. J Investig Allergol Clin Immunol. 1999;9(5):305-13.
Zetterstrom O, Buhl R, Mellem H, et al. Improved asthma control with budesonide/formeterol in a single inhaler, compared with budesonide alone. Eur Respir J. 2001;18(2):262-8. [pmid: 11529282].
Zhalnenkov N N. Portable devices adopted by the Russian Ministry of Health for home medical care. Biomed Eng. 1997;31(2):120-4.
Zhao X, Niu J, Wang Y, et al. Genotoxicity and chronic health effects of automobile exhaust: a study on the traffic policemen in the city of Lanzhou. Mutat Res. 1998;415(3):185-90. [pmid: 9714799].
Zheltikova T M, Ovsyannikova I G, Gervazieva V B, et al. Comparative detection of mite allergens in house dust of homes in Moscow by enzyme-linked immunosorbent assay and acarologic analysis. Allergy. 1994;49(10):816-9. [pmid: 7709990].
Zimmerman R K, Giebink G S. Childhood immunizations: A practical approach for clinicians. Am Fam Phys. 1992;45(4):1759-72.
Zuskin E, Mustajbegovic J, Schachter E N, et al. Respiratory function in shoe manufacturing workers. Am J Ind Med. 1997;31(1):50-5. [pmid: 8986254].
Zwemer R J, Karibo J. Use of laminar control device as adjunct to standard environmental control measures in symptomatic asthmatic children. Ann Allergy. 1973;31(6):284-90. [pmid: 4710748].