# Appendix: Acronyms and Abbreviations

AHRQ | Agency for Healthcare Research and Quality
AAHP | American Association of Health Plans
CDC | Centers for Disease Control and Prevention
CDSR | Cochrane Database of Systematic Reviews
CI | Confidence interval
CONSORT | Consolidated Standards of Reporting Trials
DARE | Database of Abstracts of Reviews of Effectiveness
DHHS | Department of Health and Human Services
HEPA | High efficiency particulate air
HRQOL | Health-related quality of life
IgE | Immunoglobulin E
IT | Immunotherapy
MSA | Metropolitan Statistical Area
NA | Not available
NHANESII | The National Health and Nutrition Examination Survey, 1976-80
NMES | National Medical Expenditure Survey
OR | Odds ratio
OTC | Over-the-counter
PHS | Public Health Service
QOL | Quality of life
RAST | Radioallergosorbent testing
RCT | Randomized controlled trial
RQLQ | Rhinoconjunctivitis Quality of Life Questionnaire
SE | Standard error
SF-36 | Medical Outcome Study Short-Form Health Survey
WPAI-AS | Allergy-specific Work Productivity and Activity Impairment questionnaire