# Evidence Tables

Evidence Table 1. Study characteristics

| k | n
Total | 53 | 4,558
Publication Year
1988 - 1994 | 11 | 1,030
1995 - 2001 | 42 | 3,528
Accrual Years Reported | 13 | 1,226
Study Location
USA | 28 | 1,869
Canada | 2 | 73
Western Europe | 20 | 1,807
Australia/New Zealand | 2 | 65
Multicontinental | 1 | 744
Study Design
Prospective | 21 | 1,800
RCT | 10 | 1,042
nRCT | 1 | 71
Case control | 2 | 321
UCS | 8 | 366
Retrospective | 1 | 94
Case series | 1 | 94
Cross-sectional | 31 | 2,664
Interventional - all | 17 | 1,348
Observational - all | 36 | 3,210
CFS Diagnostic Criteria Used*
CDC 1988 | 23 | 2,267
CDC 1994 | 20 | 1,912
Oxford 1991 | 18 | 2,173
Australia 1990 | 1 | 744

k = number of studies

n = number of patients with CFS

RCT = randomized controlled trial

nRCT = non-randomized controlled trial

UCS = uncontrolled case series

CDC = Centers for Disease Control

* Numbers sum to greater than the total number of studies, as some studies used more than one of these criteria.

Evidence Table 2. Study quality and validity

| k | n
MacMahon Quality Criteria - Longitudinal
I a | 10 | 1,312
I b | 3 | 140
III a | 3 | 300
III b | 6 | 142
MacMahon Quality Criteria - Cross-sectional
II a | 4 | 520
II b | 14 | 409
IV a | 9 | 1,639
IV b | 4 | 96
MetaWorks Internal Validity Score (2-6 points)
2 | 2 | 136
3 | 5 | 424
4 | 15 | 1,779
5 | 21 | 950
6 | 10 | 1,269
MetaWorks External Validity Score (0-2 points)
0 | 35 | 1,737
1 | 3 | 403
2 | 15 | 2,418
MetaWorks Total Validity Score (mean) (range 2-8) | 5.2 | 4,558
Jadad Quality Score - RCT only (mean) (range 0-5) | 3.3 | 1,042

k = number of studies

n = number of patients with CFS

Jadad Quality Scores (0-5): Higher numbers = best quality

MacMahon Quality Criteria (Ia - IVb): Lower numbers = best quality

MetaWorks Total Validity Score (2-8): Higher numbers = best validity

Evidence Table 3. Patient demographics, history, and employment status

Demographics | CFS | | | Healthy Controls
Demographics | % of patients or mean* | k | n | % of patients or mean* | k | n
Total patients (enrolled/randomized) | 100 | 53 | 4,507 | 100 | 22 | 775
Percent female | 76 | 49 | 4,378 | 73 | 19 | 605
Mean age (years) | 38.4 | 48 | 4,372 | 37.7 | 19 | 596
Mean CFS or symptom duration (years) | 5.5 | 40 | 3,976 | NA | -- | --
Mean total education, years | 14.1 | 14 | 1,310 | 14.4 | 6 | 212
Comorbid conditions
Patients with any current psychiatric diagnosis | 39 | 17 | 1,830 | 6 | 4 | 200
Patients with any current psychiatric diagnosis | 65 | 12 | 930 | 12 | 4 | 200
Patients with depression or dysthymia** | 45 | 13 | 1,718 | 12 | 2 | 65
Employment Status
Total employed^1^ | 42 | 35 | 2,652 | 90 | 9 | 340
Employed full time | 19 | 16 | 967 | 75 | 2 | 53
Unemployed^2^ | 54 | 37 | 2,720 | 9 | 9 | 340
Disability benefits | 51 | 6 | 364 | 4 | 1 | 47
Disability or temporary sick leave | 55 | 10 | 511 | 1 | 2 | 89
Work limitations due to illness | 64 | 20 | 1,919 | 0 | 1 | 38

* For those studies where the value is known

** All patients with reported history of depression or dysthymia diagnoses.

k = number of studies contributing data

n = number of patients in studies contributing data (less than the total number of patients enrolled at the study level, because some studies did not account for, or present demographic information for all patients

1 Employed includes working or in school

2 Unemployed includes retired, not working, or unable to continue schooling

Employed + unemployed does not sum to 100% of patients because complete employment data could not be extracted for all patients.

Number of studies reporting number of patients employed does not equal number of studies reporting number of patients unemployed because 2 studies only reported number unemployed, and the remainder of the patients were either employed or unaccounted for.

Evidence Table 4. Employment status and impairment domains

Employment Status | Domain Totals by Work Data Reported*
Employment Status | Cognitive | | Disease Severity/Symptoms | | Exercise Testing | | Functional | | General Health | | Mental (Psych/Affective) | | Physical Activity
k | n | k | n | k | n | k | n | k | n | k | n | k | n
Employed | 6 | 478 | 18 | 1634 | 6 | 183 | 4 | 455 | 10 | 659 | 20 | 1572 | 11 | 1246
Full time | 4 | 363 | 6 | 717 | 3 | 35 | 3 | 288 | 3 | 122 | 8 | 632 | 4 | 517
Part time | 2 | 310 | 5 | 574 | 3 | 35 | 2 | 169 | 3 | 122 | 6 | 579 | 3 | 398
Unemployed | 7 | 519 | 19 | 1675 | 6 | 183 | 4 | 455 | 11 | 700 | 21 | 1613 | 12 | 1287
Disability benefit | 0 | 0 | 3 | 240 | 1 | 2 | 0 | 0 | 1 | 51 | 2 | 208 | 2 | 208
Disability benefit or temporary sick leave | 4 | 165 | 4 | 202 | 1 | 2 | 0 | 0 | 4 | 202 | 6 | 336 | 4 | 252
Work limitations due to illness | 6 | 181 | 9 | 694 | 3 | 150 | 3 | 264 | 4 | 184 | 12 | 702 | 4 | 237
Other work data
Work scales | 5 | 449 | 5 | 491 | 0 | 0 | 1 | 32 | 4 | 148 | 7 | 524 | 5 | 474
Mean hours worked per week | 1 | 51 | 1 | 270 | 1 | 2 | 1 | 270 | 1 | 270 | 1 | 270 | 1 | 51

* At baseline/single time point or at outcome, all study designs

k = number of studies contributing data

n = number of patients in studies contributing data

Evidence Table 5. Employment and physical impairments

Author | Year | Validity Score | # CFS patients | % CFS patients employed | # Healthy controls | % Healthy controls employed | Significant differences: CFS vs. healthy controls | No significant differences: CFS vs. healthy controls
Buchwald | 1996 | 7 | 185 | 46 | 99 | 91 | MOS SF-36 - physical function: 40 vs. 96 (p<=.001) MOS SF-36 - general health: 32 vs. 81 (p<=.001)
Claypoole | 2001 | 5 | 22 | 41 | 22 | 86 | | VO2 max: 18.9 vs. 20.5 ml/kg/min
Garcia-Borrequero | 1998 | 5 | 42 | 27* | 41 | 100 | POMS - fatigue: 19.9 vs. 6.3 (p<.0001) POMS - vigor/activity: 8.0 vs. 19.0 (p<.0001)
Lloyd | 1994 | 5 | 12 | 42 | 13 | 100 | POMS - fatigue: 18.1 vs. 2.2 (p<.05) | MVC (% decline after exercise): 61.8 vs. 63.8
Natelson | 1995 | 6 | 41 | 18** | 36 | 100 | POMS - vigor: 6 vs. 21 POMS - fatigue: 21 vs. 2
Ray | 1993 | 5 | 24 | 13*** | 24 | 71*** | PFRS - fatigue: 4.0 vs. 0.7 (p<.001) PFRS - somatic symptoms: 2.6 vs. 0.4 (p<.001)
Schmaling | 1998 | 4 | 15 | 13 | 11 | 91 | MOS SF-36 - health perception: 23.3 vs. 95.8 (p<.001) MOS SF-36 - physical functioning: 37.0 vs. 95.8 (p<.001)
Vercoulen | 1997 | 7 | 51 | 49 | 53 | 89 | Actometer: 23.3 vs. 35.5 (p<.05) SIP - mobility: 26.2 vs. 33.5 (p<.05) SIP - walking: 31.6 vs. 40.8 (p<.05)

Measures of dispersion are not included in this table, p values are listed when reported.

MOS SF-36 = Medical Outcomes Study Short-Form General Health Survey

POMS = Profile of Mood States

MVC = Maximal Voluntary Contraction

PFRS = Profile of Fatigue-Related Symptoms

SIP = Sickness Impact Profile

CIS = Checklist Individual Strength

* This study reported the number of patients with vocational disability. It was assumed that the remainder of patients were employed.

For controls, vocational disability was reported as N/A, and 100% employment was assumed.

** This study reported the number of patients disabled, and it was assumed that the remainder of patients were employed.

*** This study reported only the number of patients employed full-time.

Evidence Table 6. Neuropsychological tests and work status for CFS patients vs. healthy controls (Key Question 2)

Author | Year | Validity Score | # CFS patients | % CFS patients employed | # Healthy controls | % Healthy controls employed | Significant differences: CFS vs. healthy controls | No significant differences: CFS vs. healthy controls
Buchwald | 1996 | 7 | 185 | 46 | 99 | 91 | MOS SF-36 - mental health: 57 vs. 83 (p<.001)
Claypoole | 2001 | 5 | 22 | 52 | 22 | 86 | | Hopkins verbal learning: 26.1 vs. 27.4
Garcia-Borrequero | 1998 | 5 | 42 | 27* | 41 | 100 | POMS - confusion: 12.0 vs. 5.9 (p<.0001) POMS - depression: 9.2 vs. 5.4 (p<.05) | POMS - tension/anxiety (scores not reported) POMS - anger/hostility (scores not reported)
Lloyd | 1994 | 5 | 12 | 42 | 13 | 100 | POMS - confusion: 14.8 vs. 2.4 (p<.1) POMS - depression: 21.5 vs. 0.6 (p<.001)
Michiels | 1996 | 5 | 35 | 26 | 33 | 100 | WAIS digit span forward: 45.3 vs. 52.6 (p<.0005)
Natelson | 1995 | 6 | 41 | 18** | 6 | 100 | POMS - depression/dejection: 10 vs. 3 POMS - confusion: 14 vs. 2
Ray | 1993 | 5 | 24 | 13*** | 24 | 71*** | EAQ: 35.6 vs. 49.3 (p<.001) PFRS - emotional distress: 3.5 vs. 1.2 (p<.001) PFRS - cognitive difficulty: 3.8 vs. 1.0 (p<.001)
Schmaling | 1998 | 4 | 15 | 13 | 11 | 91 | SCL 90-R - depression: 59.3 vs. 25.8 (p<.001) MOS SF-36 - mental health: 69.1 vs. 85.5 (p<.001)
Vercoulen | 1997 | 7 | 51 | 49 | 53 | 89 | SIP - concentration: 35.0 vs. 2.2 (p=.0001) CIS - concentration: 5.2 vs. 1.9 (p=.0001)

Measures of dispersion are not included in this table. p values are listed when reported.

MOS SF-36 = Medical Outcomes Study Short-Form General Health Survey

POMS = Profile of Mood States

EAQ = Everyday Attention Questionnaire

PFRS = Profile of Fatigue-Related Symptoms

SCL 90-R = Symptom Checklist 90 - Revised

SIP = Sickness Impact Profile

CIS = Checklist Individual Strength

* This study reported the number of patients with vocational disability. It was assumed that the remainder of patients were employed.

For controls, vocational disability was reported as N/A, and 100% employment was assumed.

** This study reported the number of patients disabled, and it was assumed that the remainder of patients were employed.

*** This study reported only the number of patients employed full-time.

Evidence Table 7. Interventions and work or impairment domains (Key Question 3)

| Domain Totals at Follow-up, post-intervention
| Total | | Work* | | Cognitive | | Disease (Severity/Symptoms) | | Exercise Testing | | Functional | | General Health | | Mental (Psych/Affective) | | Physical Activity
Interventions | k | n | k | n | k | n | k | n | k | n | k | n | k | n | k | n | k | n
Behavioral | 4 | 143 | 2 | 62 | 1 | 32 | 3 | 92 | 1 | 30 | 2 | 62 | 2 | 83 | 3 | 92 | 1 | 30
Psychiatric | 2 | 94 | 1 | 30 | 0 | 0 | 2 | 94 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 30 | 1 | 30
Drug Therapy | 5 | 218 | 0 | 0 | 0 | 0 | 4 | 165 | 1 | 35 | 1 | 18 | 2 | 85 | 4 | 165 | 2 | 85
Physical/Exercise Therapy | 2 | 148 | 0 | 0 | 0 | 0 | 2 | 148 | 1 | 34 | 0 | 0 | 0 | 0 | 2 | 148 | 1 | 114
Dietary Therapy | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Placebo | 6 | 247 | 0 | 0 | 0 | 0 | 6 | 247 | 2 | 64 | 1 | 30 | 2 | 85 | 6 | 247 | 2 | 85
Mixed | 4 | 92 | 0 | 0 | 1 | 23 | 3 | 90 | 2 | 35 | 1 | 23 | 0 | 0 | 3 | 90 | 1 | 34
All Interventional Studies | 14 | 907 | 2 | 92 | 2 | 55 | 11 | 741 | 3 | 168 | 4 | 133 | 2 | 94 | 10 | 772 | 4 | 378

* Includes work function scales reported at follow-up, post intervention.

k = number of studies

n = number of patients

Evidence Table 8. Restoring ability to work in CFS patients (Key Question 3)

Author | Year | Validity Score | Intervention | Time of Followup Assessment (months) | # CFS patients enrolled | % Dropouts | % CFS patients employed at baseline | % CFS patients employed at followup*
Akagi | 2001 | 6 | Cognitive behavioral therapy | 6 | 51 | 0 | 29 | 53
Dyck | 1996 | 3 | Rehabilitation program | 3 | 2 | 0 | 0 | 50
Fulcher | 1997 | 5 | Exercise therapy | 15 | 66 | 29 | 39 | 47
Marlin | 1998 | 2 | Individualized programs | 6 | 71 | 28 | 0 | 44
Tiersky | 2001 | 4 | None | 42 | 47 | 26 | 32 | 23
Vercoulen | 1994 | 7 | None | 18 | 298 | 17 | 31 | 24

* % of patients employed at follow-up = # patients employed at followup/ # patients enrolled

Evidence Table 9. Baseline characteristics for CFS patients Reported as improved (Key Question 4)

Author | Year | Validity Score | Intervention | Time of Outcome Assessment (months) | # CFS patients enrolled in study | # CFS patients evaluated for improvement | % CFS patients improved | Baseline Characteristics of Improved vs. Unimproved patients
Bombardier | 1995 | 4 | none | 18 | 226 | 226 | 61 | Absence of dysthymia (r= −.15, p<.03)
Butler | 1991 | 5 | CBT | 1.5 | 32 | 27 | 85 | Absence of treatment-resistant affective disorder (BDI: 8.3 vs. 11.7) Same gender, disease severity, disease duration (numbers not reported).
Deale | 1997 | 6 | CBT | 6 | 60 | 27 | 70 | No significant difference on any pretreatment characteristic (numbers not reported).
Kruesi | 1989 | 4 | Acyclovir or placebo | 6 | 28 | 24 | 88 | No significant difference on clinical, chemical, immunologic, or serologic features (numbers not reported).
Lerner | 1997 | 4 | Ganciclovir | 6 | 38 | 18 | 72 | Male gender (3 men in study, all improved), Shorter mean duration of symptoms (1.6 vs. 2.8 yrs)
Peterson | 1991 | 6 | none | onset of illness | 177 | 177 | 12 | Female: 61.9% vs 80.1% (p=.09) Employed at presentation: 66.7% vs. 49.4% (p=.06) Physical functioning scores: 68.5 vs.58.9 (p=.01) Social functioning scores: 3.2 vs.42.8 (p=.02) SCL-90 anxiety scores: 0.43 vs. 0.66 (p=.01) SCL-90 Obsessive/compulsive sco
Saltzstein | 1998 | 4 | none | 24 | 15 | 15 | 12 | Perception that physician's prognosis was positive, social support (numbers not reported).
Tiersky | 2001 | 4 | none | 42 | 47 | 35 | 57 | Higher anxiety: median score 38 vs. 27 (p=.02), Ability to perform light duty. No significant differences in age, education, illness severity or duration, employment status, gender, level of depression (all p>.05).
Vercoulen | 1994 | 7 | none | 18 | 298 | 246 | 20 | Self-reported improvement was related to younger age, shorter disease duration, less symptom severity, less functional impairment, more sense of control over symptoms (numbers not reported). "Demographic variables were not predictive for

Measures of dispersion are not included in this table. p values are listed when reported.

CBT = Cognitive Behavior Therapy

BDI = Beck Depression Inventory

SCL 90 = Symptom Checklist 90

Table 10. Studies reporting work status correlations

Study ID | Author | Year | Validity Score | n | Relationship Investigated | Finding
701825 | Bombardier | 1995 | 4 | 226 | Demographic (age, gender, education), clinical (duration of fatigue), and psychiatric (lifetime psychiatric diagnoses) variables at initial evaluation vs. return to work at follow-up (median 1.5 years later). | Among CFS patients, none of the initial demographic, clinical, or psychiatric variables were predictive of return to work.
699067 | Jason | 1999 | 5 | 32 | Demographic (age, gender, marital status), clinical (symptom severity, activity level, physical function) and psychiatric (COPE scales) measures by work status, at single time point. | Working patients with CFS were more likely to be male, younger, never married, had less severe muscle and joint pain, higher activity levels, and better physical functioning than non-working patients.
698360 | Moss-Morris | 2001 | 5 | 53 | Cognitive-behavioral factors at initial evaluation vs. SIP Work subscale at 6 month follow-up. | Somatic illness identity (extent of symptoms associated with illness) and limiting coping (extent to which patients limited stress, exercise, and activity) were significant predictors of work dysfunction.
698505 | Wilson | 2001 | 6 | 744 | Symptom severity self-report and history of major depressive episode vs. ability to work, at single time point. | Severe functional impairment correlated with inability to work. Presence of major depression was not associated with ability to work.

n = number of CFS patients in study

SIP = Sickness Impact Profile