# Bibliography

Akagi H, Klimes I, Bass C. Cognitive behavioral therapy for chronic fatigue syndrome in a general hospital-feasible and effective. Gen Hosp Psychiatry. 2001;23:254-60. [pmid: 11600166].
Anderson JS, Ferrans CE. The quality of life of persons with chronic fatigue syndrome. J Nerv Ment Dis. 1997;185:359-67. [pmid: 9205421].
Antoni MH, Brickman A, Lutgendorf S, Klimas N, Imia-Fins A, Ironson G, et al Psychosocial correlates of illness burden in chronic fatigue syndrome Clin Infect Dis 1994 18Suppl 1:S73 8 8148457
Arpino C, Carrieri MP, Valesini G, Pizzigallo E, Rovere P, Tirelli U, et al. Idiopathic chronic fatigue and chronic Fatigue syndrome: A comparison of two case-definitions. Ann Ist Super Sanita. 1999;35:435-41. [pmid: 10721210].
Beck AT, Ward CH, Mendelson M, Mock J, Erbaugh J. An inventory for measuring depression. Arch Gen Psychiatry. 1961;4:561-71. [pmid: 13688369].
Bergner M, Bobbitt RA, Kressel S, et al. The Sickness Impact Profile: Conceptual formulation and methodology for the development of a health status measure. Int J Health Serv. 1976;6:393-415. [pmid: 955750].
Bombardier CH, Buchwald D. Chronic fatigue, chronic fatigue syndrome, and fibromyalgia. Disability and health-care use. Med Care. 1996;34:924-30. [pmid: 8792781].
Bombardier CH, Buchwald D. Outcome and prognosis of patients with chronic fatigue vs chronic fatigue syndrome. Arch Intern Med. 1995;155:2105-10. [pmid: 7575071].
Bou-Holaigah I, Rowe PC, Kan J, Calkins H. The relationship between neurally mediated hypotension and the chronic fatigue syndrome. JAMA. 1995;274:961-7. [pmid: 7674527].
Buchwald D, Pearlman T, Kith P, Schmaling K. Gender differences in patients with chronic fatigue syndrome. J Gen Intern Med. 1994;9:397-401. [pmid: 7931750].
Buchwald D, Pearlman T, Umali J, et al. Functional status in patients with chronic fatigue syndrome, other fatiguing illnessess, and healthy individuals. Am J Med. 1996;101:364-70. [pmid: 8873506].
Butler S, Chalder T, Ron M, et al. Cognitive behaviour therapy in chronic fatigue syndrome. J Neurol Neurosurg Psychiatry. 1991;54:153-8. [pmid: 2019842].
Report to the Chief Medical Officer of an independent working group. London: Department of Health, 2001. www.doh.gov.uk/cmo/cfsmereport/index.htm (accessed 14 Jan 2002).
Chalder T, Berelowitz G, Pawlikowska T, et al. Development of a fatigue scale. J Psychosom Res. 1993;37:147-53. [pmid: 8463991].
Claypoole K, Mahurin R, Fischer ME, et al. Cognitive compromise following exercise in monozygotic twins discordant for chronic fatigue syndrome: Fact or artifact. Appl Neuropsychol. 2001;8:31-40. [pmid: 11388121].
Creswell C, Chalder T. Defensive coping styles in chronic fatigue syndrome. J Psychosom Res. 2001;51:607-10. [pmid: 11595249].
Cruess S. Immunologic status correlates with severity of physical symptoms and perceived illness burden in chronic fatigue syndrome patients. J CFS. 2000;7:39-52.
Cruess SE, Klimas N, Antoni MH, Helder L, Maher K, Keller R, et al. Immunologic status correlates with severity of physical symptoms and perceived illness burden in chronic fatigue syndrome patients. J CFS. 2000;7:39-52.
Daly E, Komaroff AL, Bloomingdale K, Wilson S, Albert MS. Neuropsychological function in patients with chronic fatigue syndrome, multiple sclerosis, and depression. Appl Neuropsychol. 2001;8:12-22. [pmid: 11388119].
Deale A, Chalder T, Marks I, et al. Cognitive behavior therapy for chronic fatigue syndrojme: A randomized controlled trial. Am J Psychiatry. 1997;154:408-14. [pmid: 9054791].
Derogatis LR, Melisaratos N. The brief symptom inventory. Psychological Medicine. 1983;13:595-605. [pmid: 6622612].
Dyck D, Allen S, Barron J, et al. Management of chronic fatigue syndrome: Case study. AAOHN J. 1996;44:85-92. [pmid: 8694980].
Evengard B, Schacterle RS, Komaroff AL. Chronic fatigue syndrome: New insights and old ignorance. J Intern Med. 1999;246:455-69. [pmid: 10583715].
Fiedler N, Kipen HM, DeLuca J, Kelly-McNeil K, Natelson B. A controlled comparison of multiple chemical sensitivities and chronic fatigue syndrome. Psychosom Med. 1996;58:38-49. [pmid: 8677287].
Fischler B, Cluydts R, De Gucht Y, Kaufman L, De Meirleir K. Generalized anxiety disorder in chronic fatigue syndrome. Acta Psychiatr Scand. 1997;95:405-13. [pmid: 9197905].
Friedberg F, Jason LA. Chronic fatigue syndrome and fibromyalgia: Clinical assessment and treatment. J Clin Psychol. 2001;57:433-55. [pmid: 11255201].
Fukuda K, Straus S, Hickie I, et al. The chronic fatigue syndrome: A comprehensive approach to its definition and study. Ann Intern Med. 1994;121:953-9. [pmid: 7978722].
Fulcher KY, White PD. Randomised controlled trial of graded exercise in patients with the chronic fatigue syndrome. BMJ. 1997;314:1647-52. [pmid: 9180065].
Fulcher KY, White PD. Strength and physiological response to exercise in patients with chronic fatigue syndrome. J Neurol Neurosurg Psychiatry. 2000;69:302-7. [pmid: 10945803].
Garcia-Borrequero D, Dale JK, Rosenthal NE, et al. Lack of seasonal variation of symptoms in patients with chronic fatigue syndrome. Psychiatry Res. 1998;77:71-7. [pmid: 9541142].
Hill NF, Tiersky LA, Scavalla VR, Lavietes M, Natelson BH. Natural history of severe chronic fatigue syndrome. Arch Phys Med Rehabil. 1999;80:1090-4. [pmid: 10489014].
Holmes GP, Kaplan JE, Gantz NM, et al. Chronic fatigue syndrome: A working case definition. Ann Intern Med. 1988;108:387-9. [pmid: 2829679].
Jadad AR, Moore A, Carroll D, et al. Assessing the quality of reports of randomized clinical trials: Is blinding necessary?. Controlled Clinical Trials. 1996;17:1-12. [pmid: 8721797].
Jason LA, Fricano G, Taylor RR, et al. Chronic fatigue syndrome: An examination of the phases. J Clin Psychol. 2000;56:1497-508. [pmid: 11132566].
Jason LA, Richman JA, Rademaker AW, et al. A community-based study of chronic fatigue syndrome. Arch Intern Med. 1999;159:2129-37. [pmid: 10527290].
Jason LA, Taylor RR, Kennedy CL, et al. Chronic fatigue syndrome: Sociodemographic subtypes in a community-based sample. Eval Health Prof. 2000;23:243-63. [pmid: 11067190].
Jason LA, Taylor RR, Kennedy CL. Chronic fatigue syndrome, fibromyalgia, and multiple chemical sensitivities in a community-based sample of persons with chronic fatigue syndrome-like symptoms. Psychosom Med. 2000;62:655-63. [pmid: 11020095].
Johnson SK, DeLuca J, Natelson BH. Chronic fatigue syndrome: Reviewing the research findings. Ann Behav Med. 1999;21:258-71. [pmid: 10626034].
Karnofsky DA, Burchenal JH. The clinical evaluation of chemotherapeutic agents in cancer. In: MacLeod CM, (ed.). Evaluation of Chemotherapeutic Agents: New York: New York Columbia University Press. 1949:p. 191-205.
Kruesi MJ, Dale J, Straus SE. Psychiatric diagnoses in patients who have chronic fatigue syndrome. J Clin Psychiatry. 1989;50:53-6. [pmid: 2536690].
Lane TJ, Manu P, Matthews DA. Depression and somatization in the chronic fatigue syndrome. Am J Med. 1991;91:335-44. [pmid: 1951377].
Lerner AM, Zervos M, Dworkin HJ, et al. New cardiomyopathy: Pilot study of intravenous ganciclovir in a subset of the chronic fatigue syndrome. Infect Agents Dis. 1997;6:110-7.
Lloyd AR, Gandevia S, Brockman A, et al. Cytokine production and fatigue in patients with chronic fatigue syndrome and healthy control subjects in response to exercise. Clin Infect Dis. 1994;18:S142-6. [pmid: 8148442].
Lloyd AR, Hickie I, Boughton CR, et al. Prevalence of chronic fatigue syndrome in an Australian population. Med J Aust. 1990;153:522-8. [pmid: 2233474].
MacDonald KL, Osterholm MT, LeDell KH, White KE, Schenck CH, Chao CC, et al. A case-control study to assess possible triggers and cofactors in chronic fatigue syndrome. Am J Med. 1996;100:548-54. [pmid: 8644768].
MacMahon K, Lip G. Psychological factors in heart failure: A review of the literature. Arch Intern Med. 2002;162:509-16. [pmid: 11871918].
Marcel B, Komaroff AL, Fagioli LR, Kornish RJ, Albert MS. Cognitive deficits in patients with chronic fatigue syndrome. Biol Psychiatry. 1996;40:535-41. [pmid: 8879474].
Marlin RG, Anchel H, Gibson JC, et al. An evaluation of multidisciplinary intervention for chronic fatigue syndrome with long-term follow-up, and a comparison with untreated controls. Am J Med. 1998;105:110S-4S. [pmid: 9790492].
Martin M. Human Learning. 1986;5:63-74.
McKenzie R, O'Fallon A, Dale J, Demitrack M, Sharma G, Deloria M, et al. Low-dose hydrocortisone for treatment of chronic fatigue syndrome: A randomized controlled trial. JAMA. 1998;280:1061-6. [pmid: 9757853].
McNair DM, Lorr M, Droppelman LF. Profile of Mood States. San Diego, Calif: Educational and Industrial Testing Service. 1981. [pmcid: 281528].
Michiels V, Cluydts R, Fischler B, et al. Cognitive functioning in patients with chronic fatigue syndrome. J Clin Exp Neuropsychol. 1996;18:666-77. [pmid: 8941852].
Michiels V, Cluydts R. Neuropsychological functioning in chronic fatigue syndrome: A review. Acta Psychiatr Scand. 2001;103:84-93. [pmid: 11167310].
Morriss RK, Wearden AJ, Battersby L. The relation of sleep difficulties to fatigue, mood and disability in chronic fatigue syndrome. J Psychosom Res. 1997;42:597-605. [pmid: 9226607].
Morriss RK, Wearden AJ, Mullis R. Exploring the validity of the Chalder Fatigue scale in chronic fatigue syndrome. J Psychosom Res. 1998;45:411-7. [pmid: 9835234].
Morriss RK, Wearden AJ. Screening instruments for psychiatric morbidity in chronic fatigue syndrome. J R Soc Med. 1998;91:365-8. [pmid: 9771495].
Moss-Morris R, Petrie KJ. Discriminating between chronic fatigue syndrome and depression: A cognitive analysis. Psychol Med. 2001;31:469-79. [pmid: 11305855].
Mulrow CD, Oxman AD (eds). Cochrane Collaboration Handbook. The Cochrane Library. The Cochrane Collaboration; Issue 1. Oxford: Update Software; 1997. Updated quarterly.
Mulrow CD, Ramirez G, Cornell JE, et al. Defining and Managing Chronic Fatigue Syndrome. Evidence Report/Technology Assessment No. 42 (Prepared by San Antonio Evidence-based Practice Center at the University of Texas Health Science Center at San Antonio under Contract No 290-97-0012). AHRQ Publication No. 01-EO61, September 2001. Rockville, MD: Agency for Healthcare Research and Quality.
Myers C, Wilks D. Comparison of Euroqol EQ-5D and SF-36 in patients with chronic fatigue syndrome. Qual Life Res. 1999;8:9-16. [pmid: 10457734].
Natelson BH, Johnson SK, DeLuca J, et al. Reducing heterogeneity in chronic fatigue syndrome: A comparison with depression and multiple sclerosis. Clin Infect Dis. 1995;21:1204-10. [pmid: 8589144].
Peterson PK, Pheley A, Schroeppel J, et al. A preliminary placebo-controlled crossover trial of fludrocortisone for chronic fatigue syndrome. Arch Intern Med. 1998;158:908-14. [pmid: 9570178].
Peterson PK, Schenck CH, Sherman R. Chronic fatigue syndrome in Minnesota. Minn Med. 1991;74:21-6.
Peterson PK, Shepard J, Macres M, Schenck C, Crosson J, Rechtman D, et al. A controlled trial of intravenous immunoglobulin G in chronic fatigue syndrome. Am J Med. 1990;89:554-60. [pmid: 2239975].
Pheley AM, Melby D, Schenck C, Mandel J, Peterson PK. Can we predict recovery in chronic fatigue syndrome. Minn Med. 1999;82:52-6. [pmid: 10589213].
Powell P, Bentall RP, Nye FJ, Edwards RH. Randomised controlled trial of patient education to encourage graded exercise in chronic fatigue syndrome. BMJ. 2001;322:387-90. [pmcid: 26565]. [pmid: 11179154].
Prins JB, Bleijenberg G, Bazelmans E, et al. Cognitive behaviour therapy for chronic fatigue syndrome: A multicentre randomised controlled trial. Lancet. 2001;357:841-7. [pmid: 11265953].
Ray C, Jefferies S, Weir WR. Coping and other predictors of outcome in chronic fatigue syndrome: A 1-year follow-up. J Psychosom Res. 1997;43:405-15. [pmid: 9330240].
Ray C, Jefferies S, Weir WR. Coping with chronic fatigue syndrome: Illness responses and their relationship with fatigue, functional impairment and emotional status. Psychol Med. 1995;25:937-45. [pmid: 8588012].
Ray C, Jefferies S, Weir WR. Life-events and the course of chronic fatigue syndrome. Br J Med Psychol. 1995;68:323-31. [pmid: 8688371].
Ray C, Phillips L, Weir WR. Quality of attention in chronic fatigue syndrome: Subjective reports of everyday attention and cognitive difficulty, and performance on tasks of focused attention. Br J Clin Psychol. 1993;32:357-64. [pmid: 8251968].
Reid S, Chalder T, Cleare A, et al. Chronic fatigue syndrome. BMJ. 2000;320:292-6. [pmid: 10650029].
Rowe PC, Calkins H, DeBusk K, et al. Fludrocortisone acetate to treat neurally mediated hypotension in chronic fatigue syndrome: A randomized controlled trial. JAMA. 2001;285:52-9. [pmid: 11150109].
Sacks HS, Berrier J, Reitman D, Pagano D, Chalmers T. Meta-analyses of randomized control trials: An update of the quality and methodology. In: Bailar JC III, Mosteller F, editors. Medical Uses of Statistics. 2nd Edition. Boston: NEJM Books. 1992:427-442.
Saltzstein BJ, Wyshak G, Hubbuch JT, et al. A naturalistic study of the chronic fatigue syndrome among women in primary care. Gen Hosp Psychiatry. 1998;20:307-16. [pmid: 9788031].
Scheffers MK, Johnson RJ, Grafman J, Dale JK, Straus SE. Attention and short-term memory in chronic fatigue syndrome patients: An event-related potential analysis. Neurology. 1992;42:1667-75. [pmid: 1513453].
Schmaling KB, Hamilos DL, DiClementi JD, et al. Pain perception in chronic fatigue syndrome. J CFS. 1998;4:13-22.
Schmaling KB, Smith WR, Buchwald DS. Significant other responses are associated with fatigue and functional status among patients with chronic fatigue syndrome. Psychosom Med. 2000;62:444-50. [pmid: 10845358].
Shanks MF, Ho-Yen DO. A clinical study of chronic fatigue syndrome. Br J Psychiatry. 1995;166:798-801. [pmid: 7663831].
Sharpe M, Hawton K, Simkin S, Surawy C, Hackmann A, Klimes I, et al. Cognitive behaviour therapy for the chronic fatigue syndrome: A randomized controlled trial. Br Med J. 1996;312:22-6. [pmid: 8555852].
Sharpe MK, Archard LC, Banatvala JE, et al. A report - chronic fatigue syndrome: Guidelines for research. J R Soc Med. 1991;84:118-21. [pmid: 1999813].
Sisto SA, LaManca J, Cordero DL, Bergen MT, Ellis SP, Drastal S, et al. Metabolic and cardiovascular effects of a progressive exercise test in patients with chronic fatigue syndrome. Am J Med. 1996;100:634-40. [pmid: 8678084].
Straus SE, Dale JK, Tobi M, Lawley T, Preble O, Blaese RM, et al. Acyclovir treatment of the chronic fatigue syndrome. Lack of efficacy in a placebo-controlled trial. N Engl J Med. 1988;319:1692-8. [pmid: 2849717].
Straus SE. Caring for patients with chronic fatigue syndrome. BMJ. 2002;324:124-5. [pmid: 11799015].
Sumaya CV Serologic and virologic epidemiology of Epstein-Barr virus: Relevance to chronic fatigue syndrome Rev Infect Dis 1991 13Suppl 1:S19 25 1850540
Swanink CM, Vercoulen JH, Bleijenberg G, Fennis JF, Galama JM, van der Meer JW. Chronic fatigue syndrome: A clinical and laboratory study with a well matched control group. J Intern Med. 1995;237:499-506. [pmid: 7738491].
Tiersky LA, DeLuca J, Hill N, et al. Longitudinal assessment of neuropsychological functioning, psychiatric status, functional disability and employment status in chronic fatigue syndrome. Appl Neuropsychol. 2001;8:41-50. [pmid: 11388123].
Tuck I, Wallace D. Chronic fatigue syndrome: A woman's dilemma. Health Care Women Int. 2000;21:457-66. [pmid: 11261112].
Vercoulen JH, Bazelmans E, Swanink CM, et al. Physical activity in chronic fatigue syndrome: Assessment and its role in fatigue. J Psychiatr Res. 1997;31:661-73. [pmid: 9447571].
Vercoulen JH, Bazelmans E, Swanink CM, Galama JM, Fennis JF, van der Meer JW, et al. Evaluating neuropsychological impairment in chronic fatigue syndrome. J Clin Exp Neuropsychol. 1998;20:144-56. [pmid: 9777468].
Vercoulen JH, Swanink C, Fennis J, et al. Dimensional assessment of chronic fatigue syndrome. J Psychosom Res. 1994;38:383-92. [pmid: 7965927].
Vercoulen JH, Swanink C, Zitman F, et al. Randomised, double-blind, placebo-controlled study of fluoxetine in chronic fatigue syndrome. Lancet. 1996;347:858-61. [pmid: 8622391].
Vercoulen JH, Swanink CM, Fennis JF, Galama JM, van der Meer JW, Bleijenberg G. Prognosis in chronic fatigue syndrome: A prospective study on the natural course. J Neurol Neurosurg Psychiatry. 1996;60:489-94. [pmid: 8778251].
Vercoulen JH, Swanink CM, Galama JM, Fennis JF, Jongen PJ, Hommes OR, et al. The persistence of fatigue in chronic fatigue syndrome and multiple sclerosis: Development of a model. J Psychosom Res. 1998;45:507-17. [pmid: 9859853].
Ware JE, Sherbourne CD. The MOS 36-item short-form health survey (SF-36). Medical Care. 1992;30:473-83. [pmid: 1593914].
Wearden AJ, Morriss RK, Mullis R, Strickland PL, Pearson DJ, Appleby L, et al. Randomised, double-blind, placebo-controlled treatment trial of fluoxetine and graded exercise for chronic fatigue syndrome. Br J Psychiatry. 1998;172:485-90. [pmid: 9828987].
Wechsler D. Wechsler Adult Intelligence Scale - Revised (WAIS-R). 1981. New York: Harcourt Brace. [pmcid: 281528].
Wessely S, Powell R. Fatigue syndrome: A comparison of chronic "postviral" fatigue with neuromuscular and affective disorders. J Neurol Neurosurg Psychiatry. 1989;52:940-8. [pmid: 2571680].
Wessely S. Chronic Fatigue: Symptom and Syndrome. Ann Intern Med. 2001;134:838-843. [pmid: 11346319].
Wessely S. The epidemiology of chronic fatigue syndrome. Epidemiol Rev. 1995;17:139-51. [pmid: 8521932].
Whiting P, Bagnall AM, Sowden AJ, et al. Interventions for the treatment and management of chronic fatigue syndrome: A systematic review. JAMA. 2001;286:1360-8. [pmid: 11560542].
Wilson A, Hickie I, Hadzi-Pavlovic D, et al. What is chronic fatigue syndrome? Heterogeneity within an international multicentre study. Aust NZJ Psychiatry. 2001;35:520-7.
Med J Aust. 2002;176:S17-S55.
Yeomans JD, Conway SP. Biopsychosocial aspects of chronic fatigue syndrome (myalgic encephalomyelitis). J Infect. 1991;23:263-9. [pmid: 1753134].