# References

1 Mulrow CD, Ramirez G, Cornell JE, et al. Defining and Managing Chronic Fatigue Syndrome. Evidence Report/Technology Assessment No. 42 (Prepared by San Antonio Evidence-based Practice Center at the University of Texas Health Science Center at San Antonio under Contract No 290-97-0012). AHRQ Publication No. 01-EO61, September 2001. Rockville, MD: Agency for Healthcare Research and Quality.
2
3 Michiels V, Cluydts R. Neuropsychological functioning in chronic fatigue syndrome: A review. Acta Psychiatr Scand. 2001;103:84-93. [pmid: 11167310].
4 Chronic fatigue syndrome: Clinical practice guidelines - 2002. Med J Aust. 2002;176:S17-S55.
5 Jason LA, Richman JA, Rademaker AW, et al. A community-based study of chronic fatigue syndrome. Arch Intern Med. 1999;159:2129-37. [pmid: 10527290].
6 Report to the Chief Medical Officer of an independent working group. London: Department of Health, 2001. www.doh.gov.uk/cmo/cfsmereport/index.htm (accessed 14 Jan 2002).
7 Wessely S. The epidemiology of chronic fatigue syndrome. Epidemiol Rev. 1995;17:139-51. [pmid: 8521932].
8 Reid S, Chalder T, Cleare A, et al. Chronic fatigue syndrome. BMJ. 2000;320:292-6. [pmid: 10650029].
9 Evengard B, Schacterle RS, Komaroff AL. Chronic fatigue syndrome: New insights and old ignorance. J Intern Med. 1999;246:455-69. [pmid: 10583715].
10 Fukuda K, Straus S, Hickie I, et al. The chronic fatigue syndrome: A comprehensive approach to its definition and study. Ann Intern Med. 1994;121:953-9. [pmid: 7978722].
11 Holmes GP, Kaplan JE, Gantz NM, et al. Chronic fatigue syndrome: A working case definition. Ann Intern Med. 1988;108:387-9. [pmid: 2829679].
12 Sharpe MK, Archard LC, Banatvala JE, et al. A report - chronic fatigue syndrome: Guidelines for research. J R Soc Med. 1991;84:118-21. [pmid: 1999813].
13 Lloyd AR, Hickie I, Boughton CR, et al. Prevalence of chronic fatigue syndrome in an Australian population. Med J Aust. 1990;153:522-8. [pmid: 2233474].
14 Johnson SK, DeLuca J, Natelson BH. Chronic fatigue syndrome: Reviewing the research findings. Ann Behav Med. 1999;21:258-71. [pmid: 10626034].
15 Sumaya CV Serologic and virologic epidemiology of Epstein-Barr virus: Relevance to chronic fatigue syndrome Rev Infect Dis 1991 13Suppl 1:S19 25 1850540
16 Whiting P, Bagnall AM, Sowden AJ, et al. Interventions for the treatment and management of chronic fatigue syndrome: A systematic review. JAMA. 2001;286:1360-8. [pmid: 11560542].
17 Vercoulen JH, Swanink C, Zitman F, et al. Randomised, double-blind, placebo-controlled study of fluoxetine in chronic fatigue syndrome. Lancet. 1996;347:858-61. [pmid: 8622391].
18 Rowe PC, Calkins H, DeBusk K, et al. Fludrocortisone acetate to treat neurally mediated hypotension in chronic fatigue syndrome: A randomized controlled trial. JAMA. 2001;285:52-9. [pmid: 11150109].
19 McKenzie R, O'Fallon A, Dale J, et al. Low-dose hydrocortisone for treatment of chronic fatigue syndrome: A randomized controlled trial. JAMA. 1998;280:1061-6. [pmid: 9757853].
20 Peterson PK, Pheley A, Schroeppel J, et al. A preliminary placebo-controlled crossover trial of fludrocortisone for chronic fatigue syndrome. Arch Intern Med. 1998;158:908-14. [pmid: 9570178].
21 Friedberg F, Jason LA. Chronic fatigue syndrome and fibromyalgia: Clinical assessment and treatment. J Clin Psychol. 2001;57:433-55. [pmid: 11255201].
22 Prins JB, Bleijenberg G, Bazelmans E, et al. Cognitive behaviour therapy for chronic fatigue syndrome: A multicentre randomised controlled trial. Lancet. 2001;357:841-7. [pmid: 11265953].
23 Powell P, Bentall RP, Nye FJ, et al Randomised controlled trial of patient education to encourage graded exercise in chronic fatigue syndrome BMJ 2001 322(7283):387 90 26565 11179154
24 Mulrow CD, Oxman AD (eds). Cochrane Collaboration Handbook. The Cochrane Library. The Cochrane Collaboration; Issue 1. Oxford: Update Software; 1997. Updated quarterly.
25 Sacks HS, Berrier J, Reitman D, Pagano D, Chalmers T. Meta-analyses of randomized control trials: An update of the quality and methodology. In: Bailar JC III, Mosteller F, editors. Medical Uses of Statistics. 2nd Edition. Boston: NEJM Books. 1992:427-442.
26 Vercoulen JH, Swanink C, Fennis J, et al. Dimensional assessment of chronic fatigue syndrome. J Psychosom Res. 1994;38:383-92. [pmid: 7965927].
27 Bergner M, Bobbitt RA, Kressel S, et al. The Sickness Impact Profile: Conceptual formulation and methodology for the development of a health status measure. Int J Health Serv. 1976;6:393-415. [pmid: 955750].
28 Ware JE, Sherbourne CD. The MOS 36-item short-form health survey (SF-36). Medical Care. 1992;30:473-83. [pmid: 1593914].
29 Wechsler D. Wechsler Adult Intelligence Scale - Revised (WAIS-R). 1981. New York: Harcourt Brace. [pmcid: 281528].
30 Claypoole K, Mahurin R, Fischer ME, et al. Cognitive compromise following exercise in monozygotic twins discordant for chronic fatigue syndrome: Fact or artifact. Appl Neuropsychol. 2001;8:31-40. [pmid: 11388121].
31 Martin M. Human Learning. 1986;5:63-74.
32 Chalder T, Berelowitz G, Pawlikowska T, et al. Development of a fatigue scale. J Psychosom Res. 1993;37:147-53. [pmid: 8463991].
33 McNair DM, Lorr M, Droppelman LF. Profile of Mood States. San Diego, Calif: Educational and Industrial Testing Service. 1981. [pmcid: 281528].
34 Karnofsky DA, Burchenal JH. The clinical evaluation of chemotherapeutic agents in cancer. In: MacLeod CM, (ed.) Evaluation of Chemotherapeutic Agents: New York: New York Columbia University Press. 1949:p. 191-205.
35 Beck AT, Ward CH, Mendelson M, Mock J, Erbaugh J. An inventory for measuring depression. Arch Gen Psychiatry. 1961;4:561-71. [pmid: 13688369].
36 Derogatis LR, Melisaratos N. The brief symptom inventory. Psychological Medicine. 1983;13:595-605. [pmid: 6622612].
37 Wilson A, Hickie I, Hadzi-Pavlovic D, et al. What is chronic fatigue syndrome? Heterogeneity within an international multicentre study. Aust NZJ Psychiatry. 2001;35:520-7.
38 MacMahon K, Lip G. Psychological factors in heart failure: A review of the literature. Arch Intern Med. 2002;162:509-16. [pmid: 11871918].
39 Jadad AR, Moore A, Carroll D, et al. Assessing the quality of reports of randomized clinical trials: Is blinding necessary?. Controlled Clinical Trials. 1996;17:1-12. [pmid: 8721797].
40 Cruess S. Immunologic status correlates with severity of physical symptoms and perceived illness burden in chronic fatigue syndrome patients. J CFS. 2000;7:39-52.
41 Natelson BH, Johnson SK, DeLuca J, et al. Reducing heterogeneity in chronic fatigue syndrome: A comparison with depression and multiple sclerosis. Clin Infect Dis. 1995;21:1204-10. [pmid: 8589144].
42 Garcia-Borrequero D, Dale JK, Rosenthal NE, et al. Lack of seasonal variation of symptoms in patients with chronic fatigue syndrome. Psychiatry Res. 1998;77:71-7. [pmid: 9541142].
43 Kruesi MJ, Dale J, Straus SE. Psychiatric diagnoses in patients who have chronic fatigue syndrome. J Clin Psychiatry. 1989;50:53-6. [pmid: 2536690].
44 Shanks MF, Ho-Yen DO. A clinical study of chronic fatigue syndrome. Br J Psychiatry. 1995;166:798-801. [pmid: 7663831].
45 Bombardier CH, Buchwald D. Outcome and prognosis of patients with chronic fatigue vs. chronic fatigue syndrome. Arch Intern Med. 1995;155:2105-10. [pmid: 7575071].
46 Buchwald D, Pearlman T, Kith P, Schmaling K. Gender differences in patients with chronic fatigue syndrome. J Gen Intern Med. 1994;9:397-401. [pmid: 7931750].
47 Buchwald D, Pearlman T, Umali J, et al. Functional status in patients with chronic fatigue syndrome, other fatiguing illnessess, and healthy individuals. Am J Med. 1996;101:364-70. [pmid: 8873506].
48 MacDonald KL, Osterholm MT, LeDell KH, White KE, Schenck CH, Chao CC, et al. A case-control study to assess possible triggers and cofactors in chronic fatigue syndrome. Am J Med. 1996;100:548-54. [pmid: 8644768].
49 Lerner AM, Zervos M, Dworkin HJ, et al. New cardiomyopathy: Pilot study of intravenous ganciclovir in a subset of the chronic fatigue syndrome. Infect Agents Dis. 1997;6:110-7.
50 Lloyd AR, Gandevia S, Brockman A, et al. Cytokine production and fatigue in patients with chronic fatigue syndrome and healthy control subjects in response to exercise. Clin Infect Dis. 1994;18:S142-6. [pmid: 8148442].
51 Ray C, Phillips L, Weir W. Quality of attention in chronic fatigue syndrome: Subjective reports of everyday attention and cognitive difficulty, and performance on tasks of focused attention. Br J Clin Psychol. 1993;32:357-64. [pmid: 8251968].
52 Schmaling KB, Hamilos DL, DiClementi JD, et al. Pain perception in chronic fatigue syndrome. J CFS. 1998;4:13-22.
53 Vercoulen JH, Bazelmans E, Swanink CM, et al. Physical activity in chronic fatigue syndrome: Assessment and its role in fatigue. J Psychiatr Res. 1997;31:661-73. [pmid: 9447571].
54 Michiels V, Cluydts R, Fischler B, et al. Cognitive functioning in patients with chronic fatigue syndrome. J Clin Exp Neuropsychol. 1996;18:666-77. [pmid: 8941852].
55 Butler S, Chalder T, Ron M, et al. Cognitive behaviour therapy in chronic fatigue syndrome. J Neurol Neurosurg Psychiatry. 1991;54:153-8. [pmid: 2019842].
56 Deale A, Chalder T, Marks I, et al. Cognitive behavior therapy for chronic fatigue syndrojme: A randomized controlled trial. Am J Psychiatry. 1997;154:408-14. [pmid: 9054791].
57 Akagi H, Klimes I, Bass C. Cognitive behavioral therapy for chronic fatigue syndrome in a general hospital - feasible and effective. Gen Hosp Psychiatry. 2001;23:254-60. [pmid: 11600166].
58 Dyck D, Allen S, Barron J, et al. Management of chronic fatigue syndrome: Case study. AAOHN J. 1996;44:85-92. [pmid: 8694980].
59 Fulcher KY, White PD. Randomised controlled trial of graded exercise in patients with the chronic fatigue syndrome. BMJ. 1997;314:1647-52. [pmid: 9180065].
60 Marlin RG, Anchel H, Gibson JC, et al. An evaluation of multidisciplinary intervention for chronic fatigue syndrome with long-term follow-up, and a comparison with untreated controls. Am J Med. 1998;105:110S-4S. [pmid: 9790492].
61 Tiersky LA, DeLuca J, Hill N, et al. Longitudinal assessment of neuropsychological functioning, psychiatric status, functional disability and employment status in chronic fatigue syndrome. Appl Neuropsychol. 2001;8:41-50. [pmid: 11388123].
62 Peterson PK, Schenck CH, Sherman R. Chronic fatigue syndrome in Minnesota. Minn Med. 1991;74:21-6.
63 Saltzstein BJ, Wyshak G, Hubbuch JT, et al. A naturalistic study of the chronic fatigue syndrome among women in primary care. Gen Hosp Psychiatry. 1998;20:307-16. [pmid: 9788031].
64 Jason LA, Fricano G, Taylor RR, et al. Chronic fatigue syndrome: An examination of the phases. J Clin Psychol. 2000;56:1497-508. [pmid: 11132566].
65 Moss-Morris R, Petrie KJ. Discriminating between chronic fatigue syndrome and depression: A cognitive analysis. Psychol Med. 2001;31:469-79. [pmid: 11305855].
66 Straus SE. Caring for patients with chronic fatigue syndrome. BMJ. 2002;324:124-5. [pmid: 11799015].