# Appendix I. Rejected Studies Log

Rejection Reason: Abstract, letter, comment, review, editorial, case-report, meta-analysis

1. Abbey SE, Garfinkel PE. Chronic fatigue syndrome and depression: Cause, effect, or covariate. Rev Infect Dis 1991; 13:S73-83.
2. Ax S, Gregg VH, Jones D. Coping and illness cognitions: Chronic fatigue syndrome. Clin Psychol Rev 2001; 21:161-82.
3. Aylward M. Government's expert group has reached consensus on prognosis of chronic fatigue syndrome. BMJ 1996; 313:885.
4. Banks J, Prior L. Doing things with illness. The micro politics of the CFS clinic. Soc Sci Med 2001; 52:11-23.
5. Baschetti R. Fibromyalgia, chronic fatigue syndrome, and Addison disease. Arch Int Med 1999; 159:2481-3.
6. Borok G. Committee to investigate chronic fatigue syndrome. S Afr Med J 1996; 86:1301.
7. Brodsky CM. Depression and chronic fatigue in the workplace. Workers' compensation and occupational issues. Prim Care 1991; 18:381-96.
8. Buchwald D, Komaroff AL. Review of laboratory findings for patients with chronic fatigue syndrome. Rev Infect Dis 1991; 13:S12-8.
9. Capen K. Chronic fatigue syndrome gets court's nod of approval as legitimate disorder. CMAJ 1998; 159:533-4.
10. Chagpar A. Chronic fatigue syndrome: A prodrome to psychosis. Can J Psychiatry 1996; 41:536-7.
11. Chaudhuri A. Chronic fatigue syndrome is an acquired neurological channelopathy. Human Psychopharmacology 1999; 14:7-17.
12. Cleare AJ, Wessely SC. Chronic fatigue syndrome: A stress disorder. Br J Hosp Med 1996; 55:571-4.
13. Coetzer P, Lockyer I, Schorn D, Boshoff L. Assessing impairment and disability for syndromes presenting with chronic fatigue. J Insur Med 2001; 33:170-82.
14. Coetzer P, Lockyer I, Schorn D, Boshoff L. Quantitative disability evaluation of syndromes presenting with chronic fatigue. S Afr Med J 2000; 90:1034-52.
15. Cope H, David AS. Neuroimaging in chronic fatigue syndrome. J Neurol Neurosurg Psychiatry 1996; 60:471-3.
16. Couper J. Chronic fatigue syndrome and Australian psychiatry: Lessons from the UK experience. Aust N Z J Psychiatry 2000; 34:762-9.
17. Deale A, David AS. Chronic fatigue syndrome: Evaluation and management. J Neuropsychiatry Clin Neurosci 1994; 6:189-94.
18. Demitrack MA. Neuroendocrine aspects of chronic fatigue syndrome: A commentary. Am J Med 1998; 105:11S-4S.
19. Demitrack MA. Neuroendocrine correlates of chronic fatigue syndrome: A brief review. J Psychiatr Res 1997; 31:69-82.
20. Demitrack MA, Engleberg NC. Chronic fatigue syndrome. Curr Ther Endocrinol Metab 1997; 6:152-60.
21. Demitrack MA, Engleberg NC. Chronic fatigue syndrome. Curr Ther Endocrinol Metab 1994; 5:135-42.
22. Dickinson CJ. Chronic fatigue syndrome: Aetiological aspects. Eur J Clin Invest 1997; 27:257-67.
23. Dille JR. Chronic fatigue syndrome. Aviat Space Environ Med 1991; 62:1008-9.
24. DiPino RK, Kane RL. Neurocognitive functioning in chronic fatigue syndrome. Neuropsychol Rev 1996; 6:47-60.
25. Durlach J. Chronic fatigue syndrome and chronic primary magnesium deficiency (CFS and CPMD). Magnes Res 1992; 5:68.
26. Enserink M. Chronic fatigue syndrome: CDC struggles to recover from debacle over earmark. Science 2000; 287:22-3.
27. Evengard B, Schacterle RS, Komaroff AL. Chronic fatigue syndrome: New insights and old ignorance. J Intern Med 1999; 246:455-69.
28. Feinberg M. Chronic fatigue syndrome and the aviator. Aviat Space Environ Med 2000; 71:965.
29. Friedberg F, Jason LA. Chronic fatigue syndrome and fibromyalgia: Clinical assessment and treatment. J Clin Psychol 2001; 57:433-55.
30. Fry AM, Martin M. Fatigue in the chronic fatigue syndrome: A cognitive phenomenon? J Psychosom Res 1996; 41:415-26.
31. Fuller NS, Morrison RE. Chronic fatigue syndrome. Helping patients cope with this enigmatic illness. Postgrad Med 1998; 103:175-84.
32. Gantz NM, Coldsmith EE. Chronic fatigue syndrome and fibromyalgia resources on the World Wide Web: A descriptive journey. Clin Infect Dis 2001; 32:938-48.
33. Glaser R, Kiecolt-Glaser JK. Stress-associated immune modulation: Relevance to viral infections and chronic fatigue syndrome. Am J Med 1998; 105:35S-42S.
34. Goshorn RK. Chronic fatigue syndrome: A review for clinicians. Semin Neurol 1998; 18:237-42.
35. Hedrick TE. Chronic fatigue syndrome. QJM 1997; 90:723-5.
36. Holoweiko M. Holding the line on elusive ailments. Bus Health 1996; 14:30-7.
37. Hotopf M, Wessely S. Chronic fatigue syndrome: Mapping the interior. Psychol Med 1999; 29:255-8.
38. Jain SS, DeLisa JA. Chronic fatigue syndrome: A literature review from a physiatric perspective. Am J Phys Med Rehabil 1998; 77:160-7.
39. Jason LA, King CP, Frankenberry EL, Jordan KM, Tryon WW, Rademaker F, et al. Chronic fatigue syndrome: Assessing symptoms and activity level. J Clin Psychol 1999; 55:411-24.
40. Jason LA, Melrose H, Lerman A, Burroughs V, Lewis K, King CP, et al. Managing chronic fatigue syndrome: Overview and case study. AAOHN J 1999; 47:17-21.
41. Jason LA, Richman JA, Friedberg F, Wagner L, Taylor R, Jordan KM. Politics, science, and the emergence of a new disease. The case of chronic fatigue syndrome. Am Psychol 1997; 52:973-83.
42. Jason LA, Taylor SL. Monitoring chronic fatigue syndrome. J Nerv Ment Dis 1994; 182:243-4.
43. Jason LA, Tryon WW, Taylor RR, King C, Frankenberry EL, Jordan KM. Monitoring and assessing symptoms of chronic fatigue syndrome: Use of time series regression. Psychol Rep 1999; 85:121-30.
44. Jay SJ. Orthostatic hypotension and chronic fatigue syndrome. JAMA 2001; 285:1442-3.
45. Johnson SK. The biopsychosocial model and chronic fatigue syndrome. Am Psychol 1998; 53:1080-2.
46. Johnson SK, DeLuca J, Natelson BH. Chronic fatigue syndrome: Reviewing the research findings. Ann Behav Med 1999; 21:258-71.
47. Joyce J, Hotopf M, Wessely S. The prognosis of chronic fatigue and chronic fatigue syndrome: A systematic review. QJM 1997; 90:223-33.
48. Joyce J, Rabe-Hesketh S, Wessely S. Reviewing the reviews: The example of chronic fatigue syndrome. JAMA 1998; 280:264-6.
49. Kahn MF. Chronic fatigue syndrome. New developments. Joint Bone Spine 2000; 67:359-61.
50. Keenan PA. Brain MRI abnormalities exist in chronic fatigue syndrome. J Neurol Sci 1999; 171:1-2.
51. Komaroff AL, Buchwald DS. Chronic fatigue syndrome: An update. Annu Rev Med 1998; 49:1-13.
52. Kroenke K, Swindle R. Cognitive-behavioral therapy for somatization and symptom syndromes: A critical review of controlled clinical trials. Psychother Psychosom 2000; 69:205-15.
53. Krupp LB, Pollina D. Neuroimmune and neuropsychiatric aspects of chronic fatigue syndrome. Adv Neuroimmunol 1996; 6:155-67.
54. Lange G, Wang S, DeLuca J, Natelson BH. Neuroimaging in chronic fatigue syndrome. Am J Med 1998; 105:50S-3S.
55. Lawrie SM, MacHale SM, Power MJ, Goodwin GM. Is the chronic fatigue syndrome best understood as a primary disturbance of the sense of effort. Psychol Med 1997; 27:995-9.
56. Layzer RB. Asthenia and the chronic fatigue syndrome. Muscle Nerve 1998; 21:1609-11.
57. Levine PH. What we know about chronic fatigue syndrome and its relevance to the practicing physician. Am J Med 1998; 105:100S-3S.
58. Levine PH. Epidemiologic advances in chronic fatigue syndrome. J Psychiatr Res 1997; 31:7-18.
59. Levine PH. The use of transfer factors in chronic fatigue syndrome: Prospects and problems. Biotherapy 1996; 9:77-9.
60. Lewis SF, Haller RG. Physiologic measurement of exercise and fatigue with special reference to chronic fatigue syndrome. Rev Infect Dis 1991; 13 Suppl 1:S98-108.
61. Lloyd AR. Chronic fatigue and chronic fatigue syndrome: Shifting boundaries and attributions. Am J Med 1998; 105:7S-10S.
62. Lloyd AR, Hickie I, Peterson PK. Chronic fatigue syndrome: Current concepts of pathogenesis and treatment. Curr Clin Top Infect Dis 1999; 19:135-59.
63. Loblay RH. Chronic fatigue syndrome. Lancet 1998; 351:1292.
64. McCluskey DR. Chronic fatigue syndrome: Its cause and a strategy for management. Compr Ther 1998; 24:357-63.
65. McCully KK, Sisto SA, Natelson BH. Use of exercise for treatment of chronic fatigue syndrome. Sports Med 1996; 21:35-48.
66. Meisler JG, Klimas N, Wallace M. Toward optimal health: The experts discuss chronic fatigue syndrome. J Womens Health Gend Based Med 2000; 9:477-82.
67. Michiels V, Cluydts R. Neuropsychological functioning in chronic fatigue syndrome: A review. Acta Psychiatr Scand 2001; 103:84-93.
68. Mildon CA. Clinical observations of chronic fatigue syndrome. Can Dis Wkly Rep 1991; 17 Suppl 1E: 17-9.
69. Moss-Morris R, Petrie KJ, Large RG, Kydd RR. Neuropsychological deficits in chronic fatigue syndrome: Artifact or reality. J Neurol Neurosurg Psychiatry 1996; 60:474-7.
70. Mounstephen A, Sharpe M. Chronic fatigue syndrome and occupational health. Occup Med 1997; 47:217-27.
71. Mulube M. Myths dispelled about chronic fatigue syndrome. BMJ 1996; 313:839.
72. Munson P. Criminal language and poetic jailbreak: Writing chronic fatigue immune dysfunction syndrome. Lit Med 2000; 19:19-24.
73. Murtagh J. Patient education. Chronic fatigue syndrome. Aust Fam Physician 1995; 24:1297.
74. Natelson BH. Chronic fatigue syndrome. JAMA 2001; 285:2557-9.
75. Neeck G, Crofford LJ. Neuroendocrine perturbations in fibromyalgia and chronic fatigue syndrome. Rheum Dis Clin North Am 2000; 26:989-1002.
76. No Author Listed. Chronic fatigue syndrome: Any closer to an answer. Consum Rep 1996; 61:60-1.
77. Pagani M, Lucini D. Chronic fatigue syndrome: A hypothesis focusing on the autonomic nervous system. Clin Sci (Colch) 1999; 96:117-25.
78. Pearn J. Differential diagnosis: The challenge of chronic fatigue. J CFS 2000; 7:17-31.
79. Poole CJM. Guidance on ill health retirement. Br J Rheumatol 1997; 36:573-6.
80. Poole CJM, Baron CE, Gunnyeon WJ, Ohanlon M, Raoof A, Robson SA, et al. Ill health retirement - Guidelines for occupational physicians. Occup Med 1996; 46:402-6.
81. Price JR, Couper J. Cognitive behaviour therapy for chronic fatigue syndrome in adults (Cochrane Review). Cochrane Database Syst Rev 2001; 1-29.
82. Ray C, Weir W, Stewart D, Miller P, Hyde G. Ways of coping with chronic fatigue syndrome: Development of an illness management questionnaire. Soc Sci Med 1993; 37:385-91.
83. Reid S, Chalder T, Cleare A, Hotopf M, Wessely S. Chronic fatigue syndrome. BMJ 2000; 320:292-6.
84. Richman JA, Jason LA, Taylor RR, Jahn SC. Feminist perspectives on the social construction of chronic fatigue syndrome. Health Care Women Int 2000; 21:173-85.
85. Salit IE. The chronic fatigue syndrome: A position paper. J Rheumatol 1996; 23:540-4.
86. Schondorf R, Freeman R. The importance of orthostatic intolerance in the chronic fatigue syndrome. Am J Med Sci 1999; 317:117-23.
87. Sharpe M. Cognitive behavior therapy for chronic fatigue syndrome: Efficacy and implications. Am J Med 1998; 105:104S-9S.
88. Sharpe M. Cognitive behavior therapy for functional somatic complaints: The example of chronic fatigue syndrome. Psychosomatics 1997; 38:356-62.
89. Sharpe M. Chronic fatigue syndrome. Psychiatr Clin North Am 1996; 19:549-73.
90. Sharpe M. Non-pharmacological approaches to treatment. Ciba Found Symp 1993; 173:298-308.
91. Sharpe M, Chalder T, Palmer I, Wessely S. Chronic fatigue syndrome: A practical guide to assessment and management. Gen Hosp Psychiatry 1997; 19:185-99.
92. Sharpe MC, Archard LC, Banatvala JE, Borysiewicz LK, Clare AW, David A, et al. A report - chronic fatigue syndrome: Guidelines for research. J R Soc Med 1991; 84:118-21.
93. Shephard RJ. Chronic fatigue syndrome: An update. Sports Med 1901; 31:167-94.
94. Shepherd C. Chronic fatigue syndrome. Lancet 1997; 349:57-8.
95. Shlaes JL, Jason LA, Ferrari JR. The development of the chronic fatigue syndrome attitudes test: A psychometric analysis. Eval Health Prof 1999; 22:442-65.
96. Sibbald B. Chronic fatigue syndrome comes out of the closet. CMAJ 1998; 159:537-41.
97. Snell CR, Stevens SR, VanNess JM. Chronic fatigue syndrome, ampligen, and quality of life: A phenomenological perspective. J CFS 2001; 8:117-21.
98. Social Security Administration. Social Security Ruling, SSR 99-2p.; Titles II and XVI: Evaluating cases involving chronic fatigue syndrome (CFS). Fed Regist 1999; 64:23380-4.
99. Stoner BP, Corey GR. Chronic fatigue syndrome. A practical approach. N C Med J 1992; 53:267-70.
100. Straus SE. Chronic fatigue syndrome: "Biophysical approach" may be difficult in practice. BMJ 1996; 313:831-2.
101. Streeten DHP. The nature of chronic fatigue. JAMA 1998; 280:1094-5.
102. Tattam A. CFS: An occupational hazard for nurses. Aust Nurs J 1994; 2:21-2.
103. Tiersky LA, Johnson SK, Lange G, Natelson BH, DeLuca J. Neuropsychology of chronic fatigue syndrome: A critical review. J Clin Exp Neuropsychol 1997; 19:560-86.
104. van Middendorp H, Geenen R, Kuis W, Heijnen CJ, Sinnema G. Psychological adjustment of adolescent girls with chronic fatigue syndrome. Pediatrics 2001; 107:E35.
105. Vollmer-Conna U, Lloyd A, Hickie I, Wakefield D. Chronic fatigue syndrome: An immunological perspective. Aust N Z J Psychiatry 1998; 32:523-7.
106. Wagenmakers AJM. Chronic fatigue syndrome: The physiology of people on the low end of the spectrum of physical activity. Clin Sci (Colch) 1999; 97:611-3.
107. Walker TL. Chronic fatigue syndrome. Do you know what it means. Am J Nurs 1999; 99:70-6.
108. Ware NC, Kleinman A. Culture and somatic experience: The social course of illness in neurasthenia and chronic fatigue syndrome. Psychosom Med 1992; 54:546-60.
109. Wearden AJ, Appleby L. Research on cognitive complaints and cognitive functioning in patients with chronic fatigue syndrome (CFS): What conclusions can we draw. J Psychosom Res 1996; 41:197-211.
110. Wessely S. Chronic fatigue: Symptom and syndrome. Ann Intern Med 2001; 134:838-43.
111. Wessely S. Chronic fatigue syndrome: Summary of a report of a joint committee of the Royal Colleges of Physicians, Psychiatrists and General Practitioners. J R Coll Physicians Lond 1996; 30:497-504.
112. White PD. The role of physical inactivity in the chronic fatigue syndrome. J Psychosom Res 2000; 49:283-4.
113. Whiting P, Bagnall AM, Sowden AJ, Cornell JE, Mulrow CD, Ramirez G. Interventions for the treatment and management of chronic fatigue syndrome: A systematic review. JAMA 2001; 286:1360-8.
114. Wilke WS, Fouad-Tarazi FM, Cash JM, Calabrese LH. The connection between chronic fatigue syndrome and neurally mediated hypotension. Cleve Clin J Med 1998; 65:261-6.
115. Wilson A, Hickie I, Lloyd A, Wakefield D. The treatment of chronic fatigue syndrome: Science and speculation. Am J Med 1994; 96:544-50.

Rejection Reason: Accepted CFS diagnostic criteria not defined or fulfilled

1. Ax S, Gregg VH, Jones D. Chronic fatigue syndrome: Illness attributions and perceptions of control. Homeostasis in Health & Disease 1998; 39:44-51.
2. Ax S, Gregg VH, Jones D. Chronic fatigue syndrome: Sufferers' evaluation of medical support. J R Soc Med 1997; 90:250-4.
3. Bazelmans E, Vercoulen JH, Swanink CM, Fennis JF, Galama JM, van Weel C, et al. Chronic fatigue syndrome and primary fibromyalgia syndrome as recognized by GPs. Fam Pract 1999; 16:602-4.
4. Beh HC, Connelly N, Charles M. Effect of noise stress on chronic fatigue syndrome patients. J Nerv Ment Dis 1997; 185:55-8.
5. Blakely AA, Howard RC, Sosich RM, Murdoch JC, Menkes DB, Spears GF. Psychiatric symptoms, personality and ways of coping in chronic fatigue syndrome. Psychol Med 1991; 21:347-62.
6. Bottero P. Role of rickettsiae and chlamydiae in the psychopathology of chronic fatigue syndrome (CFS) patients: A diagnostic and therapeutic report. J CFS 2000; 6:147-61.
7. Clarke JN. Chronic fatigue syndrome: Gender differences in the search for legitimacy. Aust N Z J Ment Health Nurs 1999; 8:123-33.
8. Daugherty SA, Henry BE, Peterson DL, Swarts RL, Bastien S, Thomas RS. Chronic fatigue syndrome in northern Nevada. Rev Infect Dis 1991; 13:S39-44.
9. Findley JC, Kerns R, Weinberg LD, Rosenberg R. Self-efficacy as a psychological moderator of chronic fatigue syndrome. J Behav Med 1998; 21:351-62.
10. Goodwin SS. Couples' perceptions of wives' CFS symptoms, symptom change, and impact on the marital relationship. Issues Ment Health Nurs 2000; 21:347-63.
11. Hamilton WT, Hall GH, Round AP. Frequency of attendance in general practice and symptoms before development of chronic fatigue syndrome: A case-control study. Br J Gen Pract 2001; 51:553-8.
12. Hartz AJ, Kuhn EM, Levine PH. Characteristics of fatigued persons associated with features of chronic fatigue syndrome. J CFS 1998; 4:71-97.
13. Heijmans MJ. Coping and adaptive outcome in chronic fatigue syndrome: Importance of illness cognitions. J Psychosom Res 1998; 45:39-51.
14. Hickie I, Lloyd A, Wakefield D. Immunological and psychological dysfunction in patients receiving immunotherapy for chronic fatigue syndrome. Aust N Z J Psychiatry 1992; 26:249-56.
15. Hoeck AD. Divalent cations, hormones, psyche and soma: Four case reports. J CFS 2000; 6:117-31.
16. Jason LA, Fennell PA, Taylor RR, Fricano G, Halpert JA. An empirical verification of the Fennell phases of the CFS illness. J CFS 2000; 6:47-56.
17. Jason LA, Ferrari JR, Taylor RR, Slavich SP, Stenzel CL. A national assessment of the service, support, and housing preferences by persons with chronic fatigue syndrome. Toward a comprehensive rehabilitation program. Eval Health Prof 1996; 19:194-207.
18. Katon W, Russo J. Chronic fatigue syndrome criteria. A critique of the requirement for multiple physical complaints. Arch Intern Med 1992; 152:1604-9.
19. Levine PH, Jacobson S, Pocinki AG, Cheney P, Peterson D, Connelly RR, et al. Clinical, epidemiologic, and virologic studies in four clusters of the chronic fatigue syndrome. Arch Intern Med 1992; 152:1611-6.
20. Lloyd A, Hickie I, Wakefield D, Boughton C, Dwyer J. A double-blind, placebo-controlled trial of intravenous immunoglobulin therapy in patients with chronic fatigue syndrome. Am J Med 1990; 89:561-8.
21. Lloyd AR, Gandevia SC, Hales JP. Muscle performance, voluntary activation, twitch properties and perceived effort in normal subjects and patients with the chronic fatigue syndrome. Brain 1991; 114:85-98.
22. Lloyd AR, Hickie I, Brockman A, Hickie C, Wilson A, Dwyer J, et al. Immunologic and psychologic therapy for patients with chronic fatigue syndrome: A double-blind, placebo-controlled trial. Am J Med 1993; 94:197-203.
23. Manu P, Lane TJ, Matthews DA, Castriotta RJ, Watson RK, Abeles M. Alpha-delta sleep in patients with a chief complaint of chronic fatigue. South Med J 1994; 87:465-70.
24. Montague TJ, Marrie TJ, Klassen GA, Bewick DJ, Horacek BM. Cardiac function at rest and with exercise in the chronic fatigue syndrome. Chest 1989; 95:779-84.
25. Packer TL, Sauriol A, Brouwer B. Fatigue secondary to chronic illness: Postpolio syndrome, chronic fatigue syndrome, and multiple sclerosis. Arch Phys Med Rehabil 1994; 75:1122-6.
26. Petrie K, Moss-Morris R, Weinman J. The impact of catastrophic beliefs on functioning in chronic fatigue syndrome. J Psychosom Res 1995; 39:31-7.
27. Ray C, Weir WR, Cullen S, Phillips S. Illness perception and symptom components in chronic fatigue syndrome. J Psychosom Res 1992; 36:243-56.
28. Rowe PC, Calkins H. Neurally mediated hypotension and chronic fatigue syndrome. Am J Med 1998; 105:15S-21S.
29. Schaefer KM. Sleep disturbances and fatigue in women with fibromyalgia and chronic fatigue syndrome. J Obstet Gynecol Neonatal Nurs 1995; 24:229-33.
30. Schweitzer R, Kelly B, Foran A, Terry D, Whiting J. Quality of life in chronic fatigue syndrome. Soc Sci Med 1995; 41:1367-72.
31. Soderlund A, Skoge AM, Malterud K. "I could not lift my arm holding the fork...". Living with chronic fatigue syndrome. Scand J Prim Health Care 2000; 18:165-9.
32. Stark FM, Sobetzko HM. Approaches to coping with chronic fatigue syndrome (CFS). Zentralbl Hyg Umweltmed 1999; 202:179-90.
33. Tuck I, Human N. The experience of living with chronic fatigue syndrome. J Psychosoc Nurs Ment Health Serv 1998; 36:15-9.
34. Tuck I, Wallace D, Casalnuova G, May B. Psychosocial response of sufferers of chronic fatigue syndrome. J CFS 2000; 7:49-63.
35. Twemlow SW, Bradshaw SLJ, Coyne L, Lerma BH. Patterns of utilization of medical care and perceptions of the relationship between doctor and patient with chronic illness including chronic fatigue syndrome. Psychol Rep 1997; 80:643-58.
36. Whelton CL, Salit I, Moldofsky H. Sleep, Epstein-Barr virus infection, musculoskeletal pain, and depressive symptoms in chronic fatigue syndrome. J Rheumatol 1992; 19:939-43.
37. Williams G, Pirmohamed J, Minors D, Waterhouse J, Buchan I, Arendt J, et al. Dissociation of body-temperature and melatonin secretion circadian rhythms in patients with chronic fatigue syndrome. Clin Physiol 1996; 16:327-37.
38. Wilson A, Hickie I, Lloyd A, Hadzi-Pavlovic D, Boughton C, Dwyer J, et al. Longitudinal study of outcome of chronic fatigue syndrome. BMJ 1994; 308:756-9.
39. Wilson A, Hickie I, Lloyd A, Hadzi-Pavlovic D, Wakefield D. Cell-mediated immune function and the outcome of chronic fatigue syndrome. Int J Immunopharmacol 1995; 17:691-4.

Rejection Reason: Adult CFS patients not separately extractable

1. Lloyd AR, Hickie I, Boughton CR, Spencer O, Wakefield D. Prevalence of chronic fatigue syndrome in an Australian population. Med J Aust 1990; 153:522-8.
2. Lloyd AR, Pender H. The economic impact of chronic fatigue syndrome. Med J Aust 1992; 157:599-601.

Rejection Reason: CFS population mixed with other populations

1. Cope H, Pernet A, Kendall B, David A. Cognitive functioning and magnetic resonance imaging in chronic fatigue. Br J Psychiatry 1995; 167:86-94.
2. Hotopf M, Noah N, Wessely S. Chronic fatigue and minor psychiatric morbidity after viral meningitis: A controlled study. J Neurol Neurosurg Psychiatry 1996; 60:504-9.
3. Morriss RK, Ahmed M, Wearden AJ, Mullis R, Strickland P, Appleby L, et al. The role of depression in pain, psychophysiological syndromes and medically unexplained symptoms associated with chronic fatigue syndrome. J Affect Disord 1999; 55:143-8.
4. Van Houdenhove B, Neerinckx E, Lysens R, Vertommen H, Van Houdenhove L, Onghena P, et al. Victimization in chronic fatigue syndrome and fibromyalgia in tertiary care: A controlled study on prevalence and characteristics. Psychosomatics 2001; 42:21-8.
5. White KP, Speechley M, Harth M, Ostbye T. Co-existence of chronic fatigue syndrome with fibromyalgia syndrome in the general population. A controlled study. Scand J Rheumatol 2000; 29:44-51.

Rejection Reason: No outcome related to disability

1. Johnson SK, DeLuca J, Natelson BH. Assessing somatization disorder in the chronic fatigue syndrome. Psychosom Med 1996; 58:50-7.

Rejection Reason: No work data

1. Aaron LA, Burke MM, Buchwald D. Overlapping conditions among patients with chronic fatigue syndrome, fibromyalgia, and temporomandibular disorder. Arch Int Med 2000; 160:221-7.
2. Abu-Judeh HH, Levine S, Kumar M, el-Zeftawy H, Naddaf S, Lou JQ, et al. Comparison of SPET brain perfusion and 18F-FDG brain metabolism in patients with chronic fatigue syndrome. Nucl Med Commun 1998; 19:1065-71.
3. Afari N, Schmaling KB, Herrell R, Hartman S, Goldberg J, Buchwald DS. Coping strategies in twins with chronic fatigue and chronic fatigue syndrome. J Psychosom Res 2000; 48:547-54.
4. Bazelmans E, Bleijenberg G, van der Meer JW, Folgering H. Is physical deconditioning a perpetuating factor in chronic fatigue syndrome? A controlled study on maximal exercise performance and relations with fatigue, impairment and physical activity. Psychol Med 2001; 31:107-14.
5. Blackwood SK, MacHale SM, Power MJ, Goodwin GM, Lawrie SM. Effects of exercise on cognitive and motor function in chronic fatigue syndrome and depression. J Neurol Neurosurg Psychiatry 1998; 65:541-6.
6. Blenkiron P, Edwards R, Lynch S. Associations between perfectionism, mood, and fatigue in chronic fatigue syndrome: A pilot study. J Nerv Ment Dis 1999; 187:566-70.
7. Bonner D, Ron M, Chalder T, Butler S, Wessely S. Chronic fatigue syndrome: A follow up study. J Neurol Neurosurg Psychiatry 1994; 57:617-21.
8. Borish L, Schmaling K, DiClementi JD, Streib J, Negri J, Jones JF, et al. Chronic fatigue syndrome: Identification of distinct subgroups on the basis of allergy and psychologic variables. J Allergy Clin Immunol 1998; 102:222-30.
9. Brooks JC, Roberts N, Whitehouse G, Majeed T. Proton magnetic resonance spectroscopy and morphometry of the hippocampus in chronic fatigue syndrome. Br J Radiol 2000; 73:1206-8.
10. Buchwald D, Herrell R, Ashton S, Belcourt M, Schmaling K, Goldberg J. The Chronic Fatigue Twin Registry: Method of construction, composition, and zygosity assignment. Twin Res 1999; 2:203-11.
11. Buchwald D, Pascualy R, Bombardier C, Kith P. Sleep disorders in patients with chronic fatigue. Clin Infect Dis 1994; 18:S68-72.
12. Butler JA, Chalder T, Wessely S. Causal attributions for somatic sensations in patients with chronic fatigue syndrome and their partners. Psychol Med 2001; 31:97-105.
13. Christodoulou C, DeLuca J, Lange G, Johnson SK, Sisto SA, Korn L, et al. Relation between neuropsychological impairment and functional disability in patients with chronic fatigue syndrome. J Neurol Neurosurg Psychiatry 1998; 64:431-4.
14. Clapp LL, Richardson MT, Smith JF, Wang M, Clapp AJ, Pieroni RE. Acute effects of thirty minutes of light-intensity, intermittent exercise on patients with chronic fatigue syndrome. Physical Therapy 1999; 79:749-56.
15. Cleare AJ, Blair D, Chambers S, Wessely S. Urinary free cortisol in chronic fatigue syndrome. Am J Psychiatry 2001; 158:641-3.
16. Clements A, Sharpe M, Simkin S, Borrill J, Hawton K. Chronic fatigue syndrome: A qualitative investigation of patients' beliefs about the illness. J Psychosom Res 1997; 42:615-24.
17. Cook DB, Lange G, DeLuca J, Natelson BH. Relationship of brain MRI abnormalities and physical functional status in chronic fatigue syndrome. Int J Neurosci 2001; 107:1-6.
18. Coutts R, Weatherby R, Davie A. The use of a symptom "self-report" inventory to evaluate the acceptability and efficacy of a walking program for patients suffering with chronic fatigue syndrome. J Psychosom Res 2001; 51:425-9.
19. Cox IM, Campbell MJ, Dowson D. Red blood cell magnesium and chronic fatigue syndrome. Lancet 1991; 337:757-60.
20. Cukor D, Tiersky L, Natelson B. Psychiatric comorbidity and somatic distress in sudden and gradual onset chronic fatigue syndrome. J CFS 2000; 7:33-44.
21. Davey NJ, Puri BK, Nowicky AV, Main J, Zaman R. Voluntary motor function in patients with chronic fatigue syndrome. J Psychosom Res 2001; 50:17-20.
22. De Becker P, Dendale P, De Meirleir K, Campine I, Vandenborne K, Hagers Y. Autonomic testing in patients with chronic fatigue syndrome. Am J Med 1998; 105:22S-6S.
23. De Becker P, McGregor N, De Meirleir K. A definition-based analysis of symptoms in a large cohort of patients with chronic fatigue syndrome. J Intern Med 2001; 250:234-40.
24. De Becker P, Roeykens J, Reynders M, McGregor N, De Meirleir K. Exercise capacity in chronic fatigue syndrome. Arch Int Med 2000; 160:3270-7.
25. De Lorenzo F, Hargreaves J, Kakkar VV. Lung function test findings in patients with chronic fatigue syndrome (CFS). Aust N Z J Med 1996; 26:563-4.
26. De Lorenzo F, Xiao H, Mukherjee M, Harcup J, Suleiman S, Kadziola Z, et al. Chronic fatigue syndrome: Physical and cardiovascular deconditioning. QJM 1998; 91:475-81.
27. Deale A, Chalder T, Wessely S. Illness beliefs and treatment outcome in chronic fatigue syndrome. J Psychosom Res 1998; 45:77-83.
28. Deale A, Wessely S. Patients' perceptions of medical care in chronic fatigue syndrome. Soc Sci Med 2001; 52:1859-64.
29. Deale A, Wessely S. Diagnosis of psychiatric disorder in clinical evaluation of chronic fatigue syndrome. J R Soc Med 2000; 93:310-2.
30. DeLuca J, Johnson SK, Beldowicz D, Natelson BH. Neuropsychological impairments in chronic fatigue syndrome, multiple sclerosis, and depression. J Neurol Neurosurg Psychiatry 1995; 58:38-43.
31. DeLuca J, Johnson SK, Ellis SP, Natelson BH. Cognitive functioning is impaired in patients with chronic fatigue syndrome devoid of psychiatric disease. J Neurol Neurosurg Psychiatry 1997; 62:151-5.
32. DeLuca J, Johnson SK, Ellis SP, Natelson BH. Sudden vs. gradual onset of chronic fatigue syndrome differentiates individuals on cognitive and psychiatric measures. J Psychiatr Res 1997; 31:83-90.
33. DeLuca J, Johnson SK, Natelson BH. Information processing efficiency in chronic fatigue syndrome and multiple sclerosis. Arch Neurol 1993; 50:301-4.
34. Dobbs BM, Dobbs AR, Kiss I. Working memory deficits associated with chronic fatigue syndrome. J Int Neuropsychol Soc 2001; 7:285-93.
35. Dworkin HJ, Lawrie C, Bohdiewicz P, Lerner AM. Abnormal left ventricular myocardial dynamics in eleven patients with chronic fatigue syndrome. Clin Nucl Med 1994; 19:675-7.
36. Edwards R, Suresh R, Lynch S, Clarkson P, Stanley P. Illness perceptions and mood in chronic fatigue syndrome. J Psychosom Res 2001; 50:65-8.
37. Endicott NA. Chronic fatigue syndrome in psychiatric patients: Evidence of premorbid anomalous patterns of brain organization. J CFS 1999; 5:29-45.
38. Endicott NA. Chronic fatigue syndrome in psychiatric patients: Lifetime and premorbid personal history of physical health. Psychosom Med 1998; 60:744-51.
39. Euga R, Chalder T, Deale A, Wessely S. A comparison of the characteristics of chronic fatigue syndrome in primary and tertiary care. Br J Psychiatry 1996; 168:121-6.
40. Farmer A, Chubb H, Jones I, Hillier J, Smith A, Borysiewicz L. Screening for psychiatric morbidity in subjects presenting with chronic fatigue syndrome. Br J Psychiatry 1996; 168:354-8.
41. Fischler B, Dendale P, Michiels V, Cluydts R, Kaufman L, De Meirleir K. Physical fatigability and exercise capacity in chronic fatigue syndrome: Association with disability, somatization and psychopathology. J Psychosom Res 1997; 42:369-78.
42. Fischler B, Le Bon O, Hoffmann G, Cluydts R, Kaufman L, De Meirleir K. Sleep anomalies in the chronic fatigue syndrome. A comorbidity study. Neuropsychobiology 1997; 35:115-22.
43. Forsyth LM, Preuss HG, MacDowell AL, Chiazze LJ, Birkmayer GD, Bellanti JA. Therapeutic effects of oral NADH on the symptoms of patients with chronic fatigue syndrome. Ann Allergy Asthma Immunol 1999; 82:185-91.
44. Friedberg F, Krupp LB. A comparison of cognitive behavioral treatment for chronic fatigue syndrome and primary depression. Clin Infect Dis 1994; 18:S105-10.
45. Fuentes K, Hunter MA, Strauss E, Hultsch DF. Intraindividual variability in cognitive performance in persons with chronic fatigue syndrome. Clin Neuropsychol 2001; 15:210-27.
46. Gibson H, Carroll N, Clague JE, Edwards RH. Exercise performance and fatiguability in patients with chronic fatigue syndrome. J Neurol Neurosurg Psychiatry 1993; 56:993-8.
47. Grafman J, Schwartz V, Dale JK, Scheffers M, Houser C, Straus SE. Analysis of neuropsychological functioning in patients with chronic fatigue syndrome. J Neurol Neurosurg Psychiatry 1993; 56:684-9.
48. Greco A, Tannock C, Brostoff J, Costa DC. Brain MR in chronic fatigue syndrome. Am J Neuroradiol 1997; 18:1265-9.
49. Hall GH, Hamilton WT, Round AP. Increased illness experience preceding chronic fatigue syndrome: A case control study. J R Coll Physicians Lond 1998; 32:44-8.
50. Hardt J, Buchwald D, Wilks D, Sharpe M, Nix WA, Egle UT. Health-related quality of life in patients with chronic fatigue syndrome: An international study. J Psychosom Res 2001; 51:431-4.
51. Harlow BL, Signorello LB, Hall JE, Dailey C, Komaroff AL. Reproductive correlates of chronic fatigue syndrome. Am J Med 1998; 105:94S-9S.
52. Hart B, Grace VM. Fatigue in chronic fatigue syndrome: A discourse analysis of women's experiential narratives. Health Care Women Int 2000; 21:187-201.
53. Hassan IS, Bannister BA, Akbar A, Weir W, Bofill M. A study of the immunology of the chronic fatigue syndrome: Correlation of immunologic parameters to health dysfunction. Clin Immunol Immunopathol 1998; 87:60-7.
54. Hickie I. Nefazodone for patients with chronic fatigue syndrome. Aust N Z J Psychiatry 1999; 33:278-80.
55. Hickie IB, Wilson AJ, Wright JM, Bennett BK, Wakefield D, Lloyd AR. A randomized, double-blind placebo-controlled trial of moclobemide in patients with chronic fatigue syndrome. J Clin Psychiatry 2000; 61:643-8.
56. Himmel PB, Seligman TM. A pilot study employing dehydroepiandrosterone (DHEA) in the treatment of chronic fatigue syndrome. J Clin Rheumatol 1999; 5:56-9.
57. Hudson M, Cleare AJ. The 1microg short Synacthen test in chronic fatigue syndrome. Clin Endocrinol 1999; 51:625-30.
58. Inbar O, Dlin R, Rotstein A, Whipp BJ. Physiological responses to incremental exercise in patients with chronic fatigue syndrome. Med Sci Sports Exerc 2001; 33:1463-70.
59. Johnson SK, DeLuca J, Natelson BH. Personality dimensions in the chronic fatigue syndrome: A comparison with multiple sclerosis and depression. J Psychiatr Res 1996; 30:9-20.
60. Johnson SK, Lange G, Tiersky L, DeLuca J, Natelson BH. Health-related personality variables in chronic fatigue syndrome and multiple sclerosis. J CFS 2001; 8:43-52.
61. Joyce E, Blumenthal S, Wessely S. Memory, attention, and executive function in chronic fatigue syndrome. J Neurol Neurosurg Psychiatry 1996; 60:495-503.
62. Kane RL, Gantz NM, DiPino RK. Neuropsychological and psychological functioning in chronic fatigue syndrome. Neuropsychiatry Neuropsychol Behav Neurol 1997; 10:25-31.
63. Kaslow JE, Rucker L, Onishi R. Liver extract-folic acid-cyanocobalamin vs. placebo for chronic fatigue syndrome. Arch Intern Med 1989; 149:2501-3.
64. Katon WJ, Buchwald DS, Simon GE, Russo JE, Mease PJ. Psychiatric illness in patients with chronic fatigue and those with rheumatoid arthritis. J Gen Intern Med 1991; 6:277-85.
65. Kent-Braun JA, Sharma KB, Weiner MW, Massie B, Miller RG. Central basis of muscle fatigue in chronic fatigue syndrome. Neurology 1993; 43:125-31.
66. Komaroff AL, Fagioli LR, Doolittle TH, Gandek B, Gleit MA, Guerriero RT, et al. Health status in patients with chronic fatigue syndrome and in general population and disease comparison groups. Am J Med 1996; 101:281-90.
67. Komaroff AL, Fagioli LR, Geiger AM, Doolittle TH, Lee J, Kornish RJ, et al. An examination of the working case definition of chronic fatigue syndrome. Am J Med 1996; 100:56-64.
68. Krupp LB, Jandorf L, Coyle PK, Mendelson WB. Sleep disturbance in chronic fatigue syndrome. J Psychosom Res 1993; 37:325-31.
69. Krupp LB, Sliwinski M, Masur DM, Friedberg F, Coyle PK. Cognitive functioning and depression in patients with chronic fatigue syndrome and multiple sclerosis. Arch Neurol 1994; 51:705-10.
70. Lakein DA, Fantie BD, Grafman J, Ross S, O'Fallon A, Dale J, et al. Patients with chronic fatigue syndrome and accurate feeling-of-knowing judgments. J Clin Psychol 1997; 53:635-45.
71. LaManca JJ, Peckerman A, Sisto SA, DeLuca J, Cook S, Natelson BH. Cardiovascular responses of women with chronic fatigue syndrome to stressful cognitive testing before and after strenuous exercise. Psychosom Med 2001; 63:756-64.
72. LaManca JJ, Peckerman A, Walker J, Kesil W, Cook S, Taylor A, et al. Cardiovascular response during head-up tilt in chronic fatigue syndrome. Clin Physiol 1999; 19:111-20.
73. LaManca JJ, Sisto SA, DeLuca J, Johnson SK, Lange G, Pareja J, et al. Influence of exhaustive treadmill exercise on cognitive functioning in chronic fatigue syndrome. Am J Med 1998; 105:59S-65S.
74. LaManca JJ, Sisto SA, Zhou XD, Ottenweller JE, Cook S, Peckerman A, et al. Immunological response in chronic fatigue syndrome following a graded exercise test to exhaustion. J Clin Immunol 1999; 19:135-42.
75. Lawrie SM, MacHale SM, Cavanagh JT, O'Carroll RE, Goodwin GM. The difference in patterns of motor and cognitive function in chronic fatigue syndrome and severe depressive illness. Psychol Med 2000; 30:433-42.
76. MacHale SM, Cavanagh JT, Bennie J, Carroll S, Goodwin GM, Lawrie SM. Diurnal variation of adrenocortical activity in chronic fatigue syndrome. Neuropsychobiology 1998; 38:213-7.
77. MacHale SM, Lawrie SM, Cavanagh JT, Glabus MF, Murray CL, Goodwin GM, et al. Cerebral perfusion in chronic fatigue syndrome and depression. Br J Psychiatry 2000; 176:550-6.
78. Marshall PS, Forstot M, Callies A, Peterson PK, Schenck CH. Cognitive slowing and working memory difficulties in chronic fatigue syndrome. Psychosom Med 1997; 59:58-66.
79. Marshall PS, Watson D, Steinberg P, Cornblatt B, Peterson PK, Callies A, et al. An assessment of cognitive function and mood in chronic fatigue syndrome. Biol Psychiatry 1996; 39:199-206.
80. Michiels V, Cluydts R, Fischler B. Attention and verbal learning in patients with chronic fatigue syndrome. J Int Neuropsychol Soc 1998; 4:456-66.
81. Michiels V, de Gucht V, Cluydts R, Fischler B. Attention and information processing efficiency in patients with Chronic Fatigue Syndrome. J Clin Exp Neuropsychol 1999; 21:709-29.
82. Morriss R, Sharpe M, Sharpley AL, Cowen PJ, Hawton K, Morris J. Abnormalities of sleep in patients with the chronic fatigue syndrome. BMJ 1993; 306:1161-4.
83. Natelson BH, Cheu J, Hill N, Bergen M, Korn L, Denny T, et al. Single-blind, placebo phase-in trial of two escalating doses of selegiline in the chronic fatigue syndrome. Neuropsychobiology 1998; 37:150-4.
84. Nisenbaum R, Reyes M, Mawle AC, Reeves WC. Factor analysis of unexplained severe fatigue and interrelated symptoms: Overlap with criteria for chronic fatigue syndrome. Am J Epidemiol 1998; 148:72-7.
85. Paul L, Wood L, Behan WM, Maclaren WM. Demonstration of delayed recovery from fatiguing exercise in chronic fatigue syndrome. Eur J Neurol 1999; 6:63-9.
86. Peterson PK, Pheley A, Schroeppel J, Schenck C, Marshall P, Kind A, et al. A preliminary placebo-controlled crossover trial of fludrocortisone for chronic fatigue syndrome. Arch Int Med 1998; 158:908-14.
87. Poole J, Herrell R, Ashton S, Goldberg J, Buchwald D. Results of isoproterenol tilt table testing in monozygotic twins discordant for chronic fatigue syndrome. Arch Int Med 2000; 160:3461-8.
88. Riley MS, O'Brien CJ, McCluskey DR, Bell NP, Nicholls DP. Aerobic work capacity in patients with chronic fatigue syndrome. BMJ 1990; 301:953-6.
89. Ross S, Fantie B, Straus SF, Grafman J. Divided attention deficits in patients with chronic fatigue syndrome. Appl Neuropsychol 2001; 8:4-11.
90. Sacco P, Hope PA, Thickbroom GW, Byrnes ML, Mastaglia FL. Corticomotor excitability and perception of effort during sustained exercise in the chronic fatigue syndrome. Clin Neurophysiol 1999; 110:1883-91.
91. Sandman CA, Barron JL, Nackoul K, Goldstein J, Fidler F. Memory deficits associated with chronic fatigue immune dysfunction syndrome. Biol Psychiatry 1993; 33:618-23.
92. Schmaling KB, DiClementi JD, Cullum CM, Jones JF. Cognitive functioning in chronic fatigue syndrome and depression: A preliminary comparison. Psychosom Med 1994; 56:383-8.
93. Schmaling KB, Jones JF. MMPI profiles of patients with chronic fatigue syndrome. J Psychosom Res 1996; 40:67-74.
94. Schondorf R, Benoit J, Wein T, Phaneuf D. Orthostatic intolerance in the chronic fatigue syndrome. J Auton Nerv Syst 1999; 75:192-201.
95. Schwartz SN, Jones R. Measuring outcomes of treatment in chronic fatigue syndrome: A comparison of simple questioning vs. use of a validated outcome instrument (Short Form 36). J CFS 2000; 6:3-10.
96. Schweitzer R, Robertson DL, Kelly B, Whiting J. Illness behaviour of patients with chronic fatigue syndrome. J Psychosom Res 1994; 38:41-9.
97. See DM, Tilles JG. Alpha-interferon treatment of patients with chronic fatigue syndrome. Immunol Invest 1996; 25:153-64.
98. Sendrowski DP, Buker EA, Gee SS. An investigation of sympathetic hypersensitivity in chronic fatigue syndrome. Optom Vis Sci 1997; 74:660-3.
99. Servatius RJ, Tapp WN, Bergen MT, Pollet CA, Drastal SD, Tiersky LA, et al. Impaired associative learning in chronic fatigue syndrome. Neuroreport 1998; 9:1153-7.
100. Sisto SA, Tapp WN, LaManca JJ, Ling W, Korn LR, Nelson AJ, et al. Physical activity before and after exercise in women with chronic fatigue syndrome. QJM 1998; 91:465-73.
101. Smith A, Pollock J, Thomas M, Llewelyn M, Borysiewicz L. The relationship between subjective ratings of sleep and mental functioning in healthy subjects and patients with chronic fatigue syndrome. Hum Psychopharmacol 1996; 11:161-7.
102. Smith AP, Borysiewicz L, Pollock J, Thomas M, Perry K, Llewelyn M. Acute fatigue in chronic fatigue syndrome patients. Psychol Med 1999; 29:283-90.
103. Spath M, Welzel D, Farber L. Treatment of chronic fatigue syndrome with 5-HT3 receptor antagonists: Preliminary results. Scand J Rheumatol Suppl 2000; 113:72-7.
104. Spence VA, Khan F, Belch JJ. Enhanced sensitivity of the peripheral cholinergic vascular response in patients with chronic fatigue syndrome. Am J Med 2000; 108:736-9.
105. Steinberg P, McNutt BE, Marshall P, Schenck C, Lurie N, Pheley A, et al. Double-blind placebo-controlled study of the efficacy of oral terfenadine in the treatment of chronic fatigue syndrome. J Allergy Clin Immunol 1996; 97:119-26.
106. Strayer DR, Carter WA, Brodsky I, Cheney P, Peterson D, Salvato P, et al. A controlled clinical trial with a specifically configured RNA drug, poly(I) - poly(C12U), in chronic fatigue syndrome. Clin Infect Dis 1994; 18:S88-95.
107. Taylor RR, Jason LA, Torres A. Fatigue rating scales: An empirical comparison. Psychol Med 2000; 30:849-56.
108. Tirelli U, Chierichetti F, Tavio M, Simonelli C, Bianchin G, Zanco P, et al. Brain positron emission tomography (PET) in chronic fatigue syndrome: Preliminary data. Am J Med 1998; 105:54S-8S.
109. Trigwell P, Hatcher S, Johnson M, Stanley P, House A. "Abnormal" illness behaviour in chronic fatigue syndrome and multiple sclerosis. BMJ 1995; 311:15-8.
110. Van der Werf SP, Prins JB, Jongen PJ, van der Meer JW, Bleijenberg G. Abnormal neuropsychological findings are not necessarily a sign of cerebral impairment: A matched comparison between chronic fatigue syndrome and multiple sclerosis. Neuropsychiatry Neuropsychol Behav Neurol 2000; 13:199-203.
111. Van der Werf SP, Prins JB, Vercoulen JH, van der Meer JW, Bleijenberg G. Identifying physical activity patterns in chronic fatigue syndrome using actigraphic assessment. J Psychosom Res 2000; 49:373-9.
112. Van Houdenhove B, Neerinckx E, Onghena P, Lysens R, Vertommen H. Premorbid "overactive" lifestyle in chronic fatigue syndrome and fibromyalgia. An etiological factor or proof of good citizenship. J Psychosom Res 2001; 51:571-6.
113. Van Houdenhove B, Onghena P, Neerinckx E, Hellin J. Does high 'action-proneness' make people more vulnerable to chronic fatigue syndrome? A controlled psychometric study. J Psychosom Res 1995; 39:633-40.
114. Vollmer-Conna U, Hickie I, Hadzi-Pavlovic D, Tymms K, Wakefield D, Dwyer J, et al. Intravenous immunoglobulin is ineffective in the treatment of patients with chronic fatigue syndrome. Am J Med 1997; 103:38-43.
115. Vollmer-Conna U, Wakefield D, Lloyd A, Hickie I, Lemon J, Bird KD, et al. Cognitive deficits in patients suffering from chronic fatigue syndrome, acute infective illness or depression. Br J Psychiatry 1997; 171:377-81.
116. Warren G, McKendrick M, Peet M. The role of essential fatty acids in chronic fatigue syndrome. A case-controlled study of red-cell membrane essential fatty acids (EFA) and a placebo-controlled treatment study with high dose of EFA. Acta Neurol Scand 1999; 99:112-6.
117. Wearden A, Appleby L. Cognitive performance and complaints of cognitive impairment in chronic fatigue syndrome (CFS). Psychol Med 1997; 27:81-90.
118. Wessely S, Chalder T, Hirsch S, Wallace P, Wright D. The prevalence and morbidity of chronic fatigue and chronic fatigue syndrome: A prospective primary care study. Am J Public Health 1997; 87:1449-55.
119. White C, Schweitzer R. The role of personality in the development and perpetuation of chronic fatigue syndrome. J Psychosom Res 2000; 48:515-24.
120. White PD, Cleary KJ. An open study of the efficacy and adverse effects of moclobemide in patients with the chronic fatigue syndrome. Int Clin Psychopharmacol 1997; 12:47-52.
121. Wood C, Magnello ME, Sharpe MC. Fluctuations in perceived energy and mood among patients with chronic fatigue syndrome. J R Soc Med 1992; 85:195-8.
122. Woodward RV, Broom DH, Legge DG. Diagnosis in chronic illness: Disabling or enabling--the case of chronic fatigue syndrome. J R Soc Med 1995; 88:325-9.
123. Zaman R, Puri BK, Main J, Nowicky AV, Davey NJ. Corticospinal inhibition appears normal in patients with chronic fatigue syndrome. Exp Physiol 2001; 86:547-50.
124. Zhang QW, Natelson BH, Ottenweller JE, Servatius RJ, Nelson JJ, De Luca J, et al. Chronic fatigue syndrome beginning suddenly occurs seasonally over the year. Chronobiol Int 2000; 17:95-9.

Rejection Reason: Not related to or specific for CFS

1. Aaron LA, Herrell R, Ashton S, Belcourt M, Schmaling K, Goldberg J, et al. Comorbid clinical conditions in chronic fatigue: A co-twin control study. J Gen Intern Med 2001; 16:24-31.
2. Alexander RW, Bradley LA, Alarcon GS, Triana-Alexander M, Aaron LA, Alberts KR, et al. Sexual and physical abuse in women with fibromyalgia: Association with outpatient health care utilization and pain medication usage. Arthritis Care Res 1998; 11:102-15.
3. Asbring P. Chronic illness -- A disruption in life: identity-transformation among women with chronic fatigue syndrome and fibromyalgia. J Adv Nurs 2001; 34:312-9.
4. Ax S. Coping differences between chronic fatigue syndrome sufferers and their carers. J CFS 1999; 5:57-62.
5. Axe EK, Satz P. Depressive comorbidity in the fatiguing illnesses. J CFS 2001; 8:25-9.
6. Buskila D. Fibromyalgia, chronic fatigue syndrome, and myofascial pain syndrome. Curr Opin Rheumatol 2001; 13:117-27.
7. Chalder T, Power MJ, Wessely S. Chronic fatigue in the community: 'A question of attribution'. Psychol Med 1996; 26:791-800.
8. Chida M, Inase N, Ichioka M, Miyazato I, Marumo F. Ratings of perceived exertion in chronic obstructive pulmonary disease: A possible indicator for exercise training in patients with this disease. Eur J Appl Physiol Occup Physiol 1991; 62:390-3.
9. Chisholm D, Godfrey E, Ridsdale L, Chalder T, King M, Seed P, et al. Chronic fatigue in general practice: Economic evaluation of counselling versus cognitive behaviour therapy. Br J Gen Pract 2001; 51:15-8.
10. Clarke JN. The search for legitimacy and the "expertization" of the lay person: The case of chronic fatigue syndrome. Soc Work Health Care 2000; 30:73-93.
11. Cope H, Mann A, Pelosi A, David A. Psychosocial risk factors for chronic fatigue and chronic fatigue syndrome following presumed viral illness: A case-control study. Psychol Med 1996; 26:1197-209.
12. Lorig KR, Sobel DS, Stewart AL, Brown BWJ, Bandura A, Ritter P, et al. Evidence suggesting that a chronic disease self-management program can improve health status while reducing hospitalization: A randomized trial. Med Care 1999; 37:5-14.
13. Matthews DA, Lane TJ, Manu P. Antibodies to Epstein-Barr virus in patients with chronic fatigue. South Med J 1991; 84:832-40.
14. Ray C. Positive and negative social support in a chronic illness. Psychol Rep 1992; 71:977-8.
15. Ridsdale L, Evans A, Jerrett W, Mandalia S, Osler K, Vora H. Patients with fatigue in general practice: A prospective study. BMJ 1993; 307:103-6.
16. Ridsdale L, Godfrey E, Chalder T, Seed P, King M, Wallace P, et al. Chronic fatigue in general practice: Is counselling as good as cognitive behaviour therapy? A UK randomised trial. Br J Gen Pract 2001; 51:19-24.
17. Russo J, Katon W, Clark M, Kith P, Sintay M, Buchwald D. Longitudinal changes associated with improvement in chronic fatigue patients. J Psychosom Res 1998; 45:67-76.
18. Sharpe M, Hawton K, Seagroatt V, Pasvol G. Follow up of patients presenting with fatigue to an infectious diseases clinic. BMJ 1992; 305:147-52.

Rejection Reason: Not US, UK, Canada, Australia or Western Europe

1. Borok G. Chronic fatigue syndrome: An atopic state. J CFS 1998; 4:39-57.
2. Loganovsky KN. Vegetative-vascular dystonia and osteoalgetic syndrome or chronic fatigue syndrome as a characteristic after-effect of radioecological disaster: The Chernobyl accident. J CFS 2000; 7:6-16.
3. Naschitz JE, Rosner I, Rozenbaum M, Gaitini L, Bistritzki I, Zuckerman E, et al. The capnography head-up tilt test for evaluation of chronic fatigue syndrome. Semin Arthritis Rheum 2000; 30:79-86.

Rejection Reason: Outcomes not extractable

1. Cleare AJ, Heap E, Malhi GS, Wessely S, O'Keane V, Miell J. Low-dose hydrocortisone in chronic fatigue syndrome: A randomised crossover trial. Lancet 1999; 353:455-8.
2. Cleare AJ, Miell J, Heap E, Sookdeo S, Young L, Malhi GS, et al. Hypothalamo-pituitary-adrenal axis dysfunction in chronic fatigue syndrome, and the effects of low-dose hydrocortisone therapy. J Clin Endocrinol Metab 2001; 86:3545-54.
3. Jason LA, Taylor RR, Kennedy CL, Song S, Johnson D, Torres S. Chronic fatigue syndrome: Occupation, medical utilization, and subtypes in a community-based sample. J Nerv Ment Dis 2000; 188:568-76.
4. Lerner AM, Lawrie C, Dworkin HS. Repetitively negative changing T waves at 24-h electrocardiographic monitors in patients with the chronic fatigue syndrome. Left ventricular dysfunction in a cohort. Chest 1993; 104:1417-21.
5. Levine PH, Snow PG, Ranum BA, Paul C, Holmes MJ. Epidemic neuromyasthenia and chronic fatigue syndrome in West Otago, New Zealand. A 10-year follow-up. Arch Int Med 1997; 157:750-4.
6. Lovell DM. Chronic fatigue syndrome among overseas development workers: A qualitative study. J Travel Med 1999; 6:16-23.
7. Lutgendorf SK, Antoni MH, Ironson G, Fletcher MA, Penedo F, Baum A, et al. Physical symptoms of chronic fatigue syndrome are exacerbated by the stress of Hurricane Andrew. Psychosom Med 1995; 57:310-23.
8. McCluskey DR. Pharmacological approaches to the therapy of chronic fatigue syndrome. Ciba Found Symp 1993; 173:280-7.
9. Moorkens G, Wynants H, Abs R. Effect of growth hormone treatment in patients with chronic fatigue syndrome: A preliminary study. Growth Horm IGF Res 1998; 8 Suppl B:131-3.
10. Natelson BH, Cheu J, Pareja J, Ellis SP, Policastro T, Findley TW. Randomized, double blind, controlled placebo-phase in trial of low dose phenelzine in the chronic fatigue syndrome. Psychopharmacology (Berl) 1996; 124:226-30.
11. Saisch SG, Deale A, Gardner WN, Wessely S. Hyperventilation and chronic fatigue syndrome. QJM 1994; 87:63-7.
12. Smith AP, Behan PO, Bell W, Millar K, Bakheit M. Behavioural problems associated with the chronic fatigue syndrome. Br J Psychol 1993; 84:411-23.
13. Wagner-Raphael LI, Jason LA, Ferrari JR. Chronic fatigue syndrome, chronic fatigue, and psychiatric disorders: Predictors of functional status in a national nursing sample. J Occup Health Psychol 1999; 4:63-71.
14. Ware NC. Toward a model of social course in chronic illness: The example of chronic fatigue syndrome. Cult Med Psychiatry 1999; 23:303-31.
15. Ware NC. Sociosomatics and illness in chronic fatigue syndrome. Psychosom Med 1998; 60:394-401.
16. Ware NC. Society, mind and body in chronic fatigue syndrome: An anthropological view. Ciba Found Symp 1993; 173:62-73.

Rejection Reason: Studies of lab findings/lab technique or focus on pathophysiology of CFS

1. Altemus M, Dale JK, Michelson D, Demitrack MA, Gold PW, Straus SE. Abnormalities in response to vasopressin infusion in chronic fatigue syndrome. Psychoneuroendocrinology 2001; 26:175-88.
2. Bounous G, Molson J. Competition for glutathione precursors between the immune system and the skeletal muscle: Pathogenesis of chronic fatigue syndrome. Med Hypotheses 1999; 53:347-9.
3. Evengard B, Nilsson CG, Lindh G, Lindquist L, Eneroth P, Fredrikson S, et al. Chronic fatigue syndrome differs from fibromyalgia. No evidence for elevated substance P levels in cerebrospinal fluid of patients with chronic fatigue syndrome. Pain 1998; 78:153-5.
4. Fischler B, D'Haenen H, Cluydts R, Michiels V, Demets K, Bossuyt A, et al. Comparison of 99m Tc HMPAOSPECT scan between chronic fatigue syndrome, major depression and healthy controls: An exploratory study of clinical correlates of regional cerebral blood flow. Neuropsychobiology 1996; 34:175-83.
5. Freeman R, Komaroff AL. Does the chronic fatigue syndrome involve the autonomic nervous system? Am J Med 1997; 102:357-64.
6. Hoskin L, Clifton-Bligh P, Hansen R, Fulcher G, Gates F. Bone density and body composition in young womenwith chronic fatigue syndrome. Ann N Y Acad Sci 2000; 904:625-7.
7. Ichise M, Salit IE, Abbey SE, Chung DG, Gray B, Kirsh JC, et al. Assessment of regional cerebral perfusion by 99Tcm-HMPAO SPECT in chronic fatigue syndrome. Nucl Med Commun 1992; 13:767-72.
8. Krotz D. MR spectroscopy and SPECT capture chronic fatigue. Diagn Imaging (San Franc) 1998; 20:23-5.
9. Landay AL, Jessop C, Lennette ET, Levy JA. Chronic fatigue syndrome: Clinical condition associated with immune activation. Lancet 1991; 338:707-12.
10. Lange G, DeLuca J, Maldjian JA, Lee H, Tiersky LA, Natelson BH. Brain MRI abnormalities exist in a subset of patients with chronic fatigue syndrome. J Neurol Sci 1999; 171:3-7.
11. Lindh G, Samuelson A, Hedlund KO, Evengard B, Lindquist L, Ehrnst A. No findings of enteroviruses in Swedish patients with chronic fatigue syndrome. Scand J Infect Dis 1996; 28:305-7.
12. MacHale SM. Cerebral perfusion in chronic fatigue syndrome and depression. Br J Psychiatry 2000; 176:550-6.
13. Natelson BH, Cohen JM, Brassloff I, Lee HJ. A controlled study of brain magnetic resonance imaging in patients with the chronic fatigue syndrome. J Neurol Sci 1993; 120:213-7.
14. Salit IE. Precipitating factors for the chronic fatigue syndrome. J Psychiatr Res 1997; 31:59-65.
15. Schwartz RB, Garada BM, Komaroff AL, Tice HM, Gleit M, Jolesz FA, et al. Detection of intracranial abnormalities in patients with chronic fatigue syndrome: Comparison of MR imaging and SPECT. AJR 1994; 162:935-41.
16. Scott LV, Medbak S, Dinan TG. Blunted adrenocorticotropin and cortisol responses to corticotropin-releasing hormone stimulation in chronic fatigue syndrome. Acta Psychiatr Scand 1998; 97:450-7.
17. Scott LV, Svec F, Dinan T. A preliminary study of dehydroepiandrosterone response to low-dose ACTH in chronic fatigue syndrome and in healthy subjects. Psychiatry Res 2000; 97:21-8.
18. Soetekouw PM, Wevers RA, Vreken P, Elving LD, Janssen AJ, van der Veen Y, et al. Normal carnitine levels in patients with chronic fatigue syndrome. Neth J Med 2000; 57:20-4.
19. Streeten DH, Thomas D, Bell DS. The roles of orthostatic hypotension, orthostatic tachycardia, and subnormal erythrocyte volume in the pathogenesis of the chronic fatigue syndrome. Am J Med Sci 2000; 320:1-8.
20. Tirelli U, Marotta G, Improta S, Pinto A. Immunological abnormalities in patients with chronic fatigue syndrome. Scand J Immunol 1994; 40:601-8.
21. Visser J, Graffelman W, Blauw B, Haspels I, Lentjes E, de Kloet ER, et al. LPS-induced IL-10 production in whole blood cultures from chronic fatigue syndrome patients is increased but supersensitive to inhibition by dexamethasone. J Neuroimmunol 2001; 119:343-9.
22. Vojdani A, Lapp CW. Interferon-induced proteins are elevated in blood samples of patients with chemically or virally induced chronic fatigue syndrome. Immunopharmacol Immunotoxicol 1999; 21:175-202.

Rejection Reason: Work data not extractable

1. Bruno RL, Creange SJ, Frick NM. Parallels between post-polio fatigue and chronic fatigue syndrome: A common pathophysiology. Am J Med 1998; 105:66S-73.
2. Sadlier M, Evans JR, Phillips C, Broad A. A preliminary study into the effectiveness of multi-convergent therapy in the treatment of heterogeneous patients with chronic fatigue syndrome. J CFS 2000; 7:93-101.
3. Soderberg S, Evengard B. Short-term group therapy for patients with chronic fatigue syndrome. Psychother Psychosom 2001; 70:108-11.
4. Theorell T, Blomkvist V, Lindh G, Evengard B. Critical life events, infections, and symptoms during the year preceding chronic fatigue syndrome (CFS): An examination of CFS patients and subjects with a nonspecific life crisis. Psychosom Med 1999; 61:304-10.