# Appendix H. Accepted Studies Log

1. Akagi H, Klimes I, Bass C. Cognitive behavioral therapy for chronic fatigue syndrome in a general hospital-feasible and effective. Gen Hosp Psychiatry 2001; 23: 254-60.
2. Anderson JS, Ferrans CE. The quality of life of persons with chronic fatigue syndrome. J Nerv Ment Dis 1997; 185: 359-67.
3. Antoni MH, Brickman A, Lutgendorf S, Klimas N, Imia-Fins A, Ironson G, et al. Psychosocial correlates of illness burden in chronic fatigue syndrome. Clin Infect Dis 1994; 18 Suppl 1: S73-8.
4. Arpino C, Carrieri MP, Valesini G, Pizzigallo E, Rovere P, Tirelli U, et al. Idiopathic chronic fatigue and chronic fatigue syndrome: A comparison of two case-definitions. Ann Ist Super Sanita 1999; 35: 435-41.
5. Bombardier CH, Buchwald D. Outcome and prognosis of patients with chronic fatigue vs chronic fatigue syndrome. Arch Intern Med 1995; 155: 2105-10.
  - Bombardier CH, Buchwald D. Chronic fatigue, chronic fatigue syndrome, and fibromyalgia. Disability and health-care use. Med Care 1996; 34: 924-30.
6. Bou-Holaigah I, Rowe PC, Kan J, Calkins H. The relationship between neurally mediated hypotension and the chronic fatigue syndrome. JAMA 1995; 274: 961-7.
7. Buchwald D, Pearlman T, Kith P, Schmaling K. Gender differences in patients with chronic fatigue syndrome. J Gen Intern Med 1994; 9: 397-401.
8. Buchwald D, Pearlman T, Umali J, Schmaling K, Katon W. Functional status in patients with chronic fatigue syndrome, other fatiguing illnesses, and healthy individuals. Am J Med 1996; 101: 364-70.
9. Butler S, Chalder T, Ron M, Wessely S. Cognitive behaviour therapy in chronic fatigue syndrome. J Neurol Neurosurg Psychiatry 1991; 54: 153-8.
  - Wessely S, Powell R. Fatigue syndrome: A comparison of chronic "postviral" fatigue with neuromuscular and affective disorders. J Neurol Neurosurg Psychiatry 1989; 52: 940-8.
10. Claypoole K, Mahurin R, Fischer ME, Goldberg J, Schmaling KB, Schoene RB, et al. Cognitive compromise following exercise in monozygotic twins discordant for chronic fatigue syndrome: Fact or artifact. Appl Neuropsychol 2001; 8: 31-40.
11. Creswell C, Chalder T. Defensive coping styles in chronic fatigue syndrome. J Psychosom Res 2001; 51: 607-10.
12. Cruess SE, Klimas N, Antoni MH, Helder L, Maher K, Keller R, et al. Immunologic status correlates with severity of physical symptoms and perceived illness burden in chronic fatigue syndrome patients. J CFS 2000; 7: 39-52.
13. Deale A, Chalder T, Marks I, Wessely S. Cognitive behavior therapy for chronic fatigue syndrome: A randomized controlled trial. Am J Psychiatry 1997; 154: 408-14.
14. Dyck D, Allen S, Barron J, Marchi J, Price BA, Spavor L, et al. Management of chronic fatigue syndrome: Case study. AAOHN J 1996; 44: 85-92.
15. Fiedler N, Kipen HM, DeLuca J, Kelly-McNeil K, Natelson B. A controlled comparison of multiple chemical sensitivities and chronic fatigue syndrome. Psychosom Med 1996; 58: 38-49.
16. Fischler B, Cluydts R, De Gucht Y, Kaufman L, De Meirleir K. Generalized anxiety disorder in chronic fatigue syndrome. Acta Psychiatr Scand 1997; 95: 405-13.
17. Fulcher KY, White PD. Randomised controlled trial of graded exercise in patients with the chronic fatigue syndrome. BMJ 1997; 314: 1647-52.
  - Fulcher KY, White PD. Strength and physiological response to exercise in patients with chronic fatigue syndrome. J Neurol Neurosurg Psychiatry 2000; 69: 302-7.
18. Garcia-Borreguero D, Dale JK, Rosenthal NE, Chiara A, O'Fallon A, Bartko JJ, et al. Lack of seasonal variation of symptoms in patients with chronic fatigue syndrome. Psychiatry Res 1998; 77: 71-7.
19. Jason LA, Fricano G, Taylor RR, Halpert J, Fennell PA, Klein S, et al. Chronic fatigue syndrome: An examination of the phases. J Clin Psychol 2000; 56: 1497-508.
20. Jason LA, Richman JA, Rademaker AW, Jordan KM, Plioplys AV, Taylor RR, et al. A community-based study of chronic fatigue syndrome. Arch Int Med 1999; 159: 2129-37.
  - Jason LA, Taylor RR, Kennedy CL. Chronic fatigue syndrome, fibromyalgia, and multiple chemical sensitivities in a community-based sample of persons with chronic fatigue syndrome-like symptoms. Psychosom Med 2000; 62: 655-63.
  - Jason LA, Taylor RR, Kennedy CL, Jordan K, Song S, Johnson DE, et al. Chronic fatigue syndrome: Sociodemographic subtypes in a community-based sample. Eval Health Prof 2000; 23: 243-63.
21. Kruesi MJ, Dale J, Straus SE. Psychiatric diagnoses in patients who have chronic fatigue syndrome. J Clin Psychiatry 1989; 50: 53-6.
  - Straus SE, Dale JK, Tobi M, Lawley T, Preble O, Blaese RM, et al. Acyclovir treatment of the chronic fatigue syndrome. Lack of efficacy in a placebo-controlled trial. N Engl J Med 1988; 319: 1692-8.
22. Lane TJ, Manu P, Matthews DA. Depression and somatization in the chronic fatigue syndrome. Am J Med 1991; 91: 335-44.
23. Lerner AM, Zervos M, Dworkin HJ, Chang CH, Fitzgerald JT, Goldstein, et al. New cardiomyopathy: Pilot study of intravenous ganciclovir in a subset of the chronic fatigue syndrome. Infect Agents Dis 1997; 6: 110-7.
24. Lloyd A, Gandevia S, Brockman A, Hales J, Wakefield D. Cytokine production and fatigue in patients with chronic fatigue syndrome and healthy control subjects in response to exercise. Clin Infect Dis 1994; 18: S142-6.
25. MacDonald KL, Osterholm MT, LeDell KH, White KE, Schenck CH, Chao CC, et al. A case-control study to assess possible triggers and cofactors in chronic fatigue syndrome. Am J Med 1996; 100: 548-54.
26. Marcel B, Komaroff AL, Fagioli LR, Kornish RJ, Albert MS. Cognitive deficits in patients with chronic fatigue syndrome. Biol Psychiatry 1996; 40: 535-41.
  - Daly E, Komaroff AL, Bloomingdale K, Wilson S, Albert MS. Neuropsychological function in patients with chronic fatigue syndrome, multiple sclerosis, and depression. Appl Neuropsychol 2001; 8: 12-22.
27. Marlin RG, Anchel H, Gibson JC, Goldberg WM, Swinton M. An evaluation of multidisciplinary intervention for chronic fatigue syndrome with long-term follow-up, and a comparison with untreated controls. Am J Med 1998; 105: 110S-4S.
28. McKenzie R, O'Fallon A, Dale J, Demitrack M, Sharma G, Deloria M, et al. Low-dose hydrocortisone for treatment of chronic fatigue syndrome: A randomized controlled trial. JAMA 1998; 280: 1061-6.
29. Michiels V, Cluydts R, Fischler B, Hoffmann G, Le Bon O, De Meirleir K. Cognitive functioning in patients with chronic fatigue syndrome. J Clin Exp Neuropsychol 1996; 18: 666-77.
30. Moss-Morris R, Petrie KJ. Discriminating between chronic fatigue syndrome and depression: A cognitive analysis. Psychol Med 2001; 31: 469-79.
31. Myers C, Wilks D. Comparison of Euroqol EQ-5D and SF-36 in patients with chronic fatigue syndrome. Qual Life Res 1999; 8: 9-16.
32. Natelson BH, Johnson SK, DeLuca J, Sisto S, Ellis SP, Hill N, et al. Reducing heterogeneity in chronic fatigue syndrome: A comparison with depression and multiple sclerosis. Clin Infect Dis 1995; 21: 1204-10.
33. Peterson PK, Schenck CH, Sherman R. Chronic fatigue syndrome in Minnesota. Minn Med 1991; 74: 21-6.
  - Peterson PK, Shepard J, Macres M, Schenck C, Crosson J, Rechtman D, et al. A controlled trial of intravenous immunoglobulin G in chronic fatigue syndrome. Am J Med 1990; 89: 554-60.
  - Pheley AM, Melby D, Schenck C, Mandel J, Peterson PK. Can we predict recovery in chronic fatigue syndrome. Minn Med 1999; 82: 52-6.
34. Powell P, Bentall RP, Nye FJ, Edwards RH. Randomised controlled trial of patient education to encourage graded exercise in chronic fatigue syndrome. BMJ 2001; 322: 387-90.
35. Prins JB, Bleijenberg G, Bazelmans E, Elving LD, de Boo TM, Severens JL, et al. Cognitive behaviour therapy for chronic fatigue syndrome: A multicentre randomised controlled trial. Lancet 2001; 357: 841-7.
36. Ray C, Jefferies S, Weir WR. Coping with chronic fatigue syndrome: Illness responses and their relationship with fatigue, functional impairment and emotional status. Psychol Med 1995; 25: 937-45.
  - Ray C, Jefferies S, Weir WR. Coping and other predictors of outcome in chronic fatigue syndrome: A 1-year follow-up. J Psychosom Res 1997; 43: 405-15.
  - Ray C, Jefferies S, Weir WR. Life-events and the course of chronic fatigue syndrome. Br J Med Psychol 1995; 68: 323-31.
37. Ray C, Phillips L, Weir WR. Quality of attention in chronic fatigue syndrome: Subjective reports of everyday attention and cognitive difficulty, and performance on tasks of focused attention. Br J Clin Psychol 1993; 32:357-64.
38. Rowe PC, Calkins H, DeBusk K, McKenzie R, Anand R, Sharma G, et al. Fludrocortisone acetate to treat neurally mediated hypotension in chronic fatigue syndrome: A randomized controlled trial. JAMA 2001; 285: 52-9.
39. Saltzstein BJ, Wyshak G, Hubbuch JT, Perry JC. A naturalistic study of the chronic fatigue syndrome among women in primary care. Gen Hosp Psychiatry 1998; 20: 307-16.
40. Scheffers MK, Johnson RJ, Grafman J, Dale JK, Straus SE. Attention and short-term memory in chronic fatigue syndrome patients: An event-related potential analysis. Neurology 1992; 42: 1667-75.
41. Schmaling KB, Hamilos DL, DiClementi JD, Jones JF. Pain perception in chronic fatigue syndrome. J CFS 1998; 4:13-22.
42. Schmaling KB, Smith WR, Buchwald DS. Significant other responses are associated with fatigue and functional status among patients with chronic fatigue syndrome. Psychosom Med 2000; 62: 444-50.
43. Shanks MF, Ho-Yen DO. A clinical study of chronic fatigue syndrome. Br J Psychiatry 1995; 166: 798-801.
44. Sharpe M, Hawton K, Simkin S, Surawy C, Hackmann A, Klimes I, et al. Cognitive behaviour therapy for the chronic fatigue syndrome: A randomized controlled trial. Br Med J 1996; 312: 22-6.
45. Sisto SA, LaManca J, Cordero DL, Bergen MT, Ellis SP, Drastal S, et al. Metabolic and cardiovascular effects of a progressive exercise test in patients with chronic fatigue syndrome. Am J Med 1996; 100: 634-40.
46. Tiersky LA, DeLuca J, Hill N, Dhar SK, Johnson SK, Lange G, et al. Longitudinal assessment of neuropsychological functioning, psychiatric status, functional disability and employment status in chronic fatigue syndrome. Appl Neuropsychol 2001; 8: 41-50.
  - Hill NF, Tiersky LA, Scavalla VR, Lavietes M, Natelson BH. Natural history of severe chronic fatigue syndrome. Arch Phys Med Rehabil 1999; 80: 1090-4.
47. Tuck I, Wallace D. Chronic fatigue syndrome: A woman's dilemma. Health Care Women Int 2000; 21: 457-66.
48. Vercoulen JH, Bazelmans E, Swanink CM, Fennis JF, Galama JM, Jongen PJ, et al. Physical activity in chronic fatigue syndrome: Assessment and its role in fatigue. J Psychiatr Res 1997; 31: 661-73.
  - Vercoulen JH, Bazelmans E, Swanink CM, Galama JM, Fennis JF, van der Meer JW, et al. Evaluating neuropsychological impairment in chronic fatigue syndrome. J Clin Exp Neuropsychol 1998; 20: 144-56.
  - Vercoulen JH, Swanink CM, Galama JM, Fennis JF, Jongen PJ, Hommes OR, et al. The persistence of fatigue in chronic fatigue syndrome and multiple sclerosis: Development of a model. J Psychosom Res 1998; 45: 507-17.
49. Vercoulen JH, Swanink CM, Fennis JF, Galama JM, van der Meer JW, Bleijenberg G. Dimensional assessment of chronic fatigue syndrome. J Psychosom Res 1994; 38: 383-92.
  - Swanink CM, Vercoulen JH, Bleijenberg G, Fennis JF, Galama JM, van der Meer JW. Chronic fatigue syndrome: A clinical and laboratory study with a well matched control group. J Intern Med 1995; 237: 499-506.
  - Vercoulen JH, Swanink CM, Fennis JF, Galama JM, van der Meer JW, Bleijenberg G. Prognosis in chronic fatigue syndrome: A prospective study on the natural course. J Neurol Neurosurg Psychiatry 1996; 60: 489-94.
50. Vercoulen JH, Swanink CM, Zitman FG, Vreden SG, Hoofs MP, Fennis JF, et al. Randomised, double-blind, placebo-controlled study of fluoxetine in chronic fatigue syndrome. Lancet 1996; 347: 858-61.
51. Wearden AJ, Morriss RK, Mullis R, Strickland PL, Pearson DJ, Appleby L, et al. Randomised, double-blind, placebo-controlled treatment trial of fluoxetine and graded exercise for chronic fatigue syndrome. Br J Psychiatry 1998; 172: 485-90.
  - Morriss RK, Wearden AJ. Screening instruments for psychiatric morbidity in chronic fatigue syndrome. J R Soc Med 1998; 91: 365-8.
  - Morriss RK, Wearden AJ, Battersby L. The relation of sleep difficulties to fatigue, mood and disability in chronic fatigue syndrome. J Psychosom Res 1997; 42: 597-605.
  - Morriss RK, Wearden AJ, Mullis R. Exploring the validity of the Chalder Fatigue scale in chronic fatigue syndrome. J Psychosom Res 1998; 45: 411-7.
52. Wilson A, Hickie I, Hadzi-Pavlovic D, Wakefield D, Parker G, Straus SE, et al. What is chronic fatigue syndrome? Heterogeneity within an international multicentre study. Aust N Z J Psychiatry 2001; 35: 520-7.
53. Yeomans JD, Conway SP. Biopsychosocial aspects of chronic fatigue syndrome (myalgic encephalomyelitis). J Infect 1991; 23: 263-9.