# Appendix G. Reviewer Questionnaire

The following two pages comprise the peer reviewer form to be used in providing comments on the draft evidence report, Review of the Current Medical and Scientific Research Related to Chronic Fatigue Syndrome.

Page 2 is the reviewer "level of agreement" rating form, and page 3 provides a space for written comments. Here we would like you to provide: a) A brief explanation of both positive and negative answers;

b Suggestions for improvement of the content or format of this review;
c Suggestions for additional analyses of this dataset worth including in this report, or in future reports;
d Any other comments you may wish to provide regarding this draft report.

**We would prefer that you complete and return this form electronically. However, you may also fax the forms back to us, or fax back an annotated version of the draft report if you prefer.

Please contact Cindy Levine, M.D., Principal Investigator with any questions regarding the content of the draft report.

As a reminder, the draft evidence report in your possession must remain confidential and is not to be shared or distributed. Once all reviewer comments are received, these will be incorporated as appropriate, into the final evidence report that is sent to AHRQ for publication. We ask for your cooperation in maintaining the confidentiality of all information contained in this draft evidence report.

Thank you in advance for your time in completing this form and giving us your feedback. We value your input and greatly appreciate your efforts.

Please send the completed form and comments to MetaWorks by July 29, 2002.

Contacts: Cindy B. Levine, M.D. Associate Medical Director MetaWorks Inc. Phone: (781) 395-0700 Fax: (781) 395-7336 E-mail: clevine@metawork.com Rhonda P. Estok, RN, BSN, CNOR Clinical Information Specialist Metaworks Inc. Phone: (781) 395-0700 x254 Fax: (781) 395-7336 E-mail: restok@metawork.com

Reviewer Questionnaire

AHRQ Task Order: Review of the Current Medical and Scientific Research Related to Disability and Chronic Fatigue Syndrome

Appendix G. Reviewer Questionnaire

Please indicate your level of agreement with each of the following Statements, by placing an "X" in the appropriate column.
Statements | Very much agree | Moderately agree | Not very much in agreement | Do not agree at all
Accuracy:
1. Facts are easily distinguished from assumptions, assertions, or opinions in report.
2. The author's interpretations and conclusions are sound.
Attribution:
3. The theoretical or scientific basis used to support assertions, conclusions and discussions within the report is clearly stated.
4. Given the objectives of this project and the data, all clinically important outcomes were considered.
Clarity and Composition:
5. The purpose of the report is apparent and explicitly stated.
6. The report is well-written and content is organized in a coherent fashion that facilitates understanding.
7. Content is consistent with the purpose of the report.
8. The methods are presented in such a way as to be reproducible.
9. The results are clearly stated.
Figures and Tables:
10. Figures and tables are clear, useful, accurate and easy to interpret.
11. Titles and legends are appropriate.
Relevance:
12. This topic is relevant to healthcare decision-making (clinical practice and policy making) in 2002.
13. Authors should seek publication of a manuscript describing some or all aspects of this report. (please suggest possible journals and priority for publication)
Study Selection:
14. Based on selection criteria used, it is not likely that relevant studies were missed.
Overall:
15. I agree with the conclusions presented in the report.

Reviewer Questionnaire

AHRQ Task Order: Review of the Current Medical and Scientific Research Related to Disability and Chronic Fatigue Syndrome

Please print legibly or type comments here:

_____________________________________________________________________________

_____________________________________________________________________________

_____________________________________________________________________________

_____________________________________________________________________________

_____________________________________________________________________________

_____________________________________________________________________________

_____________________________________________________________________________

_____________________________________________________________________________

_____________________________________________________________________________

_____________________________________________________________________________

_____________________________________________________________________________

_____________________________________________________________________________

_____________________________________________________________________________

_____________________________________________________________________________

_____________________________________________________________________________

_____________________________________________________________________________

_____________________________________________________________________________

____________________ (signature) | | ____________________ (date)
____________________ (print name)