# Appendix F. Technical Expert Panel Members and Peer Reviewers

## Members of the Technical Experts Panel

- Michael B. Brimacombe, Ph.D.
- Associate Professor
- Department of Preventive Medicine & Community Health
- University of Medicine & Dentistry of New Jersey-New Jersey Medical School
- Newark, NJ

- Virginia E. Byrnes, MD
- Consultant in Internal Medicine and General Pediatrics
- Department of Disability determination
- Massachusetts Rehabilitation
- Boston, MA

- James F. Jones, M.D.
- Professor of Pediatrics
- University of Colorado School of Medicine
- Denver, CO

- Gudrun Lange, Ph.D.
- Associate Professor, Clinical Neuropsychologist
- Departments of Psychiatry and Radiology
- University of Medicine & Dentistry of New Jersey-New Jersey Medical School
- Newark, NJ

- Paul H. Levine, M.D.
- Clinical Professor of Medicine, Professor of Epidemiology and Biostatistics
- George Washington University Medical Center
- Washington, DC

- Robert J. MacBride, M.D.
- Medical Director, Disability Management
- Prudential Group Insurance
- Parsippany, NJ

- Benjamin H. Natelson, M.D.
- Professor
- Department of Neurosciences
- University of Medicine & Dentistry of New Jersey-New Jersey Medical School
- Newark, NJ

- Norma C. Ware, Ph.D.
- Associate Professor
- Departments of Social Medicine and Psychiatry
- Harvard Medical School
- Cambridge, MA

## Peer Reviewers

- Lynn Gerber, MD
- Warren Grant Magnuson Clinical Center (CC)
- National Institutes of Health
- Bethesda, Maryland 20892
- Specialty: Disability

- Ian Hickie, M.D.
- School of Psychiatry
- University of New South Wales
- Sidney, Australia 2052
- Specialty: Psychiatry

- Leonard A. Jason, Ph.D.
- Director, Center for Community Research
- De Paul University
- Chicago, Illinois
- Specialty: Professor of Clinical and Community Psychology

- Howard Kipen, M.D., Ph.D.
- Director and Professor of Occupational Health
- Environmental & Occupational Health Sciences Institute
- UMDNJ - Robert Wood Johnson Medical School
- Specialty: Occupational Medicine

- Cheryl Lambing, M.D.
- Assistant Clinical Professor
- Department of Family Medicine
- University of California
- Co-director, Rheumatology Clinics at Ventura County Medical Center
- Faculty, VCMC Family Practice Residency Program
- Specialty: Family Practice

- Andrew Lloyd, M.D.
- Associate Professor, Clinical School of Medical Sciences
- Prince Henry/Prince of Wales Hospital
- University of New South Wales
- Sidney, Australia
- Specialty: General Medicine

- Kathleen A. McCormick, RN, Ph.D
- Scientific Director, HRS, Bioinformatics and Life Sciences
- SRA International, Inc.

- Marcia Scott, M.D.
- VP Medical Services, Retired
- Prudential Disability
- Cambridge, MA
- Specialty: Psychiatry

- Michael Sharpe, M.D.
- Royal Edinburgh Hospital
- The University of Edinburgh
- Edinburgh, Scotland
- Specialty: Psychiatry