# Appendix E. Scale Names and Citations

Scale Name | Acronym | Reference
Beck Depression Inventory | BDI | Beck AT, Ward H, Mendelson M, Mock J, Erbaugh J. An inventory for measuring depression. Arch Gen Psychiatry. 1961; 561-71.
Chalder Fatigue Scale | | Chalder T, Berelowitz G, Pawlikowska T, Watts L, Wessely S, Wright D, et al. Development of a fatigue scale. J Psychosom Res 1993; 37: 147-53.
Checklist of Individual Strength | CIS | Vercoulen JHMM, Swanink CMA, Galama JMD, Fennis JFM, van der Meer JWM, Bleijenberg G. Dimensional assessment in chronic fatigue syndrome. J Psychosom Res 1994; 38: 383-92.
Everyday Attention Questionnaire | EAQ | Martin M. Human Learning 1986; 5: 63-74.
Hopkins Verbal Learning | | Claypoole K, Mahurin R, Fischer ME, Goldberg J, Schmaling KB, Schoene RB, et al. Cognitive compromise following exercise in monozygotic twins discordant for chronic fatigue syndrome: Fact or artifact. Appl Neuropsychol 2001; 8: 31-40.
Karnofsky Performance Score | KPS | Karnofsky DA, Burchenal JH. The clinical evaluation of chemotherapeutic agents in cancer. In: Macleod CM, ed. Evaluation of Chemotherapeutic Agents. New York: New York Columbia University Press; 1949; p.191-205.
Medical Outcomes Study - Short Form 36 | MOS SF-36 | Ware JE, Sherbourne CD. The MOS 36-item short-form health survey (SF-36). Med Care 1992; 30: 473-83.
Physical Activity Rating Scale | PARS | Vercoulen JH, Bazelmans E, Swanink CM, Fennis JF, Galama JM, Jongen PJ, et al. Physical activity in chronic fatigue syndrome: Assessment and its role in fatigue. J Psychiatr Res 1997; 31: 661-73.
Profile of Fatigue-related Symptoms | PFRS | Ray C, Weir WRC, Phillips S, Cullen S. Development of a measure of symptoms in chronic fatigue syndrome: The Profile of Fatigue-Related Symptoms (PFRS). Psychology and Health. 1992; 7: 27-43.
Profile of Mood States | POMS | McNair DM, Lorr M, Droppelman LF. Profile of Mood States. San Diego, Calif: Educational and Industrial Testing Service, 1981.
Sickness Impact Profile | SIP | Bergner M, Bobbitt RA, Kressel S, Pollard WE, Gilson BS, Morris Jr. The Sickness Impact Profile: Conceptual formulation and methodology for the development of a health status measure. Int J Health Serv 1976; 6: 393-415.
Symptom Checklist 90 - Revised | SCL 90R | Derogatis LR, Melisaratos N. The brief symptom inventory. Psychol Med 1983; 13: 595-605.
Wechsler Adult Intelligence Scale - Revised | WAIS-R | Wechsler D. Wechsler Adult Intelligence Scale - Revised (WAIS-R). 1981. New York: Harcourt Brace.