# Appendix D. Quality Scoring Tools

## Study Quality Criteria^1^

Study quality was graded according to design follows:

Ia: Prospective longitudinal study with sufficient patient number, well-matched groups, and well-validated measurement instruments.

Ib: Prospective longitudinal study with low patient number, but with well-matched groups and well-validated measurement instruments.

IIa: Cross-sectional study with sufficient patient number, well-matched groups, and well-validated measurement instruments.

IIb: Cross-sectional study with low patient number, but with well-matched groups and well-validated measurement instruments.

IIIa: Prospective, longitudinal study with sufficient patient number, but with poorly matched groups and/or less well-validated measurement instruments.

IIIb: Prospective, longitudinal study with low patient number, poorly matched groups, and/or less well-validated measurement instruments.

IVa: Cross-sectional study with sufficient patient number, but with poorly matched groups and/or less well-validated measurement instruments.

IVb: Cross-sectional study with low patient number, poorly matched groups, and/or less well-validated measurement instruments.

## CFS Disability Validity Rating Scale (developed internally)

### Internal Validity

(0-1 points, 0 if absent, 1 if present)

1. CFS is defined according to at least one of the acceptable criteria. All patients meet these criteria.
2. Tests for medically determinable physical and/or mental impairment are specified and reported.
3. Control group was similar in clinically important demographic factors at start of the study (well matched).
4. All subjects enrolled (patients and control groups) were accounted for in follow-up.
5. 95% confidence limits and assessment of chance (p-values) are given for numerical results.
6. Work activity or work/disability status reported.

### External Validity

(0-2 points)

7 Patient sample was not self-selected from CFS population (i.e., random or all comers).

## Jadad Quality Score Assessment (RCTs only)^2^

Please read the articles and try to answer the following:

1. Was the study described as randomized (this includes the use of words such as randomly, random, and randomization)?
2. Was the study described as double blind?
3. Was there a description of withdrawals and dropouts?

Scoring the items:

Either give a score of 1 point for each `yes' or 0 for each `no'. There are no in-between marks.

1 point if:

For question 1, the method to generate the sequence of randomization was described and it was appropriate (table of random numbers, computer generated, coin tossing, etc.)

and/or:

If for question 2 the method of double-blinding was described and it was appropriate (identical placebo, active placebo, dummy, etc.)

For question 1, the method to generate the sequence of randomization was described and it was inappropriate (patients were allocated alternately, or according to date of birth, hospital number, etc.)

and/or:

For question 2 the study was described as double-blind but the method was inappropriate (e.g., comparison of tablet vs. injection with no double dummy)

### Guidelines for assessment

1. Randomization:

A method to generate the sequence of randomization will be regarded as appropriate if it allowed each study participant to have the same chance of receiving each intervention and the investigators could not predict which treatment was next. Methods of allocation using date of birth, date of admission, hospital numbers or alternation should not be regarded as appropriate.

2. Double-blinding:

A study must be regarded as double-blind if the word double-blind is used. The method will be regarded as appropriate if it is stated that neither the person doing the assessments nor the study participant could identify the intervention being assessed, or if the absence of such a statement the use of active placebos, identical placebos or dummies is mentioned.

3. Withdrawals and dropouts:

Participants who were included in the study but did not complete the observation period or who were not included in the analysis must be described. The number and the reasons for withdrawal in each group must be stated. If there were no withdrawals, it should be stated in the article. If there is no statement on withdrawals, this item must be given no points.

## References

1 MacMahon KMA, Lip GYH. Psychological factors in heart failure: A review of the literature. Arch Intern Med. 2002;162:509-16. [pmid: 11871918].
2 Jadad AR, Moore A, Carroll D, et al. Assessing the Quality of Reports of Randomized Clinical Trials: Is Blinding Necessary?. Controlled Clinical Trials. 1996;17:1-12. [pmid: 8721797].