# Appendix C. Screening and Data Extraction Forms

AHRQ: DIAGNOSIS AND MANAGEMENT CFS DISABILITY Level II Screening

  Reviewed by ______________________________ First Author ______________________________ | MetaHub Study ID ______________________________ Year Publihsed _________________________________

Status: Accept Reject If accepted, # of refs. from Bib: __________

If REJECT, Specify Reason:

  _____ | Abstracts, letters, comments, editorials, case report.
  _____ | Animal or in vitro or tissue level studies
  _____ | Fewer than 10 patients per study
  _____ | Not related to CFS
  _____ | Not specific to CFS
  _____ | No outcome related to disability (sample of signals: disabled, unfit, incapacitated, lost worktime, sick leave, cost of illness, physical function, work endurance, absenteesim, ADL, productivity, days lost, light duty)
  _____ | Languages other than English
  _____ | Outcomes not extractable
  _____ | Pediatric patients
  _____ | Pharmacodynamic or Pharmacokinetic Study
  _____ | Not US, UK, Canada, Australia or Western Europe
  _____ | Studies published prior to 1996
  _____ | Studies of lab findings/lab technique or focus on pathophysiology of CFS
  _____ | Type of Study: Review or Meta-analysis (Reject for extraction, but hold study for discussion)
  _____ | CFS population mixed with other populations
  _____ | Other ______________________________
If ACCEPT, then record: Geographic location: US__________ Western Europe_____ UK _____Canada _____Australia _____ # Patients Enrolled: _________________ Type of Study: Observational:_____ Retrospective_____Prospective_____XS Interventional:_____ RCT _____ non-RCT_____XS Elements of Causal Pathway presents: Check all applicable elements; 1. In the population of CFS patients _____ Yes _____ No This paper focuses on; 2. The _____ diagnosis and/or _____management Of a; 3. Mediacally determinable (as demonstrated by _____ clinical finding _____ lab test finding _____ other test result); 4. Impairment (_____physical _____ mental); 5. Disability _____ Yes _____No; If yes, please record disability outcome: ___________________________________________ If the answers to 1 and 5 are not both 'Yes", REJECT PAPER for reason: Not population of interest_____ or No outcome of interest _____

Extracted by: ________ | Phase I | Consensed by: ________
Date: ________ | Data Extraction Form | Date: ________
| AHRQ CFS

Impairment: weakening, damage, or deterioration e.g., as a result of injury or disease Disability: loss of function and earning power
Study Characteristics
  Study ID: _______________ First Author: ____________________ Pub. Date: __________
  Study Location: | | Institution: _______________________
  _____US _____Australia/NZ | | ____________________________________________
  _____Canada | | Kin(s):___________________________
  _____Western Europe__________________ | | ____________________________________________
  Patients Enrolled: | _____Total # | Intervention duration: (Max/median)______mos
  | _____CFS
  | _____Controls | Observation duration (Max/median)______mos
  | _____Other
  ________________________________________________ | | Funding Source/Industry Sponsorship:
  | | YES______________________________
  Study Design: | | NR
  Observational: Retrospective / Prospective
  Interventional: RCT / nRCT / XS / Case-series
  CFS Definition Used:
  ____ CDC 1988 _____Oxford 1991
  ____ CDC 1994 _____ Australia 1990
Patient Characteristics
  | Group 1 | Group 2
  # Enrolled / Randomized | / | /
  Age (Mean, Median, Range)
  # Male / # Female | / | /
  Race and/or ethnicity
  Duration of CFS (yrs)
  Education (yrs)

Study ID_____ | Phase I
| Data Extraction Form
| AHRQ CFS

Impairment | Disability | Indeterminate

Activities of Daily Living (ADL) | Fennell Phase Inventory | Physical Activities Rating Scale (PARS)
Actometer | General Health Questionaire (GHQ) | Quality of Life (QoL)
Beck Depression Inventory (BDI) | Illness Management Questionaire (IMQ) | Sickness Impact Profile (SIP)
Checklist Individual Strength (CIS) | Karnofsky Scale | Walking
Activities | Likert Scale | Mobility
CFS Severity Index | Medical Outcomes Study | Work & Social Adjustment Scale
Fatigue Severity Scale | MOS-SF-23
| MOS - SF - 36

Extracted by: ________ | Phase II DEF | Consensed by: ________
Date: ________ | AHRQ CFS | Date: ________

Study Characteristics
  Study ID: _______________ First Author: ____________________ Pub. Date: _______
  Study Location: | | Institution:_______________________
  _____US _____Australia/NZ | | ___________________________________
  ____Canada | | Kin(s):___________________________
  ____Western Europe__________________ | | ____________________________________
  Patients Enrolled: | ___ Total # | ____ Single time point only
  | ____ CFS
  | ____ Healthy Controls | CFS Definition Used (all that apply):
  | ____ Other Controls | ____ CDC 1988 _____Oxford 1991
  _________________________________ | | ____ CDC 1994 _____ Australia 1990
  Study Design: | | Quality Score:
  Retrospective / Prospective | | _____(rand) +_____(blind) +_____(w/drwl) =_____(Total)
  RCT / nRCT / Case-series
  XS | | Accrual Years: _______-_______

Entered: ___________ QC'd: _____________

First Author _____________ | Phase II DEF
Study ID _______________ | AHRQ CFS

Patient Characteristics (Time _0_)
Group Category: | CFS
# Enrolled OR Randomized
Age (Mean OR Median / Range) | / | /
# Male/ # Female | / | /
Race and/or ethnicity:
(W / B / H / A /___) | / / / / | / / / /
CFS or symptom duration (years) Mean OR Median / Range | / | /
inclusion criteria min / max (yrs) | / | /
Total education (years)
Employment Status:
Employed (# of patients)
Full time
Part time
Unemployed (# of patients)
Disability benefits (# of patients)
Disability or temporary sick leave (# pts)
Work limitations due to illness (# pts)
Mean OR Median # hours/week worked OR % of time worked
Psychiatric and other history:
# pts w/ any current psychiatric dx
# pts w/ lifetime psychiatric dx (specify)
Dysthymia
Generalized anxiety disorder
Major depression
Panic disorder
Somatization disorder
Other lifetime diagnosis: (specify)
# pts w/ other dx (specify):
# pts currently on medication (specify):

Entered: ___________ QC'd: _____________

First Author _____________ | Phase II DEF
Study ID _______________ | AHRQ CFS

Intervention

Categories:
B = Behavioral Therapy | E = Physical/Exercise Therapy
Ψ = Psychiatric Therapy | D = Dietary Therapy
Rx = Drug Therapy | P = Placebo O = Other: __________________

Outcomes @ T_1_ (________ months after T_0_)
| Group 1 (CFS) | Group 2:
# of pts. Evaluated at follow-up
Employed (# of patients)
Unemployed (# of patients)
Disability benefits (# of patients)
Disability benefits or temp. sick leave (# pts)
Work limitations due to illness (# pts)
Mean OR Median # hours/week worked
Symptom Improvement:
# pts Improved
# pts No change
# pts Worse

Entered: ___________ QC'd: _____________

First Author _____________ | Phase II DEF
Study ID _______________ | AHRQ CFS

Group 1 (CFS)

*Objective of Subjective Scale
Domain key:
C = Cognitive | G = General Health | L = Lab Measures | P = Physical Activity
DS = Disease severity/symptoms | E = Exercise Testing | M = Mental (Psych/Affective) | W = Work
| | | O = Other ______________________

Other Outcomes (circle or specify): | Between-scale correlations | Work status correlations
| ________________ | ________________ | _________________ | _________________
| ________________ | ________________ | _________________ | _________________
Other groups/timepoints (specify): | t _nadir_ | type of profession | Income level
| ________________ | ________________ | _________________ | _________________

Entered: ___________ QC'd: _____________

First Author _____________ | Phase II DEF
Study ID _______________ | AHRQ CFS

Group 2

*Objective of Subjective Scale
Domain key:
C = Cognitive | G = General Health | L = Lab Measures | P = Physical Activity
DS = Disease severity/symptoms | E = Exercise Testing | M = Mental (Psych/Affective) | W = Work
| | | O = Other _______________________________

Other Outcomes (circle or specify): | Between-scale correlations | Work status correlations
| ________________ | ________________ | _________________ | _________________
| ________________ | ________________ | _________________ | _________________
Other groups/timepoints (specify): | t _nadir_ | type of profession | Income level
| __________________ | __________________ | ___________________ | ___________________

Entered: ___________

QC'd: _____________