# Appendix A. Work Plan and Causal Pathway

Review of the Current Medical and Scientific Research Related to Disability and Chronic Fatigue Syndrome

Contract # 290-97-0016 December 11, 2001

## 1. Objective

To conduct a systematic review of the literature and develop an evidence report that will assist the Social Security Administration (SSA) in ensuring that it is using the most current medical knowledge for evaluating disability in persons with Chronic Fatigue Syndrome (CFS). The evidence report will also serve to augment SSA's knowledge base concerning new scientific or medical developments in the diagnosis and treatment of persons with CFS.

Seven key questions were posed to guide the systematic review:

1. What is the evidence that individuals with CFS have a discrete physical impairment ? What is the evidence that individuals with CFS have a coexisting mental impairment ? For example, what is the evidence that comorbid psychiatric/neurologic conditions frequently reported in CFS are present and, if present, are a result of CFS or are an integral part of the CFS disease process?
2. What is the evidence that there are specific clinical tests that can be used to reliably diagnose CFS, for example, are there specific anatomical, psychological, physiological, or medical imaging indices that are diagnostic for CFS?
3. When cognitive deficits are alleged, what is the evidence that individuals with CFS have such deficits and what is the evidence that these potential deficits contribute to functional limitations or inability to do work activity ?
4. Do current neuropsychological tests reliably detect cognitive or mental impairments in the CFS population? Are there certain tests that are preferred in terms of reliability and validity? Are there certain tests or diagnostic tools that contain reliable correlations between test result(s) and either ability or inability to perform designated work-related functions (e.g., ability to relate to coworkers and supervision appropriately, ability to maintain concentration or pace, suitable memory capacity for work activities, etc.).
5. What treatments have been shown to be most effective for CFS in terms of restoring an individual's ability to do work activity?
6. What are the patient characteristics that best define improvement or positive outcomes in the CFS population such that they experience improvement in functioning? Where it occurs, how is this improvement in functioning related to the ability to engage in work activity ?
7. What evidence is available from related fields (e.g., sleep medicine, autonomic nervous system abnormalities, endocrinology, gastrointestinal illness, neurocognitive therapy) that would be applicable to the assessment, functional evaluation, and treatment for CFS?

## 2. Background

The topic "Review of the Current Medical and Scientific Research Related to Disability and CFS" was nominated by SSA to assist in answering several key questions of diagnosis and management of disability in persons with CFS. This research will assist SSA in ensuring that it is using the most current medical knowledge for evaluating disability in persons with CFS.

Disability is defined by the SSA as the inability to engage in any substantial gainful activity by reason of any medically determinable (by clinical signs, symptoms, and laboratory findings) physical or mental impairment. Disability is thus the crux of this Task Order, and it should be possible to focus the review on CFS literature addressing diagnosis, measurement, and treatment of disability resulting from medically determinable physical and mental impairment in persons with CFS, even though the etiology, diagnosis, and treatment of CFS itself remain elusive.

## 3. Methods

MetaWorks will apply the latest and established best methods in the evolving science of review research.

A flow diagram outlining the systematic review process is located in Appendix A.

The following tasks will proceed sequentially.

Expert Panel Meeting

In consultation with the Task Order Officer (TOO), through networking with our nominating partner, our co-principal investigator, professional organizations, and purchasers of health care, a panel of experts with a broad range of clinical expertise in CFS was convened in Washington, DC, on November 30, 2001. This meeting had three primary purposes:

1. To establish a working definition of CFS for purposes of this task order.
2. To refine the key questions.
3. To receive the experts' recommendations regarding the breadth of the literature to be reviewed, analyses that should be performed, sources of data that should be accessed, etc., to ensure an evidence report that is responsive to SSA concerns.

A preliminary review of the literature was performed prior to the meeting and the results were shared with the attendees at the meeting. This included the preliminary search strategy and databases used, criteria for determining eligibility for inclusion in evidence synthesis, and results of Level I and Level II screening.

For purposes of guiding the literature review, a draft causal pathway was also developed prior to the meeting and shared with attendees who were asked to provide feedback.

Experts who attended the meeting have been asked to form the Technical Expert Panel (TEP). They will be asked to respond to questions during the process of the literature review, and will be asked to review the draft Evidence Report.

Results of expert meeting

The full report describing the expert meeting has been submitted to AHRQ. The following summarizes the decisions reached at the meeting:

Definition of CFS

It was agreed that four diagnostic criteria for CFS would be accepted for the purpose of this task order:

- 1988 CDC criteria
- 1994 CDC revised criteria
- 1991 Oxford criteria
- 1990 Australia criteria

The details of these criteria are outlined in Appendix B.

### Definition of Disability

As defined in the task order and refined and agreed upon by the expert panel, this review will focus on disability in persons with CFS. Disability, per SSA guidelines, is defined based on inability to engage in any substantial gainful activity by reason of any medically determinable (by clinical signs, symptoms, and laboratory findings) physical or mental impairment. Disabled persons cannot do work that they did previously, and cannot adjust to other work. Disability must be expected to last for at least one year. Therefore, treatment and diagnosis will be considered only as they relate to disability in CFS.

#### Revised Key Questions

1. What is the evidence that some individuals with CFS have discrete impairments that are associated with disability? (Note that impairments include both physical and mental impairments).
2. What is the evidence that in the CFS population, current neuropsychological tests reliably detect cognitive or affective impairments associated with decreased ability to work?
3. What is the evidence that in individuals with CFS, treatments are effective in restoring the ability to work?
4. What patient characteristics best define improvement in functioning or positive outcomes in the CFS population? Where it occurs, how is improvement in functioning related to the ability to engage in work activity?

The previous question 2 was removed, as it was agreed that this question was not directly pertinent to disability. Questions 1 and 3 were combined into Question 1. Question 7 has been removed, as it was agreed that this question falls outside of the scope of this project.

No additional questions were recommended by the expert panel.

#### Breadth of Literature

It was agreed that the literature search should go back to 1988, when the first case definition of CFS was published. It was also agreed that searching Medline, Current Contents?, Cochrane, Psychlit, and bibliographies of accepted articles and recent review articles should be sufficient to identify the majority of articles that address the key questions.

The inclusion and exclusion criteria were reviewed. It was agreed that English language literature from the United States, Canada, Western Europe, and Australia would be sufficient.

The expert panel did not recommend searching additional databases.

### Literature Screening

This task involves identifying and retrieving all potentially relevant literature on the current medical and scientific research related to CFS disability, categorizing by study design, and other key study, patient, and intervention level details for each of the five key questions. Studies which meet the eligibility criteria (see below) will undergo data extraction and data entry.

The published literature, English language and adult population only will be searched from 1988 to 2001, utilizing the following search strategy:

fatigue syndrome, chronic [MeSH] or chronic fatigue [syndrome]. Limits: English language, human subjects.

In addition to the MedLine search described above, MetaWorks will search other suitable electronic databases, including Current Contents?, Cochrane Controlled Trials Register (CCTR), and PsychLit, as well as a manual search of accepted study references and review articles published within the past two years. The Cochrane Library and the National Guidelines Clearinghouse will also be searched for additional information on these topics. In addition, pertinent Internet sites will be checked for potential leads to additional studies.

The search cut-off date will be November 15, 2001 and the retrieval cut-off date will be determined after all abstracts have been screened.

All citations and abstracts will be printed and screened at MetaWorks for any mention of diagnosis and/or treatment of CFS disability or impairment (Level 1 screening) and reviewed for the following exclusion criteria:

### Exclusion Criteria

Abstracts demonstrating any of the following characteristics will be rejected:

- Review, meta-analysis, abstracts, letters, case reports, editorials, and commentaries.
- Unpublished study reports and abstracts.
- Studies published prior to 1988.
- Studies written in languages other than English.
- Studies not conducted in the US, Canada, Australia or Western Europe.
- Pharmacokinetic and pharmacodynamic studies.
- Animal or in vitro or tissue level studies.
- Studies not related to or not specific to CFS disability or impairment.
- Studies containing < 2 patients as total sample size.
- Pediatric patient population.
- No information related to disability or impairment.
- Outcomes not extractable.
- Mixed population (unable to separate CFS from other populations).
- Studies focused on pathophysiology of CFS (lab findings/lab technique).

In some cases, it may not be possible from the abstract alone to determine the eligibility of the study. Full studies of abstracts lacking obvious exclusion criteria will be retrieved for Level 2 screening, where inclusion and exclusion criteria will be applied.

### Inclusion Criteria

The following study designs will be accepted: observational [prospective, retrospective, and cross sectional (XS)], or interventional [randomized controlled trials (RCTs), non-randomized controlled trials (nRCTs), uncontrolled case series (UCS)].

- Adult patients with CFS and disability.
- Studies focusing on diagnosis and/or management of a medically determinable physical or mental impairment in CFS.
- Medically determinable impairment must be demonstrated by clinical finding, lab or other test result:
- physical findings, lab tests, imaging tests
- assessment of cognitive or mental impairments
- Studies reporting at least one objective measure related to disability or impairment as measured by:
  - Physical function
  - Work endurance
  - Work or school absenteeism
  - Sick leave
  - Days lost
  - Light duty
  - Productivity
  - Activities of Daily Living (ADL)
  - Quality of Life (QoL)
  - Hospitalizations or admissions to chronic care facilities
  - Emergency room or clinic visits
  - oxygen capacity (VO_2_)
  - neuropsychological or QoL measures of functioning that are derived from validated instruments.
  - Other

Upon completion of Level 2 screening, all accepted articles will be eligible for data extraction.

### Causal Pathway

Based on the results of a preliminary literature review, a Causal Pathway was developed (Appendix C). All of the events described in this pathway take place within the CFS universe; i.e., only patients already diagnosed with CFS are included. Patients with fibromyalgia, Gulf War Syndrome, and other related conditions are not included. To diagnose disability in the CFS universe, patients must have a medically determinable condition (defined by clinical signs and symptoms, laboratory abnormalities, or other abnormalities), leading to physical or mental impairment, that results in disability, as defined by the SSA. This Causal Pathway was presented at the Experts Meeting described above.

### Assessment of Quality in Primary Studies

All studies will be appraised according to a previously published Level of Evidence (Appendix D). An additional assessment of external and internal validity will be developed.

### Data Extraction

Data extraction forms (DEFs) will be created specifically for this project. Data will be extracted onto the DEF independently by one reviewer and the completed DEF will be 100% checked against the original articles by a second reviewer. Any differences will be resolved by consensus; thus, two reviewers must agree on all data. In all cases, at least one physician reviews all data elements. The data will then be entered in MetaWorks' relational database, MetaHub?. At this time, it is anticipated that the following data elements will be extracted.

These preliminary selections may change prior to finalization of the DEF, based on initial review of the literature.

#### Study level characteristics

- Publication year
- Geographical location of study
- Study design
- Methodological assessment
- Level of Evidence (I-V)
- Assessment of External and Internal Validity
- Total number of patients enrolled
- If RCT, number of patients randomized
- Funding source/industry sponsorship (name if yes or no/NR)
- Intervention duration
- Observation duration
- CFS definition used
  - CDC 1988
  - Revised CDC 1994
  - Oxford 1991
  - Australia 1990
- Elements of CFS definition identified
- Duration of symptoms
- Relation to exertion
- Relation to rest
- Reduction in previous levels of occupational, educational, social, or personal activity
- Laboratory screening tests
- Clinical findings (sore throat, tender lymphadenopathy, muscle pain, joint pain, new headaches)
- Unrefreshing sleep
- Postexertion malaise
- Neuropsychological symptoms

#### Patient characteristics (by group)

- Age: years (mean or median, range)
- Gender distribution
- Race and/or ethnicity
- Age at diagnosis
- Duration of symptoms
- Presence of symptoms listed in CFS diagnostic criteria
- Baseline healthcare utilization
- Hospitalizations or admissions to chronic care facilities
- Emergency room or clinic visits
- Other
- Baseline work-related characteristics
- Work or school absenteeism
- Use of sick leave
- Productivity
- Other
- Baseline occupation or employment status
- Baseline ADL assessment (instrument and score)
- Baseline QoL (instruments and score or result on domains related to impairment and/or disability
- Baseline VO_2_
- Baseline impairment
- Physical _____________ determined by _________test and baseline result
- Mental ______________ determined by __________test and baseline result
- Other co-morbid conditions

#### Diagnostic Interventions (by group)

- Physical Impairment (test and baseline result)
- Mental Impairment (test and baseline result)

#### Treatment interventions (by group)

- Treatment of physical impairment
- Treatment of mental impairment

#### Impairment or Disability Outcomes (by group)

- Healthcare utilization outcomes
- Hospitalizations or admissions to chronic care facilities
- Emergency room or clinic visits
- Other
- Work-related outcomes
- Work or school absenteeism
- Use of sick leave
- Productivity
- Other
- Number of patients with changed occupation or employment status
- Other outcomes:
- Symptomatic improvement or worsening (documented motor improvement and other manifestations of disease severity)
- Follow-up ADL assessment (instrument and score)
- Follow-up QoL (instruments and score or results on domains related to impairment and/or disability)
- Follow-up VO_2_
- Follow-up impairment
- Physical _____________ determined by _________test and follow-up result
- Mental ______________ determined by __________test and follow-up result

### Database Development

All consensed data will be entered into the MetaWorks MetaHub^™^ database. 100% of entered data is checked back to the DEFs after each form is completely entered. In addition, a 20% random sampling of data in the completed database will be checked by the QC group at MetaWorks against the data extraction forms. All discrepancies in data are reconciled by referring back to the original papers. Error rates in excess of 2% of checked data will trigger a 100% check of all data elements in the data base.

Once the accuracy of the database has been verified as described above, it is locked. No further changes are allowed after the data is locked. This is the dataset that will be used by the statisticians for analysis and to create raw data tables displaying key data elements of interest, by study.

All data are maintained in the MetaHub database, in a manner suitable to allow outputs to: a) spreadsheet programs for customized evidence table displays; b) to statistical programs for analysis.

## 4. Data Synthesis & Reporting

Qualitative and quantitative syntheses will be performed, as data permit, in order to answer the key questions. Results will be provided in a draft Final Report.

## 5. Peer Review

The draft Evidence Report will be circulated for feedback to the TEP and external peer reviewers.

Each peer reviewer will also receive a reviewer's form to be completed and returned to MetaWorks. This form will contain a checklist of items to be assessed as well as provide room for free-form text comments. The form will be pre-screened by the AHRQ TOO and SSA representatives prior to being sent to the peer reviewers. Reviewers will be given at least 3 weeks to respond. All feedback will be stored in a project folder at MetaWorks. A statement of response to each reviewer's comments will be prepared and stored with each reviewer's comments. This response will also be returned to the reviewer.

A summary of the main comments and responses will be prepared and shared with the TOO. Reviewer comments and additional analyses and text resulting from the response to reviewer critique will be incorporated into the final iteration of the evidence report.

## 6. Manuscript

After completion of the final Evidence Report, MetaWorks will prepare a manuscript describing key aspects of the work for publication in a peer reviewed journal. An abstract of same may also be submitted for presentation at professional meetings.

## Work Plan Acceptance

AHRQ

By: ___________________________ Name: Marian James, PhD Title: Task Order Officer

Social Security Administration

By: ____________________________ Name: Frank Schuster, MD Title: SSA Representative

MetaWorks Inc.

By: ____________________________ Name: Cindy Levine, M.D. Title: Principal Investigator, MetaWorks

By: ____________________________ Name: Nelson Gantz, M.D. Title: Co-Principal Investigator, Pinnacle Health System

## Attachment A: MetaWorks Flow Diagram

[image]

## Attachment B: CFS Diagnostic Criteria

### CDC 1988 CFS definition

- Major criteria:
  - new onset of persistent or relapsing, debilitating fatigue in a person without a previous history of such symptoms that does not resolve with bedrest and that is severe enough to reduce or impair average daily activity to less than 50% of the patient's premorbid activity level for at least 6 months
  - fatigue that is not explained by the presence of other evident medical or psychiatric illnesses
- Minor criteria:
  - at least six symptoms plus at least two signs, or at least eight symptoms from the list below
  - Symptoms:
    - mild fever or chills
    - sore throat
    - painful adenopathy (posterior or anterior, cervical or axillary)
    - generalized muscle weakness
    - myalgias
    - prolonged generalized fatigue after previously tolerated levels of physical activity
    - generalized headaches
    - migratory arthralgia without swelling or redness
    - neuropsychologic complaints
    - sleep disturbance
    - main symptom complex developing over a few hours to a few days
  - Physical Signs:
    - low-grade fever
    - nonexudative pharyngitis
    - palpable or tender anterior or posterior, cervical or axillary lymph nodes

From: Holmes GP, Kaplan JE, Gantz NM, et al. Chronic fatigue syndrome: A working case definition. Ann Intern Med 1988; 108: 387-9.

### CDC 1994 CFS definition

- Clinically evaluated, unexplained, persistent or relapsing chronic fatigue lasting > 6 months
  - of new or definite onset
  - not the result of ongoing exertion
  - not substantially alleviated by rest
  - substantial reduction in previous levels of occupational, educational, social, or personal activities
  - Clinical evaluation:
    - History and Physical, Mental Status examination
    - Laboratory screening including CBC, ESR, LFTs, TP, albumin, globulin, CA, PO_4_, glucose, BUN, CRE, electrolytes, TSH, urinalysis
- 4 symptoms concurrently present for > 6 months
  - Sore throat
  - Tender cervical or axillary lymph nodes
  - Muscle pain
  - Multijoint pain
  - New headaches
  - Unrefreshing sleep
  - Postexertion malaise
- Exclusion criteria
  - Active, unresolved, or suspected disease likely to cause fatigue
  - Psychotic, melancholic or bipolar depression-(but not uncomplicated major depression)
  - Psychotic disorders
  - Dementia
  - Anorexia or bulimia nervosa
  - Alcohol or other substance misuse
  - Severe obesity

From: Fukuda K, Straus SE, Hickie I, et al. The chronic fatigue syndrome: A comprehensive approach to its definition and study. Ann Intern Med 1994; 121: 953-9.

### Oxford CFS definition

- Severe, disabling fatigue lasting > 6 months that:
  - affects both physical and mental functioning
  - is present for > 50% of the time
- Other symptoms may be present:
  - myalgia
  - sleep disturbances
  - mood disturbance
- Exclusion criteria:
  - Active, unresolved, or suspected disease likely to cause fatigue
  - Psychotic, melancholic or bipolar depression-(but not uncomplicated major depression)
  - Psychotic disorders
  - Dementia
  - Anorexia or bulimia nervosa

From: Sharpe MK, Archard LC, Banatvala JE, et al. A report - chronic fatigue syndrome: Guidelines for research. J R Soc Med 1991; 84: 118-21.

### Australian CFS definition

- Disabling and prolonged feelings of physical tiredness or fatigue, exacerbated by physical activity.
- Present for at least 6 months.
- Unexplained by an alternative diagnosis reached by history, laboratory, or physical examinations.
- Accompanied by new onset of neuropsychological symptoms including impaired short-term memory and concentration, decreased libido, and depressed mood. These symptoms usually have their onset at the same time as the physical fatigue, but are typically less severe and less persistent than those seen in classic depressive illness.
- Exclusion criteria:
  - Chronic medical condition that may result in fatigue
  - History of schizophrenia, other psychotic illnesses, or bipolar affective disorder
- Drug or alcohol dependence makes CFS very unlikely.

From: Lloyd AR, Hickie I, Boughton CR, et al. Prevalence of chronic fatigue syndrome in an Australian population. Med J Aust 1990; 153: 522-8.

## Attachment C: Causal Pathway

[image]

References used:

1. Fukuda K, Straus SE, Hickie I, et al. The chronic fatigue syndrome: A comprehensive approach to its definition and study. Ann Intern Med 1994; 121: 953-9.

2. SSR 99-2p: Policy interpretation ruling Titles II and XVI: Evaluating cases involving chronic fatigure syndrome (CFS).

## Attachment D: Level of Evidence

1. Evidence based on randomized controlled clinical trials (or meta-analysis of such trials) of adequate size to ensure a low risk of incorporating false-positive or false-negative results.
2. Evidence based on randomized controlled trials that are too small to provide level I evidence. These may show either positive trends that are not statistically significant or no trends and are associated with a high risk of false-negative results.
3. Evidence based on nonrandomized, controlled or cohort studies, case series, case-controlled studies or cross-sectional studies.
4. Evidence based on the opinion of respected authorities or that of expert committees as indicated in published consensus conferences or guidelines.
5. Evidence which expresses the opinion of those individuals who have written and reviewed these guidelines, based on their experience, knowledge of the relevant literature and discussion with their peers.

These 5 levels of evidence do not directly describe the quality or credibility of evidence. Rather, they indicate the nature of the evidence being used. In general, a randomized, controlled trial has the greatest credibility (level I); however, it may have defects that diminish its value, and these should be noted. Evidence that is based on too few observations to give a statistically significant result is classified as level II. In general, level III studies carry less credibility than level I or II studies, but credibility is increased when consistent results are obtained from several level III studies carried out at different times and in different places.

Decisions must often be made in the absence of published evidence. In these situations it is necessary to use the opinion of experts based on their knowledge and clinical experience. All such evidence is classified as "opinion" (levels IV and V). Distinction is made between the published opinion of authorities (level IV) and the opinion of those who have contributed to these guidelines (level V). However, it should be noted that by the time level V evidence has gone through the exhaustive consensus-building process used in the preparation of these guidelines, it has achieved a level of credibility that is at least equivalent to level IV evidence.

From: The Steering Committee on Clinical Practice Guidelines for the Care and Treatment of Breast Cancer. CMAJ 1998:158