# Appendixes

Appendix A. Work Plan and Causal Pathway

Appendix B. Expert Meeting Information

Appendix C. Screening and Data Extraction Forms

Appendix D. Quality Scoring Tools

Appendix E. Scale Names and Citations

Appendix F. Technical Expert Panel Members and Peer Reviewers

Appendix G. Reviewer Questionnaire

Appendix H. Accepted Studies Log

Appendix I. Rejected Studies Log