# Meta-Analyses

Results of the meta-analyses of diagnostic test performance are presented in this chapter. We used the summary ROC method (Figure S1, S2) and a random effects model to combine independently the sensitivity and specificity values across studies (Table S1–S3). The methodologies for performing meta-analyses were described in Chapter 2.

## SROC and Combined Sensitivity and Specificity Analyses

## Figure S1. SROC curve of AirShields Minolta bilirubinometer Measuring at Forehead as a Screening Tool for Serum Bilirubin Level ≥ 13 mg/dL in Healthy Infants with GA ≥ 34 weeks not on Phototherapy or Exchange Transfusion

[image]

Table S1. Pooled Estimates of the Test Performance of AirShields Minolta TcB measurements to Serum Bilirubin Level of 13 mg/dL at Forehead in Healthy Infants with GA ≥ 34 weeks not on Phototherapy or Exchange Transfusion

Study Characteristics and Pooled Results
# | Study | TP/FN | FP/TN | Sens | 95% CI | Spec | 95% CI | 1/Var. | Threshold
1 | Lin | 12/6 | 57/230 | 0.67 | 0.41–0.86 | 0.80 | 0.75–0.84 | 3.9427 | Var
2 | Bilgen | 17/0 | 35/44 | 1.00 | 0.80–1.00 | 0.56 | 0.44–0.67 | 0.8560 | 13
3 | Knudsen, 1993 | 30/0 | 28/15 | 1.00 | 0.88–1.00 | 0.35 | 0.21–0.51 | 0.8577 | 15
4 | Tsai | 19/2 | 16/141 | 0.90 | 0.68–0.98 | 0.90 | 0.84–0.94 | 2.1373 | 16
5 | Bhutta | 35/5 | 28/35 | 0.88 | 0.72–0.95 | 0.56 | 0.43–0.68 | 3.8087 | 17
6 | Knudsen, 1990 | 24/4 | 66/113 | 0.86 | 0.67–0.95 | 0.63 | 0.56–0.70 | 3.6711 | 17
7 | Harish | 24/1 | 14/21 | 0.96 | 0.78–1.00 | 0.60 | 0.42–0.76 | 1.4773 | 18
8 | Schumacher | 16/1 | 20/69 | 0.94 | 0.69–1.00 | 0.78 | 0.67–0.85 | 1.5284 | 20
9 | Karrar | 36/13 | 11/95 | 0.73 | 0.59–0.85 | 0.90 | 0.82–0.94 | 5.1256 | 21
10 | Taha | 11/15 | 8/96 | 0.69 | 0.42–0.88 | 0.92 | 0.85–0.96 | 2.5759 | 22.5
11 | Maisels | 7/0 | 5/145 | 1.00 | 0.59–1.00 | 0.97 | 0.92–0.99 | 0.6847 | 24
| Total (Range) | 268 | 1292 | 0.67–1.00 | | 0.35–0.97
| | REM Pooled | | 0.85 | 0.77–0.91 | 0.77 | 0.66–0.85

Var = TcB ≥ 11, ≥ 16, or ≥ 20 on the 1st, 2nd, and following days of life

Table S2. Pooled Estimates of Test Performance of AirShields Minolta TcB measurements to Serum Bilirubin Level of 11 mg/dL at Forehead in Healthy Infants with GA ≥ 34 weeks not on Phototherapy or Exchange Transfusion

Study Characteristics and Pooled Results
# | Study | TP/FN | FP/TN | Sens | 95% CI | Spec | 95% CI | 1/Var. | Threshold
1 | Dai | 8/0 | 11/21 | 1.00 | 0.63–1.00 | 0.66 | 0.47–0.81 | 0.7232 | 17
2 | Sheridan-Per | 4/0 | 13/40 | 1.00 | 0.40–1.00 | 0.75 | 0.61–0.86 | 0.6259 | 20
3 | Fok | 16/0 | 64/122 | 1.00 | 0.79–1.00 | 0.66 | 0.58–0.72 | 0.8706 | 22
| Total(Range) | 28 | 271 | 1.00–1.00 | | 0.66–0.75
| | REM Pooled | | 0.95 | 0.77–0.99 | 0.67 | 0.61–0.73

## Figure S2. Summary ROC of AirShields Minolta bilirubinometer to Serum Bilirubin Level of 11 mg/dL at Forehead in Healthy, Term or Near-Term Infants not on Phototherapy or Exchange Transfusion

[image]

Table S3. Pooled Estimates of Test Performance of AirShields Minolta TcB measurements to Serum Bilirubin Level of 15 mg/dL at Forehead in Healthy Infants with GA ≥ 34 weeks not on Phototherapy or Exchange Transfusion

Study Characteristics and Pooled Results
# | Study | TP/FN | FP/TN | Sens | 95% CI | Spec | 95% CI | 1/Var. | Threshold
1 | Knudsen 1992 | 21/7 | 38/72 | 0.75 | 0.55–0.89 | 0.65 | 0.56–0.74 | 4.6245 | 9
2 | Knudsen 1990 | 68/27 | 21/91 | 0.72 | 0.61–0.80 | 0.81 | 0.73–0.88 | 9.2969 | 10.2
3 | Maisels | 20/2 | 14/121 | 0.91 | 0.70–0.98 | 0.90 | 0.83–1.94 | 2.1111 | 20
| Total (Range) | 145 | 357 | 0.72–0.91 | | 0.65–0.90
| | REM Pooled | | 0.76 | 0.64–0.85 | 0.80 | 0.63–0.91

## Meta-analysis of Correlation Coefficients

The results of the meta-analysis of correlation coefficients should be interpreted carefully due to several limitations:

- The correlation coefficient does not provide any information about the clinical utility of the diagnostic test.
- Although correlation coefficients (r) measure the association between transcutaneous bilirubin and “standard” serum bilirubin measurements, the correlation coefficient is highly dependent on the distribution of serum bilirubin in the study population selected.
- Correlation measures ignore bias and measure relative rather than absolute agreement.

The analytic issues, which arose regarding potential duplication of information, were described in Chapter 2, Methodology.

The meta-analysis of correlation coefficients figures on the following pages indicate:

- Abbreviated name of the measurement site/metric being analyzed (e.g. forehead)
- Article citation (author and year)
- Number of subjects used in the comparison
- Graphic description of the individual effects and 95% confidence intervals
- Combined random effects model estimate and its confidence bounds

## Figure S3. Overall Meta-Analysis of Correlation Coefficients for Minolta AirShields bilirubinometer

[image]

## Figure S4. Meta-analysis of Correlation Coefficients for Minolta AirShields Bilirubin Measurements on Different Measurement Sites

[image]

## Figure S5. Effect of Gestational Age or Birth Weight

[image]

## Figure S6. Effect of Race or Skin Color Measured at Forehead

[image]

## Figure S7. Effect of Phototherapy

[image]

## Figure S8. Overall Meta-Analysis of Correlation Coefficients for BiliCheck™ Measurements

[image]

## Figure S9. Overall Meta-Analysis of Correlation Coefficients for Ingram Icterometer Bilirubin Measurements

[image]