# Evidence Tables

Evidence Table 1. Question 1 - Studies evaluating association of neonatal hyperbilirubinemia to neurodevelopmental outcomes - Part I

Author, Year | Demographics | | | | Inclusion Criteria | Exclusion Criteria | Study Design (Duration)
Bengtsson, 1974 [#74170112] | Location: Sweden | | | | Healthy term infants with SB > 20 mg/dl | Any iso-immunization (positive Coombs tests) | Prospective cohorts (6.5–13 years)
| Setting: Hospital | | | | BW > 2500 g | Obstructive jaundice
| Birth years: 1957 to 1962 | | | | GA 38–42 | Sepsis, Asphyxia, other serious neonatal disorders
| Number of centers: ND | | | | | Mom with prolonged labor, difficult delivery, C/S or other
| Enrolled subjects: 111 (115 controls) | | | | | pregnancy complication
| Evaluated subjects: 105 (113)
| Mean GA (range): 38–42 wks
| Mean BW (range): > 2500 g
| Mean Apgar score at 5 min: ND
| Breastfed: ND
| Male: ND
| Race: ND
Boggs, 1967 [#67261091] | Location: US | | | | Unselected live-born singletons sample | Death (426) | Preliminaryreport of a prospective longitudinal study
| Setting: CPP | | | | For current review, only infants with BW > 2500 g were evaluated | Institutionalization (8)
| Birth years: 1959 to 1964
| Number of centers: 14
| Enrolled subjects: 23000
| Evaluated subjects: 18484
| Mean GA (range): ND
| Mean BW (range): > 2500 g
| Mean Apgar score at 5 min: 3% < 7; 97% 7–10
| Breastfed: ND
| Male: ND
| Race: ND
Boo, 1994 [#95018454] | Location: Malaysia | | | | Jaundiced term infants admitted to the out-born nursery | Aminoglycoside Rx (5) | Prospective and retrospective cohorts: data collection was prospective but analysis was retrospective
| Setting: Hospital | | | | | Congenital cyanotic heart disease (1)
| Birth years: 6/1/1984 to 12/32/1984 | | | | | Congenital infection (2)
| Number of centers: 1
| | [underlined: Controls] | | [underlined: Hearing loss]
| Enrolled subjects: | Total=136
| Evaluated subjects: | 100 | | 28
| Mean GA (range): | 39.9±0.6 | | 39.6±1.0 wks
| Age at recruitment: days | 7.1±3.6 | | 11.6±18.6
| Mean BW (range): | 3021.7±501.8 | | 3023±365.1 g
| Mean Apgar score at 1 min: | ND | | ND
| Breastfed (%): | 20% | | 32%
| Male (%): | 80/128=62.5%
| Race (%) -
| Malays: | 50% | | 54%
| Chinese: | 38% | | 29%
| Indians: | 11% | | 10%
Chen, 1995 [#96017937] | Location: Taiwan | | | | GA 38–41 wks | ND | Prospective longitudinal study (2 year)
| Setting: Hospital | | | | Uncomplicated pregnancy and delivery
| Birth years: ND | | | | Apgar ≥ 7 @ 5 min
| Number of centers: 1 | | | | Normal fetal growth
| | [underlined: Subjects] | | [underlined: Controls] | No congenital abnormalities
| Enrolled subjects: | 72 | | 22 | Uneventful neonatal course except jaundice
| Mean GA (range): | 39.2±1.1 | | 39.5±1.1 wks
| Mean BW (range): | 3436.7 | | 3350.2±241 g
| Mean Apgar score at 5 min: | | ≥7
| Breastfed (%): | ND | | ND
| Male (%): | 53% | | 55%
| Race (%): | Asian | | Asian
Culley, 1970 [#70266548] | Location: UK | | | | Non-hemolytic jaundice group: jaundice infants in nursery diagnosed by icterometers. For current review, only infants with BW ≥ 2500 g were evaluated. | No follow-up for mild jaundice (icterometer reading ≤ 3) infants. | Prospective cohort (6 years)
| Setting: Hospital | | | | Controls: non-jaundiced infants. For current review, only infants with BW ≥ 2500 g were evaluated. | Lost to follow-up or incomplete assessment at 6 years old.
| Birth years: 1958 to 1966
| Number of centers: 1
| Enrolled subjects: 83 (209 controls)
| Evaluated subjects: 73 (48)
| Mean GA (range): ND
| Mean BW (range): ≥ 2500 g
| Mean Apgar score at 1 min: ND
| Breastfed: ND
| Male: ND
| Race: ND
Esbjorner, 1991 [#91281442] | Location: Sweden | | | | Healthy, AGA infants with hyperbilirubinemia requiring treatment | ND | Prospective cross-sectional study
| Setting: Hospital | | | | No malformations
| Birth years: ND
| Number of centers: 1
| Enrolled subjects: 9
| Evaluated subjects: 9
| Mean GA (range): 38.3 (35–42) wks
| Mean BW (range): 3297 (2440–4420) g
| Mean Apgar score at 5 min: 9–10
| Breastfed: ND
| Male: ND
| Race: ND
Escher-Gäub, 1986 [#87136731] | Location: Switzerland | | | | Singleton birth at term (38–42 weeks) BW > 10^th^%tile | Congenital malformations | Prospective cross-sectional study
| Setting: Hospital | | | | No PhotoRx | Perinatal asphyxia
| Birth years: ND | | | | | Birth trauma
| Number of centers: 1 | | | | | Neonatal illness
| | [underlined: Subjects] | | [underlined: Controls] | | Hemolytic disease
| Enrolled subjects: | 996
| Evaluated subjects: | 76 | | 401
| Mean GA (range): | 40.3±1.12 wks | | 40.6±1.07
| Mean BW (range): | 3387±354 | | 3475±403 g
| Mean Apgar score at 1, 5 min: | 8.36±1. 02 | | 8.31±1.04 @1 min
| | 9.45±0.60 | | 9.30±0.63 @5 min
| Breastfed (%): | ND | | ND
| Male (%): | 53% | | 45%
| Race (%): | Swiss | | Swiss
Grimmer, 1999 [#99345621] | Location: West Germany | | | | Subjects: healthy non-hemolytic term newborns with TSB 20–30 mg/dl | Blood group incompatibility (18) | Prospective cohorts
| Setting: Hospital | | | | Controls: for every jaundiced infant recruited, infant born next in the same hospital who had the same sex and whose total SB levels never exceeded 12 mg/dl was chosen as a control | Hemolytic anemia (2)
| Birth years: 1978 to 1988 | | | | | BW < 2500 g or GA < 37 wks (6)
| Number of centers: 1 | | | | | Hydrocephalus (1)
| Enrolled subjects: 58 | | | | | Septicemia (1)
| Evaluated subjects: 16 (18 controls) | | | | | Hepatobiliary disease (1)
| Mean GA (range): ≥ 37 wks | | | | | Mechanical ventilation (3)
| Mean BW (range): ≥ 2500 g | | | | | Families of the children were unsuccessfully followed-up (11)
| Mean Apgar score at 1 min: ND | | | | | Failed to come to examination date (2)
| Breastfed: ND
| Male: ND
| Race: ND
Grunebaum, 1991 [#91231060] | Location: Israel | | | | Clinical jaundice consistent throughout the first 3 weeks of life or later | Infants with abnormal physical or lab. findings | Prospective single-arm study
| Setting: Hospital
| Birth years: 1/1/1980 to 6/30/1984
| Number of centers: 1
| Enrolled subjects: 60
| Evaluated subjects: 46
| Mean GA (range): 25% < 37 wks
| Mean BW (range): 3090±430 (2010–4020) g
| Mean Apgar score at 1 min: ND
| Breastfed: 100%
| Male: ND
| Race: ND
Gupta, 1990 [#91244386] | Location: India | | | | Infants with hyperbiliurbinemia at level exceeding ET as per Cockington charts, who were admitted to NICU | GA < 37 weeks | Prospective cohort
| Setting: Hospital | | | | | BW < 1500 gms
| Birth years: 3/1989–11/1989 | | | | | Low Apgar scores
| Number of centers: 1 | | | | | Exposure to ototoxic and/or bilirubin binding drugs
| Enrolled subjects: 25(20) | | | | | Infections
| Evaluated subjects: ND | | | | | Craniofacial malformations
| Mean GA ( range): 40.4 ± 0.6
| Mean BW: 2680 ± 260 g
| Mean Apgar score at 1 min: 8.52 ± 0.34
| Mean Apgar score at 1 min: 9.14 ± 0.46
| Breastfed (%): ND
| Male(%): 60
| Race(%): Indian
Gupta, 1998 [#98355379] | Location: India | | | | GA 37–40 weeks | Adverse perinatal factors | Prospective longitudinal cohort
| Setting: Hospital | | | | No abnormalities on physical exams | Neonatal infection
| Birth years: 1/1/1980 to 6/30/1984 | | | | | LBW
| Number of centers: 1 | | | | | Malformations of head and neck
| Enrolled subjects: 60 | | | | | Birth asphyxia
| Evaluated subjects: 60 | | | | | Meningitis
| Mean GA (range): 37.8 wks
| Mean BW (range): 2.43 Kg
| Mean Apgar score at 1 min: ND
| Breastfed: ND
| Male: 42%
| Race: 100% Indian
Holmes, 1968 [#68310019] | Location: US | | | | Clinically normal weight (> 2500 g or more) | Respiratory distress syndrome, sepsis, congenital malformations, positive test for syphilis, prolonged labor, difficult deliveries, C/S, abnormal presentations or other major complications of pregnancy labor or delivery | Prospective cohorts (4 y 7 m – 7 y 8 m)
| Setting: Hospital | | | | | For subject group excluded if only one bilirubin level done
| Birth years: 3/1/1957 to 3/31/1960
| Number of centers: 1
| Enrolled subjects: 195 eligible from charts; 82 available; 2 later excluded
| Evaluated subjects: 63 (17 controls)
| Mean GA (range): Term
| Mean BW (range): > 2500 g
| Mean Apgar score at 1 min: ND
| Breastfed: ND
| Male: ND
| Race: ND
Hyman, 1969 [#69132491] | Location: US | | | | Infants < 1 weeks of age with a diagnosis of hemolytic disease of the newborn or indirect hyperbilirubinemia of at least 15 mg/dl | ND | Prospective cohort (4 years)
| Setting: Hospital | | | | Infants whom "it was possible to follow "for at least 4 years
| Birth years: 1955 to 1961
| Number of centers: 1
| Enrolled subjects: 742
| Evaluated subjects: 405
| Mean GA (range): 90% Term; 10% Preemies
| Mean BW (range): ND
| Mean Apgar score at 1 min: ND
| Breastfed: ND
| Male: 54%
| Race: 93% White, 72% Black, <1% Asian
Johnston, 1967 [#67081206] | Location: Canada | | | | Subjects: infants with indirect SB level > 20 mg/dl | Lost to follow-up | Prospective cohorts (5–6 years)
| Setting: Hospital | | | | Control group I: infants with “low bilirubin levels” in newborn period
| Birth years: 1957 to 1958 | | | | Control group II: older, unaffected siblings
| Number of centers: 1
| Enrolled subjects: 168
| Evaluated subjects: 129 (95 controls)
| Mean GA (range): ND (11% preemies)
| Mean BW (range): ND
| Mean Apgar score at 1 min: ND
| Breastfed: ND
| Male: ND
| Race: ND
Naeye, 1978 [#79054333] | Location: US | | | | Unselected 53518 pregnancies in US between 1959 and 1966 | Multiple births | Prospective longitudinal cohort (8 years)
| Setting: CPP | | | | | Major congenital malformation
| Birth years: 1959 to 1966 | | | | | Down's syndrome
| Number of centers: 14 | | | | | Hydrocephalus
| Enrolled subjects: 53518 | | | | | Lead intoxication
| Evaluated subjects: 45347 → 41444 @ 7 yrs | | | | | Fractured skull
| Mean GA (range): ND | | | | | Inborn error of metabolism (hypothyroidism …)
| Mean BW (range): ND
| Mean Apgar score at 1 min: ND
| Breastfed (%): ND
| Male (%): ND
| Race (%): ND
Newman, 1993 [#94021217] | Location: US | | | | Live-born infants | Nonsingleton birth (1148) | Prospective longitudinal cohort (7 years)
| Setting: CCP | | | | | BW < 2500 g or unknown (226)
| Birth years: 1959 to 1966 | | | | | Not white or African American (3595)
| Number of centers: 12 | | | | | No bilirubin measurements were recorded (2510)
| | [underlined: White] | | [underlined: Black] | | Died before 1 year old (391)
| Enrolled subjects: | 54795
| Evaluated subjects: | 21375 | | 19949
| Mean GA (range): | 39.8±2.3 | | 38.7±3.2 wks
| Mean BW (range): | 3369 | | 3195 g
| Mean Apgar score at 1 min: | ND | | ND
| Breastfed (%): | 12% | | 3%
| Male (%): | 52% | | 51%
| Race (%): 52% White; 48% Black
Odell, 1970 [#70075541] | Location: US | | | | 32 children, ages 4–7 years old, had been patients in the hospital nurseries | ND | Prospective cohort
| Setting: Hospital | | | | For current review, only infants with BW ≥ 2500 g were included
| Birth years: ND
| Number of centers: 1
| Enrolled subjects: 32
| Evaluated subjects: 14
| Mean GA (range): ND
| Mean BW (range): 3002.3 (2540–3827) g
| Mean Apgar score at 1 min: ND
| Breastfed (%): ND
| Male (%): 71%
| Race (%): ND
Ozmert, 1996 [#97154941] | Location: Turkey | | | | Peak bilirubin > 17 mg/dl | BW < 3000 g | Prospective cohorts
| Setting: Hospital | | | | | GA < 37 wks
| Birth years: 1/1980 to 12/1985 | | | | | Twins
| Number of centers: 1 | | | | | Apgar < 3 @5 min
| Enrolled subjects: 416 | | | | | IVH, sepsis, meningitis, intrauterine infection, neonatal abnormalities, inborn errors of metabolism
| Evaluated subjects: 102 (27 controls) | | | | | G6PH deficiency
| Mean GA (range): ND | | | | | Congenital abnormalities
| Mean BW (range): ND
| Mean Apgar score at 1 min: ND
| Breastfed (%): ND
| Male (%): 68%
| Race (%): ND
Paludetto, 1986 [#86296856] | Location: Italy | | | | Uneventful pregnancy, vaginal delivery w/o complication, single birth, no congenital malformation, Apgar>7 @5 min, at term, AGA, breast feeding, no perinatal complications | Received PhotoRx, ET or presented other associated disease | Prospective cohorts
| Setting: Hospital | | | | Subjects: Bilirubin > 8 mg/dl on 3^rd^days of life.
| Birth years: ND | | | | Controls: matched for sex, mother's age, parity and father's profession
| Number of centers: 1
| | [underlined: Subjects] | | [underlined: Controls]
| Enrolled subjects: | 32 | | 17
| Evaluated subjects: | 17 | | 17
| Mean GA (range): | 39 (37–40) | | 39 (37–41)wks
| Mean BW (range): | 3345 | | 3427 g
| | (2700–4000) | | (2770–3850)
| Mean Apgar score at 1 min: | 8 (6–9) | | 7.5 (4–9)
| Breastfed (%): | 100% | | 100%
| Male (%): | 64.7% | | 64.7%
| Race (%): | ND | | ND
Perlman, 1983 [#84041257] | Location: Israel | | | | GA 37–41 weeks | ND | Prospective cohorts
| Setting: Hospital | | | | Pregnancy and delivery uncomplicated
| Birth years: 2/1981 to 5/1981 | | | | BW and HC 10^th^to 90^th^%tile for GA
| Number of centers: ND | | | | Absence of congenital anomalies
| | [underlined: Subjects] | | [underlined: Controls] | Neonatal course uncomplicated
| Enrolled subjects: | 24 | | 19 | Informed consent
| Evaluated subjects: | 24 | | 19
| Mean GA (range): | 38.5±1.3 | | 39.5±0.9 wks
| Mean BW (range): | 3300±368 | | 3270±336 g
| Man Apgar score
| @ 1 min: | 8.25±0.74 | | 8.47±0.7
| @ 5 min: | 9.5±0.51 | | 9.47±0.51
| Breastfed (%): | ND | | ND
| Male (%): | 58% | | 47%
| Race (%): | ND | | ND
Rapisardi, 1989 [#89213178] | Location: US | | | | Healthy FT AGA infants with uncomplicated labors and deliveries | Multiple births | Prospective cross-sectional cohort
| Setting: Hospital | | | | No PhotoRx | Congenital anomalies
| Birth years: ND | | | | | Gross intrauterine infections
| Number of centers: 1
| Enrolled subjects: 29
| Evaluated subjects: 29
| Mean GA (range): 38–41 wks
| Mean BW (range): 2650–4390 g
| Mean Apgar score at 5 min: > 8
| Breastfed (%): ND
| Male (%): ND
| Race (%): ND
Rosta, 1971 [#72185033] | Location: Budapest | | | | BW ≥ 2500 g | Lost to follow up | Prospective cohort (7–9.5 years)
| Setting: Hospital | | | | SB ≥ 15 mg/dl
| Birth years: 1960 to 1962
| Number of centers: 1
| Enrolled subjects: 102
| Evaluated subjects: 84
| Mean GA (range): ND
| Mean BW (range): ≥ 2500 g
| Mean Apgar score at 1 min: ND
| Breastfed (%): ND
| Male (%): ND
| Race (%): ND
Rubin, 1979 [#79153498] | Location: US | | | | Subjects were selected from the participants both in the EFS and the Minnesota section of the CPP | ND | Prospective cohorts (7 years)
| Setting: CPP + EFS | | | | Subjects: SB ≥ 11 mg/dl
| Birth years: | | | | Controls: infants randomly selected from the remainder of the EFS population, with SB ≤ 10 mg/dl
| Number of centers: 1
| | [underlined: Moderate Jaundice] | [underlined: Severe Jaundice] | [underlined: Controls]
| Enrolled subjects: | | 1613
| Evaluated subjects: | 164 | 77 | 125
| Mean GA (range): | 40.5±2.6 | 39.6±3.1 | 38.6±2.8
| Mean BW (range): | 3374±465 | 3215±590 | 3003±654
| Mean Apgar score | 7.7±1.8 | 7.8±1.7 | 7.9±1.6
| at 1, 5 min: | 8.7±1.2 | 8.7±1.1 | 8.5±1.5
| Breastfed (%): | ND | ND | ND
| Male (%): | ND | ND | ND
| Race (%): | 96.5% White
Scheidt, 1977 [#77209363] | Location: US | | | | Unselected 53518 pregnancies in US between 1959 and 1966 | Multiple births | Prospective longitudinal cohort (1 year)
| Setting: CPP | | | | Infants examined within 2 wks of age 8 months and within 4 wks of age 12 months | Major congenital malformation
| Birth years: 1959 to 1964 | | | | For current review, only infants with GA≥36 wks and BW>2500 g were included | Down's syndrome
| Number of centers: 14 | | | | | Hydrocephalus
| Enrolled subjects: 24524 @8 months; 27270 @12 months | | | | | Lead intoxication
| Evaluated subjects: ND | | | | | Fractured skull
| Mean GA (range): ≥ 36 wks | | | | | Inborn error of metabolism (hypothyroidism …)
| Mean BW (range): > 2500 g
| Mean Apgar score at 1 min: ND
| Breastfed (%): ND
| Male (%): ND
| Race (%): mixed Whites and Blacks
Seidman, 1991 [#91375839] | Location: Israel | | | | Unselected subjects identified through the computerized data base of the Jerusalem Perinatal Study | ND | Retrospective cohort (17 years)
| Setting: Hospital | | | | 95.3% records ere obtained and matched to military draft medical records.
| Birth years: 11/1970–12/1971
| Number of centers: 1
| Enrolled subjects: 2044
| Evaluated subjects: 1948
| Mean GA ( range): 39.3 weeks
| Mean BW(g): 3378.4 g
| Mean Apgar score at 1 & 5 min: 8.8
| Breastfed (%): ND
| Male(%): 53%
| Race(%): Israel, Asia, Euro-America; Africa
Soorani-Lunsing, 2001 [#11726727] | Location: Netherlands | | | | Subjects: “healthy” term Caucasian infants whose TSB > 12.9 mg/dl | ND | Prospective longitudinal cohorts (1 year)
| Setting: Hospital | | | | Controls: “healthy” Caucasian infants without hyperbilirubinemia, born in the same period and matched for sex & GA
| Birth years: 11/1997 to 6/1998
| Number of centers: 1
| | [underlined: Subjects] | | [underlined: Controls]
| Enrolled subjects: | ND | | ND
| Evaluated subjects: | 20 | | 20
| Mean GA (range): | 272±12 | | 278±12 day
| Mean BW (range): | 3480±403 | | 3357±402 g
| Mean Apgar score at 1 min: | ND | | ND
| Breastfed (%): | 75% | | 70%
| Male (%): | 75% | | 75%
| Race (%): | Caucasian | | Caucasian
Suresh, 1997 [#98374505] | Location: US, Europe, Australia, Saudi Arabia | | | | Information was obtained on 42 Crigler-Najjar Syndrome Type I (CN1) patients returned by 14 physicians (primary pediatricians and gastroenterologists) and in 3 cases, by parents of patients | ND | Survey
| Setting: Questionnaires
| Birth years: ND
| Number of centers: multiple
| Enrolled subjects: open
| Evaluated subjects: 42
| Mean GA (range): 3 (7%) “preterm”
| Age @ recruitment: 2 months to 21 years old
| Mean BW (range): ND
| Mean Apgar score at 1 min: ND
| Breastfed (%): ND
| Male (%): 75%
| Race (%): ND
Tan, 1992 [#92139200] | Location: Singapore | | | | Subjects: Healthy (w/o infection or trauma/contusion/caphalhematoma) term infants who had nonhemolytic hyperbilirubinemia | Controls: subsequent jaundice > 8.2 mg/dl (5) | Prospective cohorts
| Setting: Hospital | | | | Controls: healthy term infants with SB < 8.2 mg/dl
| Birth years: ND
| Number of centers: 1
| | [underlined: Subjects] | | [underlined: Controls]
| Enrolled subjects: | 30 | | 36
| Evaluated subjects: | 30 | | 31
| Mean GA (range): | 38.8±0.35 | | 38.8±0.31 wks
| Mean BW (range): | 3411 | | 3354 g
| Mean Apgar score at 1 min: | ND | | ND
| Breastfed (%): | ND | | ND
| Male (%): | 47% | | 48%
| Race (%): | ND | | ND
Upadhyay, 1971 [#71238892] | Location: US | | | | Subjects: bilirubin > 20 mg/dl and BW > 2500 g | Subjects: high risk mothers (6), SB measured prior to standardized method (5), lost to follow-up (2), death with kernicterus (1) | Prospective cohorts
*Hardy, 1971 [#71238891] provide more detail info. on the Johns Hopkins Collaborative Perinatal Study cohort | Setting: Hospital | | | | Controls: “matched”
| Birth years: ND
| Number of centers: 1
| | [underlined: Subjects] | | [underlined: Controls]
| Enrolled subjects: | 34 | | 20
| Evaluated subjects:x | 20 | | 20
| Mean GA (range): | 38.45 | | 38.90 wks
| Mean BW (range): | 3411 | | 3354 g
| Mean Apgar score at 1 min: | ND | | ND
| Breastfed (%): | ND | | ND
| Male (%): | 65% | | ND
| Race (%):
| White: | 20% | | ND
| Black: | 80% | | ND
Valaes, 1980 [#81031849] | Location: Greece | | | | Living in the island of Lesbos | Moving out of the area (103) | Prospective follow-up study of subjects of the prior RCT of PB
| Setting: Follow-up study of RCT of PB | | | | All children in phase I RCT | Failed to trace the family (28)
| Birth years: 10/1968 to 11/1971 | | | | Randomly selected children in phase II RCT from each area | Death (13)
| Number of centers: multiple | | | | Children not included in the previous group but with mark jaundice | Noncompliance (80)
| Enrolled subjects: 719 | | | | | Missing formal IQ test (1)
| Evaluated subjects: 489
| Mean GA (range): ≥ 33 wks
| Mean BW (range): ≥ 2100 g
| Mean Apgar score at 1 min: ND
| Breastfed (%): ND
| Male (%): ND
| Race (%): ND
Vohr, 1989 [#89328704] | Location: US | | | | Term infants in the normal nurseries with or without jaundice | Perinatal asphyxia | Prospective cross-sectional study
Vohr, 1990 [#90339225] | Setting: Hospital | | | | Informed consent | Cogenital malformations
| Birth years: ND | | | | | Hemorrhage
| Number of centers: ND | | | | | Sepsis
| | [underlined: Subjects] | | [underlined: Controls] | | Infection
| Enrolled subjects: | 50 | | | | Rh incompatibility
| Evaluated subjects: | 25 | | 25
| Mean GA (range): | 39.9±0.4 | | 40±1 wks
| Mean BW (range): | 3248±547 | | 3245±463 g
| Mean Apgar score at 1 min: | ND | | ND
| Breastfed (%): | ND | | ND
| Male (%): | 52% | | 40%
| Race (%): | ND | | ND
Wolf, 1997 [#98030356] | Location: Zimbabwe | | | | Severe jaundice (SB > 23.4 mg/dl) in the 1^st^week of life | Apgar < 7 @ 5 min | Prospective longitudinal cohort (4 months; 1 year)
Wolf, 1999 [#99156393] | Setting: Hospital | | | | For current review, only infants, GA ≥ 34 weeks, were evaluated @ 1 year of age | Hypoxic-ischaemic brain injury
| Birth years: 7/1991 to 6/1992 | | | | | Died before the age of 4 month (2)
| Number of centers: 1 | | | | | Lost to follow up (3 by 4 months; additional 2 by 1 year)
| Enrolled subjects: 50
| Evaluated subjects: 35
| Mean GA (range): 37.8 wks
| Mean BW (range): 2660 g
| Mean Apgar score at 5 min: ≥ 7
| Breastfed (%): ND
| Male (%): ND
| Race (%): 100% African
Yilmaz, 2001 [#21125314] | Location: Turkey | | | | Newborns who were treated in the hospital for indirect hyperbilirubinemia. | Preterms | Prospective cohort
| Setting: Hospital | | | | | SGA
| Birth years: 1/1990 to 12/1996 | | | | | Metabolic abnormalities
| Number of centers: 1 | | | | | Infection
| Enrolled subjects: 755 | | | | | Hypoxia-ischemia
| Evaluated subjects: 87 | | | | | Congenital malformation
| Mean GA (range): Term | | | | | ET
| Mean BW (range): 3349.8 g | | | | | Unable to reach
| Mean Apgar score at 5 min: ND
| Breastfed (%): ND
| Male (%): 67%
| Race (%): ND

Evidence Table 1. Question 1 - Studies evaluating association of neonatal hyperbilirubinemia to neurodevelopmental outcomes - Part II

Author, Year | Disease/Condition Type (N) | Potential Confounding Factors | Outcomes | Outcome Definitions
Bengtsson, 1974 [#74170112] | Group I: ABO-compatible FT jaundiced infants (N=66) | 36.4% Group I subjects received ET | @6.5–13 years old: Neurologic exam
| Group II: ABO-incompatible FT jaundiced infants (N=45) | 44.4% Group II subjects received ET | Hearing loss | General exam, gross motor, fine motor
| Controls: non-jaundiced infants (N=115) | | IQ | Standard audiometry. Reduction of at least 30 dB at 2 frequencies between 500 and 6000 c/s
| | | Psychological disturbance | 6.5–7 years old — Terman-Merrill Test
| | | | 8–13 years old — WIT
| | | | “noteworthy symptoms and functional maladjustment” ex. Anxiety, aggressiveness
Boggs, 1967 [#67261091] | CCP subjects, BW > 2500 g (N=18,484) | Coombs' test positive and negative | @8 months: BSID
| | Some subjects received ET | | Abnormal: MDI < 75 (10^th^%tile); PDI < 25 (10^th^%tile)
| | Including infants with congenital malformations
Boo, 1994 [#801] | Controls: Infants without hearing loss (N=100) | Some hemolytic disease in both groups | Hearing loss | Mild: no BSER at 45 dB nHL
| Cases: Infants with hearing loss (N=28) | | | Moderate: no BSER at 65 dB nHL
| Peak TSB (mg/dl): | | | Severe: no BSER at 85 dB nHL
| Controls: 18.4±7.4
| Cases: 21.6±7.5
| Peak indirect SB (mg/dl):
| Controls: 17.5±7.1
| Cases: 20.9±7.4
Chen, 1995 [#96017937] | Subjects: healthy infants w/ SB ≥ 10 mg/dl | All infants w/ SB ≥ 15 mg/dl (64%) underwent PhotoRx; all infant w/ SB ≥ 20 mg/dl (29%) underwent ET. | VEP | Latency N1, P2, N2
| Controls: healthy infant w/ SB < 10 mg/dl | | @1 year: | Amplitudes N1-P2, P1-N2
| | | Neurologic Exam | ND
| | | Neurodevelopment | DDST
Culley, 1970 [#70266548] | Subjects: healthy Infants w/ moderate or severe non-hemolytic jaundice (SB ≥ 12 mg/dl) (N=73) | SB levels were estimated by icterometers | @6 years of age: | Assessments were done by 2 pediatricians, an audiologist, and by a team of psychologists and psychiatric social workers
| Controls: healthy non-jaundiced infants (N=48) | | Overall handicap
| | | IQ
| | | CNS deficit
| | | hearing
Esbjorner, 1991 [#91281442] | Jaundice infants requiring Rx (SB>16.7 mg/dl) (N=9). | All infants receive PhotoRx, but none underwent ET | @4 (3.5–6) days, post Rx: ABR | ABR was recorded without sedation, immediately after feeding.
| Causes of Jaundice: | | | Latency I, II, III, V
| ABO incompatibility (1) | | | IPL I-V
Escher-Gräub, 1986 [#87136731] | Subjects: healthy jaundiced infants w/ max. bilirubin 11.7–14.6 mg/dl (N=76) | Meconium staining of the amniotic fluid was more frequently observed in control group (20%) than in the jaundice group (7.9%) | BNBAS | Infants' behaviors: habituation, orientation, motor performance, range of state, regulation of state, autonomic regulation
| Controls: healthy infants w/ max. SB < 5.8 mg/dl (N=401) | | | 9-point scale was used to divide behavior categories (“low”, “moderate”, and “high”) according to the criteria of Als et al.
Grimmer, 1999 [#99345621] | Subjects: healthy non-hemolytic jaundiced infants with TSB 20–30 mg/dl (N=16) | All subjects received PhotoRx | @85 (61–187) months: Neurological outcome | Touwen Subscales: Sensorimotor apparatus, Posture, Balance of the trunk, Coordination of the extremities, Fine manipulative abilities, Choreiform dyskinesia, Gross motor functions, Quality of motility; Associated movements
| Controls: non-jaundiced infants (N=18)
Grunebaum, 1991 [#91231060] | Healthy breast-milk jaundiced infants (N=46) | 25% infants were treated with PhotoRx | Measured at age 31.1±16.6 months:
| Mean maximal TSB in first 2 weeks = 12.06±2.6 mg/dl | | Growth | Wt, Ht, and HC
| | | Neurological exam | ND
| | | Neurodevelopment | DDST
Gupta, 1990 [#91244386] | Subjects: full term infants(N=25) | Exchange transfusion | @10±3 days of life: | Latency I, III, V and I-P IPL
| Cause of jaundice: | | BAER
| ABO incompatibility: 7/25 | | Auditory threshold
| Rh incompatibility: 10/25
| Subaponeurotic bleed:1/25
| Cause unclear: 7/25
| Controls: non icteric full term infants(N=20)
Gupta, 1998 [#98355379] | Group I: Infants with SB > 18 mg/dl (N=15) | None was found | @1 and 6 months: ABR | Interpeak Latency (IPL) I-III, III-V, I-V
| Group II: Infants with SB 12–18 mg/dl (N=30) | | @1 and 6 months: IPL recovery | Full recovery: normal wave pattern and normal I-P latencies both at 80 dB and 40 dB
| Causes of Jaundice: | | | Partial recovery: Normal responses at 80 dB and delayed I-P latencies at 40 dB
| 38% G6PD deficiency | | | No recovery: absence of normal wave pattern or delayed I-P latencies both at 40 dB and 80 dB
| 20% ABO incompatibility
| 42% unknown
| Controls: matched normal neonates without jaundice or SB < 12 mg/dl during the first 6 days of life (N=15)
Holmes, 1968 [#68310019] | Group I: healthy infants with “low” bilirubin level (TSB 6.4–12.5 mg/dl) (N=29) | 2 (7%) Group I subjects received ET; 4 (14%) received streptomycin | @4 y 7 m – 7 y 8 m: Neurologic examination
| Group II: healthy infants with “high” bilirubin level (TSB 15–24 mg/dl) (N=34)_ | 9 (26%) Group II received ET; 9 (26%) received streptomycin | Hearing | Physical exam for any neurological signs
| | | Motor development | Audiometer with an ascending descending technique. Frequencies reported from 250 to 4000
| | | | Modified Oseretsky test. Measures motor maturation and development of motor skills. Oseretsky and modifications by Holbrook and Sloan with additional modifications by study: 5 categories static coordination and body balance; dynamic manual coordination; general dynamic coordination; speed; simultaneous movements. Each item given 4 points for adequate and complete; partial for adequate but incomplete
Hung, 1989 [#90054139] | Group I: infants with kernicterus (N=10)
| Group II: jaundice infants with ABR testing before and after ET (N=6)
| Group III: jaundice infants who only had ABR testing after ET (N=20)
| Group IV: infants who need only PhotoRx, with ABR testing after PhotoRx (N=39)
| Causes of Jaundice: mostly ABO incompatibility, G6PH deficiency and unknown factors
Hyman, 1969 [#69132491] | Infants w/ hemolytic disease or SB ≥ 15 mg/dl (N=405) | 87% receive ET and streptomycin Rx | @4 yrs or more of age:
| | Prematurity (determined by BW) | Sensori-neural hearing loss | Hearing absence when 15 dB in 2 or more frequencies in the speech range
| | Neonatal complications | IQ | Stanford-Binet, WISC, Merrill-Palmer Scales, Raven Progressive Matrices, and Madeleine Thomas Completion Stories
| | | Auditory rote memory difficulties | EEG findings
| | | CNS abnormalities
Johnston, 1967 [#67081206] | Subjects: infants with SB > 20 mg/dl (N=129) | 95% subjects received one or more ET | @5–6 yrs of age:
| Causes of Jaundice: | Prematurity (19% in subject group; 12% in control group) | Audiological assessment | Hearing loss (Not defined)
| 71% iso-immunization | | Neurological assessment | ND
| 20% ABO incompatibility | | IQ | Stanford-Binet
| 9% other
| Control group I: infants with “low” bilirubin levels (N=95)
| Control group II: older, unaffected siblings (N=82)
Naeye, 1978 [#79054333] | CPP subjects, mixed term and preterm infants (N=41,444) | Placental infection, respiratory distress as a probable indication of acute inflammation | @4 yrs of age: IQ | ND
| | Prematurity | @7 yrs of age: Neurologic exam
Newman, 1993 [#94021217] | CPP subjects, BW > 2500 g (N=41,324) | About 50% infants with SB ≥ 20 mg/dl received ET | @7 yrs old: Adjusted IQ | WISC adjusted for center, maternal education, BW, BW squared, gender, feeding method, maternal oxytocin used, Coomb's test, maternal age, maternal age squared, parity, and prematurity by analysis of covariance.
| | Including infants with hemolytic disease (2% infants had Coombs positive tests) | Neurologic exams | “Complete normal”, “neurologically suspicious”; “neurologically abnormal”
| | | Hearing loss | Diagnosed by audiometry. Sensorineural hearing loss was defined as an air conduction loss of 30 dB or more at 2 or more frequencies in both ears, with an average air-bone gap across those same frequencies of 10 dB or less.
Odell, 1970 [#70075541] | Group I: infants w/ SB ≤ 19 mg/dl (N=6) | 71% received one or more ET | @4–7 yrs old: IQ
| Group II: infants w/ SB > 19 mg/dl (N=8) | | Visual motor coordination | Stanford-Binet test for children < 5 years old
| Causes of Jaundice: | | Short-tem memory | WISC for children ≥ 5 years old
| 43% Rh incompatibility | | | Bender Visual-Motor Gestalt test and Sequin Form Board
| 14% ABO incompatibility | | | Children's Embedded Figures test and Reitan's Trial Making test
| 14% Other blood incompatibility
| 21% Unknown
Ozmert, 1996 [#97154941] | Group I: infants w/ SB 17–20 mg/dl and negative direct Coombs' test (N=13) | None was found | @8–13 yrs of age: BAEP
| Group II: infants w/ SB 20–22 mg/dl and negative direct Coombs' test (N=26) | | IQ | Abnormal BAEP: IPL I-V values > 4.34±0.15 msec
| Group III: infants w/ SB 22–25 mg/dl and negative direct Coombs' test (N=27) | | | WISC-R: full, verbal, and performance IQs
| Group IV: infants w/ SB > 25 mg/dl and negative direct Coombs' test (N=19)
| Group V: infants w/ SB > 20 mg/dl and positive direct Coombs' test (N=17) (11 children had Rh and 6 ABO incompatibility)
| Controls: randomly chosen among children of the same age admitted to hospital outpatient and w/o hyperbilirubinemia (N=27)
Paludetto, 1986 [#86296856] | Group I: Healthy term infants w/ bilirubin > 8 mg/dl on 3^rd^days of life (N=17) | Not all controls had bilirubin measurement | BNBAS | Infants' behaviors: habituation, orientation, motor performance, range of state, regulation of state, autonomic regulation
| Controls: matched term infants w/ bilirubin < 6 mg/dl on 3^rd^days of life (N=17)
Perlman, 1983 [#84041257] | Subjects: FT infants w/ SB > 15 mg/dl (N=24) | All subjects received PhotoRx; 3 (12.5%) also received ET | ABR loss of waves | Loss of waves I, III, and wave complex IV-V on at least one occasion
| Cause of jaundice: | | Amplitudes | Amplitude ratio — III: I; IV-V:I
| 25% ABO incompatibility | | Latencies | Amplitude difference — III minus I, IV-V minus I
| 4% Rh incompatibility | | | Brainstem transmission time
| Controls: FT infants in whom jaundice was not observed during the first 6 days of life, or SB < 12 mg/dl (N=19)
Rapisardi, 1989 [#89213178] | Group I: Healthy FT infants w/ SB > 12 mg/dl (N=9) | Group I infants were significantly older when assessed | Cry variability | As an indicator of “neurophysiological functioning”.
| Group II: Healthy FT infants w/ SB 6–12 mg/dl (N=10)
| Group III: Healthy FT infant w/ SB < 6 mg/dl (N=10)
Rosta, 1971 [#72185033] | Infants w/ SB ≥ 15 mg/dl (N=84) | Some subjects received ET, streptomycin, and/or other treatments | @8 yrs of age:
| Cause of jaundice: nearly equal distribution Rh and ABO immune-haemolysis, and hyperbilirubinemia of unknown origin | | Hearing loss | Kamplex OB-3 apparatus of suspect sensorineural hearing loss. Rabari's exhaustion test and speech audiometry
| | | Neurology | Neurologic exam and IQ
Rubin, 1979 [#79153498] | Moderate jaundice: infants w/ SB 11–15 mg/dl (N=146) | GA and BW are significantly different between groups | @8 months: BSID
| Severe jaundice: infants w/ SB 16–23 mg/dl (N=77) | (Unknown Rx effect) | @1 yr of age: Neurologic exams | MDI & PDI
| Controls: infant w/ SB ≤ 10 mg/dl (N=125) | | IQ | Stanford-Binet
| *Subjects were from CPP | | @5, 6 years: | MRT
| | | School readiness | ITPA
| | | Language | WISC
| | | @7 yrs of age:
| | | IQ
| | | Neurologic exam
Scheidt, 1977 [#77209363] | Group IV: Healthy infants with GA ≥ 36 wks and BW > 2500 g (N=?). Subgroups: SB ≤ 9, 10–14, 15–19, ≥ 20 mg/dl. | Significantly more white infants had elevated bilirubin level (SB 15–19 or >20 mg/dl), than did Black infants | @8 months: Bayley's MDI; PDI | Bayley Scales of Mental and Motor Development
| Group V: Healthy infants with GA ≥ 37 wks and BW > 2500 g (N=?). Subgroups: SB ≤ 9, 10–14, 15–19, ≥ 20 mg/dl.
Seidman, 1991 [#91375839] | Racially diverse term infants (N=1,948) | Some subjects receive PhotoRx and/or ET | @17 years old: IQ | Wechsler Adult Intelligence Scale (translated version of the verbal test and nonverbal matrices test)
| | Some subjects had Coombs positive test
Soorani-Lunsing, 2001 [#11726727] | Subjects: Healthy infants with billirubin > 12.9 mg/dl (N=20) | 50% subjects received PhotoRx | @3–8 days, 3 and 12 months: Neurologic dysfunction | Neurological exam was used standardized technique of Prechtl
| Controls: matched infants w/o hyperbilirubinemia (N=20) | | @12 months: Behavioral problem | @3 months: abnormal — marked hypertonia, hypotonia, asymmetries or hyperexcitability syndrome
| | | | @12 months:
| | | | Minor neurologic dysfunction type 1 — presence of hypotonia w/o significant reflex or postural deviancies
| | | | Minor neurologic dysfunction type 2 (more severe) — mild abnormalities in muscle tone regulation in combination with significant reflex or postural deviancies
| | | | By parental questionnaire
Suresh, 1997 [#98374505] | CN1 patients (N=42), aged 2 months to 21 years old | 7% “Preterm” | @2 months to 21 years old: Hearing loss | According to patients' survey
| CN1 =Complete absence of the hepatic enzyme UDP glucurony transferase, resulting in a lifelong unconjugated hyperbilirubinemia | 39 (93%) received Rx — 79% PhotoRx, 28% ET, 20% Phenobarbitone; Cholestyramin, albumin infusions, and plasmapheresis in 1 case | Neurodevelopmental status
| Mean peak TSB = 26.6±5.8 mg/dl | | School Performance
| Mean TSB (typical) = 19.8±4.5 mg/dl
| Postneonatal period birubin levels — 10% < 15 mg/dl, 37.5% 15–19 mg/dl, 42.5% 20–29 mg/dl; 10% > 30 mg/dl
Tan, 1992 [#92139200] | Subjects: healthy term infants with non-hemolytic jaundice (N=30) | Subjects received PhotoRx | @Pre- and post- Rx: BAER | Latency V
| Controls: healthy term infants with SB < 8.2 mg/dl (N=31) | | | IPL: III-V, I-V
Upadhyay, 1971 [#71238892] | Subjects: infants with billirubin > 20 mg/dl (N=20) | 11 (55%) jaundiced infants had ET | @8 months: Bayley's MDI; PDI | Non-normal: abnormal (BSID mental score ≤ 75; motor score ≤ 27. Definitions are from Hardy's paper) or suspect (short attention span, motor hyperactivity and poor motor coordination)
| Cause of Jaundice: | | @12 month: Neurologic exam
| 50% ABO incompatibility | | @36 months: Hearing, language and speech
| 35% Rh incompatibility | | @48 months: Stanford-Binet IQ
| 5% Septicemia with a gram-negative organism
| 10% Unknown
| Controls: infants with bilirubin < 10 mg/dl (N=20)
Valaes, 1980 [#81031849] | Subjects: infants with marked jaundice (SB > 16 mg/dl) (N=44) | Prematurity, defined as 33–36 wks; BW 2100–3000 g (16% in subject group) | @61–81 months of age:
| Cause of Jaundice: | ET (20% in subject group) | VMI | Visual-Motor integration test
| ABO incompatibility (13) | Prenatal PB | DAW | Draw-a-Woman test (language development)
| G6PD deficiency (1) | | VOC | Georgas Vocabulary test
| Unknown (24) | | Hearing Loss | Same as CPP project
| Controls: infants without marked jaundice (N=445)
Vohr, 1989 [#89328704] Vohr, 1990 [#90339225] | Subjects: infants with moderate bilirubin level (SB 10–20 mg/dl) (N=25) | 16 (64%) subjects had PhotoRx, while none of control infants had PhotoRx (p<0.001) | On day 1 to 2:
| Cause of Jaundice: | | BNBAS | Clusters
| 60% ABO incompatibility | | BAER | Auditory items
| Controls: infants with low bilirubin level (SB < 8 mg/dl) (N=25) | | | Latency I, III, IV, V
| | | | Interpeak I-III, III-V, I-IV,V
Wolf, 1997 [#98030356] Wolf, 1999 [#99156393] | Infants w/ TSB > 23.4 mg/dl | All received PhotoRx | @4 months of age: neurodevelopmental examination | Infant motor screen (IMS) according to Nickel et al. Test rating (normal, suspect, abnormal) and test score (0–28)
| Cause of Jaundice: | 4 (11%) infants received ET | @1 year of age: BSID | Normal = PDI > 84
| 23% ABO incompatibility | 2 (6%) infants had HIV seropositive at 1 year | | Suspect = PDI 68–83 = between 1 SD and 2 SD below the mean
| 14% Sepsis | | | Abnormal = PDI < 67
| 3% Congenital syphilis
| 60% Unknown
Yilmaz, 2001 [#21125314] | Infants w/ TSB ≥ 12 mg/dl (N=87) | 11.4% treated only with PhotoRx | @10–72 months: neurological exam
| Cause of jaundice: | 11.5% treated with both PhotoRx and ET | Hearing loss | DDST
| 44% ABO incompatibility | | | BAER
| 16% Rh incompatibility
| 40% non-hemolytic jaundice

Evidence Table 1. Question 1 - Studies evaluating association of neonatal hyperbilirubinemia to neurodevelopmental outcomes - Part II

Author, Year | Associations found | | | Biases / Limitations | Comments
Bengtsson, 1974 [#74170112] | There were 4, 1 ABO-compatible and 3 ABO-incompatible, (3.7%) children in the hyperbilirubinemia group (N=108) had neurogenic hearing loss. No cases of sensorineural hearing loss were found among the control children. The difference between the 2 groups was not significant. | | | None stated | No data on funding source
| The mean IQ was 106.6±17.26, 105.9±15.49, and 105.9±16.76 in children with ABO-compatible hyperbilirubinemia (N=66), ABO-incompatible hyperbilirubinemia (N=42), and control (N-115) children. | | | | Internal validity: B
| No significant correlation was found between the IQ values and the maximal bilirubin values in either of the hyperbilirubinemia groups.
| 7 (11%) of children with ABO-compatible hyperbilirubinemia had IQ < 85.
| 5 (11%) of children with ABO-compatible hyperbilirubinemia had IQ < 85.
| None of the control children had IQ < 85.
| Psychological disturbances were found in 6 (5.4%) of the children in the hyperbilirubinemia group and in 3 (2.6%) of those in the control group. This difference is not statistically significant. No significant correlation was found between the maximal bilirubin values and the presence of psychological disturbances.
Boggs, 1967 [#67261091] | There were significant linear association between the maximum total SB levels in the neonatal period, and, low total motor score (PDI < 27) and low mental score (MDI < 75) at 8 months, in both BW 2501–3000 g and BW ≥ 3000 g (N=13,568) groups. | | | Not stratified by gestational age | Study was government funded
| For infants with BW 2501–3000 g (N=4,916), the estimated increase in per cent of infants with a low PDI score was 1.2% for each 1 mg/dl rise in total SB level. The estimated increase in percent of infants with a low MDI score was 0.8% for each 1 mg/dl rise in total SB level. | | | Included babies with hemolytic anemia, ET, and congenital malformations. | Internal validity: B
| For infants with BW ≥ 3000 g (N=13,568), the estimated increase in per cent of infants with a low PDI score was 0.5% for each 1 mg/dl rise in total SB level. The estimated increase in percent of infants with a low MDI score was 0.3% for each 1 mg/dl rise in total SB level.
Boo, 1994 [#801] | Infants with hearing loss had significant higher mean peak TSB levels, compared to those without hearing loss (21.6±7.5 vs. 18.4±7.4 mg/dl, respectively, p=0.02). However, there was no significant difference in the prevalence of hearing loss, when comparing infants with lower peak total hyperbilirubinemia (peak TSB ≤ 19.8 mg/dl) to those with high peak TSB > 19.8 mg/dl (16% vs. 33%, p=0.11). | | | Not all methods were reported | No data on funding source
| Controlling for various confounding factors, the significant risk factors associated with hearing loss in term jaundiced neonates were severe hyperbilirubinemia which needed exchange transfusion and the age of onset of hyperbilirubinemia. The probability of hearing loss increased with exchange transfusion and lowered with the age of onset of hyperbilirubinemia. | | | Statistics method used to build the predicting model was not appropriate | Internal validity: C
Chen, 1995 [#96017937] | The latency of VEPs were significantly prolonged in infants w/ SB ≥ 15 mg/dl (N=46), compared with infants w/ SB 10–15 mg/dl (N=26) and controls (N=22). | | | 14% subjects were lost to follow-up for DDST and neurological exam at 1 year of age | No data on funding source
| At 1 year of age, none of the infants w/ SB 10–20 mg/dl (N=44) showed any abnormality in the DDST and neurological examination. Among infants w/ SB > 20 mg/dl (N=18), 4 (22%) were abnormal in gross motor and fine motor skills of DDST. | | | | Internal validity: C
Culley, 1970 [#70266548] | At 6-year follow up, of 49 moderate (SB 12–16 mg/dl) non-hemolytic jaundice infants, BW ≥ 2500 g, 1 (2%) had CNS deficit and 1 (2%) had IQ < 80. | | | No GA was given. BW ≥ 2500 g was used as the indicator of term gestational age. | Study was privately funded
| At 6-year follow up, of 24 severe (SB > 16 mg/dl) non-hemolytic jaundice infants, BW ≥ 2500 g, 1 (2%) had CNS deficit and none (0%) had IQ < 80. | | | Bilirubin levels were estimated by icterometer | Hemolytic jaundice group was not included for current review, because it's difficult to rule out prematurity and Rx effects.
| None of control infants had CNS deficit or IQ < 80 at 6-year follow up. | | | | Internal validity: B
| CNS deficit didn't correlated with level of jaundice.
| All IQs were within normal range. IQ didn't vary due to bilirubin levels in children stratified by BW. Even severe jaundice had no effect on IQ except 1 brain damaged, deaf child.
Esbjorner, 1991 [#91281442] | Significant correlations between the latencies to wave I, III, V, IPL I–V and the reserve albumin concentration (r=-0.89, p<0.01) | | | Small sample size | Study was hospital funded
| No significant correlation between the latency to wave V and the total bilirubin concentration was found (r=0.02, p=0.95) | | | Indirect method for measuring serum albumin concentrations | Internal validity: C
Escher-Gräub, 1986 [#87136731] | Jaundiced infants not required PhotoRx (SB 11.7–14.6 mg/dl) (N=76) showed a less mature behavioral organization than the infants of the control group (SB < 5.8 mg/dl) (N=401). The jaundiced infants were more sleepy, showed more often a poor capacity to attend and to process environmental events, more floppiness, and poorer organizational capacities with respect to state control; and, were more difficult to console. | | | Neonatal assessment only, no long-term follow-up | Study was hospital funded
| | | | | Internal validity: B
Grimmer, 1999 [#99345621] | At age 61–187 months, none of the children studies had medical problems or overtly abnormal neurological findings. | | | Selection bias (58 infants with bilirubin 20–30 mg/dl → 29 excluded → only 18 of 29 was traced → only 16 of the 18 children was studies) | No data on funding source
| When examined by a standardized, age-adjusted neurological follow-up assessment according to Touwen, cluster profiles didn't differ significantly between formerly jaundiced children (N=16) and controls (N=18), except for worse scores of formerly jaundiced children on the choreiform dyskinesia scale. | | | Age at follow-up ranged from 61 to 187 months (5–15 years) | Internal validity: C
Grunebaum, 1991 [#91231060] | 46 children with BMJ had growth, neurological examination, and DDST at mean age of 31 months. It was found that growth and neurological examination was normal in all infants. All but 2 children had normal DDST. | | | 27% lost to follow-up for the neuro-developmental outcomes | No data on funding source
| Of the two children with abnormal DDST, one was delay in language ability, and the other one was delay in fine motor performance. However, both children had normal DDST for the repeated DDST at 1 month later. | | | Incomplete data | Internal validity: C
Gupta, 1990 [#91244386] | Auditory threshold raised in 48% subjects | | | Some patients were given 20mg/Kg of Triclofan for testing, unclear which subjects received the medication | No data on funding source
| Wave III, V and I–V IPL latencies were significantly prolonged in subjects (p<0.01) as compared to controls | | | Bilirubin levels in the controls is unclear | Internal validity: C
| Wave | Subjects | Controls | Exchange transfusion may have caused increased abnormality in ABR
| III | 5.22±0.20 | 5.01±0.19 P<0.05
| V | 7.34±0.14 | 7.10± 0.08 P<0.01
| I-P IPL | 5.36 ± 0.11 | 5.14 ± 0.09 P<0.001
| ABR abnormalities occurred in greater frequency in hyperbilirubinemic infants requiring exchange transfusion (mean serum bilirubin : 30.8 ± 2.4 mg%) than in those with serum bilirubin ranging between 20–25mg%(p<0.001)
| ABR abnormalities however improved in all infants on follow up retesting at 3 months
Gupta, 1998 [#98355379] | Infants with severe jaundice (SB>18 mg/dl) (N=15) and those with moderate jaundice (SB 12–18 mg/dl) (N=30) both had significantly prolonged IPL I–III, III–V, and I–V, compared with non-jaundiced infants (SB<12 mg/dl) (N=15). | | | “Noncooperative children” were sedated with promethazine hydochloride | No data on funding source
| Combined severe and moderate jaundiced infants (N=45), the mean IPL I–III, III–V, and I–V was 2.88±0.30, 3.50±0.24, and 5.92±0.22, respectively. All but IPL I–II were significantly prolonged, compared to non-jaundiced infants' (2.48±0.60, 3.20±0.54, and 5.12±0.26, respectively) | | | Testing at intensity of 80 dB and 40 dB to define recovery @ 6 months | Internal validity: B
| At 6 months, 60% of severe jaundiced infants (N=15) who showed full recovery of IPL had a mean SB level of 21.98 mg/dl, whereas 27% of severe jaundiced infants with a mean SB level of 25.4 mg/dl showed partial recovery of IPL. There were 3 (13%) severe jaundice infants showed no recovery of IPL with mean SB level of 26.3 mg/dl. | | | Unknown Rx effect
| At 6 months, 83% of moderate jaundiced infants (N=30) who showed full recovery of IPL at 6 months had a mean SB level of 16.14 mg/dl, whereas 13% of moderate jaundiced infants with a mean SB level of 17 mg/dl showed partial recovery of IPL. There were 1 (3%) moderate jaundice infants showed no recovery of IPL with mean SB level of 17.7 mg/dl.
Holmes, 1968 [#68310019] | All infants with low and high bilirubin levels had normal neurologic exam; all had normal hearing, even subset with streptomycin | | | None stated | Study was government funded
| Oseretsky test score correlates with age: age effects held constant; correlation of peak SB level with test score showed r=0.23 (opposite of what expected). They then did youngest and oldest age groups for covariance and found no differences. | | | | Study reviewed 10 more studies published before 1966 for the relationship between neonatal jaundice and later neurological outcomes
| In normal FT babies there is no relationship between mild to moderate hyperbilirubinemia (TSB 6.4 to 24 mg/dl) and later motor development as measured by the Oseretsky test. Physical exams were normal. No hearing impairment. | | | | Internal validity: C
| All controls had normal neurologic, audiometric, and Oreletsky exams. Correlation was not done in the control group.
Hyman, 1969 [#69132491] | Among infants with SB < 20 mg/dl (N=243), 5 (2%) developed sensorineural hearing loss. Among infants with SB ≥ 20 mg/dl (N=108), 11 (10%) developed sensorineural hearing loss. All infants received ET and streptomycin Rx; thus, the significant association was between sensorineural hearing loss and high SB levels (p<0.01) | | | BW was used as measure of maturity, so no GA was given | Study was government funded
| Of 38 patients assessed for intelligence outcomes, 5 (4 term and one preemie) had subnormal mentality. Of them, three had very high bilirubin exposure, ≥ 30 mg/dl. No association was found between high bilirubin exposure and low IQ. | | | Low incidence of specific CNS abnormalities | Internal validity: B
| Auditory rote memory difficulties were found in 10 (8 term and 2 preemies) (48%) of 21 patients tested who had high bilirubin and 5 (29%) (all term) of 17 patients who had low bilirubin. No statistical significant difference in the prevalence of auditory rote memory difficulties between infants with SB ≥ 20 mg/dl (N=17) and infants with SB < 20 mg/dl (N=21)
| No significant difference in incidence of CNS abnormalities among infants exposed to different levels of bilirubin below 20 mg/dl. However, among infants exposed to bilirubin levels above 20 mg/dl, the incidence of CNS abnormalities increased sharply.
Johnston, 1967 [#67081206] | Infants with SB > 20 mg/dl (N=129) had mean IQ of 104.8. It's no different from the mean IQ (102.8) among their older, unaffected siblings (N=82) | | | No exclusion criteria given but assume was lost to follow-up | No data on funding source
| Infants with SB > 20 mg/dl had a significant more sensorineural hearing loss (7%), compared to infants with “low” bilirubin levels (N=95) (0%). | | | Limited demographic data was given | Internal validity: C
| Mild athetosis was found in 3 infants with SB > 20 mg/dl.
Naeye, 1978 [#79054333] | IQs, measured at 4 years of age, showed an increased frequency of mental impairment in subjects with peak bilirubin > 7 mg/dl | | | Outcomes definitions are not clear | Study was government funded
| The frequency of low IQs with increasing bilirubin levels increased more rapidly in infected than non-infected infants. | | | Don't know if the results were confounded by any Rx | Internal validity: C
| An increase in the prevalence of abnormalities detected by neurologic test at 7 years of age started at peak neonatal bilirubin levels of 12 to 13 mg/dl. The prevalence of these neurologic abnormalities were more frequent in those had prior amniotic fluid infections than in those not infected. | | | Subjects' demographic data was not given
| Amniotic fluid infections as reflected by inflammation in placental were associated with long-term IQ and neurologic impairment ONLY in children who had displayed respiratory distress as newborns
Newman, 1993 [#94021217] | For CPP white infants with SB < 20 mg/dl, the mean adjusted IQ was 103.4. | | | Follow-up to age 7 years old was available in only about 80% of the infants originally enrolled, and only about half of these had hearing evaluations. | Study was government funded.
| For CPP black infants with SB < 20 mg/dl, the mean adjusted IQ was 93.3. | | | Study data didn't show how many subjects were evaluated for 7-year IQ outcome. | The authors fairly reported both the limitations and advantages. Methodology and statistical methods were reported in detail. Although there was no description of subjects who were lost to follow up, systematic bias is unlikely to happen. Overall, this is a good quality research, but the language is too statistically orientated.
| No significant difference in adjusted IQ between children with SB < 20 mg/dl and ≥ 20 mg/dl in either race. | | | 33,272 subjects were evaluated for 7-year neurologic examination, and, 16,886 children were evaluated for hearing loss | Internal validity: A
| RR of IQ < 85, comparing SB < 20 to ≥ 20 mg/dl, was 0.74 (95%CI 0.41–1.36) in whites, and 1.06 (95%CI 0.79–1.41) in blacks.
| There was no significant association between peak SB and IQ in either race (r=0.13 in whites; r=0.34 in blacks, p>0.05).
| 3.8% of white infants with SB < 20 had abnormal neurologic exam, while 4.5% of white infants with SB ≥ 20 mg/dl had abnormal neurologic exam.
| 15.1% of black infants with SB < 20 had abnormal neurologic exam, while 22.4% of black infants with SB ≥ 20 mg/dl had abnormal neurologic exam.
| Adjusted OR of abnormal neurologic exam, comparing SB < 20 to ≥ 20 mg/dl, was 1.1 (95%CI 0.6–2.1).
| A significant linear trend association was found while increasing in bilirubin levels, the proportion of children with abnormal neurologic exams increased (p=0.06). The specific neurologic examination items most associated with bilirubin levels were mild and nonspecific motor abnormalities.
| 2.2% of CPP subjects had hearing loss. Adjusted OR of hearing loss was 1.08 (95% CI 0.3–3.5)
| There was evidence of effect modification by race (p=0.02), when examining IQ and neurologic outcomes. There was no evidence of effect modification by gender, prematurity, Coombs' test result, or ET. No evidence of effect modification by any of the variables was found when outcome was hearing loss.
| When bilirubin was dichotomized, there was 7% of girls only 3% of boys with bilirubin ≥ 20 mg/dl had abnormal neurologic exams (p=0.02). However, there was no interaction when bilirubin was categorized.
Odell, 1970 [#70075541] | The mean IQ of infants w/ maximum SB ≤ 19 mg/dl (N=6) was 86.3 (75–100). Of them, 2 (33%) children had IQ < 80. | | | Only 1/3 of original group available for analyses | Study was government funded
| The mean IQ of infants w/ maximum SB > 19 mg/dl (N=8) was 93.8 (64–118). Of them, 2 (25%) children had IQ < 80. | | | No control or comparison group | Internal validity:C
| “A correlation was not found between the maximum SB concentration and the subsequent presence of either low IQ and psychometric scores or cerebral palsy.” | | | No GA given
| No significant effects of BW, gender hemolytic disease, ET, and SB levels to the presence or absence of brain damage
| Highly significant correlation of the saturation of patients' sera with bilirubin as measured by index to the children's psychometric test results was found. All (100%) of the children with abnormal psychometric test results (N=8) had the index ≥ 8. Three (50%) of the six children with normal psychometric test results (N=6) had the index ≥ 8.
Ozmert, 1996 [#97154941] | Compared to infants w/o hyperbilirubinemia (N=27), the prevalence of abnormal BAEP was significantly more frequent among infants w/ SB 20–22 mg/dl and negative Coombs' test (35%) (N=26), infants w/ SB 22–25 mg/dl and negative Coombs' test (48%) (N=27), and infant w/ SB > 20 mg/dl and positive Coombs' test (41%) (N=17) infants. | | | Of 416 eligible children, only 102 were located and could participate. | No data on funding source
| No difference in verbal IQs was found between groups. | | | Control group not from same birth cohort | Internal validity: C
| Infants w/ SB > 20 and positive Coombs' test (N=17) had significant lower both performance and full IQs, compared to normal controls (N=27). However the mean performance IQ (93.00±12.93) was within normal range. On the other hand, the full IQ was below normal (87.28±20.36). | | | Don't know if subjects underwent Rx for hyperbilirubinemia
Paludetto, 1986 [#86296856] | There was no difference in any behavioral item of the Brazelton Scale at 1^st^(3^rd^days of life), 2^nd^(4^th^days of life), and 3^rd^(1 month of age) observation between jaundiced infants (N=17 @1^st^observation, N=7 @2^nd^observation; N=10 @3^rd^observation) and matched controls. | | | Only 4 controls had bilirubin measurement | No data on funding source
| | | | Small sample size | Internal validity: C
Perlman, 1983 [#84041257] | Ten (42%) of 24 hyperbilirubinemic infants (SB>15 mg/dl) had loss of waves, whereas these waves were present in all recordings in control infants (SB<12 mg/dl) | | | Babies had received PhotoRx. Effect of PhotoRx is not excluded | No data on funding source
| There is no difference in the mean wave amplitudes between jaundiced (N=24) and non-jaundiced infants (N=19). | | | Small sample | Internal validity: B
| Brainstem transmission time was significantly prolonged in jaundiced infants (5.97±0.30 ms), compared to non-jaundiced infants (5.78±0.28 ms).
| The mean maximum bilirubin level in jaundiced infants with absent waves (N=10) was 18.9±2.6 mg/dl, compared with 18.6±2.9 mg/dl in jaundiced infants without absent waves (N=14) (p>0.5)
| Regression of latencies and amplitudes against maximum SB didn't demonstrate statistically significant correlation.
Rapisardi, 1989 [#89213178] | The purpose of the study was to test the hypothesis that infant cry variability is increased in moderately high-risk infants. It was found that infants with the highest levels of bilirubin showed a greater coefficient of variation (CV) of the format frequency 1 (F1) during phonation (PF1) than infants with lower or medium levels of bilirubin (P<0.05). The CV of F1 during dysphonation (DF1) was also greater in the group of infants with the highest level of bilirubin compared to the group of infants with medium bilirubin (p<0.05) | | | “High bilirubin” defined as SB > 12 mg/dl | Study was government funded
| The correlation between the CV of F1 during phonation (PF1) and level of bilirubin was significant (r=0.37, p<0.05), suggesting that more variability in F1 was related to higher concentrations of bilirubin. | | | No long-term follow-up | Internal validity: B
| | | | Small sample size
Rosta, 1971 [#72185033] | Severe sensorineural hearing loss was detected in 5 (6%), a mild to moderate one in 9 (11%) patients. “The above incidence was surpassing the frequency of similar alterations in the normal population.” | | | Large amount of missing data | No data on funding source
| “Perceptive hearing loss was related to the gravity of jaundice and, in addition, to the presumable side effect of streptomycin treatment.” | | | Didn't give details by outcomes | Internal validity: C
| Distribution of IQ was the same as in the normal population. 4 (5%) children had an IQ below 0.70, 11 (13%) had an IQ between 0.70 and 0.80. | | | Included diagnoses such as 5 children with febrile seizures
| Of the 84 jaundice infants, 35 (42%) had peak SB level below the “limit of ET”, 27 (32%) had peak SB level exceeding the limit of ET but not representing an absolute indication for ET; and, 20 (24) had peak SB level above the limit of ET. Summing up all the findings in the three groups, “sequelae” were found in 34%, 37%, and 55%, respectively. | | | Unable to tell which of the abnormal “sequelae” were included in the report by subgroups
| | | | Many general statements made without data
Rubin, 1979 [#79153498] | Infants with SB 16–23 mg/dl (N=153) had significantly lower Bayley's MDI and PDI scores at 8 months of age, compare to infants with SB 11–15 mg/dl (N=66) and those with SB ≤ 10 mg/dl (N=120). Controlling for GA, there was no longer a difference on MDI, but PDI remained significant. | | | Some lost to follow up | No data on funding source
| Infants with SB 16–23 mg/dl (N=153) had significantly more neurologic abnormalities at 1 year of age, compare to infants with SB 11–15 mg/dl (N=69) and those with SB ≤ 10 mg/dl (N=120). Controlling for GA, the difference still remained significant. | | | | Internal validity: B
| No significant differences were found between groups for MRT & ITPA at 5 and 6 year of age, IQ at 7 years of age, and neurologic abnormalities at 7 years of age.
| The mean IQ at 7 years of age was 100.06±12.74, 101.75±13.79, and 102.02±15.01 for infants with SB 0–10, 11–15, and 16–23 mg/dl, respectively.
Scheidt, 1977 [#77209363] | For white term (GA ≥ 36 wks and BW > 2500 g) and FT (GA ≥ 37 wks and BW > 2500 g) infants, Bayley's PDI score was significantly decreased with elevated SB levels (SB≥10 mg/dl). However, significant decrease in Bayley's MDI score only occurred in white term infants with SB≥15 mg/dl. | | | Don't know if the results were confounded by any Rx | Study was government funded
| For black term (GA ≥ 36 wks and BW > 2500 g) infants, both Bayley's MDI and PDI scores were significantly decreased with elevated SB levels (SB≥10 mg/dl). However, no association between SB levels and Bayley's MDI and PDI scores was found in black FT (GA ≥ 37 wks and BW > 2500 g) infants. | | | The authors noted that the mean scores for each comparison tend to be progressively lower at bilirubin levels above 14 mg/dl because of small sample size | Internal validity: B
| The study examined the potentially confounding factors found that race is significant confounder, SES is not associate with bilirubin levels; and, BW and GA appear to be more powerful determinants of Bayley's MDI & PDI test performance than levels of maximum SB.
Seidman, 1991 [#91375839] | For males (N=1031), the mean IQ was 105.2±1.7, 105.5±1.9, and 103.9±2.4 for those had no jaundice, moderate jaundice (5–8 mg/dl on day 1, 10–15 mg/dl on day 2, or 13–20 mg/dl thereafter, and severe jaundice (>8 mg/dl on day 1, >15 md/dl on day 2, or >20 mg/dl thereafter) respectively. | | | Not a true prospective study even though authors claim that it is a “historical” prospective study. | No data on funding source
| For females (N=917), the mean IQ was 103.4±1.5, 104.7±1.9, and 102.4±2.6 for those had no jaundice, moderate jaundice and severe jaundice, respectively. | | | Not all the details of logistic analysis were presented. | Internal validity: B
| Adjusted odds for full-term, coombs negative male with severe hyperbilirubinemia was 2.96 (95%CI 1.29–6.79)
Soorani-Lunsing, 2001 [#11726727] | None of jaundiced or control infants had abnormal neurologic exams through the study period. | | | Small sample size | No data on funding source
| At 3–8 days of life, infants with SB > 12.9 mg/dl (N=20) had significant higher prevalence of mild neurologic dysfunction (70%), than controls (25%) (N=20). Controlling for other factors, the odds of developing mild neurologic dysfunction was 6.62 (95%CI 1.59–27.51), compared jaundiced infants to controls. | | | No data on TSB level available for control group | Internal validity: C
| At 3 months of life, infants with SB > 12.9 mg/dl (N=20) had significant higher prevalence of mild neurologic dysfunction (55%), than controls (25%). Controlling for other factors, the odds of developing mild neurologic dysfunction was 3.75 (95%CI 1.03–14.53), compared jaundiced infants to controls.
| At 1 year of life, infants with SB > 12.9 mg/dl (N=20) had significant higher prevalence of mild neurologic dysfunction (50%), than controls (10%). Controlling for other factors, the odds of developing mild neurologic dysfunction was 9.47 (95%CI 1.67–53.65), compared jaundiced infants to controls.
| At 1 year of life, all 5 children with minor neurologic dysfunction type 2 had had total SB ≥ 19.6 mg/dl. 4 of them received PhotoRx. None of the controls had minor neurologic dysfunction type 2.
| Behavior of the study and control children at age of 12 months didn't differ according to the parental questionnaire.
| Study also found BW, group membership and male gender are best explanation of neurologic dysfunction in the logistic model.
Suresh, 1997 [#98374505] | Hearing was normal in 34 (94%) patients (reported in 36 patients). 1 children with hearing loss had conductive loss from otitis media. | | | Questionnaires mailed to 27 physicians “thought to be in contact with CN1 patients” — 14 physicians and 3 parents returned information on 42 CN1 patients. | No data on funding source
| No sensorineural hearing loss was reported despite bilirubin levels 20–29 and ≥30 mg/dl in some patients | | | No objective measures of hearing loss | Internal validity: C
| All 42 patients are reported to be of normal height and weight. | | | Lack of definitions of outcomes.
| The neurodevelopmental status (reported in 39 patients) is reportedly normal (with good school performance) in 77% (30/39).
| 2 patients have kernicterus.
| 4 have cerebellar symptoms.
| 1 each has developmental delay, mild intention tremor, and mild speech delay.
Tan, 1992 [#92139200] | Before PhotoRx, infants with hyperbilirubinemia (mean SB 16.7 mg/dl) (N=30) had significantly prolonged latency V and IPL III–V and I–V. BAER significantly improved after day 1 Rx, and there was no difference in latencies and IPL between subjects and controls. | | | Post-Rx latencies and IPL was not given. Data was presented in graphs. | No data on funding source
| In PhotoRx group, there was significant difference between the preexposure and postexposure values of latency V and IPL III–V and I–V. | | | No long-term follow-up | Internal validity: A
| The correlation between the bilirubin levels and the BAER values during PhotoRx was highly significant r=0.967 and p<0.001 for latency V; r=0.999 and p< 0.001 for IPL I–V; and r=0.963 and p< 0.001 for IPL III–V.
| “The amplitude measurements proved too unreliable for meaningful comparison.”
Upadhyay, 1971 [#71238892] | Significantly more infants with hyperbilirubinemia (bilirubin>20 mg/dl) were non-normal in Bayley's developmental outcomes at 8 months, compared to those with bilirubin<10 mg/dl (4/17 vs. 0/18, respectively. P<0.01). No differences in neurologic exams at 12 months; and, hearing language and speech outcomes at 36 months between the two groups. | | | Definitions of abnormal, suspect, or non-normal were not clearly given | No data on funding source
| At 48 months, 2 (10%) hyperbilirubinemic children had IQ scores below 80 (49 and 68). 4 (20%) control children (bilirubin<10 mg/dl) had IQ scores below 80 but none below 70. | | | Large amount of missing data | Internal validity: C
| The mean IQ scores between the two groups were not significantly different. The mean IQ of the hyperbilirubinemic children was 93.5 and that of the controls was 90.5.
Valaes, 1980 [#81031849] | Degree of jaundice was found no Association to VMI, DAW and VOC scores. | | | Didn't followed all of the RCT subjects | No data on funding source
| Two children had hearing loss in the high frequency scored low in the verbal test but other tests were not different from the population. | | | Majority of subjects pre-exposed to prenatal PB | Internal validity: B
| RCT of PB found PB significantly decreased the prevalence of jaundice. | | | Including infants with hemolytic disease and few preemies
Vohr, 1989 [#89328704] Vohr, 1990 [#90339225] | Moderately jaundiced infants (N=23), SB 10–20 mg/dl, scored significantly lower in the orientation (p<0.04), state range (p<0.01), and state regulation (p<0.03) cluster scores; and, all auditory items, compared with infants with SB < 8 mg/dl (N=27). | | | No long-term follow-up | No data on funding source
| Infants with moderate jaundice also showed significantly prolonged Latency IV or B; and, Interpeak I–V, both reflecting central conduction time, when compared with infants with low bilirubin level. | | | Small sample size | Internal validity: A
| All items in BNBAS were significantly correlated to levels of SB. The correlation showed that increased levels of SB with decreased scores on the individual BNBAS items. After control for PhotoRx by partial correlations, most of correlations remained significant except for state regulation and autonomic stability.
| Increased bilirubin level also correlated with an increased latency of BAER wave IV, V (r=0.25, p<0.05)
Wolf, 1997 [#98030356] Wolf, 1999 [#99156393] | @ 4 months of age (N=45, mixed term and preterm infants): | | | Infants were enrolled only if clinically jaundiced. | No data on funding source
| Linear correlation showed an association of maximum TSB and test rating at 4 months (r=0.32, p<0.05) and test scores at 4 months (r=0.44, p<0.03) | | | Treatment effects couldn't be ruled out. | Internal validity: C
| No association was found between GA and TSB | | | No control group
| No relationship between the cause of jaundice and 4-month neurodevelopmental outcomes. | | | Not all detail was given
| Mean TSB in the normal IMS group was 27.3±5.3 mg/dl; in the suspect and abnormal IMS group the mean TSB was 28±4 mg/dl and 33.7±10.3 mg/dl, respectively. These differences were not significant (p=0.06)
| @ 1 year of age (N=35, term infants only):
| 8 (23%) term infants, with mean TSB 33.4 mg/dl, had abnormal and suspect BSID and clinical diagnosis at 1 year.
| 27 (77%) term infants, with mean TSB 26.5 mg/dl, scored normal on the BSID at 1 year.
| “Relationship between Bayley motor score and TSB correlation was 0.59 (p<0.01)”
Yilmaz, 2001 [#21125314] | Neurological dysfunction was observed in 10 (11.5%) of the 87 subjects. Subjects with maximum SB levels < 20 mg/dl (N=10) didn't show any neurological abnormalities, whereas 4 (9.3%) of the subjects with SB 20–23.9 mg/dl (N=43) had only dysconjugated gaze movements and 6 (17.6%) of the subjects with SB ≥ 24 mg/dl had neurological manifestations. | | | Large amount of missing data | No funding source
| The mean peak SB level was 26.1±4.9 mg/dl in subjects with neurological dysfunction (N=10), while that was 23.2±3.4 mg/dl in subjects with normal neurological function (N=77) (p<0.05). | | | | Internal validity: C
| The duration of jaundice was significantly longer in neurologically abnormal subjects (6.1±1.9 days), than in neurologically normal subjects (4.7±2.4) (p<0.05).

Evidence Table 1A. Question 2 - Study evaluating evidence for effect modification - Part I

Author, Year | Demographics | Inclusion Criteria | Exclusion Criteria | Study Design (Duration)
Naeye, 1978 [#79054333] | Location: US | Unselected 53518 pregnancies in US between 1959 and 1966 | Multiple births | Prospective longitudinal cohort (8 years)
| Setting: CPP | | Major congenital malformation
| Birth years: 1959 to 1966 | | Down's syndrome
| Number of centers: 14 | | Hydrocephalus
| Enrolled subjects: 53518 | | Lead intoxication
| Evaluated subjects: 45347 → 41444 @ 7 yrs | | Fractured skull
| Mean GA (range): ND | | Inborn error of metabolism (hypothroidism …)
| Mean BW (range): ND
| Mean Apgar score at 1 min: ND
| Breastfed (%): ND
| Male (%): ND
| Race (%): ND

Evidence Table 1A. Question 2 - Study evaluating evidence for effect modification - Part II

Author, Year | Disease/Condition Type (N) | Potential Confounding Factors | Outcomes | Outcome Definitions
Naeye, 1978 [#79054333] | CPP subjects, mixed term and preterm infants (N=41,444) | Placental infection, respiratory distress as a probable indication of acute inflammation | @4 yrs of age: IQ | ND
| | Prematurity | @7 yrs of age: Neurologic exam

Evidence Table 1A. Question 2 - Study evaluating evidence for effect modification - Part III

Author, Year | Associations found | Biases / Limitations | Comments
Naeye, 1978 [#79054333] | IQs, measured at 4 years of age, showed an increased frequency of mental impairment in subjects with peak bilirubin > 7 mg/dl | Outcomes definitions are not clear | Study was government funded
| The frequency of low IQs with increasing bilirubin levels increased more rapidly in infected than non-infected infants. | Don't know if the results were confounded by any Rx | Internal validity: C
| An increase in the prevalence of abnormalities detected by neurologic test at 7 years of age started at peak neonatal bilirubin levels of 12 to 13 mg/dl. The prevalence of these neurologic abnormalities were more frequent in those had prior amniotic fluid infections than in those not infected. | Subjects' demographic data was not given
| Amniotic fluid infections as reflected by inflammation in placental were associated with long-term IQ and neurologic impairment ONLY in children who had displayed respiratory distress as newborns

Evidence Table 2 . Question 3: Section I - Treatment Effect on Decreasing Bilirubin Levels and Changing Auditory Brainstem Response in Term or Near-Term Jaundiced Infants - Part I

Author, Year | Demographics | | | Inclusion Criteria | Exclusion Criteria | Study Design (Duration)
Agrawal, 1998 [#99232291] | Location: India | | | Subjects: Term infants with SB > 15 mg/dl | Birth asphyxia (Apgar < 7 @ 5 min) | Prospective longitudinal study (1 year)
| Setting: Hospital | | | Controls: Term infants with uneventful perinatal period and a peak SB < 12 mg/dl | IVH
| Birth years: 8/1995 to 4/1996 | | | | Sepsis or meningitis
| Number of centers: 1 | | | | Aminoglycoside administration
| | [underlined: Subjects] | [underlined: Controls] | | Craniofacial malformations
| Enrolled subjects | 30 | 25
| Evaluated subjects: | 30 | 25
| Mean GA (range): | ND | ND
| Mean BW (range): | 2.63±0.16 | 2.65±0.21 Kg
| Mean Apgar score at 1 min: | ND | ND
| Breastfed (%): | ND | ND
| Male (%): | 53% | ND
| Race (%): | ND | ND
Bhandari, 1993 [#94075016] | Location: India | | | Plasma bilirubin ≥ 15mg/dL | Asphyxia | Prospective cross-sectional study
| Setting: Hospital | | | | CNS infection
| Birth years: 9/1988– 8/1989 | | | | Congenital malformations
| Number of centers: 1 | | | | Septicemia
| Enrolled subjects: ND
| Evaluated subjects: 30
| Mean GA ( range): 37.9 ± 3.1 weeks
| Mean Apgar score at 1 minute: ND
| Breastfed (%): ND
| Male(%): ND
| Race(%): Indian
Deorari, 1994 [#95189280] | Location: India | | | Hyperbilirubinemia | GA < 37 or > 42 weeks | Prospective cohorts
| Setting: Hospital | | | Total serum bilirubin> 15 mg/dL | Apgar score < 6 at 1 minute
| Birth years: 4/1988– 5/1989 | | | | Congenital malformations
| Number of centers: 1 | | | | Neonatal complications
| Enrolled subjects: ND | | | | BW and/or HC < 10%tile or > 90%tile
| Evaluated subjects: 18 (20)
| Mean GA ( range): 39.0 ± 0.41 weeks
| Mean Apgar score at 1 minute: >6
| Breastfed (%): ND
| Male(%): 80%
| Race(%): Indian
Funato, 1996 [#97104685] | Location: Japan | | | Bilirubin ≥ 20mg/dL | Newborn with CNS disorders-asphyxia, meningitis, hemorrhage | Prospective cohorts
| Setting: Hospital | | | Received exchange transfusion
| Birth years: 1987-1993
| Number of centers: 1
| Enrolled subjects: 10
| Evaluated subjects: 10
| Mean GA ( range): 38.2 ± 2.1 weeks
| Mean Apgar score at 1 minute: ND
| Breastfed (%): ND
| Male(%): ND
| Race(%): Asian 100%
Hung, 1989 [#90054139] | Location: Taiwan | | | Infants with hyperbilirubinemia in the nursery and NICU, as well as those with overt bilirubin encephalopathy from outpatient clinics. | Prematurity Sepsis Meningitis Asphyxia and IVH | Unclear (prospective or retrospective)
| Setting: Hospital | | | All were FT and BW ≥ 2500 g
| Birth years: 1984 to 1986 | | | For current review, only group II, 6 jaundice infants with ABR testing before and after ET, was included
| Number of centers: 1
| Enrolled subjects: 75
| Evaluated subjects: 6
| Mean GA (range): Full term
| Mean BW (range): ≥ 2500 g
| Mean Apgar score at 1 min: ND
| Breastfed: ND
| Male: 50%
| Race: ND
Kuriyama, 1986 [#89246798] | Location: Japan | | | Admitted for hyperbilirubinemia and treated with exchange transfusion | Asphyxia | Prospective cohorts (21 days to 6 months)
| Setting: Hospital | | | Peak bilirubin 21.5 ± 4.62 mg/dL
| Birth years: ND
| Number of centers: 1
| Enrolled subjects: 6 (8)
| Evaluated subjects: 6 (8)
| Mean GA (range): 34–41 weeks
| Mean Apgar score at 1 & 5 minute: 10
| Breastfed (%): ND
| Male(%): ND
| Race(%): 100% Japanese
Nwaesei, 1984 [#85037769] | Location: Canada | | | Term infants with exchange transfusion for hemolytic disease-peak bilirubin 22.3 ± 1.4 mg/dL (20.7–24.7) | GA < 38 weeks or > 41 weeks | Prospective cross-sectional study
| Setting: Hospital | | | | Pregnancy complications
| Birth years: 1/1/1982–4/30/1983 | | | | BW and/or HC < 10%tile or > 90%tile
| Number of centers: 1 | | | | Neonatal complications or anomalies orbilirubin binding drugs
| Enrolled subjects: 17
| Evaluated subjects: 9
| Mean GA ( range): 39 ± 1.5 weeks
| Mean Apgar score at 5 minutes: > 7
| Breastfed (%): ND
| Male(%): 44.4%
| Race(%): ND
Sabatino, 1996 [#9717477] | Location: Italy | | | Subjects: FT newborns with SB 14–25.8 mg/dl | Rh or ABO incompatibilities | Prospective cross-sectional cohort
| Setting: Hospital | | | Controls: “age-matched” | Congenital malformations
| Birth years: ND | | | | Hemorrhage, sepsis or other infections
| Number of centers: 1 | | | | Abnormal BAEP components or lacking some of these components
| | [underlined: Subjects] | [underlined: Controls]
| Enrolled subjects: | 90 | ND
| Evaluated subjects: | 48 | 40
| Mean GA (range): | 40.2±1.1 | 40.3±1.3 wks
| Mean BW (range): | 3312±411 | 3492±501 g
| Mean Apgar score at 1 min: | ND | ND
| Breastfed (%): | ND | ND
| Male (%): | 42% | 45%
| Race (%): | ND | ND

Evidence Table 2. Question 3: Section I - Treatment Effect on Decreasing Bilirubin Levels and Changing Auditory Brainstem Response in Term or Near-Term Jaundiced Infants - Part II

Author, Year | Disease/Condition Type (N) | Treatments | Outcomes | Outcome Definitions
Agrawal, 1998 [#99232291] | Subjects: Term infants with SB > 15 mg/dl (N=30) | 47% subjects received ET; 53% subjects received PhotoRx | BAER | Latency I, II, III, IV, V
| Causes of Jaundice: | Two subjects w/kernicterus | @1 year: neurodevelopment | Interpeak Latency (IPL) I–III, III–V, I–V
| 63% idiopathic | | | DDST (gross motor, language, fine motor adaptive and personal social development)
| 10% Rh incompatibility
| 27% ABO incompatibility
| Controls: Term infants with SB < 12 mg/dl (N=25)
Bhandari, 1993 [#94075016] | Subjects: infants with TSB ≥ 15mg/dL(N=30) | Rx (not specified) | @5.3±1.7 days of life: BAER | BAER using 80dB stimuli Latency I, III, V and IP I–III, I–V, III–V
| Cause of jaundice:
| ABO incompatibility:6/30
| Rh isoimmunization: 2/30
| G6PD deficiency: 9/30
| No apparent cause: 13/30
Deorari, 1994 [#95189280] | Subjects: term neonates with TSB> 15mg/dL (N=18) | Phototherapy but if BAER was considered abnormal in addition to raised bilirubin level, double volume exchange transfusion was done | BAER: | BAER on the day hyperbilirubinemia is detected and subsequently every 24–48 hours total serum bilirubin is < 15mg/dL and repeated at 1 month ± 7 days, 6 months V 15 days and 12 months V 15 days.
| Cause of jaundice: | | @6 & 12 months: Hearing | -presence or absence of wave complexes III, IV–V
| ABO incompatibility: 5/18 | | DQ | -latency of waves I, III and V
| Rh isoimmunization: 2/18 | | | -interwave conduction time wave V to I
| G6PD deficiency: 2/18 | | | Hearing was evaluated by parental questioning, behavioral audiometry and impedance audiometry
| Idiopathic: 9/18 | | | Nancy Bayley Scale:
| Controls: term neontes without jaundice (N=20) | | | DMQ: motor development scale
| | | | DmeQ: mental development scale
Funato, 1996 [#97104685] | Subjects: infants with TSB ≥ 20 mg/dL ( N=10) | All received Exchange transfusion | @admission, pre- and post- Rx, 3 months: BAER | Latencies of wave I, I–III, I–V interpeak and amplitude of wave I, III and V
| Cause of jaundice: | | @1–6 years: Developmental and intelligence quotient | Mother-Child-Counseling
| ABO incompatibility: 1 | | | Baby test at 1–2 years of age
| Polycythemia: 3 | | | Suzuki-Binet IQ test at 3 years of age
| Cephalhematoma:1 | | | Japanese/Wechsler Intelligence Scale for Children-Revised IQ test at 6 years
| Idiopathic jaundice: 5
Hung, 1989 [#90054139] | FT infants with ABR testing before and after ET (N=6) | All received exchange transfusion | @pre- and post- ET: ABR | Latency I, III, V Amplitudes
| | | | Amplitudes
Kuriyama, 1986 [#89246798] | Subjects: Near-term and term infants( N=6) | All subjects received exchange transfusion | BAER prior to and within 3 months of ET | Latency I, III, V
| Cause of jaundice: | | | Interpeak I–III, I–V, III–V
| Hemolytic disease: 83%
| Hemoperitoneum: 17%
| TSB 14–30mg/dL
| Controls: Term infants without jaundice (N=8)
Nwaesei, 1984 [#85037769] | Term infants with exchange transfusion for hemolytic disease (N=9) | All received ET | @pre- and post- ET: ABR | Latencies
| Causes of Jaundice: | | | Amplitudes
| 33% Rh incompatibility
| 67% ABO incompatibility
Sabatino, 1996 [#9717477] | Subjects: Healthy FT infants w/ SB 14–25.8 mg/dl | All subjects were treated with PhotoRx and ET according to APP guideline | Pre- and Post-Rx BAER | Latency I, III, V
| Controls: age-matched infants (No bilirubin level was given) | | @6, 18, 30 months: neuropsychological evaluation | Interpeak I–III, III–V, I–V
| | | | Brunett-Lezine test

Evidence Table 2. Question 3: Section I - Treatment Effect on Decreasing Bilirubin Levels and Changing Auditory Brainstem Response in Term or Near-Term Jaundiced Infants - Part III

Author, Year | Associations found | Biases/Limitations | Comments
Agrawal, 1998 [#99232291] | The mean latencies I, II, III, IV, and V and IPL I–III, III–V, I–V were significantly higher in infants with SB > 15 mg/dl (N=30) before Rx, as compared to controls (N=25). | Large amount of missing data | No data on funding source
| Latency of different waves and IPL significantly decreased (returned towards normal) after Rx. Follow up BAER at 14.4±2.2 weeks (N=21) revealed that only 3 (14%) were persistent abnormalities on BAER. All 3 had initial SB > 24 mg/dl, and 2 also had kernicterus. | Unable to sort out effect of treatments on BAER or just bilirubin levels | Internal validity: C
| DDST at 1 year of age revealed that neurological development was normal in all infants with SB 15–20 mg/dl, in 89% infants with SB 21–25 mg/dl, and in 67% infants with SB > 25 mg/dl. | Bilirubin levels for Rx were not stated
| | Small sample size
Bhandari, 1993 [#94075016] | Initial BERA response showed delayed appearance of waves I, III, V in jaundiced babies which tended to return to normal in some at repeat BERA. | Rx was not specified | No data on funding source
| 13.2% of babies with jaundice had absence of waveforms at 80dB on initial examination. Half of these improved and half continued to show absent waves on repeat BERA. One baby who had waveforms on initial examination at peak of jaundice showed absent waveforms after bilirubin values had decreased to < 10 mg/dL. | No control group | Internal validity: B
Deorari, 1994 [#95189280] | BAER- Loss of waves: 5 of 18 subjects (with TSB > 24 mg/dL) demonstrated loss of waves I, III and wave complex IV–V and none of the controls (p<0.001). Wave complex IV–V was absent bilaterally in 3 and unilaterally in 2. | Indian infants only | No data on funding source
| Latencies and interwave conduction times: In 4 neonates with TSB> 22 mg/dL I–V conduction time was +2 SD more than mean as compared to controls. Following exchange transfusion wave complexes reappeared, amplitude, latency and interwave conduction time improved. | Response to exchange transfusion evaluated but not response to phototherapy | Internal validity: B
| Hearing evaluation at 12 months: Normal in 7 subjects underwent ET and 16 controls that reported for follow up.
| Development Quotient: Mean development motor quotient and mean development mental quotient in study and control groups were comparable and normal at 1 year of age.
| Neurological sequelae: None of the study or control group babies developed seizures, motor deficits or features of cerebral palsy on follow up at 1 year of age
Funato, 1996 [#97104685] | ABR latencies were measured in non-hyperbilirubinemic term controls at 3 days, 3 months, and 6 months. Compared to these values at 3 days of life (N=16), subjects' (N=8) mean latencies of wave I, I–III, and I–V in the bilateral ears were significantly prolonged before ET. | Small sample size | No data on funding source
| Follow up: | | Internal validity: C
| 2 of the 9 infants ABR still showed abnormal findings at 3 and 6 months of age, which normalized by 1.5 years and 5 years respectively.
| Developmental follow up at 1.5 to 6 years of age was normal with DQ/ IQ > 85 except for 1 patient who developed borderline intelligence with IQ=77 at 6 years old.
Hung, 1989 [#90054139] | Five of the 6 patients had abnormal ABRs before ET. Three of them became normal and the other 2 showed improvement after ET. | Small sample size | No data on funding source
| The Latency I, III, and V were shortened and the amplitude increased after ET. | No long-term follow-up | Internal validity: B
Kuriyama, 1986 [#89246798] | Before the treatment the latencies of waves III, V and I–IV and I–III were significantly prolonged as compared to controls. | 6 newborns included, 4 full term, one 34 wk and one 35 wk NB. | No data on funding source
| All latencies and IPLs decreased after ET and those of waves I, III, V and I–V IPLs decreased significantly. | 5 with hemolytic disease and 1 with hemoperitoneum | Internal validity: B
| Follow-up at 25 days to 6 months in 5 of the 6 infants found normal development and not hearing abnormalities. | Only 5 of 6 had follow up-age ranged from 25 days to 6 months at follow up
Nwaesei, 1984 [#85037769] | Study documented improvement in auditory brainstem response and amplitudes before and after exchange transfusion in 9 term infants with serum bilirubin 22.3±1.4 mg/dl pre-exchange. It was found that ABR latencies and amplitudes significantly decreased after ET. Findings interpreted as indicating the existence of a “transient bilirubin toxicity of the brainstem.” | Only 9 of 19 infants studies | No data on funding source
| | No follow-up studies | Internal validity: C
| | No controls
Sabatino, 1996 [#9717477] | Pre-treatment Latency III, V, and, IPL III–V, I–V were significantly prolonged in infants with SB 14–25.8 mg/dl, compared to controls'. Post-treatment Latency and IPL were all reverted to normal. | How controls were selected was not clear | No data on funding source
| Neuropsychological evaluations performed in subjects at 1, 2, and 3 years of age showed scores similar to those of “age-matched” controls. | Controls' bilirubin level not reported | Internal validity: B
| | Small sample size
| | No detailed results for neuropsychological outcomes

Evidence Table 3. Question 3: Section II - Studies evaluating treatments for neonatal hyperbilirubinemia in relation to later neurodevelopmental outcomes - Part I

Author, Year | Demographics | Inclusion criteria | Exclusion criteria | Study design
Abrol, 1998 [#20235719] | Location: India | GA 37–40 weeks | Gross congenital malformation | Prospective cohort
| Setting: Hospital | BW between 10th and 90th %tile
| Study period: ND | No gross congenital malformation
| No. of centers: 1 | No illness during study period
| Enrolled subjects: 30 | Apgar score at least 8 at 1 and 5 minutes
| Evaluated subjects: ND
| Mean GA ( range): 37–40 weeks
| Mean Apgar score at 1 & 5 minute: > 8
| Breastfed (%): ND
| Male(%):
| Race(%): Indian
Granati, 1984 [#84283738] | Location: Italy | Full term | ND | Prospective cohort
| Setting: Hospital | Treated for bilirubin ≥ 14mg/dL
| Study period: Jan 1981-April 1982
| No. of centers: 1
| Enrolled subjects: 110(110)
| Evaluated subjects: 110(110)
| Mean GA ( range): 39.4 ± 1.1 (37–42)
| Mean Apgar score at 5 minutes: 9 ± 0.5(7–10)
| Breastfed (%): ND
| Male(%): ND
| Race(%): 100% Italian
Ju, 1991 [#91289763] | Location: Taiwan | Normal pregnancy | Infants with hemolysis as indicated by a positive Coombs test | Randomized controlled trial
| Setting: Hospital | Spontaneous delivery or cesarean section without complication | G6PD deficiency
| Study period: ND | Singleton birth
| No. of centers: 1 | Full term (38–42 weeks gestation)
| Enrolled subjects: 29(14) | BW between 10th and 90th percentile
| Evaluated subjects: ND | No congenital anomalies
| Mean GA ( range): | Apgar scores ≥ 7 at 1 and 5 minutes
| PT group: 38.9 ± 0.9 | No perinatal complications other than hyperbilirubinemia
| Non PT group: 39.2 ± 0.8
| Controls: 39.6 ± 1.2
| Mean BW (range):
| PT group: 3435 ± 280
| Non PT group: 3293 ± 378
| Controls: 3320 ± 333
| Mean Apgar score at 1 minute:
| PT group: 8.3 ± 0.9
| Non PT group: 8.8 ± 0.4
| Controls: 8.8 ± 0.4
| Mean Apgar score at 5 minute:
| PT group: 9.5 ± 0.5
| Non PT group: 9.8 ± 0.5
| Controls: 9.6 ± 0.5
| Breastfed (%):
| PT group: 61.5
| Non PT group: 69.2
| Controls: 57.1
| Male(%):
| PT group: 61.5 Non
| PT group: 30.7
| Controls: 42.8
| Race(%): ND
Khanna, 1984 [#85103758] | Location: India | Term | ND | Retrospective cohort
| Setting: Hospital | Normal intrauterine growth
| Study period: ND | Bilirubin levels > 15 mg/dL
| No. of centers: 1
| Enrolled subjects: 56(56)
| Evaluated subjects: 56(56)
| Mean GA ( range): ND
| Mean Apgar score at 1 and 5 minutes: ND
| Breastfed (%): ND
| Male(%): Study group: 1.5: 1
| Control group: 1.3: 1
| Race(%): 100% Indian
Misra, 1980 [#80203306] | Location: India | Phototherapy | ND | Non-randomized clinical controlled trial
| Setting: Hospital | Bilirubin level 10–30mg/dl
| Study period: 36 months
| No. of centers:1
| Enrolled subjects:81(60)
| Evaluated subjects: 81(60)
| Mean GA(range): 38.1
| Mean BW: 2650g
| Mean Apgar score: 9.8
| Breastfed(%): ND
| Male: ND
| Race: 100% Indian
Paludetto,1983 [#84057358] | Location: Italy | Uncomplicated pregnancy | Special care nursery transfer | Prospective cohort
| Setting: Hospital | Spontaneous labor | Hemolysis
| Study period: ND | No medication or anesthesia during delivery | Other perinatal disease
| No. of centers: 1 | Uncomplicated vaginal delivery
| Enrolled subjects: 30(30) | Single birth
| Evaluated subjects: ND | No congenital malformation
| Mean GA ( range): 39.3 (37–41) | Apgar score > 7 at 5 minutes
| Mean Apgar score at 1 minute: 8.3 (3–10) | Full term infants weighing at least 2500 g
| Breastfed (%): 100 | Breastfeeding
| Male(%): 73.3 | No perinatal complications other than clinically visible jaundice
| Race(%): ND
Seidman, 1994 [#94223372] | Location: Israel | Severe hyperbilirubinemia defined as TSB levels | ND | Historical prospective cohort
| Setting: Hospital | >8mg/dl on 1^st^ day of life
| Study period: 11/1970–12/1971 + 17 years | >15mg/dl on 2^nd^ day of life
| No. of centers: 1 | >20mg.dl thereafter
| Enrolled subjects: 42(42)
| Evaluated subjects:
| Mean GA ( range): 37.9 ± 0.4 weeks
| Mean BW(g): 3060 ± 98
| Mean Apgar score at 1 & 5 min: ND
| Breastfed (%): ND
| Male(%): ND
| Race(%): ND
Telzrow, 1980 [#380225471] | Location: US | BW> 300gms | H/o of intrapartum complications | Prospective cohort
| Setting: Hospital | Apgar score > 7 at 1 min and > 8 at 5 min | Abnormalities on physical examination
| Study period: ND | GA 39–41 weeks | Post-natal complications other than hyperbilirubinemia
| No. of centers: 1 | Minimal amount of maternal analgesia | Infants of Rh mothers
| Enrolled subjects: 10(10) | No general anesthesia used
| Evaluated subjects: 10
| Mean GA ( range): 39 .8 weeks (39–41 weeks)
| Mean Apgar score at 1 minute: 8.3
| Mean Apgar score at 5 minute: 9.4
| Breastfed (%): 40
| Male(%): 60
| Race(%): ND
Valkeakari, 1981 [#81156354] | Location: Finland | Full term | Perinatal complications as asphyxia, hypoglycemia, neonatal infections, birth injuries and prematurity | Prospective cohort
| Setting: Hospital | Coomb negative
| Study period: ND | Received prophylactic phototherapy > 100 hours during 1st week of life
| No. of centers: 1
| Enrolled subjects: 41(42)
| Evaluated subjects: ND
| Mean GA ( range): 37–41 weeks
| Mean BW: 3552 ± 436 gm
| Mean Apgar score at 1 & 5 minute: 9 or 10
| Breastfed (%): ND
| Male(%): 52.5
| Race(%): ND

Evidence Table 3. Question 3: Section II - Studies evaluating treatments for neonatal hyperbilirubinemia in relation to later neurodevelopmental outcomes - Part II

Author, Year | Disease /condition type N | Treatment | Potential Confounding Factors | Outcomes | Outcome Definitions
Abrol, 1998 [#20235719] | Subjects: full term infants with TSB 12.1–15.0 mg/dL(N=15) | Phototherapy | | Brazelton neonatal behavior assessment scale 24–48 hours after starting phototherapy and 24–48 hours after cessation of phototherapy in subjects and at corresponding age in controls | Orientation visual animate
| Controls: full term infants with TSB 8–12 mg/dL (N=15) | | | | Orientation visual animate
| | | | | Orientation auditory animate
| | | | | Orientation auditory inanimate
| | | | | Orientation visual and auditory
| | | | | Alertness
| | | | | Cuddliness
| | | | | Consolability
Granati, 1984 [#84283738] | Subjects: full term infants | Phototherapy | SB levels were measured with a phocoictometer | Growth | Visual function: ophthalmological examination determining Strabismus and Visual acuity measured with “tumbling E”
| Plasma indirect bilirubin ≥ 14mg/dL (N=110) | | | Visual function | Hearing function: Behavioral audiometry which measured the response to a click stimulus upto an intensity of 30dB
| Cause of jaundice: | | | Hearing function | Physical growth: weights and heights on charts adapted from Tanner and percentiles determined
| ABO incompatibility: 22.72% | | | Neurodevelopmental status | Intellectual growth: observation of child's spontaneous behavior in a set condition
| Rh incompatibilty: 4.54% | | | | Neuromotor development: Schemes of postures and movement of Milani and Bobath
| Severe nonhemolytic jaundice: 72.72%
| Controls: nonincteric full term infants (N=110)
Ju, 1991 [#91289763] | Subjects: infants with TSB between 12–15 mg/dL were randomly assigned to phototherapy or no phototherapy group (N=29) | Phototherapy | Complete blinding was not possible since controls had no or mild clinically observable jaundice | Neonatal behavior assessment scale at entry, just after PT, 24 hours after PT and 2 weeks after treatment | 21 neurologic or reflex items on a 4 point scale to assess neurologic adequacy.
| Serum bilirubin at entry in PT group 13.1 ± 0.9 Non-PT group 12.7 ± 0.5 | | Only 5 infants in control group returned for follow up at 2 weeks age | | 28 behavioral items are divided into 6 behavioral clusters, on a 9 point scale to assess behavioral adequacy
| Controls: infants with TSB < 12 mg /dL ( N=14) TSB at entry 8.8 ± 1.3
Khanna, 1984 [#85103758] | Subjects: full term infants with bilirubin levels>15 mg/dL .(N=52) | Phototherapy and 32 of the subjects also had exchange transfusion | | Orthoptic check up | This included tests for ocular movements, Hirschberg test, Cover test, Maddox rod test, Syntophore convergence, Maddox wing test, Worth's four dot test and accommodation.
| Controls: with physiological jaundice or no jaundice(520) | | | Neurological examination | In younger and uncooperative children gross vision was tested by reception of light and visualization of toys detected by checking the relevant eye movements. Color vision was checked by asking the children to match objects of different colors.
| | | | | Refraction was done after full dilatation of pupils.
Misra, 1980 [#80203306] | Subjects: Full term infants with peak bilirubin levels between 10–30mg/dl (N=81) | Phototherapy | Large drop-out rate at different periods of follow up 81→ 31→ 12 (from 60 → 15 controls) | Physical examination | Physical growth assessed by crown- heel length, head circumference, chest circumference and weight and compared with ICMR standards
| Cause of jaundice (%) | | | Neurological examination by a short term follow up, up to 6 months (in all 81 subjects and 60 controls) and by a long term follow up in up to 36 months (12 subjects and 15 controls) | Neurological assessment by Attainment quotient (AQ) according to Illingworth
| Physiological: 30.9
| Rh incompatibility: 20.9
| ABO incompatibility: 2.47
| Septicemia: 17.28
| G-6-P-D deficiency: 1.23
| Unknown: 27.16
| Controls: full term infants with peak bilirubin levels of 8.5mg/dl (N=60)
Paludetto,1983 [#84057358] | Subjects: Full term infants, mean bilirubin level 13.3mg/100ml (N=30) | Phototherapy | Poor compliance in follow up at 1 months | Brazelton Neonatal behavioral assessment scale on 3rd day of life, 24 hours after 1st observation and at 1 month of age | Habituation
| Controls: full term infants with mean bilirubin level 9.6mg/100ml (N=30) | | Subjects: 18/30 and controls: 15/30 | | Orientation
| | | | | Motor performance
| | | | | Range of state
| | | | | Regulation of state
| | | | | Autonomic regulation
Seidman, 1994 [#94223372] | Subjects: full term infants with peak bilirubin level 20.0 ± 0.4 mg/dl (N=42) who received phototherapy | Phototherapy | 31 of the 42 subjects treated with phototherapy also needed exchange transfusion | Physical examination | IQ score was determined by translated version of verbal Otis test and a non-verbal matrices test and translated into values that correlate with Wechsler Adult Intelligence scale
| Controls: full term infants with peak bilirubin levels 18.8 ± 0.3 mg/dl (N=42) who did not receive phototherapy | Exchange transfusion | | IQ score at 17 years of age
Telzrow, 1980 [#80225471] | Subjects:Full term infants with TSB 17.07 mg%(N=10) | Phototherapy | Small sample size | Brazelton neonatal behavioral assessment scale at 3,6 and 10 days of age | Response decrement
| Controls: Full term non-icteric infants(N=10) | | No bilirubin determination made in control group | | Orientation
| | | | | Motor
| | | | | Range of state
| | | | | Regulation of state
| | | | | Autonomic stability
Valkeakari, 1981 [#81156354] | Subjects: Full term Coomb negative infants (N=41) | Phototherapy | | General pediatric examination | Developmental history and status with special interest to neurological signs and symptoms including measurement of head circumference, cranial nerve tests and tendon reflexes. Observation of muscular strength and voluntary movements. Total erythrocyte count, Hb concentration, PCV, Conjugated and total bilirubin, Alkaline phosphatase, ASAT, ALAT and serum protein
| Controls: full term infants (N=42) | | | Ophthalmologic examination | Ophthalmologic exam included vision screening, tests for strabismus, nystagmus, pupil reaction to light, convergence and examination of media fundi with an ophthalmoscope
| | | | Psychological examination | Psychological examination by Vineland Social Maturity scale
| | | | Routine EEG at 3 years of age

Evidence Table 3. Question 3: Section II - Studies evaluating treatments for neonatal hyperbilirubinemia in relation to later neurodevelopmental outcomes - Part III

Author, Year | Result | Bias / Limitations | Quality
Abrol, 1998 [#20235719] | Study group scored significantly in the orientation response to visual inanimate, visual animate and visual and auditory animate(P<0.01) | ND | A
| In follow-up assessment the same items under the cluster interactive processes continued to show significantly poor performance in study group compared to control group (P<0.05)
| No significant difference was found in other items of same cluster and all other items in other clusters between the 2 groups both in initial and follow-up assessment
Granati, 1984 [#84283738] | There was no significant difference in growth parameters, between the study and control groups | Basic testing of vision and hearing may not have detected subtle measurements | B
| Reduced visual acuity was seen in 3 of 81 IP treated infants and 4 of 89 controls and strabismus was seen in one infant in each group. | Bilirubin ranged from 14.0–24.6 in subjects( mean 19.5)
| No hearing deficit was detected in either group
| Neurological and Psychological examination revealed no difference between the 2 groups
| 2 children in IP group and 1 in controls had a single episode of febrile convulsions at age 1.5–3 years
Ju, 1991 [#91289763] | In 1st NBAS examination there was no difference in the 7 cluster scores between the 3 groups. | Incomplete blinding since control group had mild or no clinically observable jaundice | A
| In 2nd examination the groups differed in the mean orientation cluster score (p<0.01) and 4 of the 7 orientation items, including animate visual and auditory (p<0.05), inanimate visual and auditory (p<0.05), animate visual and alertness (p<0.05). Duncan post-hoc analysis showed that PT group performed poorer in the above mentioned 4 orientation items and had lower mean orientation scores than non PT and control groups (P<0.05). The non-PT and control group did not differ significantly. The remaining 6 cluster scores were comparable in the 3 groups | Large number of dropouts at 2 wk follow up in control group
| In 3rd examination significant difference existed in the animate auditory (P<0.05), animate visual (P<0.05), animate visual and auditory (P<0.05) and alertness (P<0.05) items of orientation cluster and the mean orientation scores (P<0.05). Duncan post-hoc analysis showed that PT group performed poorer in the above mentioned 4 orientation items and had lower mean orientation scores than non PT and control groups (P<0.05). The non-PT and control group did not differ significantly. | Small sample size
| At 2-week examination the scores were comparable in 3 groups
Khanna, 1984 [#85103758] | 6 children in study and 2 children in the control group had squint but convergence test, Visual acuity and the amplitude and range of accommodation was within normal limits in both groups. Tests for gross vision and color vision did not reveal any abnormalities. There was no significant difference in occurrence of hypermetropia, myopia and astigmatism in both groups. There was also no significant relationship between duration of phototherapy and incidence of refractory errors or strabismus. Dyslexia test also showed no abnormalities. There was no significant difference in the fundus examination results between the 2 groups. | Unclear how the total cohort of 112 was selected. | C
| | Wide age range at follow up( 6 months to 7 years)
| | Wide bilirubin age (15–69.2 mg/dL)
Misra, 1980 [#80203306] | Both study and control groups showed normal growth pattern comparable to ICMR standards both at short and long-term follow-up. | Large number of patients lost to follow up 81→ 12 | C
| Ten of the 81 subjects manifested some degree of mental retardation at some or the other time during follow up while all the 60 controls were normal. But on long term follow up 3 of the 31 subjects remained retarded with AQ<90 at their last examination and remaining 7 had become normal. | Unable to sort out effect of phototherapy from higher bilirubin as control group had lower bilirubin
Paludetto, 1983 [#84057358] | On 3rd day of life: for 6 of 26 items in the Brazelton scale higher values were found in the control group including items in the orientation cluster (inanimate visual (P<0.05)), animate visual (P<0.01) , visual and auditory (P<0.005) and alertness (P<0.005), motor performance (pull to sit( P<0.001)) and regulation of state (Cuddliness (P<0.001)) | Loss of subject and matched control at each observation 30→14→12 at one moth of age | B
| On 4th day of life: control group scored better in the orientation cluster (inanimate visual (P<0.01), animate visual (P<0.05), visual and auditory (P<0.01) and alertness (P<0.05) especially in visual orientation. There were no longer any difference in pull to sit and cuddliness but post-treated infants performed better than controls on defense (p<0.05) and worse on self quieting (p<0.05)
| At one month of age: Control group still scored better on 2 items of orientation cluster (inanimate visual (P<0.05) and visual and auditory (P<0.05))
Seidman, 1994 [#94223372] | The phototherapy group showed an average IQ score of 108 ± 2 at 17 years which was not significantly different from the average IQ score of 107 ± 2 in the control group. | Methodologically a prospective study but is actually a retrospective study | B
Telzrow, 1980 [#80225471] | On day 3 subjects had lower scores for three of the six orientation items including inanimate visual (p<0.01), animate visual and auditory (p<0.05) and alertness (p<0.05) and consolability (p<0.05) as compared to controls | Small sample size | B
| On day 6 subjects had lower score for 5 items of orientation cluster including inanimate visual (p<0.01), animate visual and auditory (p<0.05) and alertness (p<0.05) and animate visual (p<0.05) and 2 of the 5 motor items including muscle tonus (p<0.01) and pull to sit (p<0.05) and also consolabilty(p <0.05) | Bilirubin level not estimated in control group
| On day 10 the subjects had lower score on 2 of the orientation items including animate visual (p<0.05) and inanimate visual (p<0.05) and on self-quieting (p<0.05), response decrement to rattle (p<0.05) and were more tremulous during examination.
Valkeakari, 1981 [#81156354] | There were no differences in the physical parameters between subjects and controls. | No information about the bilirubin levels of study or control group | B
| Heights, weights, head circumference, the distribution of age at which children were able to make their 1st steps or talk their 1st sentence if at least 2 words were same.
| There were 2 children with febrile convulsions and1 with breath holding spell in phototherapy group and 1 with febrile convulsions in control group
| There was no difference in the visual acuity, distribution of strabismus, changes in fundi and media or pupil reaction between 2 groups
| Psychological examination showed social maturity, ability to control bladder and bowel, ability to articulate “R” and “S” correctly in both groups was equal
| EEG showed pathological findings in 4 and 6 of control and phototherapy groups respectively and slight or questionable changes in 11 children of each group.
| The hair and nails were normal in all children. The no. of allergic skin manifestations was not different.
| Lab dimensions did not show any difference between the 2 groups

Evidence Table 4. Question 4 - Studies evaluating the accuracy of various strategies for predicting hyperbilirubinemia - Part I

Author, Year | Demographic | Inclusion Criteria | Exclusion Criteria | Study Design
Awasthi, 1998[#20234451] | Location: India | Newborns born between 4am and 4pm on weekdays and whose SB were measured within 18–24 hrs of birth and then daily for the next 4 days | Asphyxia (Apgar score < 5 at 5 min and/or requiring intubation lasting for > 4 min) | Prospective cross-sectional study
| Setting: Hospital | | Rh incompatibility
| Study period: 9/1993 to 9/1994 | | Life threatening congenital malformations
| Mean GA (range): 28% “preterm” | | Mothers with gestational DM or history of drugs affecting the fetal liver
| Mean BW (range): 2.73±0.43 Kg
| Mean Apgar score at 1 min: ND
| Breastfed proportion: 28% within 12 hrs
| Male: ND
| Race: ND
| Enrolled subjects: 654
| Evaluated subjects: 274
| Number of centers: 1
Bhutani, 1999 [#99117600] | Location: US | Healthy term and near-term AGA newborns (BW≥2000 g for GA≥36 wks or BW≥2500 g for GA≥35 wks) | Neonatal illness | Prospective cross-sectional study
| Setting: Hospital | Completed all requirements for the follow-up and had at least 1 post-discharge SB measurements | Positive direct Coombs' test
| Study period: 1993-1997 | | TSB measured after PhotoRx
| Mean GA (range): 38.7±1.3 wk | | TSB not measured at hospital laboratory
| Mean BW (range): 3318±457 g | | Requiring PhotoRx before 60 hours to control unexplained rapidly rising TSB (\|8)
| Mean Apgar score at 1 min: ND | | Transferred to ICU (118)
| Breastfed proportion: 50% breastfed, 41% formula-fed, 10% breastfed+supplement
| Male: 50%
| Race: 43% White, 41% Black, 4% Hispanic, 4% Asian, 8% Other
| Enrolled subjects: 13,003
| Evaluated subjects: 2840
| Number of centers: 1
Carbonell, 2001 [#21130776] | Location: Spain | Not clear “Healthy term newborns” | ND | Prospective cross-sectional study
| Setting: Hospital
| Study period: 4/21/1998 to 12/31/1998 (phase I); 1/1/1999 to 12/31/1999 (phase II)
*also in Evidence Table 5.1 | Mean GA (range): 39 (37–42) wk
| Mean BW (range): 3230±491 g
| Mean Apgar score at 1 min: ND
| Breastfed proportion: 90%
| Male: ND
| Race: ND
| Enrolled subjects: 2004 (610 in phase I; 1394 in phase II)
| Evaluated subjects: 574 in phase I; 865 in phase II
| Number of centers: 1
Knudsen, 1989 [#89189829] | Location: Denmark | Not clear | ND | Prospective cohorts
| Setting: Hospital | No cases of rhesus disease
| Study period: 12/1986 to 4/1987 | No mother with DM
| Mean GA (range):
| Sample 1: 39.9±2.1 wk
| Sample 2: 40.0±1.5 wk
| Mean BW (range):
| Sample 1: 3406±631 g
| Sample 2: 3550±524 g
| Mean Apgar score at 1 min:
| Sample 1: 9.26±1.51
| Sample 2: 9.32±1.56
| Breastfed proportion: ND
| Male: ND
| Race: ND
| Enrolled subjects: 291
| Evaluated subjects: 291
| Number of centers: 1
Knudsen, 1992 [#92306741] | Location: Denmark | Not clear | “Sick newborns” | Prospective cross-sectional study
| Setting: Hospital | “Mature newborns” | Rhesus sensitization
| Study period: ND
*also in Evidence Table 5.1 | Mean GA (range): 40 (38–43) wk
| Mean BW (range): 3495 (2571–4456) g
| Mean Apgar score at 1 min: 9.8 (7.1–10.0)
| Breastfed proportion: ND
| Male: 50%
| Race: ND
| Enrolled subjects: 138
| Evaluated Subjects: 138
| Number of centers: 1
Newman, 2000 [#20529193] | Location: US | All: BW > 2000 g; GA > 36 weeks | Cases: GA < 36 weeks (2) | Case-control study
| Setting: Hospital | Cases: TSB within the first 30 days of life ≥ 25 mg/dl | Controls: hospitalization record not found
| Study period: 1995 to 1996 | Controls: randomly selected sample with TSB < 25 mg/dl | (1); BW or GA didn't meet criteria (3)
| Mean GA (range): ≥ 36 wk
| Mean BW (range): > 2000 g
| Mean Apgar score at 1 min: ND
| Breastfed proportion: ND
| Male:
| Cases: 67%
| Control: 54%
| Race:
| Cases: 44% White, 4% Black, 15% Hispanic, 32% Asian; 5% Others
| Controls: 49% White, 9% Black, 22% Hispanic, 17% Asian; 3% Others
| Enrolled subjects: 75 Cases; 427 Controls
| Evaluated subjects: 73 Cases; 423 Controls
| Number of centers: 11
Okuyama, 2001 [#AN - 1472573] | Location: Japan | Inborn infants, GA ≥ 37 weeks and BW ≥ 2500 g | Maternal smoking | Prospective cross-sectional study
| Setting: Hospital | | Diabetic mother
| Study period: 1/1/1995 to 2/29/1996 | | Hemolytic disease
| Mean GA (range): 39.3 (37.3–41.6) wk | | Polysythemia
| Mean BW (range): 3108 (2514–3788) g
| Mean Apgar score at 1 min: 8.7
| Breastfed proportion: 4% exclusive breastfed, 12% formula-fed; 84% mixed-fed
| Male: 51%
| Race: 100 Asian (assumed)
| Enrolled subjects: 51
| Evaluated subjects: 51
| Number of centers: 1
Risemberg, 1977 [#77156212] | Location: US | Cases: term newborns of heterospecific pregnancies | Six infants transferred to other neonatal program. | Prospective cohorts
| Setting: Hospital | Control: term infants of homospecific pregnancies | All of them had severe hyperbilirubinemia
| Study period: ND | None of subjects received PhotoRx or exchange transfusion
| Mean GA (range): Term
| Mean BW (range): ND
| Mean Apgar score at 1 min: ND
| Breastfed proportion: ND
| Male: ND
| Race: ND
| Erolled subjects: ND
| Evaluated subjects: 91 Cases; 30 Controls
| Number of centers: ND
Seidman, 1999 [#20110115] | Location: Israel | Healthy full-term (GA ≥ 37 wk) infants | ABO or Rh incompatibility | Prospective cross-sectional study
| Setting: Hospital | | Coomb's test positive
| Study period: 10/29/1995 to 12/31/1995 | | G6PD deficiency
| Mean GA (range): 39.8±1.3 wk
| Mean BW (range): 3250±455 g
| Mean Apgar score at 1, 5 min: 8.8±0.6, 9.5±0.7
| Breastfed proportion: 61% exclusive breastfed, 7.3% non-breastfed; 31% partial breastfed
| Male: 47%
| Race: 72% Jewish, 26% Arab, 2% Others
| Enrolled subjects: 1177
| Evaluated subjects: 1177
| Number of centers: multiple
Stevenson, 2001 [#11433051] | Location: US + International | GA ≥ 35 wks and if enrollment could be completed within the first 36 hours of life | Neonatal illness that would require admission to NICU before 24 hours | Prospective cross-sectional study
| Setting: Hospital | | Sever congenital anomalies
| Study period: 2/20-1998 to 2/22/1999 | | Infants in incubators, who had pulmonary disease requiring oxygen or ventilatory assistance, who had significant nasal obstruction, who had BW ≤ 850 g or who had respiratory rates ≤ 10 or ≥ 100 breaths pre min
| Mean GA (range): ≥ 35 wks | | Didn't participate in the testing (88)
| Mean BW (range): ND | | Lost to follow-up (272)
| Mean Apgar score at 1 min: ND | | Technical problem (131)
| Breastfed proportion: 35% | | Couldn't be tested with the Co-Stat (32)
| Male: 49% | | Didn't adhere to the study protocol (175)
| Race: 33% White, 16% Black, 4% Hispanic, 39% Asian, 8% Other | | TcB instead of TSB (131)
| Enrolled subjects: 1895
| Evaluated subjects: 1370
| Number of centers: 9

Evidence Table 4. Question 4 - Studies evaluating the accuracy of various strategies for predicting hyperbilirubinemia - Part II

Author, Year | Disease/Condition Type (N) | Strategies for Predicting Hyperbilirubinemia | Definition of True Positive | Referece Standard
Awasthi, 1998 [#20234451] | Healthy term and preterm infants (274) | Serum bilirubin at 18–24 hours | SB > 3.99 mg/dl at 18–24 hours in predicting peak SB > 15 mg/dl | Laboratory-base assay of TSB:
| | | | spectrophotometry on Toyo Bilirubin Analyzer
Bhutani, 1999 [#99117600] | Healthy term and near-term AGA newborns (2840) | Hour-specific bilirubin percentiles | Predischarge risk zone ≥ 40^th^ %tile, ≥ 75^th^ %tile, and ≥ 95^th^ %tile in | Laboratory-base assay of TSB: 2,5-DPH diazo method
| | | predicting subsequent significant
| | | hyperbilirubinemia (subsequent risk zone ≥ 95^th^ %tile)
Carbonell, 2001 [#21130776] | Healthy term infants (574 in phase I + 865 in phase II) | Cord bilirubin level | SB ≥ 17 mg/dl in the first 4 day of life | Laboratory-base assay of TSB:
| | Serum bilirubin at 24 and 48 hours | | Bilirubinometer Bil-Red by direct reading at 461 mcm
*also in Evidence Table 5.1
Knudsen, 1989 [#89189829] | Healthy term infants (291) - | Cord bilirubin level | CB > 40 μmole/l in predicting clinical jaundice (visual assessment by 7 observers) | Laboratory-base assay of TSB: standard method of Blom and Doumas
| Sample 1: Jaundiced infant (84) | | CB > 40, > 35, > 30, > 25; > 20 μmole/l in predicting PhotoRx (clinical jaundice following TSB 170
| Sample 2: Non-jaundiced infant (207) | | μmole/l for infants BW 1500–2000 g, 200
| Mean TSB in the 84 infants with clinical jaundice was 185 (110–330) μmole/l | | μmole/l for infants BW 2000–2500 g; 250
| Coomb's test positive (1) | | μmole/l for infants BW > 2500 g)
| Receiving PhotoRx (11)
| No exchange transfusion
Knudsen, 1992 [#92306741] | Healthy term infants (138) | Cord bilirubin level | CB ≥ 20, ≥ 25, ≥ 30, ≥ 35; ≥ 40 in predicting SB > 11.7 mg/dl (or 200 μmole/l) at day 3 | Laboratory-base assay of TSB: at 3rd postnatal day, by standard direct spectroscopic method
*also in Evidence Table 5.1 | Six infants received PhotoRx (6)
| Median CB was 32.3 (20–45.5) μmol/l
| Median TcB at day 1 was 8.48 (5.0–12.5)
Newman, 2000 [20529193] | Near-term or term infants (496) - | Risk index = 6 (Exclusive breastfeeding) + 6 | Risk index > 10 in predicting maximum | Laboratory-base assay of TSB: data from the KPMCP integrated laboratory information system
| Cases: infants with hyperbilirubinemia (73) | (Family history of jaundice in a newborn)+ 4 (Bruising noted) + 4 (Asian race) + 3 (Cephalhematoma noted) + 3 (Maternal age ≥ 25 y) + 1 (Male sex) -2 (Black race) + 2 (40-GA) | TSB ≥ 25 mg/dl in infants without early jaundice
| Controls: infants without hyperbilirubinemia (423)
Okuyama, 2001 [#1472573] | Full-term infants (51) | End-tidal CO (ETCOc), measured every 6 hrs during the first 72 hours of life | ETCOc ≥ 1.6 p.p.m. at 36 hours of age; ≥ 1.8 p.p.m. at 42, 48, and 60 hours of age, in predicting hyperbilirubinemia (peak SB ≥ 15 mg/dl) | Laboratory-base assay of TSB: TcB were measured every 12 hours during the first 5 days. When TcB ≥ 22, TSB was measured with UB analyzer
Risemberg, 1977 [#77156212] | Term infants (121)- | Cord bilirubin level | CB > 4 mg/dl (or 68 μmole/l) in predicting SB > 16 and ≥ 10 mg/dl at 36 hours of age | Laboratory-base assay of TSB: assumed
| Cases: newborns of heterospecific pregnancies (91) | Serum bilirubin at 12 hours and 24 hours | SB at 12 hours of age > 10 mg/dl in predicting SB > 16 and ≥ 10 mg/dl at 36 hours of age
| Controls: infants of homospecific pregnancies (30) | | SB at 24 hours of age > 15 mg/dl in predicting SB > 16 and ≥ 10 mg/dl at 36 hours of age
Seidman, 1999 [#20110115] | Healthy FT infants (1177) | Day 1 TSB | Day 1 TSB > 5 mg/dl in predicting hyperbilirubinemia (TSB > 10 mg/dl at day 2, > 14 mg/dl at day 3; and, > 17 mg/dl at day 4 or 5) | Laboratory-base assay of TSB: Unistat Bilirubinometer
| | Prediction model: day1 TSB, the change in TSB from day 1 to day 2, maternal age and education, blood type O, and full breastfeeding | All model variables in predicting hyperbilirubinemia
| | | All variables without day 1 TSB in predicting hyperbilirubinemia
| | | Prediction only by day 1 TSB (per 1 mg/dl)
Stevenson, 2001 [#11433051] | Term infants | ETCOc at 36±6 hrs | ETCOc ≥ population mean (1.48±0.49 p.p.m.) in predicting TSB ≥ 95^th^ %tile | Laboratory-base assay of TSB: each site used its own clinical laboratory and method
| | TSB at 36±6 hrs | TSB 75^th^–95^th^ %tile in predicting TSB ≥ 95^th^ %tile
| | Combine ETCOc and TSB at 36±6 hrs | Combined ETCOc and TSB (either an TSB between 75^th^ and 95^th^ %tile or an ETCOc ≥
| | | population mean or both @ 36±6 hrs) in
| | | predicting subsequent TSB ≥ 95^th^ %tile

Evidence Table 4. Question 4 - Studies evaluating the accuracy of various strategies for predicting hyperbilirubinemia - Part III

Author, Year | Result | | | | | | Biases or Limitations | Comments
Awasthi, 1998 [#20234451] | For SB > 3.99 mg/dl at 18–24 hrs in predicting peak SB > 15 mg/dl in term and preterm infants (N=274), the sensitive, specificity, PPV, and NPV was 69%, 66%, 23%, and 93%, respectively. The prevalence of hyperbilirubinemia (peak SB > 15 mg/dl) was 12.8% (35/274) | | | | | | None stated | Study was privately funded
| Stratified analysis to test the association between peak SB > 15 mg/dl and the prediction test found a significant interaction between feeding types within 12 hrs of birth. The crude OR for prediction test positive when breastfeeding within 12 hrs of birth was 29 (95%CI 3.53–640); if the infant was not breastfed, the crude OR was 2.01. | | | | | | | Internal validity: A
Bhutani, 1999 [#99117600] | Predischarge Risk Assessment: | | | | | | None stated | Study was hospital funded
| Risk Zone or Risk Index | Total # of Subject | Outcome present | Outcome absent | Likeli-hood Ratio | Proba-bility of Disease | | Internal validity: A
| High-risk (> 95^th^ %tile) | 172 | 68 | 104 | 14.08 | 2/5
| Upper-intermediate (76^th^ – 95^th^ %tile) | 356 | 46 | 310 | 3.20 | 1/8
| Lower - intermediate (40^th^ – 75^th^ %tile) | 556 | 12 | 554 | 0.48 | 1/46
| Low-risk (< 40^th^ %tile) | 1756 | 0 | 1756 | 0 | 0
| For healthy near-term or term infants (N=2840), the sensitive, specificity, PPV, and NPV (predischarge risk zone ≥ 95^th^ %tile in predicting subsequent TSB ≥ 95^th^ %tile) was 54%, 96%, 40%, and 98%, respectively.
| For healthy near-term or term infants (N=2840), the sensitive, specificity, PPV, and NPV (predischarge risk zone ≥ 75^th^ %tile in predicting subsequent TSB ≥ 95^th^ %tile) was 91%, 85%, 22%, and 99.5%, respectively.
| For healthy near-term or term infants (N=2840), the sensitive, specificity, PPV, and NPV (predischarge risk zone ≥ 40^th^ %tile in predicting subsequent TSB ≥ 95^th^ %tile) was 100%, 65%, 12%, and 100%, respectively.
| PhotoRx was usually initiated when at least 2 consecutive TSB values were in the high-risk zone. This occurred in a total 117 out of 2480 newborns (4.1%). None of newborns in the low-risk zone received PhotoRx. No newborn in the study required an exchange transfusion or developed a TSB ≥ 25 mg/dl
| None developed acute signs of bilirubin encephalopathy
| No kernicterus at 1 year of age according to the telephone interviews.
Carbonell, 2001 [#21130776] | For healthy term infants (N=585), the sensitive, specificity, PPV, and NPV (Cord bilirubin ≥ 37 μmole/l in predicting SB ≥ 17 mg/dl) was 22%, 95%, 12%, and 97%, respectively. | | | | | | None stated | No data on funding source
*also in Evidence Table 5.1 | For healthy term infants in the phase I study (N=169), the sensitive and specificity ESB ≥ 6 mg/dl @ 24 hrs in predicting SB ≥ 17 mg/dl) was 100% and 46%. The sensitive and specificity (SB ≥ 9 mg/dl @ 48 hrs in predicting SB ≥ 17 mg/dl) was 100% and 64% | | | | | | | Internal validity: A
| For healthy term infants in the phase II study (N=423, the sensitive and specificity ESB ≥ 6 mg/dl @ 24 hrs in predicting SB ≥ 17 mg/dl) was 100% and 60%. The sensitive and specificity (N=830) (SB ≥ 9 mg/dl @ 48 hrs in predicting SB ≥ 17 mg/dl) was 98% and 45%.
Knudsen, 1989 [#89189829] | For infants with clinical jaundice, judged by visual assessment (N=84), the sensitive, specificity, PPV, and NPV (Cord bilirubin > 40 μmole/l in predicting PhotoRx) was 36%, 96%, 57%, and 91%, respectively. | | | | | | Gold standard was not TSB | Study was privately funded
| Different thresholds of cord bilirubin as a test for development of clinical jaundice in all term infants (N=291) were analyzed: | | | | | | Only infants with clinical jaundice, judged by visual assessment had TSB measurement | Internal validity: B
| The sensitive, specificity, PPV, and NPV was 13%, 99%, 85%, and 72%, respectively, when CB > 40 μmole/l was used as the cutoff point. | | | | | | No outline of how clinical jaundice was diagnosed
| The sensitive, specificity, PPV, and NPV was 31%, 95%, 72%, and 75%, respectively, when CB > 35 μmole/l was used as the cutoff point.
| The sensitive, specificity, PPV, and NPV was 58%, 87%, 67%, and 82%, respectively, when CB > 30 μmole/l was used as the cutoff point.
| The sensitive, specificity, PPV, and NPV was 86%, 63%, 51%, and 91%, respectively, when CB > 25 μmole/l was used as the cutoff point.
| The sensitive, specificity, PPV, and NPV was 98%, 36%, 41%, and 97%, respectively, when CB > 20 μmole/l was used as the cutoff point.
Knudsen, 1992 [#92306741] | The prevalence of hyperbilirubinemia in all term infants (N=138) was 20%. | | | | | | Inclusion and exclusion criteria were not clear | Study was hospital funded
*also in Evidence Table 5.1 | The correlation between cord bilirubin and TSB was significant (Pearson's r was 0.5). | | | | | | | ROC curves were given
| Different thresholds of cord bilirubin as a test for later development of hyperbilirubinemia (SB > 11.7 mg/dl or 200 μmole/l) in all term infants (N=138) were analyzed: | | | | | | | Internal validity: A
| The sensitive, specificity, PPV, and NPV was 39%, 85%, 39%, and 85%, respectively, when CB > 40 μmole/l was used as the cutoff point.
| The sensitive, specificity, PPV, and NPV was 71%, 68%, 36%, and 90%, respectively, when CB > 35 μmole/l was used as the cutoff point.
| The sensitive, specificity, PPV, and NPV was 89%, 42%, 28%, and 94%, respectively, when CB > 30 μmole/l was used as the cutoff point.
| The sensitive, specificity, PPV, and NPV was 96%, 21%, 24%, and 95%, respectively, when CB > 25 μmole/l was used as the cutoff point.
| The sensitive, specificity, PPV, and NPV was 100%, 5%, 21%, and 100%, respectively, when CB > 20 μmole/l was used as the cutoff point.
Newman, 2000 [#20529193] | Predischarge Risk Assessment: | | | | | | Case-control study (retrospective) is subject to selection bias | Study was government and privately funded
| Risk Zone or Risk Index | Total # of Subject | Outcome present | Outcome absent | Likeli-hood Ratio | PPV | | Internal validity: B
| Risk Index ≤ 7 | 130 | 1 | 129 | 0.053 | 1/15653
| Risk Index 8–10 | 121 | 6 | 115 | 0.36 | 1/2327
| Risk Index 11–15 | 147 | 27 | 120 | 1.5 | 1/540
| Risk Index 16–20 | 52 | 17 | 35 | 3.3 | 1/251
| Risk Index > 20 | 11 | 8 | 3 | 18.2 | 1/47
| For near-term or term infants without early jaundice (N=461), the sensitive, specificity, PPV, and NPV (Risk Index > 10 in predicting TSB ≥ 25 mg/dl) was 88%, 61%, 25%, and 97%, respectively.
| Of 23 cases exceeded the AAP PhotoRx threshold before their TSB ≥ 25 mg/dl, only 26% received PhotoRx within 8 hrs of exceeding the threshold. The use of PhotoRx within 8 hrs of the AAP guidelines in the control group and in additional group of 30 randomly selected newborns whose maximum TSB were 20–24.9 mg/dl was only 33%. No significant difference was found between cases and controls.
Okuyama, 2001 [#1472573] | For FT Japanese infants (N=51), the sensitive, specificity, PPV, and NPV (ETCOc ≥ 1.6 p.p.m. at 36 hours of age in predicting TSB ≥ 15 mg/dl) was 71%, 61%, 23%, and 93%, respectively. The prevalence of hyperbilirubinemia was 13.7%. | | | | | | TcB was used as gold standard | No data on funding source
| For FT Japanese infants (N=51), the sensitive, specificity, PPV, and NPV (ETCOc ≥ 1.8 p.p.m. at 42 hours of age in predicting TSB ≥ 15 mg/dl) was 86%, 80%, 40%, and 97%, respectively. | | | | | | Only infants with TcB ≥ 22 had TSB measurements | ROC curve was given
| For FT Japanese infants (N=51), the sensitive, specificity, PPV, and NPV (ETCOc ≥ 1.6 p.p.m. at 48 hours of age in predicting TSB ≥ 15 mg/dl) was 86%, 73%, 29%, and 94%, respectively. | | | | | | | Internal validity: B
| For FT Japanese infants (N=51), the sensitive, specificity, PPV, and NPV (ETCOc ≥ 1.6 p.p.m. at 60 hours of age in predicting TSB ≥ 15 mg/dl) was 86%, 66%, 29%, and 97%, respectively.
Risemberg, 1977 [#77156212] | Test performance was analyzed in infants of heterospecific pregnancies (N=91): | | | | | | Only cases (N=91) were analyzed for test performance | No data on funding source
| The sensitive, specificity, PPV, and NPV (CB > 4 mg/dl or 68 μmole/l in predicting SB > 16 mg/dl at 36 hr) was 92%, 100%, 100%, and 99%, respectively. | | | | | | No description of how SB was measured | Internal validity: B
| The sensitive, specificity, PPV, and NPV (CB > 4 mg/dl or 68 μmole/l in predicting SB ≥ 10 mg/dl) was 43%, 100%, 100%, and 80%, respectively. | | | | | | Subjects' details were missing
| The sensitive, specificity, PPV, and NPV (SB > 10 mg/dl at 12 hr in predicting SB > 16 mg/dl at 36 hr) was 100%, 100%, 100%, and 100%, respectively.
| The sensitive, specificity, PPV, and NPV (SB > 10 mg/dl at 12 hr in predicting SB > 10 mg/dl at 36 hr) was 46%, 100%, 100%, and 81%, respectively.
| The sensitive, specificity, PPV, and NPV (SB > 15 mg/dl at 24 hr in predicting SB > 16 mg/dl at 36 hr) was 100%, 100%, 100%, and 100%, respectively.
| The sensitive, specificity, PPV, and NPV (SB > 15 mg/dl at 24 hr in predicting SB > 10 mg/dl at 36 hr) was 46%, 100%, 100%, and 81%, respectively.
| Of the 91 infants of heterospecific pregnancies, 13 (14%) developed severe hyperbilirubinemia (SB>16 mg/dl), and 15 (17%) developed moderate hyperbilirubinemia (SB 10–16 mg/dl) at 36 hours of life. All of infants with severe hyperbilirubinemia required exchange transfusion.
| 31 (34%) of cases had Coomb's test positive
| All of the 30 controls had Coomb's test negative, and cord bilirubin < 2 mg/dl (34.2 μmole/l). None of them developed significant jaundice.
Seidman, 1999 [#20110115] | The prevalence of hyperbilirubinemia in all 1177 healthy FT infants was 5% (60/1177). | | | | | | None noted | No data on funding source
| The sensitivity of day 1 TSB > 5 mg/dl in predicting hyperbilirubinemia (defined as TSB > 10 mg/dl at day 2, > 14 mg/dl at day 3; and, > 17 mg/dl at day 4 or 5) was 82% (49/60). | | | | | | | Internal validity: A
| Prediction model = day 1 TSB per 1 mg/dl (OR=3.1, 95%CI 2.4–4.1), change in TSB from day 1 to day 2 per 1 mg/dl (OR=2.4, 95%CI 1.9–3.0), maternal age per year (OR=1.1, 95%CI 1.0–1.2), maternal education per year (OR=0.8, 95%CI 0.7–0.9), maternal blood type O (OR=2.9, 95%CI 1.5–5.8), full breastfeeding (OR=0.4, 95%CI 0.2–0.9); day 1 TSB > 5 mg/dl (OR=36.5, 95%CI 15.9–83.6)
| For all model variables in predicting hyperbilirubinemia in healthy FT infants (N=1177), the sensitive, specificity, PPV, and NPV was 82%, 83%, 20%, and 99%, respectively.
| For all model variables without day 1 TSB in predicting hyperbilirubinemia in healthy FT infants (N=1177), the sensitive, specificity, PPV, and NPV was 58%, 90%, 24%, and 98%, respectively.
| For prediction of hyperbilirubinemia only by day 1 TSB per 1 mg/dl in healthy FT infants (N=1177), the sensitive, specificity, PPV, and NPV was 63%, 94%, 37%, and 97%, respectively.
Stevenson, 2001 [#11433051] | For tem infants, GA≥35 wks (N=1370), the sensitive, specificity, PPV, and NPV (ETCOc > population mean, 1.48±0.49 p.p.m. @36 hrs, in predicting TSB ≥ 95^th^ %tile) was 77%, 51%, 13%, and 96%, respectively | | | | | | Infants with TSB ≥ 95^th^ %tile @ 30±6 hrs were excluded from the TSB and combined ROC analyses because they had been found to be hyperbilirubi-nemic by the predicting measurements. | Study was privately funded
| Four (0.65%) of 620infnats had an STB < 4-th %tile @ 30±6 hrs but subsequently had an TSB ≥ 95^th^ %tile. The NPV was 99%. | | | | | | | ROC curves were reported
| TSB between 75^th^ and 95^th^ %tile @ 36±6 hrs in predicting subsequent TSB ≥ 95^th^ %tile had 17% PPV and 98% NPV. | | | | | | | Internal validity: A
| The sensitivity, specificity, PPV, and NPV for the combined ETCOc and TSB method (either an TSB between 75^th^ and 95^th^ %tile or an ETCOc ≥ population mean or both @ 36±6 hrs) was 90%, 65%, 6.4%, and 99%, respectively.
| Breastfed infants had significantly higher mean TSB levels @ 96 hrs, compared with those who were formula-fed exclusively.
| Mean ETCOc were significantly higher in hyperbilirubinemia (N=120) infants then in non-hyperbilirubinemia infants (N=1250)

Evidence Table 5.1. Question 5 - Studies evaluating the accuracy of AirShields Minolta bilirubinometer - Part I

Author, Year | Demographics | Inclusion Criteria | Exclusion Criteria | Study Design
Bhat, 1987 [#88085341] | Location: India | Not clear | ND | Prospective cross-sectional study
| Setting: Dept. of Pediatrics
| Study period: 8/85 to 11/85
| Mean GA (range): 63 babies ≥ 37 wk; 37 babies < 37 wk
| Age at measurement: 1 to 4 d
| Mean BW (range): 37 babies > 2500 g; 63 babies ≤ 2500 g
| Mean Apgar score at 1 min: ND
| Breastfed proportion: ND
| Male: ND
| Race: ND
| Enrolled subjects: 100
| Evaluated subjects: 100
| Evaluated TcB & SB pairs: ND
| Number of centers: 1
Bhutta, 1991 [#92015688] | Location: Pakistan | Consecutive jaundiced newborns | ND | Prospective cross-sectional study
| Setting: Hospital
| Study period: ND
| Mean GA (range):
| Term: 39.1 wk
| Preterm: 35.3 wk
| Age at recruitment: ND
| Mean BW (range):
| Term: 2985 g
| Preterm: 2298 g
| Mean Apgar score at 1 min: ND
| Breastfed proportion: 100%
| Male: ND
| Race: ND
| Enrolled subjects: 63
| Evaluated subjects: 63
| Evaluated TcB & SB pairs: 100
| Number of centers: 1
Bilgen, 1998 [#99123665] | Location: Turkey | Healthy term newborns with jaundice. | ND | Prospective cross-sectional study
| Setting: Hospital | None had received PhotoRx
| Study period: 1/97 to 3/97
| Mean GA (range): 39.6 (38–42) wk
| Age at recruitment: 1 to 5 d
| Mean BW (range): 3380(2560–4700) g
| Mean Apgar score at 1 min: ND
| Breastfed proportion: ND
| Male: 58%
| Race: 100% Turkish
| Enrolled subjects: 96
| Evaluated subjects: 96
| Evaluated measurement pairs:
| Minolta AirShields: 96
| Minolta AirShields: 96
| Ingram icterometer: 96
| Number of centers: 1
Boo, 1984 [#85085660] | Location: Malaysia | Term jaundiced infants had not yet been subjected to PhotoRx or exchange transfusion | ND | Prospective cross-sectional study
| Setting: Hospital
| Study period: ND
| Mean GA (range):
| Malay: 40.0±0.9 wk
| Chinese: 40.1±1.0 wk
| Indian: 40.1±1.2 wk
| Mean age at measurement:
| Malay: 2.9±1.0 d
| Chinese: 3.5±1.3 d
| Indian: 3.2±2.7 d
| Mean BW (range):
| Malay: 3.0±0.5 Kg
| Chinese: 3.2±0.4 Kg
| Indian: 2.9±0.6 Kg
| Mean Apgar score at 1 min: ND
| Breastfed proportion: ND
| Male:
| Malay: 36%
| Chinese: 35%
| Indian: 29%
| Race: 100% Asian
| Enrolled subjects: 105
| Evaluated subjects: 105
| Evaluated TcB & SB pairs: ND
| Number of centers: 1
Bourchier, 1987 [#88247126] | Location: New Zealand | Postnatal wards | Infants receiving concurrent PhotoRx | Prospective cross-sectional study
| Setting: Hospital | Full-term, jaundiced infants who were > 24 hours old
| Study period: 8/1983 to 6/1985 | SB estimation to be made if the TcB ≥ 17 or if requested by medical staff
| Mean GA (range): ND | Complete data on race (as recorded in the maternal case records)
| Mean age at measurement: ND
| Mean BW (range): ND
| Mean Apgar score at 1 min: ND
| Breastfed proportion: ND
| Male: ND
| Race: 57% Caucasian; 43% Maori
| Enrolled subjects: 729
| Evaluated subjects: 729
| Evaluated TcB & SB pairs: 2026
| Number of centers: ND
Carbonell, 2001 [#21130776] | Location: Spain | Not clear | ND | Prospective cross-sectional study
*Also in Evidence Table 4 | Setting: Hospital | “Healthy term newborns”
| Study period: 4/21/1998 to 12/31/1998 (phase I); 1/1/1999 to 12/31/1999 (phase II)
| Mean GA (range): 39 (37–42) wk
| Mean BW (range): 3230±491 g
| Mean Apgar score at 1 min: ND
| Breastfed proportion: 90%
| Male: ND
| Race: ND
| Enrolled subjects: 2004 (610 in phase I; 1394 in phase II)
| Evaluated subjects: 574 in phase I; 865 in phase II
| Number of centers: 1
Christo, 1988 89253855 | Location: South India | Not clear | Post-exchange infants | Prospective cross-sectional study
| Setting: Hospital
| Study period: 9/1986 to 11/1986
| Mean GA (range): ND
| Mean age at measurement: ND
| Mean BW (range): ND
| Mean Apgar score at 1 min: ND
| Breastfed proportion: ND
| Male: ND
| Race: ND
| Enrolled subjects: 138
| Evaluated subjects: 138
| Evaluated TcB & SB pairs: ND
| Number of centers: 1
Dai, 1996 [#97093944] | Location: Canada | Not clear | ND | Prospective (cross-sectional) andretrospective (chartreview) of 1600 bilirubin tests
| Setting: Hospital | Healthy term infants on which serum bilirubin had been ordered
| Study period: 8/1995 to 9/1995
| Mean GA (range): Term
| Mean age at measurement: ND
| Mean BW (range): 3392 g
| Mean Apgar score at 1 min: ND
| Breastfed proportion: ND
| Male: ND
| Race: mixed races
| Enrolled subjects: 45
| Evaluated subjects: 45
| Evaluated TcB & SB pairs: 40 each site
| Number of centers: 1
Fok, 1986 [#86268743] | Location: Hong Kong | Full-term Chinese infants not receiving PhotoRx | ND | Prospective cross-sectional study
| Setting: Hospital
| Study period: ND
| Mean GA (range): Full Term
| Mean age at measurement: ND
| Mean BW (range): ND
| Mean Apgar score at 1 min: ND
| Breastfed proportion: ND
| Male: 59%
| Race: 100% Asian
| Enrolled subjects: 202
| Evaluated subjects: 202
| Evaluated TcB & SB pairs: 605 from forehead; 291 from mid-sternum
| Number of centers: 1
Goldman, 1982 [#82241425] | Location: US | Infants who had SB determinations ordered by their primary physician | PhotoRx | Not clear
| Setting: Hospital | For current review, only infants whose GA > 38 weeks were included
| Study period: 6/81 to 7/81
| Mean GA (range): > 38 wk
| Mean age at measurement: ND
| Mean BW (range): ND
| Mean Apgar score at 1 min: ND
| Breastfed proportion: ND
| Male: ND
| Race: 45% White; 55% Black
| Enrolled subjects: 125
| Evaluated subjects: 84
| Evaluated TcB & SB pairs: 95 in Whites; 105 in Blacks
| Number of centers: 1
Hanneman, 1982 82105249 | Location: US | Infants for whom serum bilirubin was determined | For current review, preterm infants (GA < 34 wks) were excluded (N=32) | Prospective cross-sectional study
| Setting: ND
| Study period: ND
| Mean GA (range): ND
| Mean age at measurement: ND
| Mean BW (range): ND
| Mean Apgar score at 1 min: ND
| Breastfed proportion: ND
| Male: ND
| Race: 67% White; 33% Black
| Enrolled subjects: 161
| Evaluated subjects: 129
| Evaluated TcB & SB pairs: 221
| Number of centers: ND
Harisk, 1998 98373176 | Location: India | Clinically appreciable jaundice | Exchange transfusion under 24 hours of age | Prospective cross-sectional study
| Setting: Hospital | | For current review, preterm AGA group (N=12) was excluded
| Study period: 3–92 to 11/92
| Mean GA (range):
| Term: 39.5±0.9 wk
| SGA: 36.7±2.9 wk
| PhotoRx: 38.4±2.3 wk
| Mean age at measurement: 2 to 20 d (only 15 babies ≥ 10 d)
| Mean BW (range):
| Term: 2935±208 g
| SGA: 2280±268 g
| PhotoRx: 2639±625 g
| Mean Apgar score at 1 min: ND
| Breastfed proportion: ND
| Male: ND
| Race: ND
| Enrolled subjects: 145
| Evaluated subjects: 133
| Evaluated TcB & SB pairs: ND
| Number of centers: 1
Hegyi, 1981 [#81144434] | Location: US | Not clear | For current review, Group II (8 black infants) and Group III (9 white infants w/ PhotoRx) were excluded because of sample size < 10. | Prospective cross-sectional study
| Setting: Hospital
| Study period: ND
| Mean GA (range): Term
| Mean age at measurement: ND
| Mean BW (range): ND
| Mean Apgar score at 1 min: ND
| Breastfed proportion: ND
| Male: ND
| Race: 100% White
| Enrolled subjects: 60
| Evaluated subjects: 43
| Evaluated TcB & SB pairs: 102
| Number of centers: 1
Karrar, 1989 [#89271698] | Location: Saudi Arabia | Healthy, full-term infants | Preterm infants, those on phototherapy or requiring exchange transfusion as well as ill newborns were excluded | Prospective cross-sectional study
| Setting: Hospital
| Study period: ND
| Mean GA (range): ND
| Mean age at measurement: 4 to 10 d
| Mean BW (range): ND
| Mean Apgar score at 1 min: ND
| Breastfed proportion: ND
| Male: ND
| Race: ND
| Enrolled subjects: 155
| Evaluated subjects: 155
| Evaluated TcB & SB pairs: 155
| Number of centers: 1
Kenny, 1984 [#89271698} | Location: US | Not clear | Communicable disease | Prospective cross sectional study
| Setting: Hospital | | PhotoRx
| Study period: ND | | Exchange transfusion
| Mean GA (range): ND
| Mean age at measurement: ND
| Mean BW (range): 2000–4000 g
| Mean Apgar score at 1 min: ND
| Breastfed proportion: ND
| Male: ND
| Race: ND
| Enrolled subjects: 53
| Evaluated subjects: 53
| Evaluated TcB & SB pairs: 139
| Number of centers: 1
Kivlaha, 1984 [#84296964] | Location: US | 32 white infants in intensive care nursery | Infants receiving PhotoRx | Prospective cross-sectional study
| Setting: Hospital
| Study period: ND
| Mean GA (range): 34 wk
| Mean age at measurement: ND
| Mean BW (range): ND
| Mean Apgar score at 1 min: ND
| Breastfed proportion: ND
| Male: ND
| Race: 100% White
| Enrolled subjects: 32
| Evaluated subjects: 32
| Evaluated TcB & SB pairs: 60
| Number of centers: 1
Knudsen, 1989 [#89189829]Knudsen, 1990 [#90242782] | Location: Denmark | Not clear | ND | Prospective cross-sectional study
| Setting: Hospital | Healthy infants, GA > 36 weeks
| Study period: ND | None had hemolytic anemia or had mothers who suffered from diabetes.
| Mean GA (range): 40 (37–42) wk | None had received PhotoRx or exchange transfusion
| Mean age at measurement: ≤ 5 d
| Mean BW (range): 3470 (2440–4400) g
| Mean Apgar score at 1 min: ND
| Breastfed proportion: ND
| Male: ND
| Race: ND
| Enrolled subjects: 76/136
| Evaluated subjects: 76/136
| Evaluated TcB & SB pairs: ND
| Number of centers: 1
Knudsen, 1990 [#91196560] | Location: Denmark | Unselected jaundiced infants. | Hemolytic anemia | Prospective cross-sectional study
| Setting: Hospital | All are icteric, but otherwise healthy newborns, GA>36 and BW > 2500 g
| Study period: ND | No PhotoRx when the first TcB measurement was taken
| Mean GA (range): 40.1 (37–42.4) wk
| Mean age at measurement: 67.9 (25.9–103) hrs
| Mean BW (range): 3475 (2550–4337) g
| Mean Apgar score at 1 min: ND
| Breastfed proportion: ND
| Male: 56%
| Race: ND
| Enrolled subjects: 207
| Evaluated subjects: 207 Evaluated TcB & SB pairs: 207 (+99 repeating sample)
| Number of centers: 1
Knudsen, 1992 [#92306741} | Location: Denmark | Not clear | “Sick newborns” | Prospective cross-sectional study
*also in Evidence Table 4 | Setting: Hospital | “Mature newborns” | Rhesus sensitization
| Study period: ND
| Mean GA (range): 40 (38–43) wk
| Mean BW (range): 3495 (2571–4456) g
| Mean Apgar score at 1 min: 9.8 (7.1–10.0)
| Breastfed proportion: ND
| Male: 50%
| Race: ND
| Enrolled subjects: 138
| Evaluated subjects: 138
| Number of centers: 1
Knudsen, 1993 [#93333142] | Location: Denmark | Study group: healthy newborns, slightly icteric at the time of discharge on 3 or 4 days after birth, and who were seen a few days later in the outpatient clinic for a check-up | GA < 36 weeks | Prospective cohorts
| Setting: Hospital | Control group: healthy newborns who were jaundiced 1–4 days after birth | Suspicion of infection or hemolytic disease
| Study period: ND | | Low Apgar score
| Mean GA (range): | | Non-Danish descent
| Study grp: 271 (253–294) d | | Mothers with endocrinological disease
| Control grp: 281 (254–292) d
| Mean age at measurement:
| Study grp: 6.6 (4.7–12.3) d
| Control grp: 12.9 (1.1–4.1) d
| Mean BW (range):
| Study grp: 3275 (2640–4150) g
| Control grp: 3420 (2640–4400) g
| Mean Apgar score at 1 min:
| Study grp: 9.7 (7.9–10)
| Control grp: 9.8 (7.2–10)
| Breastfed proportion: 100%
| Male: ND
| Race: 100% Danish
| Enrolled subjects: 125
| Evaluated subjects: 125
| Evaluated TcB & SB pairs: ND
| Number of centers: 1
Knudsen, 1995 [#93333142] | Location: Denmark | Mature healthy newborns of Danish descent without isoimmunization or suspected hemolytic disease | ND | Prospective cross sectional study
| Setting: Hospital
| Study period: ND
| Mean GA (range): Term
| Mean age at measurement: 9–33 hrs after birth
| Mean BW (range): 3500 (2550–4370) g
| Mean Apgar score at 1 min: > 6
| Breastfed proportion: 100%
| Male: 49%
| Race: 100% Danish
| Enrolled subjects: 110
| Evaluated subjects: 110
| Evaluated TcB & SB pairs: ND
| Number of centers: 1
Kumar, 1992 [#93084314] | Location: Aligarh | Randomly selected 125 full term infants from 1740 live born babies | ND | Prospective cross-sectional study
| Setting: Hospital
| Study period: 3/87 to 3/88
| Mean GA (range): Term
| Mean age at measurement: ND
| Mean BW (range): ND
| Mean Apgar score at 1 min: ND
| Breastfed proportion: ND
| Male: 50%
| Race: ND
| Enrolled subjects: 125
| Evaluated subjects: 125
| Evaluated TcB & SB pairs: 822
| Number of centers: 1
Laeeq, 1993 [#93267865] | Location: Lahore, Pakistan | Full term infants had not yet received PhotoRx or exchange transfusion | ND | Prospective cross-sectional study
| Setting: Hospital
| Study period: 11/1991 to 3/1992
| Mean GA (range): Term
| Mean age at measurement: 4.39±2 d
| Mean BW (range): 3050±430 g
| Mean Apgar score at 1 min: ND
| Breastfed proportion: ND
| Male: 58%
| Race: ND
| Enrolled subjects: 105
| Evaluated subjects: 105
| Evaluated TcB & SB pairs: ND
| Number of centers: 1
Lin, 1993 [#93383693] | Location: Taiwan | Full term newborns (GA 37–42) | Newborns who had hyperbilirubinemia related to hemolysis, polycythemia, sepsis, hypoxia | Prospective cross-sectional study
| Setting: Hospital | Apgar score > 6 | TcB indices in infants who required PhotoRx were excluded from study once PhotoRx was employed
| Study period: 4/1989 to 8/1989
| Mean GA (range): 37–42 wk
| Mean age at measurement: ND
| Mean BW (range):
| Mixed-fed: 3194±433 g
| Formula-fed: 3284±404 g
| Mean Apgar score at 1, 5 min:
| Mixed-fed: 8.4±0.8, 9.4±0.6
| Formula-fed: 8.5±0.7, 9.4±0.6
| Breastfed proportion: Mixed (breast+formula) 30%
| Male: 57%
| Race: 100% Asian
| Enrolled subjects: 305
| Evaluated subjects: 305
| Evaluated TcB & SB pairs: 227 at forehead; 217 at mid-sternum
| Number of centers: 1
Linder, 1994 [#94325008] | Location: Israel | Full-term inborn, apparently healthy infants with GA > 37 weeks, BW 2500–4500 g, and 5-minite Apgar score of 8 or more | Maternal blood type O or Rh negative, or if any other proven hemolytic antigen was present | Prospective cross-sectional study
| Setting: Hospital | Jaundiced at 3 to 5 days | Infants treated with PhotoRx or exchange transfusion
| Study period: ND | | Diagnosis of acute illness such as sepsis or respiratory distress
| Mean GA (range): > 37 wk | | Infants born on weekends or between the hours of midnight and 6 am were not included
| Mean age at measurement: ND
| Mean BW (range): 2500–4500 g
| Mean Apgar score at 5 min: > 8
| Breastfed proportion: ND
| Male: ND
| Race: various middle eastern
| Enrolled subjects: 389
| Evaluated subjects: 123
| Evaluated TcB & SB pairs: 161
| Number of centers: 1
Maisels, 1982 [#82273864] | Location: US | FT white infants | ND | Prospective cross-sectional study
| Setting: Hospital | None received PhotoRx
| Study period: ND
| Mean GA (range): Full Term
| Mean age at measurement: 3 d
| Mean BW (range): ND
| Mean Apgar score at 1 min: ND
| Breastfed proportion: ND
| Male: ND
| Race: 100% White
| Enrolled subjects: 157
| Evaluated subjects: 157
| Evaluated TcB & SB pairs: 157 at forehead; 135 at mid-sternum
| Number of centers: 1
Maisels, 1997 [#97247177] | Location: US | Newborn infants born at 36 weeks' gestation or later | ND | Prospective cross-sectional study
| Setting: Hospital
| Study period: ND
| Mean GA (range): ≥ 36 wks
| Mean age at measurement: ND
| Mean BW (range): ND
| Mean Apgar score at 1 min: ND
| Breastfed proportion: ND
| Male: ND
| Race: ND
| Enrolled subjects: 356
| Evaluated subjects: 356
| Evaluated TcB & SB pairs: ND
| Number of centers: 1
Schumacher, 1985 [#85241873] | Location: US | White, term infants with visible jaundice, GA > 36 weeks, aged 1–5 days | ND | Prospective cross-sectional study
| Setting: Hospital | None received PhotoRx
| Study period: 6/83 to 11/83
| Mean GA (range): > 36 wk
| Mean age at measurement: 1–5 d
| Mean BW (range): ND
| Mean Apgar score at 1 min: ND
| Breastfed proportion: ND
| Male: ND
| Race: 100% White
| Enrolled subjects: 106
| Evaluated subjects: 106
| Evaluated measurement pairs:
| Minolta AirShields: 106
| Ingram icterometer: 106
| Number of centers: 1
Serrao, 1989 [#85241873] | Location: US | Term white infants who had TSB determinations ordered by their primary physician | ND | Prospective cross-sectional study +Prospective cohort(Part II study)
| Setting: Hospital | None received PhotoRx or exchange transfusion
| Study period: ND
| Mean GA (range): 39.9±1.3 wk
| Mean age at measurement: ND
| Mean BW (range): 3401.5±511 g
| Mean Apgar score at 1 min: ND
| Breastfed proportion: ND
| Male: ND
| Race: 100% White
| Enrolled subjects: 33 (+203 for Part II study)
| Evaluated subjects: 33 (+203 for Part II study)
| Evaluated TcB & SB pairs: ND
| Number of centers: ND
Sharma, 1988 89122266 | Location: Rajasthan, India | Not clear | ND | Prospective cross-sectional study
| Setting: Hospital
| Study period: ND
| Mean GA (range): 60% Term (≥37 wk)
| Age at recruitment: birth to 10 d
| Mean BW (range): 900–4300 g (45% <2500 g)
| Mean Apgar score at 1 min: ND
| Breastfed proportion: ND
| Male: ND
| Race: ND
| Enrolled subjects: 200
| Evaluated subjects: 120 Term; 80 Preterm
| Evaluated TcB & SB pairs: ND
| Number of centers: 1
Sheridan-Pereira, 1982 [#83021365] | Location: Ireland | Not clear | ND | Prospective cross-sectional study
| Setting: ND | For current review, 60 term infants in the study (BW> 2700 g) were included
| Study period: ND
| Mean GA (range): ND
| Mean age at measurement: ND
| Mean BW (range): > 2700 g
| Mean Apgar score at 1 min: ND
| Breastfed proportion: ND
| Male: ND
| Race: 100% Whites
| Enrolled subjects: 70
| Evaluated subjects: 60
| Evaluated TcB & SB pairs: 81
| Number of centers: 1
Smith, 1985 [#85112373] | Location: US | FT, healthy neonates. | ND | Prospective cross-sectional study
| Setting: Hospital | None receiving PhotoRx
| Study period: ND
| Mean GA (range): Full Term
| Mean age at measurement: 24±6 hrs
| Mean BW (range): ND
| Mean Apgar score at 1 min: ND
| Breastfed proportion: ND
| Male: ND
| Race: “Most were white and Mexican-American extractions”
| Enrolled subjects: 85
| Evaluated subjects: 85
| Evaluated TcB & SB pairs: 104
| Number of centers: 1
Suckling, 1995 95327901 | Location: Scotland | Well Caucasian infants not receiving PhotoRx | ND | Prospective cross-sectional study
| Setting: Hospital | Only infants with high TcB (≥18 for term AGA, or (≥16 for preterm or SGA) had TSB measurement taken
| Study period: 8/1/91 to 8/31/91
| Mean GA (range): 37 babies > 37 wks; 39 babies 34–37 wks
| Mean age at measurement: ND
| Mean BW (range): ND
| Mean Apgar score at 1 min: ND
| Breastfed proportion: ND
| Male: ND
| Race: 100% Whites
| Enrolled subjects: 122
| Evaluated subjects: 55
| Evaluated TcB & SB pairs: 76
| Number of centers: ND
Taha, 1984 [#85070990] | Location: Saudi Arabia | Term, healthy infants who needed to monitoring of serum bilirubin because of jaundice | Infants requiring exchange transfusion and those on PhotoRx | Prospective cross-sectional study
| Setting: Hospital
| Study period: ND
| Mean GA (range): Term
| Mean age at measurement: 3 to 12 d
| Mean BW (range): ND
| Mean Apgar score at 1 min: ND
| Breastfed proportion: ND
| Male: ND
| Race: ND
| Enrolled subjects: 68
| Evaluated subjects: 68
| Evaluated TcB & SB pairs: 120
| Number of centers: 1
Tan, 1985 [#86101839] Tan, 1982 [#83044572} | Location: Singapore | Not clear | ND | Prospective cross-sectional study
| Setting: Hospital | For current review, FT Chinese and Malay infants in the first 2 weeks of life were evaluated
| Study period: ND
| Mean GA (range):
| Malay: 39 (37–42) wk
| Chinese: 38.7 (37–41) wk
| Mean age at measurement:
| Malay: 4.1±2.0 (2–10) d
| Chinese: 4.6±2.9 (1–12) d
| Mean BW (range):
| Malay: 3067 (2500–3910) g
| Chinese: 3094 (2500–3900) g
| Mean Apgar score at 1 min: ND
| Breastfed proportion: ND
| Male: ND
| Race: 100% Asian
| Enrolled subjects: 152
| Evaluated subjects: 125
| Evaluated TcB & SB pairs: 205 at forehead, 172 at sternum; 150 at upper back
| Number of centers: ND
Tan, 1996 [#97017283] | Location: Singapore | Not clear | No exposure to PhotoRx or sunlight | Prospective cross-sectional study
| Setting: Hospital | “Healthy full term infants presenting with neonatal jaundice”
| Study period: ND
| Mean GA (range):
| Chinese: 38.6±1.5 wk
| Malay: 38.2±1.4 wk
| Indian: 38.2±1.4 wk
| Mean age at measurement: 2–8 d
| Mean BW (range):
| Chinese: 3229±478 g
| Malay: 3218±508 g
| Indian: 3089±517 g
| Mean Apgar score at 1 min: ND
| Breastfed proportion: ND
| Male:
| Chinese: 55%
| Malay: 53%
| Indian: 51%
| Race: 100% Asian
| Enrolled subjects: 542
| Evaluated subjects: 542
| Evaluated TcB & SB pairs: 2008
| Number of centers: ND
Tsai, 1988 [#90177720] | Location: Taiwan | Chinese newborns who had jaundice or SB measurement | ND | Prospective cross-sectional study
| Setting: Hospital | GA > 37 weeks
| Study period: 1/1988 to 3-1988 | Age < 7 days
| Mean GA (range): > 37 wks | No PhotoRx before study
| Mean age at measurement: ND
| Mean BW (range): ND
| Mean Apgar score at 1 min: ND
| Breastfed proportion: ND
| Male: ND
| Race: 100% Asian
| Enrolled subjects: 98
| Evaluated subjects: 98
| Evaluated TcB & SB pairs: 178 each site
| Number of centers: 1
Yamauchi, 1989 [#89348834] | Location: Japan | Breastfed by 10–12 hrs | Infants admitted to NICU | Prospective cross-sectional study
| Setting: Hospital | BW 2500–3800 g
| Study period: ND | GA 37–42 weeks
| Mean GA (range): 279.4±8.4 d | Apgar score at 1 min > 7
| Mean age at measurement: 5.2±2.5 (2–7) d | No Rh, ABO incompatibility
| Mean BW (range): 3183.7±340.8 g | No dehydration, infection, closed hemorrhage, and respiratory distress
| Mean Apgar score at 1 min: 8.6±0.6 | No medication except oral Vitamin K
| Breastfed proportion: 100% | Uncomplicated pregnancy and delivery
| Male: 53% | No medication that causes jaundice (oxytocin, and diazepam)
| Race: 100% Asian | No PhotoRx or exchange transfusion
| Enrolled subjects: 114 | Vaginal delivery with early cord clamping
| Evaluated subjects: 114
| Evaluated TcB & SB pairs: 192
| Number of centers: 1
Yamauchi, 1990 90273849 | Location: Japan | Breastfed by 10–12 hrs | ND | Prospective cross-sectional study
| Setting: Hospital | BW > 2500 g
| Study period: ND | GA > 36 weeks
| Mean GA (range): 280.2±10.4 d | Apgar score at 1 min > 6
| Mean age at measurement: ND | No PhotoRx or exchange transfusion
| Mean BW (range): 3272.2±429.2 g | No NICU
| Mean Apgar score at 1 min: 8.4±0.8
| Breastfed proportion: 100%
| Male: 45%
| Race: 100% Asian
| Enrolled subjects: 78
| Evaluated subjects: 78
| Evaluated TcB & SB pairs: ND
| Number of centers: 1
Yamauchi, 1991 [#92188736] | Location: Japan | Breastfed by 10–12 hrs | ND | Prospective cohorts
| Setting: Hospital | BW > 2500 g
| Study period: ND | GA > 37 weeks
| Mean GA (range): | Apgar score at 1 min > 7
| Group I: 283±9 d | Vaginally delivery
| Group II: 281±10.1 d | No sick infants; no medication except oral Vitamin K
| Mean age at measurement: ND | No PhotoRx or exchange transfusion
| Mean BW (range):
| Group I: 3208.9±293.6 g
| Group II: 3173.3±406.1 g
| Mean Apgar score at 1 min:
| Group I: 8.5±0.7
| Group II: 8.5±0.7
| Breastfed proportion: 100%
| Male:
| Group I: 37%
| Group II: 58%
| Race: 100% Asian
| Enrolled subjects: 107
| Evaluated subjects: Group I: 59; Group II: 48
| Evaluated TcB & SB pairs: 186 at forehead; 186 at sternum
| Number of centers: 1
Yamauchi, 1991 [#92188737]Yamauchi, 1988 [#89086035] | Location: Japan | Breastfed by 10–12 hrs | ND | Prospective cross-sectional study
| Setting: Hospital | BW > 2500 g
| Study period: 9/1/81 to 3/1/82 | GA > 37 weeks
| Mean GA (range): > 37 wk | Apgar score at 1 min > 7
| Mean age at measurement: 0–12 d | Free from illness or medication
| Mean BW (range): > 2500 g | No PhotoRx or exchange transfusion
| Mean Apgar score at 1 min: ND | No NICU
| Breastfed proportion: 100%
| Male: ND
| Race: 100% Asian
| Enrolled subjects: 336
| Evaluated subjects: 336
| Evaluated TcB & SB pairs: 576
| Number of centers: 1

Evidence Table 5.1. Question 5 - Studies evaluating the accuracy of AirShields Minolta bilirubinometer - Part II

Author, Year | Population (N) Subjects' Clinical Details | TcB Measurement Protocol | Definition of True Positive | Reference Standard
Bhat, 1987 [#88085341] | Term + Preterm infants (100) | Measurement tools: Minolta Tc bilirubinometer | N/A | Laboratory-based assay of TSB: Boehringer Mannheim using the diazo reagent method
| Mean TSB (range): 10.89 (0.91–21.2) mg/dl | Procedures: at forehead, 3 consecutive readings from each baby
| Mean TcB reading (range): 20.89 (9–33)
Bhutta, 1991 [#92015688] | Jaundiced infants (63) - | Measurement tools: Air Shield- Minolta Tc bilirubinometer | TcB > 17 in predicting SB > 12.5 mg/dl | Laboratory-based assay of TSB: autoanalyzer (Astra, Beckman Instruments Inc.) using the modified Jendraasik-Grof method
| Term (53) | Procedures: at forehead, 3 consecutive readings from each baby. Blood was obtained simultaneously.
| Preterm (10)
| Mean TSB (range): 12 mg/dl
Bilgen, 1998 [#99123665] | Healthy term jaundiced Turkish infants (96) | Measurement tools: AirShield-Minolta Tc bilirubinometer; Icterometer (Ingram) | Minolta AirShields: TcB ≥ 13 in predicting SB ≥ 12.9 mg/dl | Laboratory-based assay of TSB: Bilitron 444 direct spectrophotometric method
| Mean TSB (range): 12.7±2.6 mg/dl | Procedures: Minolta measuring at forehead. Icterometer measuring at nose | Icterometer: Ict ≥ 3 in predicting SB ≥ 12.9 mg/dl
| Prevalence of non-physiological jaundice (SB ≥ 12.9 mg/dl) = 18% (17/96)
Boo, 1984 [#85085660] | Jaundiced term infants - | Measurement tools: Minolta Tc bilirubinometer | N/A | Laboratory-based assay of TSB: Jendrassik's method
| Malay (38) | Procedures: at forehead, 3 consecutive readings from each baby, by one examiner
| Chinese (37)
| Indian (30)
Bourchier, 1987 [#88247126] | White FT infants (412) | Measurement tools: AirShield-Minolta Tc bilirubinometer 101 | N/A | Laboratory-based assay of TSB: photometric method (Mochida Bilimeter-D model MEB-332)
| Maori FT infants (317) | Procedures: at forehead and mid-sternum by nurses
Carbonell, 2001 [#21130776] | Healthy term infants (574 in phase I + 865 in phase II) | Measurement tools: AirShield-Minolta Tc bilirubinometer | TcB > 11 @ 24 hrs; TcB > 13 @ 48 hrs in predicting SB ≥ 17 mg/dl in the first 4 days of life | Laboratory-base assay of TSB: Bilirubinometer Bil-Red by direct reading at 461 mcm
*Also in Evidence Table 4 | | Procedures: at forehead and 'sternum, mean value was taken
Christo, 1988 [#89253855] | Term + Preterm infants (138) | Measurement tools: AirShield-Minolta Tc bilirubinometer 101 | TcB ≥ 18 in predicting SB ≥ 13 mg/dl | Laboratory-based assay of TSB: Technicon RA1000 within 0.5 and 1 hour from serum blood sample drawn
| | Procedures: 2 readings, 1 from forehead and 1 from sternum. The mean of the 2 readings was recorded. | For infants w/ high bilirubin level (TSB ≥ 13 mg/dl): TcB ≥ 23 in predicting SB ≥ 17 mg/dl
Dai, 1996 [#97093944] | Healthy term infants (45) | Measurement tools: AirShield-Minolta Tc bilirubinometer 101 | For infants not on PhotoRx (N=38, TcB N=40), TcB ≥ 17 in predicting SB ≥ 15.2 mg/dl for babies older than 1 day | Laboratory-based assay of TSB: Jendrassik-Grof method on a Hitachi 717 analyzer (Boehringer Mannheim, Laral, Quebec)
| | Procedures: 1 reading at forehead and sternum by lab technologist. 19 readings were made at a time when the infant was crying and 17 after exposure to PhotoRx. Meter testing was done only on babies for whom serum bilirubin had been ordered by the ward. It was decided to use only forehead readings in further data analysis. | Clinical judgement + TcB ≥ 15 on day 1 or ≥ 17 on day 2 or order, in predicting SB ≥ 15.2 mg/dl for babies older than 1 day
Fok, 1986 [#86268743] | Chinese full term infants (202) | Measurement tools: AirShield-Minolta Tc bilirubinometer | TcB ≥ 22 in predicting SB ≥ 15 mg/dl | Laboratory-based assay of TSB: AO Units Bilirubinometer (American Optical, USA) from capillary blood samples drawn within 15 min of TcB measurement
| Unknown cause for jaundice (177) | Procedures: 605 reading form forehead; 291 readings from mid-sternum. Each reading was the mean of 3 consecutive measurements at the same site, by one investigator.
| G-6-PD deficiency (3)
| ABO incompatible (22), but none of them show a positive Coomb's test
Goldman, 1982 [#82241425] | White FT infants (38) | Measurement tools: AirShield-Minolta Tc bilirubinometer | False positive: TcB > action level (> the lower of the 95% CI limits of the regression line), while SB < 7 mg/dl | Laboratory-based assay of TSB: Abbott Bi-chromatic Analyzer (ABA-100)
| Black FT infants (46) | Procedures: 2 readings at forehead within 1 hr of SB sample drawn. 3^rd^reading was taken if 1^st^and 2^nd^reading disagreed. | False negative: TcB < action level (< the lower of the 95% CI limits of the regression line, while SB > 10 mg/dl
Hanneman, 1982 [#82105249] | White FT infants (42) - | Measurement tools: Minolta Tc bilirubinometer | N/A | Laboratory-based assay of TSB: AO Unistat Bilirubinometer (American Optical, USA) or diazo (Jendrassik) method
| PhotoRx (7) | Procedures: at forehead, 3 consecutive readings from each baby
| White near term infants (45) -
| PhotoRx (23)
| Black infants GA ≥ 34 w/o PhotoRx (42)
Harisk, 1998 [#98373176] | Term infants (60) | Measurement tools: Minolta Tc bilirubinometer | TcB ≥ 18 in predicting SB ≥ 13 mg/dl | Laboratory-based assay of TSB: Malloy and Evelyn method
| SGA term+preterm infants (40) | Procedures: 5 measurements averaged from forehead
| Term infants on PhotoRx for < 12 hours (33)
| “Clinical appreciable jaundice”
Hegyi, 1981 [#81144434] | White term infants w/o PhotoRx (43) | Measurement tools: Minolta Tc bilirubinometer | N/A | Laboratory-based assay of TSB: spectrophotometric technique corrected for hemolysis and for increased direct bilirubin
| | Procedures: at forehead, sternum, right upper abdomen, knee, sole, elbow, palm, upper back, and lower back. 5 to 100 repetitions per patient.
Karrar, 1989 [#89271698] | Healthy Saudi infants (155) | Measurement tools: AirShield-Minolta Tc bilirubinometer | TcB > 21 in predicting SB >12.5 mg/dl | Laboratory-based assay of TSB: AO Unistat Bilirubinometer (American Optical, USA)
| Mean TSB (range): 9.1 (1.8–22) mg/dl | Procedures: 1 measurement at forehead
Kenny, 1984 [#89271698] | Caucasian, Asian, and Black infants (53) | Measurement tools: AirShield-Minolta Tc bilirubinometer | N/A | Laboratory-based assay of TSB: standard diazo method.
| | Procedures: at mid-forehead, chest and back.
Kivlaha, 1984 [#84296964] | White infants in NICU (32) | Measurement tools: AirShield-Minolta Tc bilirubinometer | N/A | Laboratory-based assay of TSB: DuPont automatic clinical analyzer
| | Procedures: at forehead within 1 hr of a measurement of SB level
Knudsen, 1989 [#89189829] Knudsen, 1990 [#90242782] | Healthy term infants (76/136) | Measurement tools: AirShield-Minolta Tc bilirubinometer | N/A | Laboratory-based assay of TSB: standard diazo method
| Clinically healthy, jaundiced infants | Procedures: at forehead, abdomen, knee, and foot. 2 readings pre site. Measuring while infants were not crying and controlled artificial light.
| No hemolytic anemia or rhesus immunization
| Mean TSB (range): 10.8 (4.0–16.5) mg/dl
| Mean TcB (range): 16 (10–23)
Knudsen, 1990 [#91196560] | Healthy term infants (207) | Measurement tools: AirShield-Minolta Tc bilirubinometer | TcB ≥ 15, ≥ 16, ≥ 17, ≥ 18, or ≥ 19 in predicting SB ≥ 10 or 13 mg/dl | Laboratory-based assay of TSB: standard diazo method
| Clinically healthy, jaundiced infants | Procedures: 2 readings from forehead. Measuring while infants were not crying in quiet conditions and controlled artificial light.
| No hemolytic anemia
Knudsen, 1992 [#92306741] | Healthy term infants (138) | Measurement tools: AirShield-Minolta Tc bilirubinometer | TcB ≥ 7, ≥ 8, ≥ 9, ≥ 10; ≥ 11 at day 1 in predicting SB > 11.7 mg/dl (or 200 μmole/l) at day 3 | Laboratory-base assay of TSB: at 3^rd^postnatal day, by standard direct spectroscopic method
*also in Evidence Table 4 | Six infants received PhotoRx (6) | Procedures: measuring at day one according to the operators manual.
| Median CB was 32.3 (20–45.5) μmol/l
| Median TcB at day 1 was 8.48 (5.0–12.5)
Knudsen, 1993 [#93333142] | Healthy Danish infants (125) - | Measurement tools: AirShield-Minolta Tc bilirubinometer | TcB ≥ 13, ≥ 14, ≥ 15, ≥ 16, or ≥ 17 in predicting SB ≥ 13 mg/dl | Laboratory-based assay of TSB: standard diazo method
| Study group: “slightly icteric” infants (73) | Procedures: at forehead, 2 readings pre site, and the average value was used in the calculation
| Control group: jaundiced infants (52)
| Mean TSB (range) -
| Study grp: 12.7 (7–17) mg/dl
| Control grp: 11.2 (6–15) mg/dl
| Mean TcB reading (range) -
| Study grp: 17 (11.8–21.1)
| Control grp: 16.5 (11.8–20.5)
Knudsen, 1995 [#93333142] | Healthy Danish infants (110) | Measurement tools: AirShield-Minolta Tc bilirubinometer | Corrected TcB at 21 hrs after birth > 9.0, > 9.5, > 10, or > 11 in predicting SB ≥ 18 mg/dl | Laboratory-based assay of TSB: standard spectrophotometric method
| No isoimmunization or suspected hemolytic disease | Procedures: at forehead, 2 readings pre site, and the average value was used in the calculation. TcB reading taken at median 21 hours of life (11–33 h) was “corrected” by the difference in TcB readings (TcB_diff_) obtained 6 hours later.
Kumar, 1992 [#93084314] | FT infants (125) | Measurement tools: AirShield-Minolta Tc bilirubinometer | N/A | Laboratory-based assay of TSB: standard diazo method. Cord blood collected at birth was used to estimate SB in 25 (20%) babies.
| | Procedures: at forehead, measurements were converted into an index (TcBI)
Laeeq, 1993 [#93267865] | FT infants (105) | Measurement tools: AirShield-Minolta Tc bilirubinometer | TcB reading (not defined) in predicting SB ≥ 9.92 mg/dl | Laboratory-based assay of TSB: standard diazo method
| Female: | Procedures: at forehead, chest and sternum, within 30 min before TSB sampling, by one examiner. Infants were not crying while measurement
| Mean TSB+2SD: 10.17+7.88 mg/dl
| Mean TcB+2SD: 18.68+7
| Male:
| Mean TSB+2SD: 9.74+6.22 mg/dl
| Mean TcB+2SD: 17.85+6.44
Lin, 1993 [#93383693] | Chinese full term infants (202) | Measurement tools: AirShield-Minolta Tc bilirubinometer | TcB ≥ 11, ≥ 16, or ≥ 20 on the 1^st^, 2^nd^, and following days of life predicting hyperbilirubinemia (SB ≥ 12.9) | Laboratory-based assay of TSB: spectro-photometric method with BB-meter-Model III
| No hemolysis, polycythemia, sepsis, hypoxia | Procedures: 5 measurements at forehead and 5 measurements at mid-sternum, within 30 min before TSB sampling. Mean of the measurement was taken. Repeated procedure every morning
Linder, 1994 [#94325008] | Healthy full term middle-eastern infants (123) | Measurement tools: AirShield-Minolta Tc bilirubinometer | TcB reading (not defined) in predicting SB > 12.9 mg/dl | Laboratory-based assay of TSB: AO Unistat Bilirubinometer (American Optical, USA)
| Initial TcB reading (range): 6–13.3 | Procedures: Initial reading was the average of 3 measurements at sternum within 4 hours of delivery. 1 to 3 readings pre baby on the day 3 or later. Correction of TcB reading by subtracting the initial reading from the measurement taken at the time that jaundice was suspected.
| TcB reading on the third day after delivery (range): 7.7–22
| TSB reading on the third day after delivery (range): 3.2–16 mg/dl
Maisels, 1982 [#82273864] | FT white infants (157) | Measurement tools: AirShield-Minolta Tc bilirubinometer | At forehead, TcB ≥ 24 in predicting SB ≥ 13 mg/dl; or, TcB ≥ 20 in predicting SB > 10 mg/dl | Laboratory-based assay of TSB: automated modified diazo method
| Mean TSB (range): 6.4±3.6 (0.5–16.1) mg/dl | Procedures: at forehead and mid-sternum, routinely on 3^rd^days at the time TSB was obtained. | At sternum, TcB ≥ 23 in predicting SB ≥ 13 mg/dl; or, TcB ≥ 19 in predicting SB > 10 mg/dl
| In 11 infants with clinical suspicion of significant jaundice, the mean TSB (range): 4.7±3.4 (0.9–10.6) mg/dl
Maisels, 1997 [#97247177] | Term infants (356) | Measurement tools: AirShield-Minolta Tc bilirubinometer | N/A | Laboratory-based assay of TSB: spectrophotometry (Bilirubinometer; Advanced Instruments, Needham Heights, MA; or Paramax, Irvine, CA)
| | Procedures: measured at the lower end of the sternum.
Schumacher, 1985 [#85241873] | White term infants (106) | Measurement tools: AirShield-Minolta Tc bilirubinometer; Icterometer (Ingram) | Minolta AirShields: TcB > 20 in predicting SB > 12.9 mg/dl | Laboratory-based assay of TSB: DuPont ACA II analyzer, a direct spectrophotometry method
| ABO incompatibility (5) | Procedures: Minolta measuring at forehead. Icterometer measuring at nose. 3 readings pre site for each instrument within 30 min of blood sample. The average was taken to the calculation. | Icterometer: Ict > 3 in predicting SB > 12.9 mg/dl
| Physiologic hyperbilirubinemia (101)
| Mean TSB (range): 10.6±2.6 (4.5–17.5) mg/dl
Serrao, 1989 [#85241873] | Term white infants (33) | Measurement tools: AirShield-Minolta Tc bilirubinometer | N/A | Laboratory-based assay of TSB: Beckman Total Bilirubin Reagent and Astra System Calibration standards, based on the modified Jendrassik-Grof method
| Mean TSB: 9.3±2.7 mg/dl | Procedures: 2 readings from mid-sternum. 3^rd^reading was taken if 1^st^and 2^nd^reading disagreed.
| Mean TcB reading: 15.66±2.7
Sharma, 1988 [#89122266] | Term + Preterm infants (200) | Measurement tools: AirShield-Minolta Tc bilirubinometer | N/A | Laboratory-based assay of TSB: SEZC-5267 Photo Analyzer (Miles India Ltd.)
| Mean TSB (range): 7.5±3.2 (3.5–20) mg/dl | Procedures: at forehead, before instituting any therapy for icterus. Mean of the 3 consecutive readings was taken.
| Mean TcB reading (range): 20.5±6.5 (5–30)
Sheridan-Pereira, 1982 [#83021365] | White term infants (60) | Measurement tools: ND (assumed AirShield-Minolta Tc bilirubinometer, because the author mentioned TcB tool has previously evaluated as Yamauchi) | TcB ≥ 20 in predicting SB > 14.5 mg/dl | Laboratory-based assay of TSB: method of Jendrassik Grof.
| ABO incompatibility (3) | Procedures: forehead only, blood was obtained simultaneously
Smith, 1985 [#85112373] | Healthy FT white infants (85) | Measurement tools: Minolta Tc bilirubinometer | Elevated TcB, Elevated ETco, or Elevated both TcB and ETco in predicting SB > 12.9 mg/dl | Laboratory-based assay of TSB: method was not reported
| 7 infants developed significant hyperbilirubinemia requiring therapy - | Procedures: 3 measurements at forehead
| ABO incompatibility (3)
| LGA (3)
| Large cephalohematoma (10)
| Unexplained perinatal asphyxia and polycythemia (1)
| Mean TcB at 24 hrs: 12.61±2.35
| Mean ETco at 24 hrs: 1.44±0.48 μL/L
Suckling, 1995 [#95327901] | Healthy Term + Preterm white infants with high TcB levels (55) | Measurement tools: Minolta Tc bilirubinometer | For term AGA infants: TcB ≥ 18 in predicting SB > 14 mg/dl (240 μmol/l) | Laboratory-based assay of TSB: standard diazo method
| | Procedures: 3 measurements at forehead | For near term or SGA infants: TcB ≥ 16 in predicting SB > 9.9 mg/dl (170 μmol/l)
Taha, 1984 [#85070990] | Healthy term infants (68) | Measurement tools: Minolta Tc bilirubinometer | TcB > 22.5 in predicting SB > 12.9 mg/dl | Laboratory-based assay of TSB: AO Unistat Bilirubinometer (American Optical, USA)
| Mean TSB (range): 9.7±3.1 (3.8–18.4) mg/dl | Procedures: at forehead, according to Yamanouchi et al. Blood was obtained simultaneously
Tan, 1985 [#86101839] Tan, 1982 [#83044572] | FT Chinese infants (68) | Measurement tools: AirShield-Minolta Tc bilirubinometer | N/A | Laboratory-based assay of TSB: AO Unistat Bilirubinometer (American Optical, USA)
| FT Malay infants (57) | Procedures: at forehead, mid-sternum, and upper back between the two scapulae.
Tan, 1996 [#97017283] | FT Chinese infants (253) | Measurement tools: AirShield-Minolta Tc bilirubinometer | N/A | Laboratory-based assay of TSB: AO Unistat Bilirubinometer (American Optical, USA)
| FT Malay infants (169) | Procedures: at sternum, and forehead, between 2 and 8 days of life
| FT Indian infants (120)
| SB (range) -
| Chinese: 5.8–21.1 mg/dl
| Malay: 2.0–21.1 mg/dl
| Indian:2.9–21.1 mg/dl
Tsai, 1988 [#90177720] | Chinese FT infants (98) | Measurement tools: AirShield-Minolta Tc bilirubinometer | TcB > 16 in predicting SB ≥ 13 mg/dl | Laboratory-based assay of TSB: BB-meter-Model III (O'Hara Co. Ltd.)
| Appeared to be doing well and be able to be nursed in open bassinets after admission | Procedures: at forehead, cheek, sternum, abdomen, upper back, lower back, palm, and sole. Total 178 pairs of data for each body site.
| TSB reading (range): 5.2–16.3
| TcB reading (range): 9–21
Yamauchi, 1989 [#89348834] | Healthy FT Japanese infants (114) | Measurement tools: AirShield-Minolta Tc bilirubinometer | N/A | Laboratory-based assay of TSB: AO Unistat Bilirubinometer (American Optical, USA)
| No Rh, ABO incompatibility | Procedures: at forehead, chest and sternum, every 20–28 hrs from birth to day 7
| No dehydration, infection, closed hemorrhage, and respiratory distress
| Mean TSB (range): 12.5±2.5 (4–21) mg/dl
Yamauchi, 1990 [#90273849] | Healthy FT Japanese infants (78) | Measurement tools: AirShield-Minolta Tc bilirubinometer | TcB at 24 hrs of life ≥ 14 in predicting SB ≥ 15 mg/dl | Laboratory-based assay of TSB: AO Unistat Bilirubinometer (American Optical, USA) on 6 days of life
| TSB on day 6: 12.4±3.6 mg/dl | Procedures: at forehead, chest and sternum, measuring from birth every 24±4 hrs for 1^st^week of life. Mean TcB from 3 sites was taken.
Yamauchi, 1991 [#92188736] | Healthy FT Japanese infants were randomly assigned to the two groups at birth: | Measurement tools: AirShield-Minolta Tc bilirubinometer | N/A | Laboratory-based assay of TSB: AO Unistat Bilirubinometer (American Optical, USA)
| Group I - infants were kept near the window which was sometimes directly exposed to sunlight (59) | Procedures: at forehead and sternum, every 20–28 hrs from birth to day 7
| Group II - infants were kept on the door side of the room, which had no direct sunlight (48)
Yamauchi, 1991 [#92188737] Yamauchi, 1988 [#89086035] | Healthy FT Japanese infants (336) | Measurement tools: AirShield-Minolta Tc bilirubinometer | N/A | Laboratory-based assay of TSB: AO Unistat Bilirubinometer (American Optical, USA)
| | Procedures: at forehead, chest, and sternum, during 3 different time periods: 0–3 days, 4–5 days, and 6–12 days

Evidence Table 5.1. Question 5 - Studies evaluating the accuracy of AirShields Minolta bilirubinometer - Part III

Author, Year | Results
Bhat, 1987 [#88085341] | Accuracy of transcutaneous measurements:
| Measure site | Population | (N) | Linear Regression Analysis
| | | | Slope | Intercept | r | TSB units | Y Axis
| Forehead | All infants (59% preterm) | 100 | 1.06 | 9.29 | 0.70 | mg/dl | TcB
| | Subgroups:
| | GA ≥ 37 wk | 63 | 1.06 | 9.09 | 0.72
| | GA<37 wk | 37 | 0.85 | 12.15 | 0.52
| | BW>2500 g | 37 | 1.3 | 6.39 | 1.03?
| | BW≤2500 g | 63 | 1.18 | 8.24 | 0.94
Bhutta, 1991 [#92015688] | Accuracy of transcutaneous measurements:
| Measure site | Population | (N) | Linear Regression Analysis
| | | | Slope | Intercept | r | TSB units | Y Axis
| Forehead | Jaundiced infants | 63 | 0.68 | 0.46 | 0.66 | mg/dl | TcB
| At forehead, the sensitivity, specificity, PPV, and NPV (TcB > 17 in predicting SB > 12.5 mg/dl) was 88%, 53%, 56%, and 87%, respectively.
Bilgen, 1998 [#99123665] | Accuracy of transcutaneous and Icterometer measurements:
| Measure site | Population | (N) | Linear Regression Analysis
| | | | Slope | Intercept | r | TSB units | Y Axis
| Forehead (Minolta) | Turkish infants | 96 | | | 0.83 | mg/dl | TcB
| Nose (lcterometer) | Turkish infants | 96 | | | 0.78
| At forehead measured by Minolta jaundice meter, the sensitivity, specificity, PPV, and NPV (TcB ≥ 13 in predicting SB ≥ 12.9 mg/dl) was 100%, 56%, 33%, and 100%, respectively. The prevalence of non-physiological jaundice (SB ≥ 12.9 mg/dl) was 18%.
| At nose measured by Ingram icterometer, the sensitivity, specificity, PPV, and NPV (Ict ≥ 3 in predicting SB ≥ 12.9 mg/dl) was 100%, 48%, 29%, and 100% respectively
| Comparing Minolta jaundice meter to Icterometer, of the total 96 pairs of measurement (TcB cutoff point ≥ 13; Ict cutoff point ≥ 3), Minolta and Icterometer agreed in 83% (80/96), and disagreed in 17% (16/96). The Kappa coefficient was 0.66.
Boo, 1984 [#85085660] | Accuracy of transcutaneous measurements:
| Measure site | Population | (N) | Linear Regression Analysis
| | | | Slope | Intercept | r | TSB units | Y Axis
| Forehead | Malay infants | 38 | 0.0428 | 9.0474 | 0.83 | μmol/l | TcB
| | Chinese infants | 37 | 0.0296 | 9.895 | 0.66
| | Indian infants | 30 | 0.0346 | 11.179 | 0.63
| Two Chinese babies with TSB ≥ 250 μmol/l (or 14.6 mg/dl) had “low” TcB indices (from the graph provided, “low” probably means TcB=13). Both babies had severe jaundice due to ABO incompatibility within the first 24 hrs of life.
Bourchier, 1987 [#88247126] | Accuracy of transcutaneous measurements:
| Measure site | Population | (N) | Linear Regression Analysis
| | | | Slope | Intercept | r | TSB units | Y Axis
| Forehead | Caucasian infants | 412 | 0.03 | 12.32 | 0.58 | μmol/l | TcB
| | Maori infants | 317 | 0.03 | 12.73 | 0.57
| Sternum | Caucasian infants | 412 | 0.03 | 10.66 | 0.67
| | Maori infants | 317 | 0.03 | 12.33 | 0.62
Carbonell, 2001 [#21130776] | Accuracy of transcutaneous measurements:
| Measure site | Population | (N) | Linear Regression Analysis
| | | | Slope | Intercept | r | TSB units | Y Axis
| Forehead and sternum | Healthy term infants | 996 | 0.804 | 5.916 | 0.92 | mg/dl | TcB
| Forehead only | <24 hrs | 120 | | | 0.77
| | 24–48 hrs | 126 | | | 0.83
| | > 48 hrs | 412 | | | 0.83
| Sternum only | < 24 hrs | 120 | | | 0.81
| | 24–28 hrs | 126 | | | 0.887
| | > 48 hrs | 412 | | | 0.94
| For healthy term infants in phase I study (N=574), the sensitivity, specificity, PPV, and NPV (TcB > 11 @ 24 hrs of life in predicting SB ≥ 17 mg/dl) was 83%, 66%, 7%, and 99%, respectively.
| For healthy term infants in phase I study (N=574), the sensitivity, specificity, PPV, and NPV (TcB > 13 @ 48 hrs of life in predicting SB ≥ 17 mg/dl) was 94%, 52%, 6%, and 99.6%, respectively.
| For healthy term infants in phase II study (N=865), the sensitivity, specificity, PPV, and NPV (TcB > 13 @ 48 hrs of life in predicting SB ≥ 17 mg/dl) was 98%, 32%, 8%, and 99.6%, respectively.
| To screen SB ≥ 13 mg/dl, “TcB shows sensitivity of 98% and specificity of 72%. This would translate to a decrease of 56% of SB determination (true negative value)”
Christo, 1988 [#89253855] | Accuracy of transcutaneous measurements:
| Measure site | Population | (N) | Linear Regression Analysis
| | | | Slope | Intercept | r | TSB units | Y Axis
| Forehead and sternum | All infants Subgroups: | 138 | 0.874 | 7.72 | 0.90 | mg/dl | TcB
| | Term not on PhotoRx | 91 | 0.866 | 7.59 | 0.89
| | Only infants w/TSB ≥ 13 mg/dl | 35 | 1.08 | 4.31 | 0.83
| | Infants on PhotoRx | 26 | 0.82 | 7.97 | 0.85
| | Preterm infants (GA 32–37 wk) | 17 | 0.902 | 8.42 | 0.90
| | SGA infants | 27 | 1.02 | 7.23 | 0.94
| For all infants (N=138), the sensitivity, specificity, PPV, and NPV (TcB ≥ 18 in predicting SB ≥ 13 mg/dl) was 95%, 83%, 69%, and 98%, respectively.
| For term infants without PhotoRx (N=91), the sensitivity, specificity, PPV, and NPV (TcB ≥ 18 in predicting SB ≥ 13 mg/dl) was 100%, 87%, 62%, and 100%, respectively.
| For infants w/TSB ≥ 13 mg/dl (N=35), the sensitivity, specificity, PPV, and NPV (TcB ≥ 23 in predicting SB ≥ 17 mg/dl) was 100%, 92%, 83%, and 100%, respectively.
Dai, 1996 [#97093944] | At forehead, for healthy term infants not on PhotoRx(N=38, TcB N=40), the sensitivity, specificity, PPV, and NPV (TcB > 17 in predicting SB ≥ 15.2 mg/dl) was 42%, 100%, 100%, and 66%, respectively.
| With the use of both clinical judgement and TcB testing in all infants, the sensitivity, specificity, PPV, and NPV (TcB ≥ 15 on day 1 or ≥ 17 on day 2 or order, in predicting SB ≥ 15.2 mg/dl) was 100%, 93%, 27%, and 100%, respectively.
| With the use of clinical judgement alone in all infants, the sensitivity, specificity, PPV, and NPV in predicting SB ≥ 15.2 mg/dl was 100%, 84%, 18%, and 100%, respectively.
Fok, 1986 [#86268743] | Accuracy of transcutaneous measurements:
| Measure site | Population | TcB(N) | Linear Regression Analysis
| | | | Slope | Intercept | r | TSB units | Y Axis
| Forehead | Chinese infants | 605 | 1.11 | 9.27 | 0.86 | μmol/l | TcB
| Sternum | | 291 | 1.19 | 8.31 | 0.91
| At forehead, the sensitivity, specificity, PPV, and NPV (TcB ≥ 22 in predicting SB ≥ 15 mg/dl) were 100%, 66%, 20%, and 100%, respectively. False positive rate was 80% (64/80). The prevalence of hyperbilirubinemia (SB ≥ 15 mg/dl) was 8%.
| At sternum, the sensitivity, specificity, PPV, and NPV (TcB ≥ 22 in predicting SB ≥ 15 mg/dl) were 63%, 85%, 26%, and 96%, respectively. False positive rate was 74% (28/38).
| 57 infants who received PhotoRx also were included. 100 readings were observed. At forehead, r=0.79; at sternum, r=0.26. Exposure to photolight significantly reduced the correlation between TcB indices and SB levels.
Goldman, 1982 [#82241425] | Accuracy of transcutaneous measurements:
| Measure site | Population | TcB (N) | Linear Regression Analysis
| | | | Slope | Intercept | r | TSB units | Y Axis
| Forehead | FT white infants | 95 | 1.0 | 7.8 | 0.705 | mg/dl | TcB
| | FT Black infants | 108 | 0.53 | 14.0 | 0.52
| Of total 95 pairs of TcB and TSB measurements in FT white infants (N=38), 2.1% was false positive; 3.2% was false negative predictions.
| Of total 108 pairs of TcB and TSB measurements in FT black infants (N=46), 7.4% was false positive; 6.5% was false negative predictions.
| It was concluded that every nursery must establish its own “action levels”, regression curves, and confidence limits.
Hanneman, 1982 [#82105249] | Accuracy of transcutaneous measurements:
| Measure site | Population | (N) | Linear Regression Analysis
| | | | Slope | Intercept | r | TSB units | Y Axis
| Forehead | White FT infants (≥38 wks) w/o PhotoRx | 35 | 1.25 | 9.63 | 0.90 | mg/dl | TcB
| | White FT infants on PhotoRx | 7 | 0.99 | 9.25 | 0.86
| | Black ≥34 wks w/o PhotoRx | 42 | 0.97 | 13.49 | 0.74
| | White 34–37 wks on PhotoRx | 23 | 1.24 | 7.59 | 0.80
| | White 34–37 wks w/o PhotoRx | 22 | 1.30 | 7.57 | 0.88
| “In white infants 34–37 wks GA undergoing PhotoRx, it is impossible to differentiate bilirubin concentrations of 6 to 12 mg/dl by the bilirubin meter.”
Harisk, 1998 [#98373176] | Accuracy of transcutaneous measurements:
| Measure site | Population | (N) | Linear Regression Analysis
| | | | Slope | Intercept | r | TSB units | Y Axis
| Forehead | Term Indian infants | 60 | 0.72 | 10.71 | 0.83 | mg/dl | TcB
| | Term Indian infants on PhotoRx | 33 | 0.62 | 12.90 | 0.65
| | SGA Indian infants | 40 | 0.61 | 12.64 | 0.76
| For term Indian infants (N=60), the sensitivity, specificity, PPV, and TcB ≥ 18 in predicting SB ≥ 13 mg/dl) was 96%, 59%, 64%, and 95%, respectively.
| For term Indian infants on PhotoRx for less than 12 hrs (N=33), the sensitivity, specificity, PPV, and TcB ≥ 18 in predicting SB ≥ 13 mg/dl) was 100%, 31%, 66%, and 95%, respectively.
| For SGA Indian infants (N=40), the sensitivity, specificity, PPV, and TcB ≥ 18 in predicting SB ≥ 13 mg/dl) was 96%, 55%, 72%, and 91%, respectively.
Hegyi, 1981 [#81144434] | Accuracy of transcutaneous measurements:
| Measure site | Population | TcB (N) | Linear Regression Analysis
| | | | Slope | Intercept | r | TSB units | Y Axis
| Forehead | White term infants w/o PhotoRx | 102 | | | 0.77
| Sternum | | | | | 0.90
| Abdomen | | | | | 0.88
| Knee | | | | | 0.87
| Sole | | | | | 0.72
| Elbow | | | | | 0.87
| Palm | | | | | 0.72
| Upper back | | | | | 0.87
| Lower back | | | | | 0.86
| Reduction in accuracy at elevated bilirubin levels. TcB was not useful in the group receiving PhotoRx.
Karrar, 1989 [#89271698] | Accuracy of transcutaneous measurements:
| Measure site | Population | (N) | Linear Regression Analysis
| | | | Slope | Intercept | r | TSB units | Y Axis
| Forehead | Saudi infants | 155 | 0.69 | 13.24 | 0.817 | mg/dl | TcB
| At forehead, the sensitivity, specificity, PPV, and NPV (TcB > 21 in predicting SB >12.5 mg/dl) was 74%, 90%, 78%, and 88%, respectively.
Kenny, 1984 [#89271698] | Accuracy of transcutaneous measurements:
| Measure site | Population | TcB (N) | Linear Regression Analysis
| | | | Slope | Intercept | r | TSB units | Y Axis
| Mid-forehead | Caucasian mixed-fed | 41 | 1.086 | 6.940 | 0.846 | mg/l | TcB
| | Caucasian Breast-fed | 24 | 1.061 | 6.722 | 0.939
| | Caucasian Formula-fed | 17 | 1.047 | 7.005 | 0.837
| Sternum/Chest | Caucasian mixed-fed | 18 | 1.001 | 7.320 | 0.933
| Upper Back | Caucasian mixed-fed | 10 | 1.255 | 5.370 | 0.826
Kivlaha, 1984 [#84296964] | Accuracy of transcutaneous measurements:
| Measure site | Population | (N) | Linear Regression Analysis
| | | | Slope | Intercept | r | TSB units | Y Axis
| Forehead | White infants | 32 | 0.9 | 8.3 | 0.89 | mg/dl | TcB
Knudsen, 1989 [#89189829] | Accuracy of transcutaneous measurements:
Knudsen, 1990 [#90242782] | Measure site | Population | (N) | Linear Regression Analysis
| | | | Slope | Intercept | r | TSB units | Y Axis
| Forehead | Healthy term infants | 76 | 0.046 | 7.75 | 0.83 | μmol/l | TcB
| Also found were correlations between TcB measurements and SB concentration in 136 healthy term infants at forehead, abdomen, knee, and foot. The r(Rho) was 0.86(0.83), 0.89(0.92), 0.82(0.85), and 0.65(0.65), respectively. Rho is calculated according to Spearman's test and is correlated for ties.
Knudsen, 1990 [#91196560] | Accuracy of transcutaneous measurements:
| Measure site | Population | (N) | Linear Regression Analysis
| | | | Slope | Rho ^a^ | r | TSB units | Y Axis
| Forehead | Healthy jaundiced infants | 207 | | 0.81 | 0.84 | μmol/l | TcB
| ^a^ Rho is calculated according to Spearman's test.
| The prevalence of hyperbilirubinemia in healthy jaundiced term infants (N=207) was 7.4% (28/207).
| In term healthy jaundiced infants (N=207), the test performances of TcB measurement at different thresholds in predicting hyperbilirubinemia (SB ≥ 13 mg/dl) were studied. It was found that:
| At forehead, the sensitivity, specificity, PPV, and NPV was 100%, 34%, and 19%, and 100% respectively, when TcB ≥ 15 was used as the cutoff point.
| At forehead, the sensitivity, specificity, PPV, and NPV was 100%, 52%, and 25%, and 100% respectively, when TcB ≥ 16 was used as the cutoff point.
| At forehead, the sensitivity, specificity, PPV, and NPV was 86%, 63%, and 27%, and 97% respectively, when TcB ≥ 17 was used as the cutoff point.
| At forehead, the sensitivity, specificity, PPV, and NPV was 79%, 75%, and 33%, and 96% respectively, when TcB ≥ 18 was used as the cutoff point.
| At forehead, the sensitivity, specificity, PPV, and NPV was 54%, 88%, and 42%, and 92% respectively, when TcB ≥ 19 was used as the cutoff point.
| In term healthy jaundiced infants (N=207), the test performances of TcB measurement at different thresholds in predicting hyperbilirubinemia (SB ≥ 10 mg/dl) were also studied. It was found the sensitivity ranged from 96% to 33%, specificity ranged from 50% to 96%, PPV ranged form 62% to 86%, and NPV ranged from 93% to 63%, from TcB cutoff point ≥ 15 to ≥ 19 respectively.
| In 99 of the total subjects, there was a clinical indication for repeating the SB concentration determination 12–24 hours after the first measurement. The quantitative relationship between the changes in TSB and TcB was poor (Rho=0.69). If using a change in TcB readings of zero or above as a test of an increase in SB concentration of 1.5 mg/dl or more, the sensitivity, specificity, PPV, and NPV would be 100%, 51%, 39%, and 100% respectively.
| It was concluded that Bilirubinometer is quite acceptable for high TSB. It can avoid about 50% of TSB measurement.
Knudsen, 1992 [#92306741] | The prevalence of hyperbilirubinemia in all term infants (N=138) was 20%.
| The correlation between TcB and TSB was significant (Pearson's r was 0.63).
| Different thresholds of TcB as a test for later development of hyperbilirubinemia (SB > 11.7 mg/dl or 200 μmole/l) in all term infants (N=138) were analyzed:
| The sensitive, specificity, PPV, and NPV was 100%, 12%, 22%, and 100%, respectively, when TcB ≥ 7 was used as the cutoff point.
| The sensitive, specificity, PPV, and NPV was 96%, 26%, 25%, and 97%, respectively, when TcB ≥ 8 was used as the cutoff point.
| The sensitive, specificity, PPV, and NPV was 75%, 65%, 35%, and 91%, respectively, when TcB ≥ 9 was used as the cutoff point.
| The sensitive, specificity, PPV, and NPV was 57%, 81%, 44%, and 88%, respectively, when TcB ≥ 10 was used as the cutoff point.
| The sensitive, specificity, PPV, and NPV was 32%, 93%, 53%, and 84%, respectively, when TcB ≥ 11 was used as the cutoff point.
Knudsen, 1993 [#93333142] | Accuracy of transcutaneous measurements:
| Measure site | Population | (N) | Linear Regression Analysis
| | | | Slope | Intercept | r | TSB units | Y Axis
| Forehead | Danish infants | 125 | 0.042 | 8.3 | 0.85 | μmol/l | TcB
| In Danish term infants with “slightly icteric” at discharge (N=73), the test performances of TcB measurement at different thresholds in predicting hyperbilirubinemia (SB ≥ 13 mg/dl) were studied. It was found that:
| At forehead, the sensitivity, specificity, PPV, and NPV was 100%, 11%, and 44%, and 100% respectively, when TcB ≥ 13 was used as the cutoff point.
| At forehead, the sensitivity, specificity, PPV, and NPV was 100%, 19%, and 46%, and 100% respectively, when TcB ≥ 14 was used as the cutoff point.
| At forehead, the sensitivity, specificity, PPV, and NPV was 100%, 35%, and 52%, and 100% respectively, when TcB ≥ 15 was used as the cutoff point.
| At forehead, the sensitivity, specificity, PPV, and NPV was 97%, 51%, and 58%, and 96% respectively, when TcB ≥ 16 was used as the cutoff point.
| At forehead, the sensitivity, specificity, PPV, and NPV was 93%, 74%, and 72%, and 94% respectively, when TcB ≥ 17 was used as the cutoff point.
| The prevalence of hyperbilirubinemia in Danish term infants with “slightly icteric” at discharge (N=73) was 41%, while it was 21% in Danish term jaundiced infants (N=52).
Knudsen, 1995 [#93333142] | At forehead, the test performances of “corrected” TcB measurement at different thresholds in predicting hyperbilirubinemia (SB ≥ 18 mg/dl) were studied. It was found that:
| At forehead, the sensitivity, specificity, PPV, and NPV was 100%, 56%, and 17%, and 100% respectively, when “corrected” TcB > 9 was used as the cutoff point.
| At forehead, the sensitivity, specificity, PPV, and NPV was 89%, 66%, and 19%, and 99% respectively, when “corrected” TcB > 9.5 was used as the cutoff point.
| At forehead, the sensitivity, specificity, PPV, and NPV was 78%, 78%, and 24%, and 98% respectively, when “corrected” TcB > 9.5 was used as the cutoff point.
| At forehead, the sensitivity, specificity, PPV, and NPV was 33%, 92%, and 27%, and 94% respectively, when “corrected” TcB > 9.5 was used as the cutoff point.
| The test performances of the difference in TcB readings 6 hours apart (TcB_diff_)at different thresholds in predicting hyperbilirubinemia (SB ≥ 18 mg/dl) were also studied. It was found the sensitivity ranged from 100% to 33%, specificity ranged from 36% to 96%, PPV ranged form 12% to 42%, and NPV ranged from 100% to 94%, from TcB_diff_cutoff point >0 (n=74), >0.5 (n=48), >1.0 (n=17), to >1.5 (n=7).
Kumar, 1992 [#93084314] | Accuracy of transcutaneous measurements:
| Measure site | Population | TcB (N) | Linear Regression Analysis
| | | | Slope | Intercept | r | TSB units | Y Axis
| Forhead | FT infants | 822 | | | 0.9090 | mg/dl | TcB
| The authors also used a filter paper technique called the SBI and correlated this to TSB with r=0.9343.
| This method required a heel stick and wet filter paper.
Laeeq, 1993 [#93267865] | Accuracy of transcutaneous measurements:
| Measure site | Population | (N) | Linear Regression Analysis
| | | | Slope | Intercept | r | TSB units | Y Axis
| Forehead, chest and sternum | Pakistanis infants | 105 | | | 0.774
| For term Pakistanis infants (N=105), the sensitivity, specificity, and PPV (in predicting SB ≥ 9.92 mg/dl, which is the mean SB of study infants) was 91%, 78%, and 64%, respectively.
| SB levels 6 and 15 mg/dl were arbitrarily selected to detect the test performance as well. The sensitivity, specificity, and PPV in predicting SB ≥ 6 mg/dl was 97%, 41%, and 89%, respectively; and, that was 90%, 98.9%, and 90% respectively for predicting SB ≥ 15 mg/dl.
Lin, 1993 [#93383693] | Accuracy of transcutaneous measurements:
| Measure site | Population | TcB | Linear Regression Analysis
| | | (N) | Slope | Intercept | r | TSB units | Y Axis
| Forehead | Chinese infants | 227 | 1.13 | 4.3 | 0.82 | mg/dl | TcB
| Sternum | | 217 | 1.2 | 3.3 | 0.86
| At forehead, the sensitivity, specificity, PPV, and NPV (TcB action levels in predicting SB ≥ 12.9 mg/dl) was 68%, 80%, 30%, and 95%, respectively.
| At sternum, the sensitivity, specificity, PPV, and NPV (TcB action levels in predicting SB ≥ 12.9 mg/dl) was 84%, 84%, 42%, and 97%, respectively.
| The prevalence of hyperbilirubinemia (SB≥ 12.9 mg/dl) in the study sample was 5.9%.
| There was no difference in peak TcB levels between the formula-fed and mixed-fed groups.
| Mid-sternum is a better site for detecting hyperbilirubinemia than forehead.
Linder, 1994 [#94325008] | Accuracy of transcutaneous measurements:
| Measure site | Population | (N) | Linear Regression Analysis
| | | | Slope | Intercept | r | TSB units | Y Axis
| Sternum | Middle-eastern infants | 123 | | | 0.96 ^a^ | mg/dl | TcB
| ^a^ “corrected” by the initial reading to account for skin color
| At mid-sternum, the “corrected” sensitivity, specificity, PPV, and NPV (predicting SB > 12.9 mg/dl) was 86%, 98%, 86%, and 98%, respectively.
| Serum bilirubin > 12.9 in 22 of the determinations (14%).
| This study determined infant skin color correction at age 4 hour of life; then subtracted this from future measurements, resulting in improved test performance (uncorrected r=0.90 → corrected r=0.96)
Maisels, 1982 [#82273864] | Accuracy of transcutaneous measurements:
| Measure site | Population | (N) | Linear Regression Analysis
| | | | Slope | Intercept | r | TSB units | Y Axis
| Forehead | FT white infants | 157 | 1.33 | 7.96 | 0.93 | mg/dl | TcB
| Mid-sternum | | 135 | 1.35 | 7.44 | 0.93
| R value was consistent for high TSB.
| Large ranges for TSB at different TcB level.
| At forehead, in FT white infants (N=157), the sensitivity, specificity, PPV, and NPV (TcB ≥ 24 in predicting SB ≥ 13 mg/dl) was 100%, 97%, 58%, and 100%, respectively.
| At forehead, in FT white infants (N=157), the sensitivity, specificity, PPV, and NPV (TcB ≥ 20 in predicting SB > 10 mg/dl) was 91%, 90%, 59%, and 98%, respectively.
| At mid-sternum, in FT white infants (N=135), the sensitivity, specificity, PPV, and NPV (TcB ≥ 23 in predicting SB ≥ 13 mg/dl) was 100%, 96%, 44%, and 100%, respectively.
| At mid-sternum, in FT white infants (N=135), the sensitivity, specificity, PPV, and NPV (TcB ≥ 19 in predicting SB > 10 mg/dl) was 100%, 85%, 37%, and 100%, respectively.
Maisels, 1997 [#97247177] | Accuracy of transcutaneous measurements:
| Measure site | Population | (N) | Linear Regression Analysis
| | | | Slope | Intercept | r | TSB units | Y Axis
| Low sternum | Term infants | 356 | 0.785 | 6.953 | 0.87 | mg/dl | TcB
| The main purpose of this study was the cost effectiveness of using TcB measurements. It was concluded that using the jaundice meter will save about $1625 per year ($2375–$750), based on a delivery population of about 5000 infants per year.
Schumacher, 1985 [#85241873] | Accuracy of transcutaneous and Icterometer measurements:
| Measure site | Population | (N) | Linear Regression Analysis
| | | | Slope | Intercept | r | TSB units | Y Axis
| Forehead (Minolta) | White term infants | 106 | 0.19 | 9.25 | 0.74 | mg/dl | TcB
| Nose (Icterometer) | White term infants | 106 | 0.12 | 1.74 | 0.63 | mg/dl
| R value lowered by absence of “non-jaundiced” infants.
| At forehead measured by Minolta bilirubin meter, the sensitivity, specificity, PPV, and NPV (TcB > 20 in predicting SB > 12.9 mg/dl) was 94%, 78%, 44%, and 99%, respectively.
| At nose measured by icterometer, the sensitivity, specificity, PPV, and NPV (Ict > 3 in predicting SB > 12.9 mg/dl) was 82%, 74%, 38%, and 96% respectively.
| At nose measured by icterometer when familiarity with the device was being obtained (102 measurements), the sensitivity, specificity, PPV, and NPV (Ict > 3 in predicting SB > 12.9 mg/dl) was 95% and 74% respectively.
| Comparing Minolta jaundice meter to Icterometer, of the total 106 pairs of measurement (TcB cutoff point > 12.9; Ict cutoff point > 3), Minolta and Icterometer agreed in 78% (83/106), and disagreed in 22% (23/106). The Chi-square = 1.09, p=0.3.
| It was concluded that both devices equally good in predicting hyperbilirubinemia after skill established.
Serrao, 1989 [#85241873] | Accuracy of transcutaneous measurements:
| Measure site | Population | (N) | Linear Regression Analysis
| | | | Slope | Intercept | r | TSB units | Y Axis
| Mid-sternum | Term white infants | 33 | 0.94 | 6.87 | 0.93 | mg/dl | TcB
| Part II study consisted of 94 ABO-incompatible (Group I and II) and 109 ABO-compatible term white infants. Newborns with BW < 2500 g, history of maternal Rh sensitization, known familial hemoglobinopathy, presence of an unusual maternal antibody, or diagnosed poly-cythemia were excluded: Group I - Coombs' test positive ABO (n=63), Group II - Coombs' test negative ABO (n=31); Group III - ABO-compatible controls. TcB in the 3 groups were done between 1 and 3 days of life. There were no significant differences in the mean TcB when groups I and II are compared with group III.
Sharma, 1988 [#89122266] | Accuracy of transcutaneous measurements:
| Measure site | Population | (N) | Linear Regression Analysis
| | | | Slope | Intercept | r | TSB units | Y Axis
| Forehead | All infants (40% preterm) | 200 | 0.99 | 8.12 | 0.87 | mg/dl | TcB
| | Subgroups:
| | Term infants | 120 | 0.99 | 8.91 | 0.74
| | Preterm infants | 80 | 0.94 | 9.12 | 0.69
| | BW ≥ 2.5 Kg | 110 | 0.96 | 7.01 | 0.85
| | BW < 2.5 Kg | 90 | 0.99 | 7.98 | 0.81
Sheridan-Pereira, 1982 [#83021365] | Accuracy of transcutaneous measurements:
| Measure site | Population | TcB (N) | Linear Regression Analysis
| | | | Slope | Intercept | r | TSB units | Y Axis
| Forehead | White infants | 81 | | | 0.70 | μmol/l | TcB
| | Subgroups:
| | Term not on PhotoRx | 57 | | | 0.65
| | Term on PhotoRx | 24 | | | 0.76
| For white term infants not on PhotoRx (TcB N=57), the sensitivity, specificity, PPV, and NPV (TcB ≥ 20 in predicting SB > 14.5 mg/dl) was 100%, 75%, 24%, and 100%, respectively.
Smith, 1985 [#85112373] | Accuracy of transcutaneous measurements:
| Measure site | Population | TcB (N) | Linear Regression Analysis
| | | | Slope | Intercept | r | TSB units | Y Axis
| Forehead | Health FT white and Mexican American infants | 104 | 1015 | 6.44 | 0.9 | mg/dl | TcB
| The prevalence of hyperbilirubinemia (SB > 12.9 mg/dl) requiring therapy was 8.2% (7/85).
| With the use of either TcB or ETco test alone, the sensitivity (TcB or ETco > 1 SD above the mean, in predicting SB > 12.9 mg/dl or requiring therapy) was 57%.
| With the use of both TcB and ETco tests, the sensitivity, specificity, PPV, and NPV in predicting SB > 12.9 mg/dl or requiring therapy was 86%, 82%, 30%, and 98%, respectively
Suckling, 1995 [#95327901] | Accuracy of transcutaneous measurements:
| Measure site | Population | TcB (N) | Linear Regression Analysis
| | | | Slope | Intercept | r | TSB units | Y Axis
| Forehead | All White infants w/ high TcB readings | 76 | | | 0.768 | μmol/l | TcB
| | Subgroups:
| | Term AGA | 37 | | | 0.802
| | Preterm or SGA | 39 | | | 0.702
| For white term AGA infants with TcB ≥ 18, PPV (predicting SB > 14 mg/dl) was 63%.
| For white preterm (34–37 weeks) or SGA infants with TcB ≥ 16, PPV (predicting SB > 14 mg/dl) was 94%.
| No false negative reading was found.
Taha, 1984 [#85070990] | Accuracy of transcutaneous measurements:
| Measure site | Population | (N) | Linear Regression Analysis
| | | | Slope | Intercept | r | TSB units | Y Axis
| Forehead | Saudi term infants | 68 | 0.909 | 10.78 | 0.878 | mg/dl | TcB
| At forehead, the sensitivity, specificity, PPV, and NPV (TcB > 22.5 in predicting SB ≥ 12.9 mg/dl) was 69%, 92%, 58%, and 95%, respectively.
Tan, 1985 [#86101839] | Accuracy of transcutaneous measurements:
Tan, 1982 [#83044572] | Measure site | Population | TcB (N) | Linear Regression Analysis
| | | | Slope | Intercept | r | TSB units | Y Axis
| Forehead | Chinese infants | 102 | 0.0576 | 7.3952 | 0.9327 | μmol/l | TcB
| | Malay infants | 103 | 0.0560 | 8.0855 | 0.8724
| Sternum | Chinese infants | 69 | 0.0614 | 6.9578 | 0.9371
| | Malay infants | 103 | 0.0598 | 7.8576 | 0.8984
| Upper Back | Chinese infants | 53 | 0.0408 | 8.2877 | 0.8612
| | Malay infants | 97 | 0.0450 | 9.0502 | 0.8666
Tan, 1996 [#97017283] | Accuracy of transcutaneous measurements:
| Measure site | Population | (N) | Linear Regression Analysis
| | | | Slope | Intercept | r | TSB units | Y Axis
| Sternum | Chinese infants | 253 | 0.04 | 10.08 | 0.78 | μmol/l | TcB
| | Malay infants | 169 | 0.06 | 8.05 | 0.87
| | Indian infants | 120 | 0.05 | 1047 | 0.83
| | Combined | 542 | 0.04 | 9.81 | 0.80
| Forehead | Chinese infants | 253 | 0.04 | 10.5 | 0.73
| | Malay infants | 169 | 0.06 | 8.60 | 0.84
| | Indian infants | 120 | 0.05 | 10.65 | 0.81
| | Combined | 542 | 0.04 | 10.29 | 0.75
Tsai, 1988 [#90177720] | Accuracy of transcutaneous measurements:
| Measure site | Population | TcB (N) | Linear Regression Analysis
| | | | Slope | Intercept | r | TSB units | Y Axis
| Forehead | Chinese FT infants | 178 | 0.87 | 5.53 | 0.87 | mg/dl | TcB
| Cheek | | | 0.73 | 6.82 | 0.76
| Sternum | | | 0.70 | 7.02 | 0.78
| Abdomen | | | 0.68 | 6.69 | 0.76
| Upper back | | | 0.58 | 6.76 | 0.69
| Lower back | | | 0.58 | 6.13 | 0.65
| Palm | | | 0.28 | 5.31 | 0.49
| Sole | | | 0.29 | 4.15 | 0.47
| Also reported correlation between jaundiced meter index at forehead and serum bilirubin concentration from 2 to 7 days of age. It was found that the correlation coefficients were significant and were compatible on different postnatal days.
| At forehead, the sensitivity, specificity, PPV, and NPV (TcB > 16 in predicting SB ≥ 13 mg/dl) was 90%, 90%, 54%, and 99%, respectively
| The authors concluded that the correlation of JMI to TSB should be assessed for each instrument in each institution before clinical application or action.
Yamauchi, 1989 [#89348834] | Accuracy of transcutaneous measurements:
| Measure site | Population | TcB (N) | Linear Regression Analysis
| | | | Slope | Intercept | r | TSB units | Y Axis
| Forehead | Japanese term breastfed infants | 192 | 0.86 | 6.96 | 0.902 | mg/dl | TSB
| Chest | | | 0.83 | 5.95 | 0.915
| Sternum | | | 0.87 | 6.19 | 0.922
| 95% CI for the regression equation was ±2.98 mg/dl at forehead, ±2.79 mg/dl at chest, and ±2.67 mg/dl at sternum
Yamauchi, 1990 [#90273849] | For healthy, FT Japanese infants (N=78), the sensitivity, specificity, PPV, and NPV (TcB reading at 24 hrs of life ≥ 14 in predicting SB ≥ 15 mg/dl on 6 days of life) was 77%, 63%, 45%, and 88%, respectively.
| For healthy, FT Japanese infants (N=78), the sensitivity, specificity, PPV, and NPV (TcB reading on 3 days of life ≥ 21 in predicting SB ≥ 15 mg/dl on 6 days of life) was 91%, 84%, 69%, and 96%, respectively.
| The prevalence of hyperbilirubinemia (SB ≥ 15 on day 6 of life) was 28.2%.
| 44 (46%) subjects had the difference in TcB reading from birth to 24 hours of life pre unit of BW (kg), TcB24-TcB0/BW, more than 1.7. The sensitivity, specificity, PPV, and NPV (TcB24-TcB0/BW ≥ 1.7 in predicting SB ≥ 15 mg/dl on 6 days of life) was 91%, 57%, 45%, and 94%, respectively.
Yamauchi, 1991 [#92188736] | Accuracy of transcutaneous measurements:
| Measure site | Population | TcB (N) | Linear Regression Analysis
| | | | Slope | Intercept | r | TSB units | Y Axis
| Forehead | Japanese infants, day 1–5, Group I | 28 | 0.65 | 1.77 | 0.812 | mg/dl | TSB
| | Japanese infants, day 6–7, Group I | 53 | 0.79 | 5.0 | 0.937
| Sternum | Japanese infants, day 1–5, Group I | 28 | 0.81 | 5.46 | 0.892
| | Japanese infants, day 6–7, Group I | 53 | 0.76 | 4.07 | 0.904
| Forehead | Japanese infants, day 1–5, Group II | 53 | 0.92 | 8.86 | 0.901
| | Japanese infants, day 6–7, Group II | 52 | 0.83 | 6.32 | 0.903
| Sternum | Japanese infants, day 1–5, Group II | 53 | 0.83 | 6.56 | 0.888
| | Japanese infants, day 6–7, Group II | 52 | 0.88 | 6.88 | 0.926
| TcB readings are affected by daylight at the forehead. Sternum readings are not affected. The poor correlation at forehead improved within 24 hours of exposure to shaded sunlight on the forehead.
Yamauchi, 1991 [#92188737] | Accuracy of transcutaneous measurements:
| Measure site | Population | TcB (N) | Linear Regression Analysis
| | | | Slope | Intercept | r | TSB units | Y Axis
Yamauchi, 1988 [#89086035] | Forehead | Healthy FT Japanese infants, days 0–3 | 68 | 0.79 | 5.98 | 0.922 | mg/dl | TSB
| Chest | | | 0.69 | 3.84 | 0.915
| Sternum | | | 0.69 | 3.49 | 0.905
| F+C+S / 3 | | | 0.74 | 4.81 | 0.927
| F+C / 2 | | | 0.75 | 5.25 | 0.931
| F+S / 2 | | | 0.76 | 5.13 | 0.927
| C+S /2 | | | 0.69 | 3.76 | 0.913
| Max (F, C, S) | | | 0.72 | 5.04 | 0.919
| Forehead | Healthy FT Japanese infants, days 4–5 | 159 | 0.77 | 4.49 | 0.814 | mg/dl | TSB
| Chest | | | 0.87 | 7.31 | 0.868
| Sternum | | | 0.90 | 7.18 | 0.856
| F+C+S / 3 | | | 0.91 | 7.75 | 0.875
| F+C / 2 | | | 0.88 | 7.24 | 0.869
| F+S / 2 | | | 0.89 | 7.20 | 0.864
| C+S /2 | | | 0.90 | 7.62 | 0.870
| Max (F, C, S) | | | 0.87 | 7.66 | 0.865
| Forehead | Healthy FT Japanese infants, days 6–12 | 349 | 0.84 | 5.86 | 0.930 | mg/dl | TSB
| Chest | | | 0.82 | 5.84 | 0.936
| Sternum | | | 0.86 | 6.18 | 0.941
| F+C+S / 3 | | | 0.86 | 6.36 | 0.946
| F+C / 2 | | | 0.85 | 6.23 | 0.942
| F+S / 2 | | | 0.87 | 6.45 | 0.946
| C+S /2 | | | 0.85 | 6.14 | 0.942
| Max (F, C, S) | | | 0.84 | 6.48 | 0.940
| Forehead | Healthy FT Japanese infants, days 0–12 | 576 | 0.826 | 5.798 | 0.910 | mg/dl | TSB
| Chest | | | 0.816 | 5.857 | 0.922
| Sternum | | | 0.850 | 6.041 | 0.922
| Abdomen | | | 0.895 | 5.008 | 0.890
| Upper Back | | | 0.943 | 6.412 | 0.888
| Lower Back | | | 1.017 | 6.079 | 0.883
| Sole | | | 1.252 | 2.558 | 0.771
| Heel | | | 1.182 | 1.897 | 0.763
| F+C+S / 3 | | | 0.852 | 6.403 | 0.930
| F+C / 2 | | | 0.842 | 6.325 | 0.928
| F+S / 2 | | | 0.862 | 6.469 | 0.929
| C+S /2 | | | 0.839 | 6.094 | 0.926
| Max (F, C, S) | | | 0.830 | 6.504 | 0.924
| Most reliable site of measurement of TcB changed from forehead to the sternum with advancing age. The author recommended: Forehead Days 0–3, Chest Days 4–5, Sternum Days 6 and after, or combined use of forehead, chest and sternum.

Evidence Table 5.1. Question 5 - Studies evaluating the accuracy of AirShields Minolta bilirubinometer - Part IV

Author, Year | Biases or Limitations | Comments
Bhat, 1987 [#88085341] | Large amount of data is missing | No data on funding source
| Method not clearly reported | Internal validity: C
| No data on test performance
Bhutta, 1991 [#92015688] | None stated | No data on funding source
| | Internal validity: A
Bilgen, 1998 [#99123665] | None noted | No data on funding source
| | Internal validity: A
Boo, 1984 [#85085660] | Not very clear on reporting of test performance data | No data on funding source
| | Internal validity: B
Bourchier, 1987 [#88247126] | Subjects' demographic data was not given | No data on funding source
| No test performance data | Internal validity: B
| Majority of subjects are with TcB ≥ 17
Carbonell, 2001 [#21130776] | None noted | No data on funding source
*Also in Evidence Table 4 | | Internal validity: A
Christo, 1988 [#89253855] | Subjects' details were missing | No data on funding source
| | Internal validity: B
Dai, 1996 [#97093944] | Missing large amount of data | No data on funding source
| | Test performance data on TcB in predicting hyperbilirubinemia was extracted from the graph (Figure 2).
| | Internal validity: C
Fok, 1986 [#86268743] | Incomplete report on test performance data | No data on funding source
| | The sensitivity at sternum reported in the text (100%) was incorrect.
| | Internal validity: B
Goldman, 1982 [#82241425] | Inadequate data presentation | No data on funding source
| Fuzzy group specifications | Internal validity: C
Hanneman, 1982 [#82105249] | Few patients with bilirubin > 12 were evaluated | No data on funding source
| No test performance data | Internal validity: B
Harisk, 1998 [#98373176] | No data on subjects' gender and breastfed proportion | No data on funding source
| | Internal validity: B
Hegyi, 1981 [#81144434] | Methods not clearly described | No data on funding source
| Slope or intercept not reported | Internal validity: B
Karrar, 1989 [#89271698] | None stated | Study was government funded
| | Internal validity: A
Kenny, 1984 [#89271698] | Incomplete data reporting | No data on funding source
| No test performance data | The discussion is worth reading, talking about error in serum bilirubin measurements
| | Internal validity: B
Kivlaha, 1984 [#84296964] | No test performance data | Study was privately funded
| Used sample of babies who were in ICU to standardize the instrument | For current review, we only took part of the whole study (defining natural causes of neonatal jaundice by feeding types)
| Sample's demographic data was not given | Internal validity: B
Knudsen, 1989 [#89189829]Knudsen, 1990 [#90242782] | No test performance data | Study was hospital funded
| Babies' gender was not given | Internal validity: B
Knudsen, 1990 [#91196560] | Only visibly jaundiced infants were tested | Study was hospital funded
| | Internal validity: A
Knudsen, 1992 [#92306741] | Inclusion and exclusion criteria were not clear | Study was hospital funded
*also in Evidence Table 4 | | ROC curves were given
| | Internal validity: A
Knudsen, 1993 [#93333142] | Confusing “Study” and “Control” group | No data on funding source
| No test performance data for “Control” group | Internal validity: B
Knudsen, 1995 [#93333142] | No description of method used to “correct” TcB reading | No data on funding source
| Confusing presentation of test performance data | ROC curve was reported
| | Internal validity: B
Kumar, 1992 [#93084314] | No test performance data | No data on funding source
| | Internal validity: B
Laeeq, 1993 [#93267865] | Only mean (calculated) values were reported | No data on funding source
| Regression Equation not explicitly stated | Internal validity: B
| R square reported as R in the article
Lin, 1993 [#93383693] | None stated | No data on funding source
| | ROC curve for each site was provided
| | Internal validity: A
Linder, 1994 [#94325008] | Convenience graph | No data on funding source
| Incomplete data reporting | Internal validity: B
Maisels, 1982 [#82273864] | No explanation of why only 135 measurements were done at mid-sternum | No data on funding source
| Subjects' demographic details were missing | Internal validity: B
Maisels, 1997 [#97247177] | Subjects' demographic details are limited | No data on funding source
| No test performance data | Internal validity: B
Schumacher, 1985 [#85241873] | None noted | No data on funding source
| | Internal validity: A
Serrao, 1989 [#85241873] | No test performance data | No data on funding source
| | Internal validity: B
Sharma, 1988 [#89122266] | Didn't discuss if subjects were ill or not | No data on funding source
| Didn't discuss measuring timing (age at test just broad range) | Internal validity: B
| No test performance data
Sheridan-Pereira, 1982 [#83021365] | Inconsistent data reporting and missing data | No data on funding source
| | Internal validity: C
Smith, 1985 [#85112373] | Incomplete data reporting | Study was government funded
| No outline of how SB was measured | Internal validity: B
Suckling, 1995 [#95327901] | No graph of correlation | Study was government funded
| No description of subjects' demographic data | Internal validity: C
| No details of test performance
| Only infants with high TcB (≥18 for term AGA, or (≥16 for preterm or SGA) were included
| Table II was unclear
Taha, 1984 [#85070990] | Test performance was based on TcB measurements, not patients | No data on funding source
| “Term and healthy” were not defined | Internal validity: B
| Typo error in the text and tables
Tan, 1985 [#86101839] Tan, 1982 [#83044572] | Incomplete data reported | No data on funding source
| No test performance data | Internal validity: B
Tan, 1996 [#97017283] | No test performance data | No data on funding source
| Study limited to mainly bilirubin < 14.6 mg/dl | Internal validity: B
Tsai, 1988 [#90177720] | None stated | No data on funding source
| | Internal validity: A
Yamauchi, 1989 [#89348834] | No test performance data | No data on funding source
| Referred to previous studies done | Internal validity: B
Yamauchi, 1990 [#90273849] | None stated | No data on funding source
| | Internal validity: A
Yamauchi, 1991 [#92188736] | No test performance data | No data on funding source
| | Internal validity: A
Yamauchi, 1991 [#92188737] Yamauchi, 1988 [#89086035] | No test performance data | No data on funding source
| | Internal validity: A

Evidence Table 5.2. Question 5 - Studies evaluating the accuracy of BiliCheck™ - Part I

Author, Year | Demographics | Inclusion Criteria | Exclusion criteria | Study Design
Bhutani, 2000 [#20381429] | Location: US | Near-term (GA≥36 wks or BW≥2000 g) or (GA=35 wks and BW≥2500 g) and term infants | Loss of serum samples during transport (11) | Prospective cross-sectional study
| Setting: Hospital | No sepsis, heart or circulatory disease, respiratory distress, or hemoglobinopathy | Loss or corruption of spectral data (3)
| Study period: 3/1998 to 10/1998 | Data before PhotoRx No exchange transfusion | Not meeting inclusion criteria (16)
| Mean GA (range): 38.9±1.5 wk
| Mean age at measurement: 24–72 hrs
| Mean BW (range): 3404±518 g
| Mean Apgar score at 1 min: ND
| Breastfed proportion: ND
| Male: ND
| Race: 59% White, 29% Black, 3% Hispanic, 4% Asian, 3% Other
| Enrolled subjects: 517
| Evaluated subjects: 490
| Evaluated TcB & SB pairs: 1788
| Number of centers: 2
Lodha, 2000 [#20368382] | Location: India | Term infants aged 2 to 7 days Icterus > 8 mg/dl | Receiving PhotoRx or exchange transfusion | Prospective cross-sectional study
| Setting: Hospital | Non-hemolytic jaundice
| Study period: ND
| Mean GA (range): 38.4±1.2 wk
| Mean age at measurement: 71.8±27 hrs
| Mean BW (range): 2870±330 g
| Mean Apgar score at 1 min: ND
| Breastfed proportion: ND
| Male: ND
| Race: 100% Indian
| Enrolled subjects: 109
| Evaluated subjects: 109
| Evaluated TcB & SB pairs: 121
| Number of centers: ND
Rubaltelli, 2001 [#21283339] | Location: Europe | Age < 28 days old | Known skin disorders | Prospective cross-sectional study
| Setting: Hospital | GA > 30 weeks | PhotoRx or exchange transfusion
| Study period: ND
| Mean GA (range): 20% ≤ 36 wk
| Mean age at measurement: 16% <48 hrs, 24% 48–72 hrs, 35% 72–95 hrs; 24% ≥ 96 hrs
| Mean BW (range): 16% <2500 g
| Mean Apgar score at 1 min: ND
| Breastfed proportion: ND
| Male: ND
| Race: 67% White, 4% African, 7% Hispanic, 15% Asian; 7% Others
| Enrolled subjects: 210 (35 from each center)
| Evaluated subjects: 210
| Evaluated TcB & SB pairs: ND
| Number of centers: 6

Evidence Table 5.2. Question 5 - Studies evaluating the accuracy of BiliCheck™ - Part II

Author, Year | Population (N) Subjects' Clinical Details | TcB Measurement Protocol | Definition of True Positive | Reference Standard
Bhutani, 2000 [#20381429] | Near-term and term infants (490) | Measurement tools: "BiliCheck " multi-wavelength Spectral Reflectance (MWSR) device. | TcB ≥ 75^th^%tile in predicting TSB > 95^th^%tile | Laboratory-based assay of TSB: High-pressure liquid chromatography (HPLC)
| No sepsis, heart or circulatory disease, respiratory distress, or hemoglobinopathy | Procedures: 2–4 measurements per patient. 11 different devices were used. Intradevice precision was determined.
Lodha, 2000 [#20368382] | North term Indian newborns (109) | Measurement tools: "BiliCheck " multi-wavelength Spectral Reflectance (MWSR) device. | TcB > 13, >15, and ≥ 18 mg/dl, in predicting SB > 13, >15, and ≥ 18 mg/dl, respectively | Laboratory-based assay of TSB: twin beam Microbilimeter (Ginevri Technologie Biomediche)
| Non-hemolytic jaundice | Procedures: at forehead
| TcB reading (range): 4.5–21.7
Rubaltelli, 2001 [#21283339] | Mixed-race term + preterm infants (210) | Measurement tools: "BiliCheck " multi-wavelength Spectral | TcB cutoff points in predicting HPLC >17, >15, or >13 mg/dl | Laboratory-based assay of TSB: High-pressure liquid chromatography (HPLC)
| | Procedures: ≥ 1 readings at forehead and ≥ 1 readings on the sternum.

Evidence Table 5.2. Question 5 - Studies evaluating the accuracy of BiliCheck™ - Part III

Author, Year | Results
Bhutani, 2000 [#20381429] | Accuracy of transcutaneous measurements:
| Measure site | Population | TcB (N) | Linear Regression Analysis
| | | | Slope | Intercept | r | TSB units | Y Axis
| ND | All newborns | 1788 | 0.84 | 0.75 | 0.91 | mg/dl | TcB
| | Subgroups:
| | White infants | 1075 | 0.852 | 0.753 | 0.907
| | Black infants | 508 | 0.810 | 0.896 | 0.912
| | Hispanic infants | 63 | 0.848 | 0.315 | 0.932
| | Asian+Other infants | 142 | 0.855 | 0.399 | 0.897
| | Near-term infants | 163 | 0.848 | 1.145 | 0.898
| | Term infants | 1625 | 0.836 | 0.750 | 0.912
| For near-term and term infants (N=419), the sensitivity, specificity, PPV, and NPV (TcB ≥ 75^th^ %tile at 24–72 hrs of age in predicting SB >95^th^ %tile) was 100%, 88%, 33%, and 100%, respectively. The likelihood ratio was 8.43.
| All infants with TSB < 40^th^ %tile also had Bilicheck Tcb < 40^th^ %tile
| Of 419 infants selected for 24 to 72 hours predischarge risk assessment, 5.7% were in high risk zone (>95^th^ %tile), 50.5% were in intermediate risk zone, and 43.8% were in low-risk zone (<40^th^ %tile)
Lodha, 2000 [#20368382] | Accuracy of transcutaneous measurements:
| Measure site | Population | (N) | Linear Regression Analysis
| | | | Slope | Intercept | r | TSB units | Y Axis
| Forehead | North Indian term infants | 109 | | | 0.833 | mg/dl | TcB
| | Subgroups:
| | TSB > 13 mg/dl | 46 | | | 0.64
| For Indian non-hemolytic jaundiced infants (N=109), the sensitivity and specificity was 69% and 89% (TcB > 13 in predicting TSB > 13 mg/dl), 47% and 99% (TcB > 15 in predicting TSB > 15 mg/dl); and, 20% and 100% (TcB ≥ 18 in predicting TSB ≥ 18 mg/dl).
| For the clinical assessment of jaundice by pediatrician, the sensitivity and specificity was 52% and 89% in predicting TSB > 13 mg/dl; and, 53% and 98% in predicting TSB > 15 mg/dl. Clinical judgement can't differentiate in TSB ≥ 18 mg/dl group.
Rubaltelli, 2001 [#21283339] | Accuracy of transcutaneous measurements:
| Measure site | Population | (N) | Linear Regression Analysis
| | | | Slope | Intercept | r | TSB units | Y Axis
| Forehead | Mixed-race Term + | 210 | 1.07 | 0.17 | 0.89 | mg/dl | HPLC
| Sternum | Preterm infants | | 1.04 | -0.59 | 0.881
| Forehead | Mixed-race Term + | 210 | 0.89 | 1.36 | 0.87 | mg/dl | TSB*
| Sternum | Preterm infants | | 0.86 | 0.89 | 0.848
| *TSB: from 6 different labs in each center
| Correlation between HPLC with Lab TSB was y=1.086x-0.17 (r=0.927, y=HPLC, x=TSB).
| In predicting HPLC SB ≥ 17 mg/dl:
| The sensitivity, specificity, PPV, and NPV was 50%, 99%, and 88%, and 92% respectively, when TcB > 17 was used as the cutoff point.
| The sensitivity, specificity, PPV, and NPV was 63%, 96%, and 73%, and 74% respectively, when TcB > 16 was used as the cutoff point.
| The sensitivity, specificity, PPV, and NPV was 77%, 91%, and 59%, and 96% respectively, when TcB > 15 was used as the cutoff point.
| The sensitivity, specificity, PPV, and NPV was 90%, 87%, and 53%, and 98% respectively, when TcB > 14 was used as the cutoff point.
| In predicting HPLC SB ≥ 15 mg/dl:
| The sensitivity, specificity, PPV, and NPV was 52%, 95%, and 82%, and 82% respectively, when TcB > 15 was used as the cutoff point.
| The sensitivity, specificity, PPV, and NPV was 63%, 92%, and 76%, and 86% respectively, when TcB > 14 was used as the cutoff point.
| The sensitivity, specificity, PPV, and NPV was 81%, 82%, and 66%, and 91% respectively, when TcB > 13 was used as the cutoff point.
| The sensitivity, specificity, PPV, and NPV was 92%, 71%, and 57%, and 95% respectively, when TcB > 12 was used as the cutoff point.
| In predicting HPLC SB ≥ 13 mg/dl:
| The sensitivity, specificity, PPV, and NPV was 66%, 89%, and 84%, and 75% respectively, when TcB > 13 was used as the cutoff point.
| The sensitivity, specificity, PPV, and NPV was 86%, 85%, and 83%, and 87% respectively, when TcB > 12 was used as the cutoff point.
| The sensitivity, specificity, PPV, and NPV was 93%, 73%, and 75%, and 92% respectively, when TcB > 11 was used as the cutoff point.
| The sensitivity, specificity, PPV, and NPV was 97%, 64%, and 70%, and 96% respectively, when TcB > 10 was used as the cutoff point.
| When the HPLC was set at 17 mg/dl, use of a cutoff point of 14 mg/dl produced similar sensitivity and specificity for TcB and for the Lab TSB.
| The variability of the difference between TcB and Lab TSB when compared with HPLC was less than 20%.
| However, the clinical importance of the 0.3 mg/dl difference between TcB (SD=2.22 mg/dl) and Lab TSB (SD=1.84 mg/dl) was found.

Evidence Table 5.2 . Question 5 - Studies evaluating the accuracy of BiliCheck™ - Part IV

Author, Year | Biases or Limitations | Comments
Bhutani, 2000 [#20381429] | Measurement site was not given | No data on funding source
| | Internal validity: A
Lodha, 2000 [#20368382] | None stated | No data on funding source
| | Instruments were provided by marketing company
| | This transcutaneous method is the multi-wavelength spectral reflectance method
| | Internal validity: A
Rubaltelli, 2001 [#21283339] | This multiple center study was intended to evaluate the pooled performance of multiple TcB devices in a diverse international population, with multiple users, and to compare the performance with multiple laboratory methods. | No data on funding source
| | ROC curve for HPLC >13, >15, and >17 mg/dl were reported
| | Internal validity: A

Evidence Table 5.3 . Question 5 - Studies evaluating the accuracy of Ingram Icterometer - Part I

Author, Year | Demographics | Inclusion Criteria | Exclusion criteria | Study Design
Chaibva, 1974[#75018763] | Location: US | Unselected Black infants who were clinically jaundiced | ND | Prospective cross- sectional study
| Setting: Hospital
| Study period: 11/1973 to 12/1973
| Mean GA (range): ND
| Mean age at measurement: 2 to 24 d
| Mean BW (range): 1050–3925 g
| Mean Apgar score at 1 min: ND
| Breastfed proportion: ND
| Male: ND
| Race: 100% Black
| Enrolled subjects: 55
| Evaluated subjects: 55
| Evaluated Ict measures: 125
| Number of centers: 1
Gupta, 1991[#92091059] | Location: India | Not clear | ND | Prospective cross- sectional study
| Setting: Hospital | For current review, only infants GA ≥ 35 weeks were included
| Study period: 9/89 to 1/90
| Mean GA (range): 35–42 wk
| Mean age at measurement: ND
| Mean BW (range):
| Term: 2.69±0.37kg
| Preterm: 1.85±0.22 Kg
| Mean Apgar score at 1 min: ND
| Breastfed proportion: ND
| Male: ND
| Race: ND
| Enrolled subjects: 161
| Evaluated subjects: 88
| Evaluated Ict measures: ND
| Number of centers: 1

Evidence Table 5.3. Question 5 - Studies evaluating the accuracy of Ingram Icterometer - Part II

Author, Year | Population (N) Subjects' Clinical Details | TcB Measurement Protocol | Definition of True Positive | Reference Standard
Chaibva, 1974 [#75018763] | Black jaundiced infants (55) | Measurement tools: Icterometer | N/A | Laboratory-based assay of TSB: AO Unistat Bilirubinometer (American Optical, USA)
| | Procedures: ND
Gupta, 1991 [#92091059] | Term infants (77) | Measurement tools: Ingram icterometer | Ict ≥ 3 in predicting SB ≥ 10 mg/dl | Laboratory-based assay of TSB: Type BM2-TOYO bilirubin analyzer
| Preterm infants GA 35–36 (11) | Procedures: on the tip of the nose as described by Gossett and Oxon.
| Term infants:
| Mean TSB: 9.95±2.86 mg/dl
| Mean Ict:10.00±2.89 mg/dl
| Preterm infants GA 35–36
| Mean TSB: 9.14±1.74 mg/dl
| Mean Ict: 8.24±1.83 mg/dl

Evidence Table 5.3. Question 5 - Studies evaluating the accuracy of Ingram Icterometer - Part III

Author, Year | Results
Chaibva, 1974 [#75018763] | Accuracy of Icterometer measurements:
| Measure site | Population | (N) | Linear Regression Analysis
| | | | Slope | Intercept | r | TSB units | Y Axis
| ND | Black infants | 55 | 3.6 | -0.4 | 0.96 | mg/dl | TSB
Gupta, 1991 [#92091059] | Accuracy of Icterometer measurements:
| Measure site | Population | (N) | Linear Regression Analysis
| | | | Slope | Intercept | r | TSB units | Y Axis
| Tip of nose | Term infants | 77 | | | 0.97
| | Preterm GA 35-36 wks | 11 | | | 0.97
| For Indian term infants w/o PhotoRx (N=77), the sensitivity, specificity, PPV, and NPV (Ict ≥ 3 in predicting SB >10 mg/dl) was 97%, 71%, 78%, and 94%, respectively.
| For Indian preterm infants, GA 35-36 wks, w/o PhotoRx (N=11), the sensitivity, specificity, PPV, and NPV (Ict ≥ 3 in predicting SB >10 mg/dl) was 50%, 86%, 67%, and 75%, respectively.

Evidence Table 5.3. Question 5 - Studies evaluating the accuracy of Ingram Icterometer - Part IV

Author, Year | Biases or Limitations | Comments
Chaibva, 1974 [#75018763] | Incomplete methods | No data on funding source
| Only “jaundiced” black infants selected | Mean, SD for each Icterometer grade provided in table
| Perhaps mixed some preemies | Internal validity: B
Gupta, 1991 [#92091059] | No race (assuming Indian), gender, feeding method described | No data on funding source
| No actual curve or regression equation given | Internal validity: B

Evidence Table 5.4. Question 5 - Studies evaluating the accuracy of Colormate III - Part I

Author, Year | Demographics | Inclusion Criteria | Exclusion criteria | Study Design
Tayaba, 1998 [#98393764] | Location: US | Sequentially enrolled infants from well nursery and NICU (n=2441) who then went on to need TSB (n=900) | Medical condition excluded handling | Prospective cross-sectional study
| Setting: Hospital | | Family psychosocial barrier
| Study period: 11/1988 to 7/1997 | | Family refused
| Mean GA (range): “term and preterm”
| Mean age at measurement: first measure at 11.9 hr (SD=+0.9; range 1–30 hr) repeated every 6 to 8 hrs until discharge
| Mean BW(range): 3135 g (SD=+612). 53/900 weighed<2000g 11/900 weighed <1500g
| Mean Apgar score at 1 min:ND
| Breastfed proportion: ND
| Male: 455/900
| Race: 72 African American;110 Caucasian; 615 Hispanic;103 Asian
| Enrolled subjects:2441
| Evaluated subjects: 900 had TSB
| Evaluated TcB measures:1600
| Number of centers:2
| Phototherapy: 61/900

Evidence Table 5.4. Question 5 - Studies evaluating the accuracy of Colormate III - Part II

Author, Year | Population (N) Subjects' Clinical Details | TcB Measurement Protocol | Definition of True Positive | Reference Standard
Tayaba, 1998 [#98393764] | 900 term and preterm infants | Measurement tool: | N/A | Laboratory based assay of TSB:
| Range of TSB that had concurrent TcB: 0.2 mg/dl to 21 mg/dl | Chromatics Colormate III | | Beckman CX7 (Beckman Instruments, Buffalo NY)
| TcB reading done on average within 40-min (SD+31) | Procedures: computer algorithm within device incorporates underlying color of normal skin and baseline evaluation and every 6–8 hrs until discharge | | IL Monarch (Instrumentation Laboratory Company, Lexington MA) Bayer Chem-1 (Technicon Instruments Corp. Tarrytown, NY)
| Clinicians ordered TSB measurements when clinically felt indicated; blinded to TcB results | TcB measure made on 3 of 4 sites: right or left cheek, back, forehead, chest and same sites used in subsequent measurements | | Coefficient of variation for lab measures between 3% and 6%
| | Protocol included color tile calibration of machine

Evidence Table 5.4. Question 5 - Studies evaluating the accuracy of Colormate III - Part III

Author, Year | Results
Tayaba 1997 [#98393764] | Accuracy of Colormate III measurements:
| Measure site | Population | TcB (N) | Linear Regression Analysis
| | | | Slope | Intercept | r | TSB units | Y Axis
| | All newborns (N=900) | 1600 | 0.986 | -0.0504 | 0.9563 | mg/dl | TcB
| | Subgroups:
| | White | 110 | | | 0.94
| | Black | 72 | | | 0.92
| | Hispanic | 615 | | | 0.94
| | Asian | 103 | | | 0.94
| | Phototherapy (N=61) | 284 | | | 0.921
| Visual estimation of jaundice and TSB n=1470 measurements in 851 patients y=1.8636 + 0.8157x ; r=0.7475
| Reproducibility evaluation in 2 separate studies:
| 5 repeated measurements of a standardized color tile by 3 different operators: coefficient of variation (COV)for the luminosity measurement was 0.019%.
| 3 different operators made sequential measurement over 30 minutes in seven infants, COV for TcB was 3.1% around mean TSB of 8.4 mg/dl.

Evidence Table 5.4. Question 5 - Studies evaluating the accuracy of Colormate III - Part IV

Author, Year | Biases or Limitations | Comments
Tayaba 1997 [#98393764] | None stated | No data on funding source
| No test performance data | Internal validity: B

Evidence Table 6.1. Clinical Data on Term Newborns with Idiopathic Jaundice Who Had Kernicterus Part I

Case ID | Year of Birth | Race | SEX | GA (wk) | BW (g) | Apgar 1′, 5′, 10′ | Blood Type | | Coombs/Sepsis | Feeding | Age at Disch. | Max Wt Loss (%) | TSB when dx of KI | Peak TSB (mg/dl)
| | | | | | | MOM | BABY
Boon13 From Boon, 1957 | 1955 | Chinese | F | Full term | 2324 | ? | No evidence of iso-immunization (Coombs test negative, ABO compatible, no Rh incompatibility) No Sepsis. | | | ? | ? | ? | ? | 43
Boon23 From Boon, 1957 | 1955 | Malay | F | Full term | 3289 | ? | | | | ? | ? | ? | ? | 54
Boon24 From Boon, 1957 | 1955 | Chinese | F | Full term | 3357 | ? | | | | ? | ? | ? | ? | 48
Boon25 From Boon, 1957 | 1955 | Chinese | F | Full term | 3289 | ? | | | | ? | ? | ? | ? | 23
Brow1 From Brown, 1968 | ? | Chinese | M | Full term | ? | ? | ABO compatible | | ? Anemia was noted | Formula | 10 days | ? | ? | 35.3
Ebbe2 From Ebbesen, 2000 | 1994 to 1998 | Palestinian | ? | 40 | 2640 | ? | ABO compatible | | G6PD (-) | Breast | ? | -9 | ? | 33.7
Ebbe6 From Ebbesen, 2000 | 1994 to 1998 | North European | M | 36 | 3440 | ? | ABO compatible | | G6PD not done | Breast | ? | -8 | ? | 35.6
Harr2 From Harris, 2001 | 1993 to 1996 | ? | ? | 38 | 3500 | ? | No hemolytic disease or sepsis G6PD(-) | | | Breast | 24 hours | 0 | ? | 30.6
Harr3 From Harris, 2001 | 1993 to 1996 | ? | ? | 40 | 2600 | ? | No hemolytic disease or sepsis | | | Breast | 24 hours | 0 | ? | 33.0
Harr4 From Harris, 2001 | 1993 to 1996 | ? | ? | 40 | 2400 | ? | No hemolytic disease or sepsis | | | Breast | 24 hours | +2 | ? | 34.8
Harr5 From Harris, 2001 | 1993 to 1996 | ? | ? | 40 | 3200 | ? | No hemolytic disease or sepsis | | | Breast | 48 hours | -7 | ? | 36.0
Harr6^‡^ From Harris, 2001 | 1993 to 1996 | ? | ? | 36 | 2800 | ? | No hemolytic disease or sepsis G6PD(-) | | | Breast | 36 hours | -18 | ? | 36.9
JohnL1^‡^ From Johnson, 1991 | ? | ? | ? | term | 3742 | ? | ABO compatible | | Coombs (-) G6PD (-) No sepsis | Breast | 4 days | -12 | 27 | 27
JohnL2 From Johnson, 1991 | ? | ? | ? | term | ? | ? | ABO compatible | | Coombs (-) G6PD (-) No sepsis | Breast | 1 day | ? | 44 | 44
JohnL4 From Johnson, 1991 | ? | ? | ? | term | ? | ? | ABO compatible | | Coombs (-) G6PD (-) No sepsis | Breast | 1 day | ? | 30 | 30
JohnL5 From Johnson, 1991 | ? | ? | ? | term | 3785 | ? | ABO compatible | | G6PD(-) No sepsis | Breast | 13 hours | ? | 45.0 | 45.0
JohnL7 From Johnson, 1991 | ? | ? | ? | 36/37 | 2700 | ? | ABO compatible | | G6PD(-) No sepsis | Breast | 2 days | -3.7 | 32.0 | 32.0
JohnW2 From Johnson, 1967 | 1957 to 1958 | ? | M | Full term | 3274 | ? | ABO compatible | | G6PD(-) No sepsis | ? | ? | ? | 30.8 | 30.8
JohnW3 From Johnson, 1967 | 1957 to 1958 | ? | M | Full term | 3430 | ? | O+ | O+ | ? | ? | ? | ? | 29.7 | 29.7
Mais1 From Maisels, 1995 | 1979 | White | M | 37 | 2820 | 7,9 | O+ | O+ | Coombs (-) No sepsis | Breast | 75 hours | -11 | ? | 49.7
Mais2^‡^ From Maisels, 1995 | 1985 | Wht | M | 37 | 3771 | 8,9 | A+ | A+ | Coombs (-) | Breast | 3 days | -22 | ? | 39.0
Mais3 From Maisels, 1995 | 1989 | White | M | 39 | 4280 | 9,9 | O+ | O- | Coombs (-) G6PD(-) | Breast | 66 hrs | -1.3 | ? | 40.3
Mais4^‡^ From Maisels, 1995 | 1990 | White | F | 37 | 4026 | 4,6,8 | B+ | B+ | Coombs (-) | Breast | Born at home | -20 | ? | 44.7
Mais5 From Maisels, 1995 | 1991 | White | F | 38 | 3374 | 9,8 | O+ | O+ | Coombs (-) G6PD(-) | Breast | 36 hours | ? | ? | 44.7
Mais6^‡^ From Maisels, 1995 | 1987 | White | M | 37 | 3175 | 8,9 | A- | A- | Coombs (-) | Breast | 52 hours | -17.9 | ? | 41.4
Mala19^†^ From Malaka-Zafiriu, 1975 | ? | ? | ? | Full term | 3200 | ? | ABO compatible | | G6PD(-) Rh (-) | ? | ? | ? | ? | 22.5
Mala22^†^ From Malaka-Zafiriu, 1975 | ? | ? | ? | Full term | 4500 | ? | ABO compatible | | G6PD(-) Rh (-) | ? | ? | ? | ? | 25.7
Mala23^†^ From Malaka-Zafiriu, 1975 | ? | ? | ? | Full term | 3250 | ? | ABO compatible | | G6PD(-) Rh (-) | ? | ? | ? | ? | 29.0
Mmwr1^‡^ From CDC, 2001 | 1994 | White | M | 37 | 3090 | 8,9 | O+ | A+ | Coombs (-) | Br | 20 hours | -17.4 | 41.5 | 41.5
Mmwr2 From CDC, 2001 | 1995 | White | M | 37 | 2863 | 8,9 | ? | ? | ? | Br | 36 hours | ? | 34.6 | 34.6
Tay3 From Tay, 1984 | ? | Chinese | M | Full term | 2700 | ? | A+ | A+ | G6PD(-) Rh (-) | ? | ? | ? | ? | 26.4
Tay5 From Tay, 1984 | ? | Chinese | F | Full term | 3500 | ? | O+ | O+ | G6PD(-) Rh (-) | ? | ? | ? | ? | 28.8
Tay8 From Tay, 1984 | ? | Malay | M | Full term | 3150 | ? | ? | ? | G6PD(-) | ? | ? | ? | ? | 24.4
Wong1 From Wong, 1980 | ? | ? | ? | Full term | ? | ? | ? | ? | G6PD(-) | ? | 3^rd^ day | ? | 34 | 34
Yoko2 From Yokochi, 1995 | ? | ? | M | 38 | 3500 | ? | ? | ? | ? | ? | ? | ? | ? | 29.5

† Cases in table 3 of the original article. Males were preferred in the study.

‡ significant weight loss

? = no data / unknown; BET = blood exchange transfusion; CP = cerebral palsy; ≈ = approximately; PhotoRx = phototherapy; Dept = department; DD = developmental delay; G6PD = glucose-6-phosphate dedydrogenase deficiency; Rh = Rhesus incompatibility; MR = mental retardation; KI = kernicterus

Evidence Table 6.1. Clinical Data on Term Newborns with Idiopathic Jaundice Who Had Kernicterus Part II

Case ID | Age at Peak SB (d) | Rx for Jaundice (x times), or other condition | Diagnoses of KI and/or Follow-up Outcomes | Follow-up
Boon13 From Boon, 1957 | 7 | ? | Drowsiness admitted on the 7^th^ day. Died on the 8^th^ day. Necropsy found yellow staining in the brain nuclei. | 8 days
Boon23 From Boon, 1957 | 3 | ? | Muscular hypertonicity, admitted on the third day. | ?
Boon24 From Boon, 1957 | 8 | ? | Muscular hypertonicity, drowsiness, admitted on the 8^th^ day. Died on the 9^th^ day. Necropsy found yellow-staining in the brain nuclei. | 9 days
Boon25 From Boon, 1957 | 3 | ? | Drowsiness, admitted on the third day. Died on the 5^th^ day. Necropsy found yellow-staining in the brain nuclei | 5 days
Brow1 From Brown, 1968 | 13 | No BET | Definite signs of kernicterus (at readmission). Severe residual neurologic damage. | ?
Ebbe2 From Ebbesen, 2000 | 1 | BET | Lethargy, dehydrate, opisthotonus, hypertonia, apnea, cyanotic attack, tonic and clonic seizure (in the neonatal dept.) DD, hypertonia, hearing loss and gaze disturbance. Died 5 months old. | 5 months
Ebbe6 From Ebbesen, 2000 | ≈3 | PhotoRx, albumin infusion, BET | Lethargy, hypotonia, opisthotonus (in the neonatal dept.) DD, dystonic athetoid CP and squint (at follow-up) | 18 months
Harr2 From Harris, 2001 | 3 ~ 6 | PhotoRx BET × 1 | Lethargy, hypotonia, irritability, arching, ophisthotonus, ? seizure (at readmission) Resolution of clinical signs & DD normal (by 3 months) Development normal (at telephone follow-up) | 6 years
Harr3 From Harris, 2001 | 3 ~ 6 | PhotoRx | Lethargy, high pitched cry, hypertonia (at readmission) Resolution of clinical signs & DD normal (by 9 months) Development normal (at telephone follow-up) | 5 years
Harr4 From Harris, 2001 | 3 ~ 6 | PhotoRx BET × 1 | Lethargy, hypertonia (at readmission) Resolution of clinical signs & DD normal (by 12 months) Development normal (at telephone follow-up) | 4 years
Harr5 From Harris, 2001 | 3 ~ 6 | PhotoRx BET × 2 | Poor feeding (at readmission) Resolution of clinical signs & DD normal (by 12 months) Development normal (at telephone follow-up) | 3.5 years
Harr6^‡^ From Harris, 2001 | 3 ~ 6 | PhotoRx BET × 1 | Lethargy, poor feeding, high pitched cry, hypo/hypertonia, ophisthotonus, seizure (at readmission) MDI & PDI severely abnormal, hearing loss, ongoing seizure, hypertonic CP and blindness, MR | 6 years
JohnL1^‡^ From Johnson, 1991 | 12 | PhotoRx BET × 2 Antibiotic | Irritable, hypertonic, high-pitched cry (at readmission) Normal neurologic and physical exam on day 20. Across the board mental deficiency, not suggestive of kernicterus (at follow-up) | ?
JohnL2 From Johnson, 1991 | 4 | BET × 2 | BAER flat (at readmission) Mild unexplained anemia, BAER normal at 2 months. Neurologic and developmental exams were normal (at follow-up) | ?
JohnL4 From Johnson, 1991 | 7 | PhotoRx BET | BAER flat (at readmission) Developmental delay, tight hell cords. BAER flat (at follow-up) | ?
JohnL5 From Johnson, 1991 | 4 | BET | High pitched cry (at readmission) Classic signs of Kernicterus (at follow-up) | ?
JohnL7 From Johnson, 1991 | 8 | BET, antibiotics, Phenobarbital, and PhotoRx | Yellow eyes, decreased crying and feeding (at readmission) Central apneic spells controlled by theophylline, BAER flat, classic signs of KI, severe brain damage (at follow-up) | ?
JohnW2 From Johnson, 1967 | 5 | BET Streptomycin | Some periodic arching of his head (at readmission) Mild athetosis, MR (IQ=56; sibling's IQ=90), aphasia, and moderately severe hearing loss. | 5~6 years
JohnW3 From Johnson, 1967 | 2 | BET antibiotic | Head retraction, high-pitched shrill cry, incomplete moro reflex, and nystagmoid eye movements (at admission) Mild athetosis and moderately severe hearing loss. IQ was normal (at follow-up) | 5~6 years
Mais1 From Maisels, 1995 | 7 | BET × 2 | Poor feeding, irritability and jerk movements (at readmission) Opisthotonus, high-pitched cry, hypotonia and poor head control (after BET) Seizures, speech & lang. Delays, sig. motor delay, questionable choreoathetoid movements (at follow-up) | ?
Mais2‡ From Maisels, 1995 | 5 | ? | Lethargy, refusal to nurse, dehydrated (at readmission) Persistent tonic neck reflex, motor delay, choreoathetosis with hypo/hypertonia, severe DD and lang. delay (at follow-up) | 8 months
Mais3 From Maisels, 1995 | 10 | BET × 2 | Seizure and opisthotonic posturing (after BET) Severe sensorineural hearing loss, sig. motor delay (at follow-up) | ?
Mais4‡ From Maisels, 1995 | 7 | BET × 3 | Back arching, opisthotonic posturing, tonic extension of extremities, increased tone, weak cry, and lethargy (when admitted to hospital) No response to BAER at age 11 d, No long-term follow-up | 11 days
Mais5 From Maisels, 1995 | 4 | BET × 2 | Irritability and failure to nurse, high-pitched cry, increased extensor tone, seizures (at readmission) Severe sensorineural hearing loss, and motor delay (at follow-up) | 7.5 months
Mais6‡ From Maisels, 1995 | 6 | BET × 3 | High-pitched cry, increased tone and stiff neck, complete absence of BAER response (after BET) Mixed spastic-athetoid CP with severe dysarthria, dental dysplasia, initial hearing impairment which subsequently improved, severe motor delay (at follow-up) | 2.5 years
Mala19† From Malaka-Zafiriu, 1975 | ? TSB= 15.5 on 10^th^ day | BET | “Kernicterus” | 10 days
Mala22† From Malaka-Zafiriu, 1975 | ? TSB= 14.0 on 10^th^ day | BET × 2 | “Kernicterus” | 10 days
Mala23† From Malaka-Zafiriu, 1975 | ? TSB= 12.0 on 10^th^ day | BET | “Kernicterus” | 10 days
Mmwr1‡ From CDC, 2001 | 11 | PhotoRx BET × 2 | Lethargy, poor feeding , dehydrated (at readmission) Athetosis, oral-motor dysfunction, and dental dysplasia (on day 11) KI was diagnosed at age 6 months | 6 months
Mmwr2 From CDC, 2001 | 5 | PhotoRx | Lethargy and poor feeding (on day 4) Opisthotonus, high-pitched cry, and poor suckling(at readmission) Athetoid CP, hearing loss and gaze paresis (at follow-up) | 18 months
Tay3 From Tay, 1984 | ? | BET × 1 | “Kernicterus” | ?
Tay5 From Tay, 1984 | ? | BET × 3 | “Kernicterus” | ?
Tay8 From Tay, 1984 | ? | No BET | “Kernicterus” | ?
Wong1 From Wong, 1980 | 6 | BET × 1 | “Obvious KI”, mental and physical retardation | 6 days
Yoko2 From Yokochi, 1995 | ? | BET | Athetotic CP | 7 years

† Cases in table 3 of the original article. Males were preferred in the study.

‡ significant weight loss

? = no data / unknown; BET = blood exchange transfusion; CP = cerebral palsy; ≈ = approximately; PhotoRx = phototherapy; Dept = department; DD = developmental delay; G6PD = glucose-6-phosphate dedydrogenase deficiency; Rh = Rhesus incompatibility; MR = mental retardation; KI = kernicterus; dx = diagnosis/diagnoses

Evidence Table 6.2. Clinical Data on Term Newborns with Comorbid Factors Who Had Kernicterus Part I

Case ID | Year of Birth | Race | SEX | GA (wk) | BW (g) | Apgar 1′, 5′, 10′ | Blood Type | | Coombs/Sepsis | Feeding | Age at Disch. | Max Wt Loss (%) | TSB when dx of KI | Peak TSB (mg/dl)
| | | | | | | MOM | BABY
Boon1 From Boon, 1957 | 1955 | Chinese | F | Full term | 3175 | ? | No evidence of iso-immunization (Coombs negative, ABO compatible, no Rh incompatibility) | | Thrush | ? | ? | ? | ? | 32.5
Boon10 From Boon, 1957 | 1955 | Chinese | M | Full term | 3901 | ? | | | Of umbilicus | ? | ? | ? | ? | 35.6
Boon12 From Boon, 1957 | 1955 | Chinese | M | Full term | 3538 | ? | | | Of umbilicus | ? | ? | ? | ? | 28.8
Boon14 From Boon, 1957 | 1955 | Malay | F | Full term | 3175 | ? | | | Pharyngitis | ? | ? | ? | ? | 37
Boon15 From Boon, 1957 | 1955 | Chinese | F | Full term | 2858 | ? | | | Of umbilicus | ? | ? | ? | ? | 23
Boon20 From Boon, 1957 | 1955 | Chinese | F | Full term | 2722 | ? | | | Pharyngitis | ? | ? | ? | ? | 37.5
Boon26 From Boon, 1957 | 1955 | Chinese | M | Full term | 4082 | ? | | | Of umbilicus | ? | ? | ? | ? | 47.8
Brow2 From Brown, 1968 | ? | Chinese | F | Full term | ? | ? | ? | ? | G6PD (+) Moderate polychroma-tophilia and anisocytosis | Formula | 1 day | ? | 28 | 28
Ebbe1^‡^ From Ebbesen, 2000 | 1994 to 1998 | North European | ? | 37 | 3950 | ? | Possible A-O blood type immunization | | G6PD (-) | Breast | 3 | -20 | ? | 31.0
Ebbe3 From Ebbesen, 2000 | 1994 to 1998 | North European | ? | 37 | 2800 | ? | Possible A-O blood type immunization | | G6PD (-) | Breast | 1 | -2 | ? | 40.0
Ebbe4 From Ebbesen, 2000 | 1994 to 1998 | North European | ? | 41 | 4360 | ? | ? | ? | G6PD (-) Spherocyto-sis | Breast | 0.5 | -8 | ? | 40.5
Ebbe5^‡^ From Ebbesen, 2000 | 1994 to 1998 | North European | ? | 40 | 3950 | ? | ? | ? | G6PD (-) Galactose-mia | Breast | 1 | -13 | ? | 43.6
Gart4 From Gartner, 1970 | 1966 to 1967 | ? | ? | 36 | 1780 | 8 | RDS, acidosis, sclerema, pulmonary atelectasis, hemorrhage and pneumonia | | | ? | ? | ? | 2.0 on day 1 | 4.0
Gibb1 From Gibbs, 1979 | ? | ? | ? | Full term | ? | ? | Anti-a | | G6PD (+) | ? | ? | ? | ? | 43.9
| | | | | | | O | A
Gibb2 From Gibbs, 1979 | ? | ? | ? | Full term | ? | ? | ? | ? | G6PD (+) | ? | ? | ? | ? | ≈31
Gibb3 From Gibbs, 1979 | ? | ? | ? | Full term | ? | ? | ? | ? | G6PD (+) | ? | ? | ? | ? | ≈25
Hank1 From Hanko, 2001 | ? | African | M | 38 | 2900 | 9,9 | O+ | A- | Coombs (-) ?Sepsis (+) | Breast | ? TSB <23.4 mg/dl at 60 hours | -6 | ? | 38.0
Hank2 From Hanko, 2001 | ? | African | M | 42 | 3700 | 9,9 | O+ | B+ | Coombs (-) G6PD (-) | Breast | ? TSB <23.4 mg/dl at 68 hours | -3 | ? | 41.9
Hank3 From Hanko, 2001 | ? | Mix African & White | F | 37 | 2900 | 9,9 | O+ | B+ | Coombs (+) Sepsis (-) G6PD (-) | Breast | ? TSB <23.4 mg/dl at 35 hours | ? | ? | 37.2
Hung1 From Hung, 1988 | ? | ? | M | Full term | > 2500 | ? | The causes of jaundice were mostly ABO incompatibility, G6PD deficiency and unknown factors. Patients with prematurity, sepsis, meningitis, asphyxia and IVH were excluded. | | | ? | ? | ? | ? | 34
Hung2 From Hung, 1988 | ? | ? | M | Full term | > 2500 | ? | | | | ? | ? | ? | ? | 36
Hung3 From Hung, 1988 | ? | ? | F | Full term | > 2500 | ? | | | | ? | ? | ? | ? | 36
Hung4 From Hung, 1988 | ? | ? | F | Full term | > 2500 | ? | | | | ? | ? | ? | ? | 51
Hung5 From Hung, 1988 | ? | ? | M | Full term | > 2500 | ? | | | | ? | ? | ? | ? | 30
Hung6 From Hung, 1988 | ? | ? | F | Full term | > 2500 | ? | | | | ? | ? | ? | ? | 30
Hung7 From Hung, 1988 | ? | ? | M | Full term | > 2500 | ? | | | | ? | ? | ? | ? | 33
Hung8 From Hung, 1988 | ? | ? | M | Full term | > 2500 | ? | | | | ? | ? | ? | ? | 19
Hung9 From Hung, 1988 | ? | ? | M | Full term | > 2500 | ? | | | | ? | ? | ? | ? | 29
JohnL3 From Johnson, 1991 | ? | ? | ? | Full term | 3150 | ? | AO incompatible | | Coombs (+) | Breast | 2 days | 0 | 29.5 | 29.5
JohnL6^†^ From Johnson, 1991 | ? | ? | ? | Full term | ? | ? | ABO compatible | | G6PD (+) No sepsis | Breast | < 24 hours | ? | 24 | 28
JohnW1 From Johnson, 1967 | 1957 to 1958 | ? | F | Full term | ? | ? | ? | ? | Sepsis neonatorum | ? | Born at home | ? | 20.1 | 20.1
JohnW7 From Johnson, 1967 | 1957 to 1958 | ? | M | Full term | 2948 | ? | Rh (+) | | ? | ? | ? | ? | 28.1 | 28.1
Macd1 From MacDonald, 1995 | 1993 to 1995 | African-American | M | 39 | 3470 | ? | ? | ? | G6PD (+) Mild anemia | Breast | 24 hours | ? | 42.5 | 42.5
Macd2^‡^ From MacDonald, 1995 | 1993 to 1995 | Mix Peruvian & Chinese | M | 37 | 2840 | ? | ? | ? | G6PD (+) Coombs (-) | Breast | <48 hours | -12.1 | 49.2 | 49.2
Macd3 From MacDonald, 1995 | 1993 to 1995 | African-American | M | 40 | 3300 | ? | ? | ? | G6PD (+) | Br | <48 hrs | ? | 26.3 | 36.0
Macd4 From MacDonald, 1995 | 1985 to 1995 | African-American | M | ? | 3400 | ? | ? | ? | G6PD (+) Severe anemia Sepsis (+) | Br | <48 hours | ? | 41.0 | 41.0
Mala6* From Malaka-Zairiu, 1975 | ? | ? | ? | Full term | 2700 | ? | ? | ? | G6PD (+) Rh (-) | ? | ? | ? | ? | 30.0
Mala8* From Malaka-Zairiu, 1975 | ? | ? | ? | Full term | 3500 | ? | ? | ? | G6PD (-) Rh (+) | ? | ? | ? | ? | 29.0
Mala10* From Malaka-Zairiu, 1975 | ? | ? | ? | Full term | 4100 | ? | ? | ? | G6PD (+) Rh (-) | ? | ? | ? | ? | 23.0
Mala11* From Malaka-Zairiu, 1975 | ? | ? | ? | Full term | 3000 | ? | ? | ? | G6PD (+) Rh (-) | ? | ? | ? | ? | 23.5
Mala22* From Malaka-Zairiu, 1975 | ? | ? | ? | Full term | 3720 | ? | ? | ? | G6PD (+) Rh (-) | ? | ? | ? | ? | 23.5
Mala25* From Malaka-Zairiu, 1975 | ? | ? | ? | Full term | 3100 | ? | ? | ? | G6PD (+) Rh (-) | ? | ? | ? | ? | 27.5
Mala28* From Malaka-Zairiu, 1975 | ? | ? | ? | Full term | 3500 | ? | ? | ? | G6PD (+) Rh (-) | ? | ? | ? | ? | 32.5
Mmwr3 From CDC, 2001 | 1997 | White | M | 37 | 3686 | 9,9 | ? | ? | ? | Breast | 22 hours Cephalohematoma & heart murmur | ? | 27 | 33.4
Mmwr4 From CDC, 2001 | 1998 | White | M | 39 | 4313 | 8,9 | AO incompatibility | | ? | ? | 52 hours | ? | 23.6 | 29.4
Ozce1 From Ozcelik, 1997 | 1978 to 1983 | ? | ? | ? | 3200 | ? | From a total of 30 patients with kernicterus sequelae (26 cases were Rh incompatibility and 4 were ABO incompatibility) None of them had meningitis and encephalitis. All had kernicterus sequelae | | | ? | ? | ? | ? | 32.0
Ozce3 From Ozcelik, 1997 | | ? | ? | ? | 3050 | ? | | | | ? | ? | ? | ? | 22.7
Ozce4 From Ozcelik, 1997 | | ? | ? | ? | 2950 | ? | | | | ? | ? | ? | ? | 34.2
Ozce6 From Ozcelik, 1997 | | ? | ? | ? | 3300 | ? | | | | ? | ? | ? | ? | 39.2
Ozce7 From Ozcelik, 1997 | | ? | ? | ? | 3250 | ? | | | | ? | ? | ? | ? | 29.2
Ozce8 From Ozcelik, 1997 | | ? | ? | ? | 2875 | ? | | | | ? | ? | ? | ? | 20.4
Ozce10 From Ozcelik, 1997 | | ? | ? | ? | 2500 | ? | | | | ? | ? | ? | ? | 26.0
Ozce12 From Ozcelik, 1997 | | ? | ? | ? | 2950 | ? | | | | ? | ? | ? | ? | 40.4
Ozce13 From Ozcelik, 1997 | | ? | ? | ? | 3100 | ? | | | | ? | ? | ? | ? | 42.2
Ozce14 From Ozcelik, 1997 | | ? | ? | ? | 2700 | ? | | | | ? | ? | ? | ? | 30.6
Ozce16 From Ozcelik, 1997 | | ? | ? | ? | 3100 | ? | | | | ? | ? | ? | ? | 21.5
Ozce17 From Ozcelik, 1997 | | ? | ? | ? | 3000 | ? | | | | ? | ? | ? | ? | 20.5
Pear1 From Pearlman, 1980 | 1971 to 1976 | ? | ? | 36 | ? | 8,9 | ? | ? | Sepsis (+) Pneumonia and pulmonary hemorrhage | ? | - | ? | ? | 15.6
Pear2 From Pearlman, 1980 | 1971 to 1976 | ? | ? | 36 | ? | 9,10 | ? | ? | Sepsis (+) Pneumonia and pulmonary hemorrhage | ? | - | ? | ? | 8.6
Penn1^†^ From Penn, 1994 | ? | ? | M | ? | 3400 | 9,9 | O+ | O+ | G6PD (+) No sepsis or hemolysis | Breast | 2 | ? | 50 | 50
Pled8 From Pledger, 1982 | 1970 to 1979 | ? | F | 36 | 3180 | ? | ? | ? | Pneumonia with abscess Rh (-) | ? | ? | ? | ? | 14.5
Pled9 From Pledger, 1982 | 1970 to 1979 | ? | F | 40+ | 2580 | ? | ? | ? | Escherichia coli meningitis Rh (-) | ? | ? | ? | ? | 21.4
Stei1 From Steinborn, 1999 | ? | ? | M | 38 | 3400 | ? | O- | A+ | ? | ? | ? | ? | 40 | 40
Suga2 From Sugama, 2001 | ? | ? | F | 34 | 1382 | ? | ? | ? | Hypoglyce-mia and thrombocyto-penia | ? | 57 | ? | 14.7 | 14.7
Tay1 From Tay, 1984 | ? | Chinese | F | Full term | 2830 | ? | Anti-a | | G6PD (-) | ? | ? | ? | ? | 30.8
| | | | | | | O+ | A+
Tay2 From Tay, 1984 | ? | Chinese | F | Full term | 2480 | ? | Anti-a | | G6PD (-) | ? | ? | ? | ? | 24.4
| | | | | | | B+ | AB+
Tay4 From Tay, 1984 | ? | Chinese | M | Full term | 2740 | ? | Anti-b | | G6PD (-) | ? | ? | ? | ? | 20.4
| | | | | | | O+ | B+
Tay6 From Tay, 1984 | ? | Chinese | F | 37 | 2270 | ? | Anti-b | | G6PD (-) | ? | ? | ? | ? | 21.4
| | | | | | | O+ | B-
Tay7 From Tay, 1984 | ? | Chinese | M | Full term | 2700 | ? | Anti-b | | G6PD (-) | ? | ? | ? | ? | 22.9
| | | | | | | O+ | B+
Walk1 From Walker, 1974 | 1953 | ? | F | 40 | 2466 | ? | Rh-hemolytic disease | | | ? | ? | ? | ? | 36
Walk2 From Walker, 1974 | 1954 | ? | M | 40 | 3969 | ? | Rh-hemolytic disease | | | ? | ? | ? | ? | 26
Walk3 From Walker, 1974 | 1959 | ? | F | 40 | 3118 | ? | Rh-hemolytic disease | | | ? | ? | ? | ? | 28
Walk4 From Walker, 1974 | 1960 | ? | F | 39 | 3856 | ? | Rh-hemolytic disease | | | ? | ? | ? | ? | 40
Wash1^†^ From Washington, 1995 | ? | ? | F | 36 | 2300 | ? | O+ | O+ | Coombs (-) G6PD (+) Grade I IVH | Formula | 2nd day | <-5 | 37.0 | 39.5
Wate5 From Waters | ? | ? | M | ? | 3600 | ? | A- | A+ | Coombs (+) | ? | ? | ? | ? | 27.6
Wong1 From Wong, 1980 | ? | Chinese | ? | Full term | ? | ? | ? | ? | G6PD (+) | ? | 4th day | ? | 40 | 40
Yilm1 From Yilmaz, 2001 | ? | ? | ? | Full term | Normal | | Hemolytic disease | | | ? | ? | ? | ? | 42
Yilm2 From Yilmaz, 2001 | ? | ? | ? | Full term | Normal | ? | Rh incompatibility | | | ? | ? | ? | ? | 17.7
Yilm3 From Yilmaz, 2001 | ? | ? | ? | Full term | Normal | ? | Hemolytic disease | | | ? | ? | ? | ? | 31
Yilm4 From Yilmaz, 2001 | ? | ? | ? | Full term | Normal | ? | Hemolytic disease | | | ? | ? | ? | ? | 36
Yilm5 From Yilmaz, 2001 | ? | ? | ? | Full term | Normal | ? | Hemolytic disease | | | ? | ? | ? | ? | 30
Yilm6 From Yilmaz, 2001 | ? | ? | ? | Full term | Normal | ? | Hemolytic disease | | | ? | ? | ? | ? | 29.4
Yilm7 From Yilmaz, 2001 | ? | ? | ? | Full term | Normal | ? | Hemolytic disease | | | ? | ? | ? | ? | 40
Yilm8 From Yilmaz, 2001 | ? | ? | ? | Full term | Normal | ? | Hemolytic disease | | | ? | ? | ? | ? | 35
Yoko1 From Yokochi, 1995 | ? | ? | M | 39 | 2900 | ? | ? | ? | Sepsis | ? | ? | ? | ? | 30.5
Yoko3 From Yokochi, 1995 | ? | ? | F | 38 | 2900 | ? | Hemolytic anemia (undermined blood type incompatibility) | | | ? | ? | ? | ? | 46.0
Zame5 From Zamet, 1975 | ? | ? | ? | Full term | 3000 | ? | ? | ? | Rh (+) | ? | ? | ? | ? | 35.2
Zame6 From Zamet, 1975 | ? | ? | ? | Full term | 2300 | ? | ? | ? | Rh (+) | ? | ? | ? | ? | 38

† G6PD deficiency was not revealed until long-term follow-up.

‡ significant weight loss

* Cases from Table 2 of the original article. Males were preferred in the study.

? = no data / unknown; BET = blood exchange transfusion; CP = cerebral palsy; ≈ = approximately; PhotoRx = phototherapy; Dept = department; DD = developmental delay; G6PD = glucose-6-phosphate dedydrogenase deficiency; Rh = Rhesus incompatibility; MR = mental retardation; KI = kernicterus

Evidence Table 6.2. Clinical Data on Term Newborns with Comorbid Factors Who Had Kernicterus Part II

Case ID | Age at Peak SB (d) | Rx for Jaundice (x times), or other condition | Diagnoses of KI and/or Follow-up Outcomes | Follow-up
Boon1 From Boon, 1957 | 6 | ? | Muscular hypertonicity, drowsiness (at admission) Jaundice disappeared completely after 4 months but the limbs were still slightly stiff and the milestones delayed. | >4 months
Boon10 From Boon, 1957 | 10 | ? | Drowsiness, cephalin-cholesterol flocculation test was strongly positive. Died on the 8th day. Necropsy found yellow-staining in the brain nuclei. | 8 days
Boon12 From Boon, 1957 | 3 | ? | Drowsiness and of umbilicus infection. Died on 5th day. Necropsy found yellow-staining in the brain nuclei. | 5 days
Boon14 From Boon, 1957 | 7 | ? | Muscular hypertonicity, admitted on the 5th day | ?
Boon15 From Boon, 1957 | 5 | ? | Drowsiness, cephalin-cholesterol liver function test positive, admitted on the 12th day. Died on the 13th day. Necropsy found yellow-staining in the brain nuclei. | 13 days
Boon20 From Boon, 1957 | 12 | ? | Muscular hypertonicity, admitted on the 8th day | ?
Boon26 From Boon, 1957 | 8 | ? | Muscular hypertonicity, drowsiness, admitted on the 6th day | ?
Brow2 From Brown, 1968 | 26.2 | BET | Drowsy (at readmission) Residual increased muscle tone of the legs (at follow-up) | ?
Ebbe1^‡^ From Ebbesen, 2000 | 7 | PhotoRx, albumin infusion | Lethargy, poor sucking, hypertonia, dehydrate, slow respiration, opisthotonus, smacking of the lips, pronation of the upper extremities, apnea, cyanotic attacks, tonic seizures, jittering, high pitched cry (at neonatal dept) DD, athetoid CP and epilepsy. Died 19 mo old | 19 months
Ebbe3 From Ebbesen, 2000 | 4 | PhotoRx, albumin infusion | Lethargy, opisthotonus, hypertonia, apnea, cyanotic attacks, tonic seizures, pronation of the upper extremities (at neonatal dept) Hearing loss (at follow-up) | 12 months
Ebbe4 From Ebbesen, 2000 | 4 | BET | Poor sucking, jittering, opisthotonus, hypertonia, irritability (at neonatal dept) Hearing loss and balance disturbances (at follow-up) | 12 months
Ebbe5^‡^ From Ebbesen, 2000 | 7 | PhotoRx, albumin infusion | Opisthotonus, hypertonia, tonic seizures, hepatomegalia (at neonatal dept) Normal during the follow-up period of 5 months | 5 months
Gart4 From Gartner, 1970 | 2 | ? | KI was diagnosed by autopsy. Died on day 3. | 60 hours
Gibb1 From Gibbs, 1979 | 7 | BET | “Kernicterus” | ?
Gibb2 From Gibbs, 1979 | 9 | BET | “Kernicterus” | ?
Gibb3 From Gibbs, 1979 | 9 | No treatment | “Kernicterus” (death) | 9 days
Hank1 From Hanko, 2001 | 1.75 | Antibiotic | Hypoglycemia and acidosis, seizures, hypotonia > 2 wk, high-pitched cry (at admission) Moderate to severe bilirubin-induced encephalopath (CP, deafness, impaired eye movements) (at follow-up) | 4 months
Hank2 From Hanko, 2001 | 2.8 | ? | Hypotonia < 4 days, high-pitched cry (at admission) Hearing loss (at follow-up) | 4 months
Hank3 From Hanko, 2001 | 1.46 | ? | Hypotonia < 2 days (at admission) Neurologic examination was normal at follow-up | 4 months
Hung1 From Hung, 1988 | 6 | BET × 1 | Spastic CP, hearing and/or speech impairment | 7 months
Hung2 From Hung, 1988 | 4 | BET × 3 | Spastic CP, hearing and/or speech impairment | 9 months
Hung3 From Hung, 1988 | 8 | BET × 1 | Athetotic CP, hearing and/or speech impairment | 2 years
Hung4 From Hung, 1988 | 5 | BET × 2 | Athetotic CP, hearing and/or speech impairment | 2 years
Hung5 From Hung, 1988 | 4 | BET × 2 | Hypotonia | 7 months
Hung6 From Hung, 1988 | 6 | BET × 4 | Spastic CP, hearing and/or speech impairment | 6 years
Hung7 From Hung, 1988 | 6 | BET × 2 | Mixed athetotic & spastic CP, hearing and/or speech impairment | 2 years
Hung8 From Hung, 1988 | 5 | BET × 1 | Spastic CP, hearing and/or speech impairment | 10 years
Hung9 From Hung, 1988 | 4 | BET × 1 | Mixed athetotic & spastic CP, hearing and/or speech impairment | 10 years
JohnL3 From Johnson, 1991 | 5 | BET PhotoRx | BAER abnormal (at readmission) BAER showed prolonged conduction time marked on left, minimal on right on day 9. Results pending at age 6 months | 6 months
JohnL6^†^ From Johnson, 1991 | ? | BET | Poor feeding, opisthotonic, acute signs of KI (before BET) Classic signs of KI (at follow-up) | ?
JohnW1 From Johnson, 1967 | 4 | Chloramphenicol BET × 1 | High-pitched cry (at admission) Mild athetosis, aphasia and moderately severe hearing loss. IQ=104. Her sibling's IQ=129. (at follow-up) | 5~6 years
JohnW7 From Johnson, 1967 | 3 | BET × 5 antibiotic | Minimal high tone hearing loss. IQ was normal (at follow-up) | 5~6 years
Macd1 From MacDonald, 1995 | 5 | BET × 2 | Lethargy on admission to NICU, apnea and cyanosis (seizure) during BET Hypotonic and opisthotonic, electroencephalogram showed a “burst-suppression” pattern. Hearing loss bilaterally, and hypotonia (at follow-up) | 13 months
Macd2^‡^ From MacDonald, 1995 | 5 | Phenobarbital BET × 2 | Decreased interest in feeding, lethargy, and staring spells, mild pyrexia, weak cry, repetitive lip smacking and opisthotonus (at admission to NICU) Seizure, posturing, electroencephalogram showed encephalopathy, deteriorating neurologic and general clinical status. | ?
Macd3 From MacDonald, 1995 | 11 | PhotoRx w/ disc. Breast-feeding BET × 2 | Jaundice (26.3) appeared on day 7; PhotoRx w/ discontinued Breast feeding decreased bilirubin to 13.8 within 48 hrs. Jaundiced again within 48 hrs starting Breast-feeding. Decreased appetite and lethargy before BET. (Staphylococcus epidermides was isolated in sig. numbers from urine.) | ?
Macd4 From MacDonald, 1995 | 6 | Phenobarbital BET × 2 | Lethargy and not feeding well on admission to NICU. Apnea, seizure before BET. At the time of discharge, evidence of neurologic damage, including hypotonia, absence of visual tracking, and intermittent sunsetting of his eyes, was shown. | ?
Mala6* From Malaka-Zairiu, 1975 | ? TSB= 26.on 10th d | BET × 1 | “Kernicterus” | 10 days
Mala8* From Malaka-Zairiu, 1975 | ? TSB= 4.9 on 10th d | BET × 1 | “Kernicterus” | 10 days
Mala10* From Malaka-Zairiu, 1975 | ? TSB= 10.5 on 10th d | BET × 2 | “Kernicterus” | 10 days
Mala11* From Malaka-Zairiu, 1975 | ? TSB= 7 on 10th d | BET × 2 | “Kernicterus” | 10 days
Mala22* From Malaka-Zairiu, 1975 | ? TSB= 22 on 10th d | No BET | “Kernicterus” | 10 days
Mala25* From Malaka-Zairiu, 1975 | ? TSB= 7 on 10th d | BET × 2 | “Kernicterus” | 10 days
Mala28* From Malaka-Zairiu, 1975 | ? TSB= 7 on 10th d | BET × 2 | “Kernicterus” | 10 days
Mmwr3 From CDC, 2001 | 4 | 15 min sunlight per day PhotoRx BET | Athetoid CP, oral-motor dysfunction, gaze paresis | 4 months
Mmwr4 From CDC, 2001 | 12 | Receive sunlight | Jaundice was noted before discharged. Infant was alert and nursed well after discharged. However, on day 12, jaundice appeared; infant was admitted to the hospital. Athetoid CP, hearing loss, and enamel hypoplasia (in 4 months) | 4 months
Ozce1 From Ozcelik, 1997 | ? | BET | “KI sequelae” Moderate hearing loss | 7 years
Ozce3 From Ozcelik, 1997 | ? | BET | “KI sequelae” Moderate hearing loss | 6 years
Ozce4 From Ozcelik, 1997 | ? | BET | “KI sequelae” Moderate + severe hearing loss | 9 years
Ozce6 From Ozcelik, 1997 | ? | BET | “KI sequelae” Moderate + severe hearing loss | 10 years
Ozce7 From Ozcelik, 1997 | ? | BET | “KI sequelae” Moderate hearing loss | 7 years
Ozce8 From Ozcelik, 1997 | ? | BET | Moderate hearing loss | 13 years
Ozce10 From Ozcelik, 1997 | ? | BET | Moderate + severe hearing loss | 6 years
Ozce12 From Ozcelik, 1997 | ? | BET | Moderate + severe hearing loss | 6 years
Ozce13 From Ozcelik, 1997 | ? | BET | Moderate + severe hearing loss | 6 years
Ozce14 From Ozcelik, 1997 | ? | BET | Moderate hearing loss | 7 years
Ozce16 From Ozcelik, 1997 | ? | BET | Moderate hearing loss | 10 years
Ozce17 From Ozcelik, 1997 | ? | BET | Moderate hearing loss | 6 years
Pear1 From Pearlman, 1980 | 136 hours | ? | No exhibition of the characteristic abnormal tone or opisthotonic posturing usually associated with KI. KI was diagnosed by autopsy: susceptible nuclei during gross examination of the brain and microscopic evidence of neuronal degeneration and necrosis in the stained regions. | 144 hours (death)
Pear2 From Pearlman, 1980 | 48 hours | ? | Same as above | 66 hours (death)
Penn1^†^ From Penn, 1994 | 4 | BET × 2 PhotoRx Antibiotic Phenobarbital | Hypertonia and opisthotonus on admission to NICU. Hypertonicity with sustained upper and lower extremities flexion, severe bilateral sensorineural hearing loss, poor head control, poor visual tracking (at 4-month follow-up) | 6 months
Pled8 From Pledger, 1982 | ? | ? | KI was diagnosed by autopsy | >3 days
Pled9 From Pledger, 1982 | ? | ? | KI was diagnosed by autopsy | >3 days
Stei1 From Steinborn, 1999 | 6 | (No Rx on day 2 when SB=18 mg/dl) BET × 1 | Hyperexcitability, high pitched cry and opisthotonus (on day 6) Full-blown picture of KI with muscle rigidity, rolling of the eyes, bradycardia and irregular respiration over the following 2 years. Severe MR, choreoathetosis, dystonia, muscle rigidity, opisthotonus and severe hearing impairment. | 2.5 yars
Suga2 From Sugama, 2001 | 5 | PhotoRx | Fever, lethargy, irritability, and opisthotonus were absent. Neurologic exam during hospitalization was normal. Hypotonia of the trunk and extremities, poor head control, and poor visual tracking, asymmetric tonic neck reflex posture, Voluntary arm movement induced involuntary oral movement (at follow-up) | 7 months
Tay1 From Tay, 1984 | ? | BET × 2 | “Kernicterus” | ?
Tay2 From Tay, 1984 | ? | BET × 2 | “Kernicterus” | ?
Tay4 From Tay, 1984 | ? | BET × 1 | “Kernicterus” | ?
Tay6 From Tay, 1984 | ? | BET × 1 | “Kernicterus” | ?
Tay7 From Tay, 1984 | ? | BET × 2 | “Kernicterus” | ?
Walk1 From Walker, 1974 | ? | BET × 1 | CNS signs: Severe athetosis. MR, can't speech, probably deaf, vision is normal. | 7~14 years
Walk2 From Walker, 1974 | ? | BET × 2 | CNS signs: Severe athetosis. MR, can't speech, probably deaf, vision is normal. | 7~14 years
Walk3 From Walker, 1974 | ? | BET × 2 | CNS signs: Severe athetosis. MR, can't speech, probably deaf, vision is normal. | 7~14 years
Walk4 From Walker, 1974 | ? | BET × 2 | CNS signs: Mild athetosis. Normal IQ, Speech is very limited, severe high frequency loss, vision is normal. | 7~14 years
Wash1^†^ From Washington, 1995 | 5 | BET Antibiotic Ventilated for 3 days | Irritability and jaundiced when admission to ED. DD, including severe choreoathetoid spastic quadriplegic CP, hearing loss, and language delay (at follow-up) | 3 years
Wate5 From Waters | 1 | ? | Fever, spasticity of the upper extremities, listless before death. Died at 67 hrs. KI was diagnosed by autopsy. | 67 hours
Wong1 From Wong, 1980 | 5 | “Chuan Lian” (a Chinese herb) | Opisthotonus. Died within 24 hrs after admission to the hospital. | 5 days
Yilm1 From Yilmaz, 2001 | ? | ? | Axial hypotonia, choreoathetoid movements, limited upward gaze Mild psychosocial, moderate motor delay, language delay | 24 months
Yilm2 From Yilmaz, 2001 | ? | BET | Mild choreoathetoid movements and dystonia Moderate motor, severe language, mild psychosocial delay | 24 months
Yilm3 From Yilmaz, 2001 | ? | ? | Dystonia, choreoathetosis, limited upward vertical gaze Moderate psychosocial-motor delay | 18 months
Yilm4 From Yilmaz, 2001 | ? | ? | Mild choreoathetosis and dystonia, limited upward gaze Mild motor and psychosocial delay, language delay | 50 months
Yilm5 From Yilmaz, 2001 | ? | ? | Dystonia, athetosis Moderate psychosocial-motor delay | 13 months
Yilm6 From Yilmaz, 2001 | ? | ? | Dystonic-choreoathetoid CP, limited vertical gaze movements to upward Moderate psychosocial-motor delay, language delay | 24 months
Yilm7 From Yilmaz, 2001 | ? | ? | Opistotonus, rigidity, athetoid movements, slow saccades Severe psychosocial-motor and language delay | 5 months
Yilm8 From Yilmaz, 2001 | ? | ? | Choreoathetosis, limited extraocular eye movements (vertical and horizontal) Severe motor delay, moderate psychosocial delay, language delay | 30 months
Yoko1 From Yokochi, 1995 | ? | BET | Athetotic CP; Mild MR | 3 years
Yoko3 From Yokochi, 1995 | ? | BET | Athetotic CP; Mild MR | 12 years
Zame5 From Zamet, 1975 | ? | ? | Clinical evidence of Kernicterus | ?
Zame6 From Zamet, 1975 | ? | ? | Clinical evidence of Kernicterus | ?

† G6PD deficiency was not revealed until long-term follow-up.

‡ significant weight loss

* Cases from Table 2 of the original article. Males were preferred in the study.

? = no data / unknown; BET = blood exchange transfusion; CP = cerebral palsy; ≈ = approximately; PhotoRx = phototherapy; Dept = department; DD = developmental delay; G6PD = glucose-6-phosphate dedydrogenase deficiency; Rh = Rhesus incompatibility; MR = mental retardation; KI = kernicterus