# References and Bibliography

From the Centers for Disease Control and Prevention. Kernicterus in full-term infants--United States, 1994-1998. JAMA 2001 Jul 18;286(3):299–300.
Kernicterus threatens healthy newborns. Sentinel Event Alert 2001 Apr;(18):1–4.
Practice parameter: management of hyperbilirubinemia in the healthy term newborn. American Academy of Pediatrics. Provisional Committee for Quality Improvement and Subcommittee on Hyperbilirubinemia. Pediatrics 1994 Oct;94(4 Pt 1):558–65.
Births and birth rates, by age and Hispanic origin of mother: United States, final 1999 and preliminary 2000. National Vital Statistics Report 1 A.D.;49(5):7–8.
Abrol P, Sankarasubramanian R. Effect of phototherapy on behaviour of jaundiced neonates. Indian Journal of Pediatrics. Jul. 1998;65(4):603-7. [pmid: 10773912].
Agarwal K, Narayan S, Kumari S, et al. Correlation of coagulation abnormalities with clinical outcome in neonates of mothers with pregnancy induced hypertension. Journal of the Indian Medical Association. Jun. 1998;96(6):171-3. [pmid: 9834564].
Agrawal V K, Shukla R, Misra P K, et al. Brainstem auditory evoked response in newborns with hyperbilirubinemia. Indian Pediatr. Jun. 1998;35(6):513-8. [pmid: 10216645].
Alpay F, Sarici S U, Tosuncuk H D, et al. The value of first-day bilirubin measurement in predicting the development of significant hyperbilirubinemia in healthy term newborns. Pediatrics. Aug. 2000;106(2):E16. [pmid: 10920172].
Amin S B, Ahlfors C, Orlando M S, et al. Bilirubin and serial auditory brainstem responses in premature infants. Pediatrics. Apr. 2001;107(4):664-70. [pmid: 11335741].
Awasthi S, Rehman H. Early prediction of neonatal hyperbilirubinemia. Indian Journal of Pediatrics. Jan. 1998;65(1):131-9. [pmid: 10771956].
Bengtsson B, Verneholt J. A follow-up study of hyperbilirubinaemia in healthy, full-term infants without iso-immunization. Acta Paediatrica Scandinavica. Jan. 1974;63(1):70-80. [pmid: 4830414].
Bertini G, Dani C, Tronchin M, et al. Is breastfeeding really favoring early neonatal jaundice?. Pediatrics. Mar. 2001;107(3):E41. [pmid: 11230622].
Bhandari V, Narang A, Mann S B, et al. Brain stem electric response audiometry in neonates with hyperbilirubinemia. Indian Journal of Pediatrics. May. 1993;60(3):409-13. [pmid: 8253490].
Bhat V, Srinivasan S, Usha T S, et al. Correlation of transcutaneous bilirubinometry with serum bilirubin in south Indian neonates. Indian Journal of Medical Research. Jul. 1987;86:49-52. [pmid: 3692559].
Bhutani V K, Gourley G R, Adler S, et al. Noninvasive measurement of total serum bilirubin in a multiracial predischarge newborn population to assess the risk of severe hyperbilirubinemia. Pediatrics. Aug. 2000;106(2):E17. [pmid: 10920173].
Bhutani V K, Johnson L, Sivieri E M. Predictive ability of a predischarge hour-specific serum bilirubin for subsequent significant hyperbilirubinemia in healthy term and near-term newborns. [see comments.]. Pediatrics. Jan. 1999;103(1):6-14. [pmid: 9917432].
Bhutta Z A, Yusuf K. Transcutaneous bilirubinometry in Pakistani newborns: a preliminary report. JPMA - Journal of the Pakistan Medical Association. Jul. 1991;41(7):155-6.
Bilgen H, Ince Z, Ozek E, et al. Transcutaneous measurement of hyperbilirubinaemia: comparison of the Minolta jaundice meter and the Ingram icterometer. Annals of Tropical Paediatrics. Dec. 1998;18(4):325-8. [pmid: 9924590].
Bland J M, Altman D G. Statistical methods for assessing agreement between two methods of clinical measurement. Lancet. Feb 8. 1986;1(8476):307-10. [pmid: 2868172].
Boggs T R Jr, Hardy J B, Frazier T M. Correlation of neonatal serum total bilirubin concentrations and developmental status at age eight months. A preliminary report from the collaborative project. Journal of Pediatrics. Oct. 1967;71(4):553-60. [pmid: 6046621].
Boo N Y, Oakes M, Lye M S, et al. Risk factors associated with hearing loss in term neonates with hyperbilirubinaemia. Journal of Tropical Pediatrics. Aug. 1994;40(4):194-7. [pmid: 7932930].
Boo N Y, Bakar A A. Transcutaneous bilirubinometry in Malay, Chinese and Indian term neonates. Medical Journal of Malaysia. Mar. 1984;39(1):35-7. [pmid: 6513837].
Boon W H. Kernicterus not associated with haemolystic disease. Archives of Disease in Childhood. 1957;32:85-90. [pmid: 13425653].
Bourchier D, Cull A B, Oettli P E. Transcutaneous bilirubinometry: 22 months experience at Waikato Women's Hospital. New Zealand Medical Journal. Sep 23. 1987;100(832):599-600. [pmid: 3452102].
Brown A K, Kim M H, Wu P Y, et al. Efficacy of phototherapy in prevention and management of neonatal hyperbilirubinemia. Pediatrics. Feb. 1985;75(2 Pt 2):393-400. [pmcid: 375534]. [pmid: 3903646].
Brown W R, Boon W H. Hyperbilirubinemia and kernicterus in glucose-6-phosphate dehydrogenase-deficient infants in Singapore. Pediatrics. Jun. 1968;41(6):1055-62. [pmid: 5652917].
Bryla D A. Randomized, controlled trial of phototherapy for neonatal hyperbilirubinemia. Development, design, and sample composition. Pediatrics. Feb. 1985;75(2 Pt 2):387-92. [pmcid: 375534]. [pmid: 3903646].
Carbonell X, Botet F, Figueras J, et al. Prediction of hyperbilirubinaemia in the healthy term newborn. Acta Paediatrica. Feb. 2001;90(2):166-70. [pmid: 11236046].
Cashore W J, Oh W. Unbound bilirubin and kernicterus in low-birth-weight infants. Pediatrics. Apr. 1982;69(4):481-5. [pmid: 7200229].
Chaibva N T, Fenner A, Wolfsdorf J. Reliability of an icterometer in Black neonates with hyperbilirubinaemia. S Afr Med J. Jul 27. 1974;48(36):1533-4. [pmid: 4417507].
Chen J Y, Ling U P, Chen J H. Early meconium evacuation: effect on neonatal hyperbilirubinemia. American Journal of Perinatology. Jul. 1995;12(4):232-4. [pmid: 7575822].
Chen Y J, Kang W M. Effects of bilirubin on visual evoked potentials in term infants. Eur J Pediatr. Aug. 1995;154(8):662-6. [pmid: 7588970].
Christo G G, Kamath S, Aroor A R, et al. Transcutaneous bilirubinometry in newborns. Indian Pediatrics. Nov. 1988;25(11):1073-7. [pmid: 3074055].
Culley P E, Powell J E, Waterhouse J A, et al. Sequelae of neonatal jaundice. Archives of Disease in Childhood. Oct. 1970;45(243):712. [pmid: 5529333].
Dai J, Krahn J, Parry D M. Clinical impact of transcutaneous bilirubinometry as an adjunctive screen for hyperbilirubinemia. Clinical Biochemistry. Dec. 1996;29(6):581-6. [pmid: 8939407].
Deorari A K, Singh M, Ahuja G K, et al. One year outcome of babies with severe neonatal hyperbilirubinemia and reversible abnormality in brainstem auditory evoked responses. Indian Pediatrics. Aug. 1994;31(8):915-21. [pmid: 7883343].
Ebbesen F. Recurrence of kernicterus in term and near-term infants in Denmark. Acta Paediatrica. Oct. 2000;89(10):1213-7. [pmid: 11083378].
Esbjorner E, Larsson P, Leissner P, et al. The serum reserve albumin concentration for monoacetyldiaminodiphenyl sulphone and auditory evoked responses during neonatal hyperbilirubinaemia. Acta Paediatrica Scandinavica. Apr. 1991;80(4):406-12. [pmid: 2058389].
Escher-Graub D C, ricker H S. Jaundice and behavioral organization in the full-term neonate. Helvetica Paediatrica Acta. Dec. 1986;41(5):425-35. [pmid: 3818329].
Fok T F, Lau S P, Hui C W, et al. Transcutaneous bilirubinometer: its use in Chinese term infants and the effect of haematocrit and phototherapy on the TcB index. Australian Paediatric Journal. May. 1986;22(2):107-9. [pmid: 3729821].
Funato M, Teraoka S, Tamai H, et al. Follow-up study of auditory brainstem responses in hyperbilirubinemic newborns treated with exchange transfusion. Acta Paediatrica Japonica. Feb. 1996;38(1):17-21. [pmid: 8992853].
Gartner L M, Snyder R N, Chabon R S, et al. Kernicterus: high incidence in premature infants with low serum bilirubin concentrations. Pediatrics. Jun. 1970;45(6):906-17. [pmid: 5422114].
Gibbs W N, Gray R, Lowry M. Glucose-6-phosphate dehydrogenase deficiency and neonatal jaundice in Jamaica. Br J Haematol. Oct. 1979;43(2):263-74. [pmid: 508636].
Goldman S L, Penalver A, Penaranda R. Jaundice meter: evaluation of new guidelines. Journal of Pediatrics. Aug. 1982;101(2):253-6. [pmid: 7097424].
Gourley G R. Measurement of serum bilirubin in newborn infants: Common clinical laboratory methods versus high performance liquid chromatography (HPLC). Pediatrics. 1999;45(4):293A.
Granati B, Largajolli G, Rubaltelli F F, et al. Efficacy and safety of the “integral” phototherapy for neonatal hyperbilirubinemia. Results of a follow-up at 6 years of age. Clinical Pediatrics. Sep. 1984;23(9):483-6. [pmid: 6467780].
Grimmer I, Berger-Jones K, Buhrer C, et al. Late neurological sequelae of non-hemolytic hyperbilirubinemia of healthy term neonates. Acta Paediatrica. Jun. 1999;88(6):661-3. [pmid: 10419253].
Grunebaum E, Amir J, Merlob P, et al. Breast mild jaundice: natural history, familial incidence and late neurodevelopmental outcome of the infant. European Journal of Pediatrics. Feb. 1991;150(4):267-70. [pmid: 2029918].
Gupta A K, Mann S B. Is auditory brainstem response a bilirubin neurotoxicity marker?. American Journal of Otolaryngology. Jul. 1998;19(4):232-6. [pmid: 9692630].
Gupta A K, Raj H, Anand N K. Auditory brainstem responses (ABR) in neonates with hyperbilirubinemia. Indian Journal of Pediatrics. Sep. 1990;57(5):705-11. [pmid: 2094672].
Gupta P C, Kumari S, Mullick D N, et al. Icterometer: a useful screening tool for neonatal jaundice. Indian Pediatr. May. 1991;28(5):473-6. [pmid: 1752673].
Hanko E, Lindemann R, Hansen T W. Spectrum of outcome in infants with extreme neonatal jaundice. Acta Paediatr. Jul. 2001;90(7):782-5. [pmid: 11519982].
Hannemann R E, Schreiner R L, DeWitt D P, et al. Evaluation of the Minolta bilirubin meter as a screening device in white and black infants. Pediatrics. Jan. 1982;69(1):107-9. [pmid: 7054743].
Hansen T W. Acute management of extreme neonatal jaundice--the potential benefits of intensified phototherapy and interruption of enterohepatic bilirubin circulation. Acta Paediatr. Aug. 1997;86(8):843-6. [pmid: 9307164].
Hardy J B, Peeples M O. Serum bilirubin levels in newborn infants. Distributions and associations with neurological abnormalities during the first year of life. Johns Hopkins Medical Journal. May. 1971;128(5):265-72. [pmid: 5556539].
Harish R, Sharma D B. Transcutaneous bilirubinometry in neonates: evaluation of Minolta Air shields jaundicemeter. [see comments.]. Indian Pediatrics. Mar. 1998;35(3):264-7. [pmid: 9707882].
Harris M C, Bernbaum J C, Polin J R, et al. Developmental follow-up of breastfed term and near-term infants with marked hyperbilirubinemia. Pediatrics. May. 2001;107(5):1075-80. [pmid: 11331689].
Haslem RHA, Kenna M. Brainstem Auditory Evoked Potential (BAEP). In: Behrman RE, Kliegman RM, and Jenson HB, editors. Nelson Textbook of Pediatrics. W.B. Saunders Company; 2000
Hegyi T, Hiatt I M, Indyk L. Transcutaneous bilirubinometry. I. Correlations in term infants. Journal of Pediatrics. Mar. 1981;98(3):454-7. [pmid: 7205460].
Holmes G E, Miller J B, Smith E E. Neonatal bilirubinemia in production of long-term neurological deficits. American Journal of Diseases of Children. Jul. 1968;116(1):37-43. [pmid: 5690519].
Hung K L. Auditory brainstem responses in patients with neonatal hyperbilirubinemia and bilirubin encephalopathy. Brain & Development. 1989;11(5):297-301. [pmid: 2817294].
Hung K L, Wu C M. Auditory brainstem response in patients with a history of kernicterus. Chung-Hua Min Kuo Hsiao Erh Ko i Hsueh Hui Tsa Chih. Jul. 1988;29(4):229-34. [pmid: 3272525].
Hyman C B, Keaster J, Hanson V, et al. CNS abnormalities after neonatal hemolytic disease or hyperbilirubinemia. A prospective study of 405 patients. American Journal of Diseases of Children. Apr. 1969;117(4):395-405. [pmid: 4975237].
Irwig L, Macaskill P, Glasziou P, et al. Meta-analytic methods for diagnostic test accuracy. J Clin Epidemiol. Jan. 1995;48(1):119-30. [pmid: 7853038].
Jegier W, Blankenship W, Lind J. Venous pressure in the first hour of life and its relationship to placental transfusion. Acta Paediatrica. Sep. 1963;52:485-96. [pmid: 14063669].
John E. Phototherapy in neonatal hyperbilirubinaemia. Aust Paediatr J. Mar. 1975;11(1):49-52. [pmid: 1137530].
Johnson L. Hyperbilirubinemia in the term infant: when to worry, when to treat. N Y State J Med. Nov. 1991;91(11):483-9. [pmid: 1771043].
Johnson L H, Bhutani V K, Brown A K. System-based approach to management of neonatal jaundice and prevention of kernicterus. J Pediatr. Apr. 2002;140(4):396-403. [pmid: 12006952].
Johnston W H, Angara V, Baumal R, et al. Erythroblastosis fetalis and hyperbilirubinemia. A five-year follow-up with neurological, psychological, and audiological evaluation. Pediatrics. Jan. 1967;39(1):88-92. [pmid: 6066698].
Ju S H, Lin C H. The effect of moderate non-hemolytic jaundice and phototherapy on newborn behavior. Chung-Hua Min Kuo Hsiao Erh Ko i Hsueh Hui Tsa Chih. Jan. 1991;32(1):31-41. [pmid: 2063675].
Karrar Z, al Habib S, al Basit O B, et al. Transcutaneous bilirubin measurements in Saudi infants: the use of the jaundice meter to identify significant jaundice. Annals of Tropical Paediatrics. Mar. 1989;9(1):59-61. [pmid: 2471447].
Kenny M, Metzger G, Landicho D, et al. Transcutaneous bilirubin monitoring of newborns. Annals of the New York Academy of Sciences. 1984;428:251-62. [pmid: 6588908].
Khanna V K, Mehta D K, Matthews M, et al. Neonatal hyperbilirubinemia. Ophthalmological evaluation of term infants treated with phototherapy. Indian Pediatrics. Sep. 1984;21(9):713-7. [pmid: 6519804].
Killander A, Michaelsson M, Muller-Eberhard U, et al. Hyperbilirubinemia in full-term newborn infants. Acta Paediatrica. Sep. 1963;52:481-4. [pmid: 14063668].
Kivlahan C, James E J. The natural history of neonatal jaundice. Pediatrics. Sep. 1984;74(3):364-70. [pmid: 6472969].
Knudsen A. Predicting the need for phototherapy in healthy mature neonates using transcutaneous bilirubinometry on the first postnatal day. Biology of the Neonate. 1995;68(6):398-403. [pmid: 8721883].
Knudsen A, Kruse C, Ebbesen F. Detection of hyperbilirubinemia by skin color measurements in icteric newborn infants at 5 to 14 days of age. Acta Paediatrica. Jun. 1993;82(67):510-3. [pmid: 8338980].
Knudsen A. Prediction of later hyperbilirubinaemia by measurement of skin colour on the first postnatal day and from cord blood bilirubin. Danish Medical Bulletin. Apr. 1992;39(2):193-6. [pmid: 1611927].
Knudsen A. The cephalocaudal progression of jaundice in newborns in relation to the transfer of bilirubin from plasma to skin. Early Human Development. Apr. 1990;22(1):23-8. [pmid: 2335140].
Knudsen A. Prediction of the development of neonatal jaundice by increased umbilical cord blood bilirubin. Acta Paediatrica Scandinavica. Mar. 1989;78(2):217-21. [pmid: 2929344].
Kumar A. Micro-invasive management of neonatal bilirubinemia. Indian Pediatrics. Sep. 1992;29(9):1101-6. [pmid: 1452305].
Kuriyama M, Tomiwa K, Konishi Y, et al. Improvement in auditory brainstem response of hyperbilirubinemic infants after exchange transfusions. Pediatric Neurology. May. 1986;2(3):127-32. [pmid: 3508686].
Laeeq A, Yasin M, Chaudhry A R. Transcutaneous bilirubinometry: clinical application. JPMA - Journal of the Pakistan Medical Association. Feb. 1993;43(2):28-30.
Lau J, Ioannidis J P, Schmid C H. Quantitative synthesis in systematic reviews. Ann Intern Med. Nov 1. 1997;127(9):820-6. [pmid: 9382404].
Lin C C, Wu T C, Wei C F, et al. Dilatation of the biliary tract in pediatric patients. Chung Hua i Hsueh Tsa Chih - Chinese Medical Journal. Jul. 1993;52(1):26-31.
Lin Y J, Ju S H, Lin C H. The clinical application of transcutaneous bilirubinometry in full-term Chinese infants. Zhonghua Min Guo Xiao Er Ke Yi Xue Hui Za Zhi. Mar. 1993;34(2):69-76. [pmid: 8372674].
Linder N, Regev A, Gazit G, et al. Noninvasive determination of neonatal hyperbilirubinemia: standardization for variation in skin color. American Journal of Perinatology. May. 1994;11(3):223-5. [pmid: 8048990].
Lodha R, Deorari A K, Jatana V, et al. Non-invasive estimation of total serum bilirubin by multi-wavelength spectral reflectance in neonates. Indian Pediatr. Jul. 2000;37(7):771-5. [pmid: 10906811].
MacDonald M G. Hidden risks: early discharge and bilirubin toxicity due to glucose 6-phosphate dehydrogenase deficiency. Pediatrics. Oct. 1995;96(4 Pt 1):734-8. [pmcid: 434508]. [pmid: 7491251].
Maisels MJ. Jaundice. In: Avery GB, Fletcher MA, and MacDonald MG, editors. Neonatology. Lippincott Williams and Wilkins; 1999. p. 791.
Maisels M J, Kring E. Transcutaneous bilirubinometry decreases the need for serum bilirubin measurements and saves money. Pediatrics. Apr. 1997;99(4):599-601. [pmid: 9093305].
Maisels M J, Newman T B. Kernicterus in otherwise healthy, breast-fed term newborns. Pediatrics. Oct. 1995;96(4 Pt 1):730-3. [pmcid: 434508]. [pmid: 7491251].
Maisels M J, Conrad S. Transcutaneous bilirubin measurements in full-term infants. Pediatrics. Sep. 1982;70(3):464-7. [pmid: 7110821].
Malaka-Zafiriu K, Tsiures J, Cassimos C. D-Glucaric acid excretion in newborns with severe jaundice of unknown etiology and due to glucose-6-phosphate dehydrogenase deficiency in Greece. Helvetica Paediatrica Acta. Jul. 1975;30(2):201-7. [pmid: 807541].
Martinez J C, Maisels M J, Otheguy L, et al. Hyperbilirubinemia in the breast-fed newborn: a controlled trial of four interventions. Pediatrics. Feb. 1993;91(2):470-3. [pmid: 8424029].
Maruo Y, Nishizawa K, Sato H, et al. Prolonged unconjugated hyperbilirubinemia associated with breast milk and mutations of the bilirubin uridine diphosphate- glucuronosyltransferase gene. Pediatrics. Nov. 2000;106(5):E59. [pmid: 11061796].
Maurer H M, Kirkpatrick B V, McWilliams N B, et al. Phototherapy for hyperbilirubinemia of hemolytic disease of the newborn. Pediatrics. Feb. 1985;75(2 Pt 2):407-12. [pmcid: 375534]. [pmid: 3903646].
Misra P K, Srivastava K L, Bajpai P C, et al. Follow-up of neonates treated with phototherapy. Indian Journal of Medical Research. Jan. 1980;71:68-76. [pmid: 7380513].
Moses L E, Shapiro D, Littenberg B. Combining independent studies of a diagnostic test into a summary ROC curve: data-analytic approaches and some additional considerations. Stat Med. Jul 30. 1993;12(14):1293-316. [pmid: 8210827].
Naeye R L. Amniotic fluid infections, neonatal hyperbilirubinemia, and psychomotor impairment. Pediatrics. Oct. 1978;62(4):497-503. [pmid: 714581].
Newman T B, Escobar G J. Frequency of neonatal bilirubin testing and hyperbilirubinemia in a large health maintenance organization. Ambul Pediatr. Mar. 2001;1(2):126. [pmid: 11888386].
Newman T B, Xiong B, Gonzales V M, et al. Prediction and prevention of extreme neonatal hyperbilirubinemia in a mature health maintenance organization. Archives of Pediatrics & Adolescent Medicine. Nov. 2000;154(11):1140-7. [pmid: 11074857].
Newman T B, Escobar G J, Gonzales V M, et al. Frequency of neonatal bilirubin testing and hyperbilirubinemia in a large health maintenance organization. Pediatrics. Nov. 1999;104(5 Pt 2):1198-203. [pmid: 10610503].
Newman T B, Klebanoff M A. Neonatal hyperbilirubinemia and long-term outcome: another look at the Collaborative Perinatal Project. [see comments.]. Pediatrics. Nov. 1993;92(5):651-7. [pmid: 8414851].
Newman T B, Maisels M J. Does hyperbilirubinemia damage the brain of healthy full-term infants?. Clin Perinatol. Jun. 1990;17(2):331-58. [pmid: 2196133].
Nwaesei C G, Van Aerde J, Boyden M, et al. Changes in auditory brainstem responses in hyperbilirubinemic infants before and after exchange transfusion. Pediatrics. Nov. 1984;74(5):800-3. [pmid: 6541781].
Odell G B, Storey G N, Rosenberg L A. Studies in kernicterus. 3. The saturation of serum proteins with bilirubin during neonatal life and its relationship to brain damage at five years. Journal of Pediatrics. Jan. 1970;76(1):12-21. [pmid: 5410148].
Okuyama H, Yonetani M, Uetani Y, et al. End-tidal carbon monoxide is predictive for neonatal non-hemolytic hyperbilirubinemia. Pediatr Int. Aug. 2001;43(4):329-33. [pmid: 11472573].
Ozcelik T, Onerci M, Ozcelik U, et al. Audiological findings in kernicteric patients. Acta Oto-Rhino-Laryngologica Belgica. 1997;51(1):31-4. [pmid: 9105480].
Ozmert E, Erdem G, Topcu M, et al. Long-term follow-up of indirect hyperbilirubinemia in full-term Turkish infants. Acta Paediatrica. Dec. 1996;85(12):1440-4. [pmid: 9001655].
Paludetto R, Mansi G, Rinaldi P, et al. Moderate hyperbilirubinemia does not influence the behavior of jaundiced infants. Biology of the Neonate. 1986;50(1):43-7. [pmid: 3741906].
Paludetto R, Mansi G, Rinaldi P, et al. The behavior of jaundiced infants treated with phototherapy. Early Hum Dev. Oct. 1983;8(34):259-67. [pmid: 6641571].
Pearlman M A, Gartner L M, Lee K, et al. The association of kernicterus with bacterial infection in the newborn. Pediatrics. Jan. 1980;65(1):26-9. [pmid: 7355031].
Penn A A, Enzmann D R, Hahn J S, et al. Kernicterus in a full term infant. Pediatrics. Jun. 1994;93(6 Pt 1):1003-6. [pmid: 7971008].
Perlman M, Fainmesser P, Sohmer H, et al. Auditory nerve-brainstem evoked responses in hyperbilirubinemic neonates. Pediatrics. Nov. 1983;72(5):658-64. [pmid: 6634269].
Pledger D R, Scott J M, Belfield A. Kernicterus at low levels of serum bilirubin: the impact of bilirubin albumin-binding capacity. A 10-year retrospective survey. Biology of the Neonate. 1982;41(12):38-44. [pmid: 7199940].
Rapisardi G, Vohr B, Cashore W, et al. Assessment of infant cry variability in high-risk infants. International Journal of Pediatric Otorhinolaryngology. Feb. 1989;17(1):19-29. [pmid: 2707975].
Risemberg H M, Mazzi E, MacDonald M G, et al. Correlation of cord bilirubin levels with hyperbilirubinaemia in ABO incompatibility. Archives of Disease in Childhood. Mar. 1977;52(3):219-22. [pmid: 557960].
Robertson A, Kazmierczak S, Vos P. Improved transcutaneous bilirubinometry: comparison of SpectR(X) BiliCheck and Minolta Jaundice Meter JM-102 for estimating total serum bilirubin in a normal newborn population. J Perinatol. Jan. 2002;22(1):12-4. [pmid: 11840236].
Rosta J, Bekefi D. A new chart for indicating exchange transfusion in neonatal hyperbilirubinaemia. Acta Paediatrica Academiae Scientiarum Hungaricae. 1971;12(3):311-6. [pmid: 5148793].
Rosta J, Makoi Z, Bekefi D, et al. Neonatal pathologic jaundice: seven to nine years follow-up. Acta Paediatr Acad Sci Hung. 1971;12(3):317-21. [pmid: 5169922].
Rubaltelli F F, Gourley G R, Loskamp N, et al. Transcutaneous bilirubin measurement: a multicenter evaluation of a new device. Pediatrics. Jun. 2001;107(6):1264-71. [pmid: 11389241].
Rubin R A, Balow B, Fisch R O. Neonatal serum bilirubin levels related to cognitive development at ages 4 through 7 years. Journal of Pediatrics. Apr. 1979;94(4):601-4. [pmid: 430298].
Sabatino G, Verrotti A, Ramenghi L A, et al. Newborns with hyperbilirubinemia: usefulness of brain stem auditory response evaluation. Neurophysiologie Clinique. 1996;26(6):363-8. [pmid: 9018698].
Scheidt P C, Bryla D A, Nelson K B, et al. Phototherapy for neonatal hyperbilirubinemia: six-year follow-up of the National Institute of Child Health and Human Development clinical trial. [see comments.]. Pediatrics. Apr. 1990;85(4):455-63. [pmid: 2179848].
Scheidt P C, Mellits E D, Hardy J B, et al. Toxicity to bilirubin in neonates: infant development during first year in relation to maximum neonatal serum bilirubin concentration. Journal of Pediatrics. Aug. 1977;91(2):292-7. [pmid: 874689].
Schneider A P. Breast milk jaundice in the newborn. A real entity. [erratum appears in JAMA 1986 Dec 19;256(23):3218.]. JAMA. Jun 20. 1986;255(23):3270-4. [pmid: 3712679].
Schreiner R L, Glick M R. Interlaboratory bilirubin variability. Pediatrics. Mar. 1982;69(3):277-81. [pmid: 7063285].
Schumacher R E, Thornbery J M, Gutcher G R. Transcutaneous bilirubinometry: a comparison of old and new methods. Pediatrics. Jul. 1985;76(1):10-4. [pmid: 4011341].
Seidman D S, Ergaz Z, Paz I, et al. Predicting the risk of jaundice in full-term healthy newborns: a prospective population-based study. Journal of Perinatology. Dec. 1999;19(8 Pt 1):564-7. [pmid: 10712101].
Seidman D S, Stevenson D K. In Letters to the Editor. The Issues of Hyperbilirubinemia. Pediatrics. 1995;96(3):1995. [pmid: 7567338].
Seidman D S, Paz I, Stevenson D K, et al. Effect of phototherapy for neonatal jaundice on cognitive performance. Journal of Perinatology. Jan. 1994;14(1):23-8. [pmid: 8169674].
Seidman D S, Paz I, Stevenson D K, et al. Neonatal hyperbilirubinemia and physical and cognitive performance at 17 years of age. Pediatrics. Oct. 1991;88(4):828-33. [pmid: 1896294].
Serrao P A, Modanlou H D. Significance of anti-A and anti-B isohemagglutinins in cord blood of ABO incompatible newborn infants: correlation with hyperbilirubinemia. [see comments.]. Journal of Perinatology. Jun. 1989;9(2):154-8. [pmid: 2738726].
Sharma J N, Singh R N, Lodha A, et al. Transcutaneous bilirubinometry in newborns. Indian Pediatrics. Aug. 1988;25(8):757-60. [pmid: 3220564].
Sheridan-Pereira M, Gorman W. Transcutaneous bilirubinometry: an evaluation. Archives of Disease in Childhood. Sep. 1982;57(9):708-10. [pmid: 7125691].
Smith D W, Inguillo D, Martin D, et al. Use of noninvasive tests to predict significant jaundice in full-term infants: preliminary studies. Pediatrics. Feb. 1985;75(2):278-80. [pmid: 3969329].
Soorani-Lunsing I, Woltil H A, Hadders-Algra M. Are moderate degrees of hyperbilirubinemia in healthy term neonates really safe for the brain?. Pediatr Res. Dec. 2001;50(6):701-5. [pmid: 11726727].
Steinborn M, Seelos K C, Heuck A, et al. MR findings in a patient with Kernicterus. Eur Radiol. 1999;9(9):1913-5. [pmid: 10602975].
Stevenson D K, Fanaroff A A, Maisels M J, et al. Prediction of hyperbilirubinemia in near-term and term infants. Pediatrics. Jul. 2001;108(1):31-9. [pmid: 11433051].
Suckling R J, Laing I A, Kirk J M. Transcutaneous bilirubinometry as a screening tool for neonatal jaundice. Scottish Medical Journal. Feb. 1995;40(1):14-5. [pmid: 7604235].
Sugama S, Soeda A, Eto Y. Magnetic resonance imaging in three children with kernicterus. Pediatr Neurol. Oct. 2001;25(4):328-31. [pmid: 11704404].
Suresh G, Lucey J F. Lack of deafness in Crigler-Najjar syndrome type 1: a patient survey. Pediatrics. Nov. 1997;100(5):E9. [pmid: 9347003].
Taha S A, Karrar Z A, Dost S M. Transcutaneous bilirubin measurement in evaluating neonatal jaundice among Saudi newborns. Annals of Tropical Paediatrics. Dec. 1984;4(4):229-31. [pmid: 6210040].
Tan K L, Chia H P, Koh B C. Transcutaneous bilirubinometry in Chinese, Malay and Indian infants. Acta Paediatrica. Aug. 1996;85(8):986-90. [pmid: 8863884].
Tan K L, Skurr B A, Yip Y Y. Phototherapy and the brain-stem auditory evoked response in neonatal hyperbilirubinemia. Journal of Pediatrics. Feb. 1992;120(2 Pt 1):306-8. [pmid: 1279153].
Tan K L. Transcutaneous bilirubinometry in Chinese and Malay neonates. Annals of the Academy of Medicine, Singapore. Oct. 1985;14(4):591-4. [pmid: 4083794].
Tan K L. Transcutaneous bilirubinometry in fullterm Chinese and Malay infants. Acta Paediatrica Scandinavica. Jul. 1982;71(4):593-6. [pmid: 7136674].
Tay J S, Low P S, Wong H B, et al. Value and limitations of bilirubin binding capacity in predicting the development of kernicterus. Australian Paediatric Journal. Mar. 1984;20(1):63-6. [pmid: 6466218].
Tayaba R, Gribetz D, Gribetz I, et al. Noninvasive estimation of serum bilirubin. Pediatrics. Sep. 1998;102(3):E28. [pmid: 9724676].
Telzrow R W, Snyder D M, Tronick E, et al. The behavior of jaundiced infants undergoing phototherapy. Developmental Medicine & Child Neurology. Jun. 1980;22(3):317-26. [pmid: 7390029].
Tsai L T, Lu C C. Clinical evaluation of transcutaneous jaundice meter in full-term newborns. Chung-Hua Min Kuo Hsiao Erh Ko i Hsueh Hui Tsa Chih. Nov. 1988;29(6):376-82. [pmid: 3272538].
Upadhyay Y. A longitudinal study of full-term neonates with hyperbilirubinemia to four years of age. Johns Hopkins Medical Journal. May. 1971;128(5):273-7. [pmid: 5556540].
Valaes T, Kipouros K, Petmezaki S, et al. Effectiveness and safety of prenatal phenobarbital for the prevention of neonatal jaundice. Pediatric Research. Aug. 1980;14(8):947-52. [pmid: 7422399].
Valkeakari T, Anttolainen I, Aurekoski H, et al. Follow-up study of phototreated fullterm newborns. Acta Paediatrica Scandinavica. Jan. 1981;70(1):21-5. [pmid: 7211376].
Vohr B R, Karp D, O'Dea C, et al. Behavioral changes correlated with brain-stem auditory evoked responses in term infants with moderate hyperbilirubinemia. J Pediatr. Aug. 1990;117(2 Pt 1):288-91. [pmid: 2246707].
Vohr B R, Lester B, Rapisardi G, et al. Abnormal brain-stem function (brain-stem auditory evoked response) correlates with acoustic cry features in term infants with hyperbilirubinemia. Journal of Pediatrics. Aug. 1989;115(2):303-8. [pmid: 2754560].
Vreman H J, Verter J, Oh W, et al. Interlaboratory variability of bilirubin measurements. Clin Chem. Jun. 1996;42(6 Pt 1):869-73. [pmid: 8969657].
Walker W, Ellis M I, Ellis E, et al. A follow-up study of survivors of Rh-haemolytic disease. Developmental Medicine & Child Neurology. Oct. 1974;16(5):592-611. [pmid: 4421870].
Washington E C, Ector W, Abboud M, et al. Hemolytic jaundice due to G6PD deficiency causing kernicterus in a female newborn. South Med J. Jul. 1995;88(7):776-9. [pmid: 7597488].
Watchko J F, Oski F A. Kernicterus in preterm newborns: past, present, and future. Pediatrics. Nov. 1992;90(5):707-15. [pmid: 1408544].
Waters WJ, Richert DA, Rawson HH. Bilirubin encephalopathy. Pediatrics 0 AD;13:319-25.
Wolf M J, Wolf B, Beunen G, et al. Neurodevelopmental outcome at 1 year in Zimbabwean neonates with extreme hyperbilirubinaemia. Eur J Pediatr. Feb. 1999;158(2):111-4. [pmid: 10048606].
Wolf M J, Beunen G, Casaer P, et al. Extreme hyperbilirubinaemia in Zimbabwean neonates: neurodevelopmental outcome at 4 months. European Journal of Pediatrics. Oct. 1997;156(10):803-7. [pmid: 9365074].
Wong H B. Singapore kernicterus. Singapore Medical Journal. Jun. 1980;21(3):556-67. [pmid: 7444473].
Yamauchi Y, Yamanouchi I. Transcutaneous bilirubinometry: effect of postnatal age. Acta Paediatrica Japonica. Oct. 1991;33(5):663-7. [pmid: 1799123].
Yamauchi Y, Yamanouchi I. Factors affecting transcutaneous bilirubin measurement: effect of daylight. Acta Paediatrica Japonica. Oct. 1991;33(5):658-62. [pmid: 1799122].
Yamauchi Y, Yamanouchi I. Clinical application of transcutaneous bilirubin measurement. Early prediction of hyperbilirubinemia. Acta Paediatrica Scandinavica. Apr. 1990;79(4):385-90. [pmid: 2349874].
Yamauchi Y, Yamanouchi I. Transcutaneous bilirubinometry in normal Japanese infants. Acta Paediatr Jpn. Feb. 1989;31(1):65-72. [pmid: 2504029].
Yamauchi Y, Yamanouchi I. Transcutaneous bilirubinometry. Evaluation of accuracy and reliability in a large population. Acta Paediatrica Scandinavica. Nov. 1988;77(6):791-5. [pmid: 3207014].
Yilmaz Y, Karadeniz L, Yildiz F, et al. Neurological prognosis in term newborns with neonatal indirect hyperbilirubinemia. Indian Pediatrics. Feb. 2001;38(2):165-8. [pmid: 11224582].
Yilmaz Y, Alper G, Kilicoglu G, et al. Magnetic resonance imaging findings in patients with severe neonatal indirect hyperbilirubinemia. J Child Neurol. Jun. 2001;16(6):452-5. [pmid: 11417616].
Yokochi K. Magnetic resonance imaging in children with kernicterus. Acta Paediatrica. Aug. 1995;84(8):937-9. [pmid: 7488821].
Zamet P, Nakamura H, Perez-Robles S, et al. The use of critical levels of birth weight and “free bilirubin” as an approach for prevention of kernicterus. Biology of the Neonate. 1975;26(34):274-82. [pmid: 1169077].
Zuelzer W W. Kernicterus: Etiologic study based on an analysis of 55 cases. Pediatrics. 1950;26(34):274-82. [pmid: 14780798].