# Conclusions

## Association of Neonatal Hyperbilirubinemia to Neurodevelopmental Outcomes

### Outcomes in Kernicterus Cases

Summarizing case reports of kernicterus from different investigators in different countries from different time periods is problematic. First, definitions used in these reports varied greatly. They included gross yellow staining of the brain, microscopic neuronal degeneration, acute clinical neuromotor impairment, neuro-auditory impairment and chronic neuromotor impairment. In some cases, the diagnoses were not established until months or years after birth. Second, case reports without controls makes interpretation difficult, especially in infants with comorbid factors, and could very well lead to misinterpretation of the role of bilirubin in neurodevelopmental outcomes. Third, different reports used different outcome measures. “Normal at follow-up” may be based on parental reporting, physician assessment, or formal neuropsychological testing. Fourth, time of reported follow up ranged from days to years. Fifth, cases were reported from different countries at different time periods and with different milieu (some have high prevalence of G6PD and some use naphthalene moth balls routinely in their dressers) and varying standards of practice concerning hyperbilirubinemia. The effect of the differences on outcomes cannot be known for certain. Finally, it is difficult to infer from case reports the true incidence of this uncommon disorder. Nevertheless, one can conclude from these data that high levels of serum bilirubin are strongly associated with kernicterus. The distribution of bilirubin levels in reported cases of kernicterus is substantially skewed compared to the population-based distribution of neonatal bilirubin levels described by Newman, Escobar, Gonzales et al. (1999). (See Figure 4.1.)

Figure 4.1 Peak total serum bilirubin (TSB) values (mg/dl) obtained from case reports of 35 otherwise healthy infants with kernicterus suprimposed on the distribution of peak TSB values from a birth cohort of 50,000 infants born in 11 California hospitals (Newman, Escobar, Gonzales et al., 1999)

Based on our summary of multiple case reports that spanned more than 30 years, we conclude that kernicterus, although infrequent, has significant mortality (at least 10 percent) and long-term morbidity (at least 70 percent). It is evident that the preponderance of kernicterus cases occurred in infants with high bilirubin (>20mg/dl). This summary affirms the role of elevated bilirubin level in kernicterus but does not provide incontrovertible proof of causality in this association.

Five of 26 (19 percent) term or near-term infants with kernicterus and reported follow-up data survived without sequelae, while only three of 63 (5 percent) infants with kernicterus and comorbid factors were reported to be normal at follow up. This suggests the importance of comorbid factors in determining long-term outcome in infants initially diagnosed with kernicterus.

### Outcomes of Hyperbilirubinemia

Only a few prospective controlled studies looked specifically at behavioral and neurodevelopmental outcomes in healthy term infants with hyperbilirubinemia. Most of these studies have a small number of subjects. Two very short-term studies with well-defined measurement of newborn behavioral organization and physiologic measurement of cry are of high quality methodology (Escher-Graub and Fricker, 1986; Rapisardi, Vohr, Cashore et al., 1989). But the significance of long term abnormalities in newborn behavior scales and variations in cry formant frequencies are unknown. There remains very little information on the long-term effects of hyperbilirubinemia in healthy term infants.

Among the mixed studies (combined term and preterm; non-hemolytic and hemolytic; non-diseased and diseased) and studies with subjects from racial backgrounds other than black and white infants, the following observations can be made:

- Excluding the Collaborative Perinatal Project (CPP) study and the studies looking at IQ, out of nine studies looking primarily at behavioral and neurodevelopmental outcomes, only three studies were of high methodologic quality. One very short-term study showed a correlation between bilirubin level and decreased scores on newborn behavioral measurements (Vohr, Lester, Rapisardi et al., 1989). One found no difference in prevalence of CNS abnormalities at age 4 years when bilirubin was below 20 mg/dl, but infants with bilirubin above 20 mg/dl had a higher prevalence of CNS abnormalities (Hyman, Keaster, Hanson et al, 1969). Another study that followed infants with bilirubin greater than 16 mg/dl found no relationship between bilirubin and neuro-visual-motor testing at 61 to 82 months of age (Valaes, Kipouros, Petmezaki et al., 1980). Although data reported in the rest of the studies are not of the highest caliber, there is a suggestion of abnormalities in neurodevelopmental screening tests in infants with bilirubin > 20 mg/dl, at least by the Denver Developmental Screening Test (DDST), when followed up at one year of age. It appears that bilirubin > 20 mg/dl may have short-term (up to one year of age) adverse effects at least by DDST, but there is no strong evidence to suggest neurologic abnormalities in children with neonatal bilirubin > 20 mg/dl when followed up to 7 years of age.
- Nine of 15 studies (excluding the CPP) addressing neuro-auditory development and bilirubin level were of high quality. Six of them showed BAER abnormalities correlate with high bilirubin levels. The majority reported resolution with treatment. Three studies reported hearing impairment associated with elevated bilirubin (> 16 mg/dl to > 20 mg/dl). We conclude that high bilirubin level does have an adverse effect on neuro-auditory development, but the adverse effect on BAER is reversible.
- Again, excluding the CPP, of the eight studies reporting intelligence outcomes in subjects with hyperbilirubinemia, four studies were considered high quality. These four studies reported no association between IQ and bilirubin level with follow up ranging from 6.5 years to 17 years. Seidman, Paz, Stevenson, et al. (1991) also reported no direct linear association between bilirubin levels and IQ scores. However, the risk for IQ score < 85 at age 17 years was found to be significantly higher among full-term Coombs-negative male subjects with serum bilirubin > 20 mg/dl. We conclude that there is no evidence to suggest a linear association of bilirubin level and IQ.
- The Collaborative Perinatal Project (CPP), with 54,795 live births between 1959 and 1966 from 12 centers in the U.S. has, by far, the largest database for the study of hyperbilirubinemia. Newman and Klebanoff (1993), focusing only on black and white infants with birthweight ≥ 2500 grams, did a comprehensive analysis of 7-year outcome in 33,272 subjects. All causes of jaundice were included in the analysis. The study found no consistent association between peak bilirubin level and IQ. Sensorineural hearing loss was not related to bilirubin level. Only the frequency of abnormal or suspicious neurologic examinations was associated with bilirubin level.

A large prospective study comprised of healthy infants ≥ 34-week gestation with hyperbilirubinemia, specifically looking at long-term neurodevelopmental outcomes, has yet to be done. The report of Newman and Klebanoff (1993) came closest to that ideal because of the large number of subjects and the study analytic approach. However, a population born from 1959 to 1966 may no longer be relevant to present day newborns. There are more infants born to non-black and non-white mothers. More infants are breastfed. Phototherapy for hyperbilirubinemia has become standard therapy. Hospital stays are shorter. All these and other factors may have unknown long-term developmental effects on present day newborns with hyperbilirubinemia.

Short-term studies reviewed in this section, while in general having good methodologic quality, use tools that have unknown long-term predictive abilities. Long-term studies suffer from high attrition rates of the study population and a non-uniform approach to defining “normal neurodevelopmental outcomes.” The total bilirubin levels reported in all the above studies were measured anywhere from first day of life to more than two weeks of life. Definitions of significant hyperbilirubinemia ranged from 12 mg/dl to 20 mg/dl.

Given the diversity of conclusions reported, except in cases of kernicterus with sequelae, it is evident that the use of a single total serum bilirubin level (within the range described in the reviewed studies) to predict long-term behavioral or neurodevelopmental outcomes is inadequate and will lead to conflicting results.

## Treatment of Neonatal Hyperbilirubinemia in Relation to Neurodevelopmental Outcomes

Regardless of different protocols of phototherapy, the NNT for prevention of serum bilirubin level exceeding 20 mg/dl ranged from six to 10 in healthy term or near-term infants. This implies that one needs to treat six to 10 healthy, but jaundiced, neonates with TSB ≥15 mg/dl by phototherapy in order to prevent one event (TSB >20 mg/dl). Evidence for the efficacy of treatments for neonatal hyperbilirubinemia was limited. Overall, the four qualifying studies showed that phototherapy had an absolute risk reduction rate of 10 percent to 17 percent for prevention of serum bilirubin exceeding 20 mg/dl in healthy and jaundiced infants (TSB ≥13 mg/dl) with a gestational age of 34 weeks or more. Phototherapy combined with cessation of breastfeeding and substitution with formula was found to be the most efficient treatment protocol for healthy term or near-term infants with jaundice.

Eight studies examined the effect of bilirubin reduction on brainstem auditory response. All consistently showed treatments for neonatal hyperbilirubinemia significantly improved abnormal BAER's in both healthy jaundiced infants and jaundiced infants with hemolytic disease.

There is no evidence to suggest that phototherapy for neonatal hyperbilirubinemia has any long-term neurodevelopmental adverse effect in either healthy jaundiced infants or infants with hemolytic disease.

Nine studies evaluated the effect of phototherapy on neurodevelopment. Of the five studies that looked at infant behavior, three reported lower scores in the orientation cluster of the Brazelton Neonatal Behavioral Assessment Scale in the phototherapy-treated infants. The other two studies did not find behavioral changes in the phototherapy group.

Three studies evaluated the effect of phototherapy on visual outcomes. All showed no short or long-term (up to 36 months) effect on vision as a result of phototherapy while infants' eyes are properly protected during treatment.

## Diagnosis of Neonatal Hyperbilirubinemia

For accuracy of various strategies for prediction of neonatal hyperbilirubinemia, 153 articles were included after title and abstract screening. Only 17 articles were included after full text screening and 10 articles remained after data abstraction, seven percent of the original number. This was the lowest yield of articles among the five questions addressed, suggesting that relatively few prospective or retrospective studies addressed this question without significant design or reporting errors, missing data or apparent bias.

A conclusion is difficult to draw from these studies. The first challenge is the lack of consistency in defining clinically significant neonatal hyperbilirubinemia. Not only did multiple studies use different levels of total serum bilirubin (TSB) to define neonatal hyperbilirubinemia, but the levels of TSB defined as significant also varied by age, yet age at TSB determination varied by study as well. For example, significant levels of TSB were defined as >11.7 mg/dl (Knudsen, 1992), ≥15 mg/dl (Okuyama, Yonetani, Uetani, et al., 2001), >15 mg/dl (Awasthi and Rehman, 1998), >16 mg/dl (Risemberg, Mazzi, MacDonald, et al., 1977), >17 mg/dl (Carbonell, Botet, Figueras, et al., 2001) and ≥25 mg/dl (Newman, Xiong, Gonzales, et al., 2000).

The second challenge is the lack of consistency in study populations. These studies were conducted among multiple racial groups in multiple countries, including China, Denmark, India, Israel, Japan, Spain and the United States. Although infants were defined as healthy term and near-term newborns, these studies included neonates with potential for hemolysis from ABO incompatible pregnancies (Risemberg, Mazzi, MacDonald, et al., 1977), as well as breastfed and bottle-fed infants (often not specified).

Finally, the validity of TSB as the “gold standard” must be questioned given the variability in TSB levels. As shown in Table 3.19 - Part 1, TSB was determined by a variety of methods in the 10 studies reviewed, even within individual studies conducted at multiple sites (Stevenson, Fanaroff, Maisels, et al., 2001). Development of an international consensus on the optimal method of laboratory determination of TSB would establish a true “gold standard” for measurement. Such a method would need to be accurate, yield reproducible results, and yet not require complex technology, such that its use would be limited by cost.

Based on the evidence from the systematic review, transcutaneous measurements of bilirubin by each of the three devices described in the literature, the Minolta AirShields bilirubinometer, the Ingram Icterometer, and the SpectRx BiliCheck™ have a linear correlation to total serum bilirubin and may be useful as screening devices to detect clinically significant jaundice and decrease the need of serum bilirubin determinations.

The Minolta AirShields bilirubinometer appears to perform less well in black infants as compared to white infants, performs best when measurements are made at the sternum, and performs less well when infants have been exposed to phototherapy. This instrument requires daily calibrations and each institution must develop its own correlation curves of TcB to TSB. As a screening test it does not perform consistently across studies as evidenced by the summary ROC curves. The Ingram Icterometer has the added limitation of lacking objectivity of the other methods as it depends on observer visualization of depth of yellow color of the skin.

The recently introduced BiliCheck™ device that utilizes reflectance data from multiple wavelengths appears to be a significant improvement over the older devices, the Ingram Icterometer and the Minolta AirShields bilirubinometer, because of its ability to determine correction factors for the effect of melanin and hemoglobin. In one study the BiliCheck™ was shown to be as accurate as the reference standard method of HPLC in predicting TSB (Rubaltelli, Gourley, Loskamp, et al., 2001). Future research should confirm these findings in larger samples of diverse populations and include effects of phototherapy.