# Results

Results of this review are presented in the following order. First, we present findings for possible association between neonatal hyperbilirubinemia and neurodevelopmental outcomes. Second, efficacy data and effects of treatment for neonatal hyperbilirubinemia are reported. Third, accuracy data for diagnosis and prediction of neonatal hyperbilirubinemia are tabulated and discussed. Fourth, limitations and summary results are discussed.

## Question 1 What is the relationship between peak bilirubin levels and/or duration of hyperbilirubinemia and neurodevelopmental outcome?

The first part of the results for this question deals with kernicterus; the second part deals with otherwise healthy term or near-term infants who had hyperbilirubinemia.

### Case Reports of Kernicterus

Our literature search identified 28 case report articles of infants with kernicterus that reported sufficient data for analyses. Most of the articles were identified in MEDLINE® and published since 1966. We retrieved additional articles published prior to 1966 based on review of references in articles published since 1966. Our report focuses on term/near-term infants (≥34 weeks gestation). Only infants with measured peak bilirubin level and known gestational age or birthweight, or with clinical or autopsy-diagnosed kernicterus were included in the analysis. It is important to note that some of these peak levels were obtained more than seven days after birth, and therefore they may not have represented the true peak levels. Because of the small number of subjects, none of the statistical tests were significant. Furthermore, because case reports in this section represent highly selected cases, interpretation of those data must be made carefully. General trends will be noted; however, analysis of these case reports is not an attempt to affirm causation of bilirubin in kernicterus as kernicterus is a priori defined by neurological impairment with a history of hyperbilirubinemia (Evidence Tables 6.1 and 6.2).

#### Demographics of Kernicterus Cases

Articles we found span from 1955 to 2001 with a total of 123 kernicterus cases. Twelve cases in two studies were reported before 1960. However, some studies reported cases that spanned almost two decades. Data on subjects' birth year were only reported in 55 cases. Feeding status, gender, racial background and ethnicity were not noted in the majority of the reports. Of studies that reported the characteristics, almost all of the subjects were breastfed and the majority were males (see Tables 3.1 and 3.2).

Table 3.1 Feeding and Gender Status in Newborns Who Had Kernicterus

| Sex | Feeding | | | Total
| | Breast | Formula | Unknown
Newborns with idiopathic jaundice with kernicterus | M | 7 | 1 | 6 | 14
| F | 2 | 0 | 4 | 6
| ? | 11 | 0 | 4 | 15
Subtotal | | 20 | 1 | 14 | 35
Newborns with comorbid factors with kernicterus | M | 8 | 0 | 17 | 25
| F | 1 | 1 | 19 | 21
| ? | 6 | 0 | 36 | 42
Subtotal | | 15 | 1 | 72 | 88
Total | | 35 | 2 | 86 | 123

Table 3.2 Racial or Ethnicity Compositions in Newborns Who Had Kernicterus

| Race/Ethnicity
| AA | AF | Chinese | Malay | White/NE | Pal | Unknown | Total
Newborns with idiopathic jaundice with kernicterus | 0 | 0 | 6 | 2 | 9 | 1 | 17 | 35
Newborns with comorbid factors with kernicterus | 4 | 2 | 14 | 1 | 6 | | 61 | 88
Total | 4 | 2 | 23 | 3 | 15 | 1 | 78 | 123

AA = African American; AF = African; NE = Northern European; Pal = Palestinian

#### Geographic Distribution of Kernicterus Cases

The 28 case reports with a total of 123 cases were from 14 different countries. The number of kernicterus cases in each study ranged from one to 12. The distribution of kernicterus cases geographically is shown in Figure 3.1.

Figure 3.1 Geographic distribution of kernicterus cases

Kernicterus has been defined by pathological findings, acute clinical findings and chronic sequelae (like deafness or athetoid cerebral palsy). Because of the small number of subjects, all definitions of kernicterus have been tabulated together in the analysis. Exceptions will be noted in the following discussion.

#### Kernicterus Cases with Unknown Etiology

Among infants ≥ 34 weeks or who had birthweight ≥ 2,500 grams and had no known explanation for kernicterus, there were 35 infants with peak bilirubin ranging from 22.5 mg/dl to 54 mg/dl. Fifteen had no information on their gender; 14 were males and six were females. Fourteen provided no information on feeding; 20 were breast-fed and one was formula-fed. The majority of the infants with kernicterus had bilirubin greater than 25 mg/dl: 25 percent of the kernicterus cases had peak total serum bilirubin (TSB) level up to 29.9 mg/d; 50 percent of the kernicterus cases had peak TSB up to 34.9 mg/dl (Figure 3.2). There was no association between the bilirubin levels and birthweights.

Figure 3.2 Distribution of Peak Total Serum Bilirubin Level in Term Newborns with Idiopathic Jaundice Who Had Kernicterus

Four infants died (Boon, 1957; Ebbesen, 2000). Four infants who had acute clinical kernicterus had normal follow-up at 3 to 6 years by telephone (Harris, Bernbaum, Polin, et al., 2001). One infant with a peak bilirubin of 44 mg/dl had a flat brain stem auditory evoked response (BAER) initially but normalized at 2 months of age; that infant had normal neurologic and developmental examinations at 6 months of age (Johnson, 1991). Ten infants had chronic sequelae of kernicterus when followed up between 6 months and 7 years of age. Seven infants were noted to have neurologic findings consistent with kernicterus but the ages of diagnosis were not provided. Nine infants had diagnosis of kernicterus with no follow-up information provided. To summarize, 11 percent of this group of infants died; 14 percent survived with no sequelae and at least 46 percent of infants had chronic sequelae (Table 3.3). The distribution of peak TSB levels was higher when only infants who died or had chronic sequelae were included (Figure 3.3).

Table 3.4 Summary of 88 Case Reports of Term Infants with Comorbid Factors Who Had Kernicterus

| | Diagnosis of KI
| | Clinical | | | | Total (N) | Mean Peak TSB±SD, mg/dl (range) | Mean BW±SD^†^, g (range) | Sex
| Comorbidity | Acute phase w/o follow-up | Acute phase but normal follow-up | Chronic sequelae | Autopsy
Term infants with cormobid factors | ABO incompatibility | 6 | 0 | 12 | 1‡ | 19 | 31.6±8.2 (19.0–51.0) | 3118±680 (2270–4313) | 6 Females; 11 Males; 2 ?
| Rhesus incompatibility | 3 | 2 | 27 | 1 | 33 | 32.1±7.1 (17.7–46.0) | 3063±387 (2300–3969) | 5 Females; 4 Male; 24 ?
| G6PD deficiency | 10 | 0 | 1 | 2 | 13 | 31.8±8.5 (23.0–50.0) | 3353±437 (2700–4100) | 2 Males; 11 ?
| Sepsis or Infections | 3 | 1 | 4 | 5 | 13 | 31.8±9.9 (14.5–47.8) | 3368±586 (2580–4360) | 7 Females; 4 Males; 2 ?
| Multiple conditions | 3 | 0 | 4 | 3 | 10 | 29.1±16.1 (4.0–49.2) | 2913±750 (1780–3686) | 3 Female; 4 Males; 3 ?
Total | | 25 | 3 | 48 | 12 | 88 | 31.6±9.0 (4.0–51.0) | 3155±534 (1780–4360) | 20 Females; 25 Males; 42 ?

KI = Kernicterus

? = Unknown

† Contain some missing data

‡ This infant had acute phase of KI and chronic KI sequelae; then died at age 19 months.

Table 3.3 Summary of 35 Case Reports of Term Infants with Idiopathic Jaundice Who Had Kernicterus

| Definitions of KI | N | Mean Peak TSB±SD, mg/dl (range) | Mean BW±SD^†^, g (range) | Sex
Term infants w/ idiopathic Jaundice | Acute phase of KI w/o long term follow-up | 9 | 33.4±11.4 (22.5–54.0) | 3496±535 (2700–4500) | 3 Females; 2 Males; 4 ?
| Acute phase of KI but normal long-term follow-up | 5 | 32.3±3.6 (27.0–36.0) | 3088±575 (2400–3742) | 5?
| Chronic KI sequelae | 17 | 37.0±5.9 (29.5–49.7) | 3271±442 (2700–4280) | 1 Females; 11 Males; 6 ?
| Death | 4^‡^ | 36.9±11.0 (23.0–48.0) | 2902±503 (2324–3357) | 2 Female; 1 Male; 1 ?
Total | | 35 | 35.4±8.0 (22.5–54.0) | 3251±512 (2324–4500) | 6 Females; 14 Males; 15 ?

KI = Kernicterus

† Contain some missing data

? = Unknown

‡ One infant had acute phase of KI and chronic KI sequelae; then died at age of 5 months. Necropsy was not done. One infant had acute phase of KI and died on the 5^th^ day of life; necropsy found yellow-staining in the brain nuclei.

Figure 3.3 Cumulative Percentage of Peak Total Serum Bilirubin Levels in Term Newborns with Idiopathic Jaundice Who Had Kernicterus

#### Kernicterus Cases with Comorbid Factors

In the 88 term and near-term infants diagnosed with kernicterus and who had hemolysis, sepsis and other neonatal complications, the bilirubin level ranged from 4.0 mg/dl to 51.0 mg/dl. Forty-two provided no information on their gender; 25 were males and 21 were females. Seventy-two had no information on feeding; 15 were breast-fed and 1 was formula-fed. The majority of those infants with kernicterus had bilirubin greater than 20 mg/dl: 25 percent of the kernicterus cases had peak total serum bilirubin (TSB) level up to 24.9 mg/dl; 50 percent of the kernicterus cases had peak TSB up to 29.9 mg/dl (Figure 3.4). In this group, there was no association between the bilirubin levels and birthweight.

Figure 3.4 Distribution of Peak Total Serum Bilirubin Level in Term Newborns with Comorbid Factors Who Had Kernicterus

Five infants without clinical signs of kernicterus were diagnosed with kernicterus by autopsy. Eight infants died of kernicterus. One infant was found to have a normal neurological exam at 4 months of age (Hanko, Lindemann, Hansen, 2001). Another one with galactosemia and a bilirubin of 43.6 mg/dl who had acute kernicterus was normal at 5 months of age (Ebbesen, 2000). Forty-nine patients had chronic sequelae ranging from hearing loss to athetoid cerebral palsy; the follow-up age reported ranged from 4 months to 14 years. Twenty-one patients were diagnosed with kernicterus with no follow-up information. To summarize, not including the autopsy diagnosed kernicterus, 10 percent of these infants died (8/82); two percent of infants were found to be normal at 4 to 5 months of age and at least 60 percent had chronic sequelae (Table 3.3). The distribution of peak TSB levels was slightly higher when only infants who died or had chronic sequelae were included (Figure 3.5)

Figure 3.5 Cumulative Percentage of Peak Total Serum Bilirubin Levels in Term Newborns with Comorbid Factors Who Had Kernicterus

### Evidence Associating Bilirubin Exposures with Neurodevelopmental Outcomes in Healthy Term or Near-Term Infants

This section examines the evidence associating bilirubin exposures with neurodevelopmental outcomes primarily in subjects without kernicterus. Studies that were designed specifically to address the behavioral and neurodevelopmental outcomes in healthy infants greater or equal to 34 weeks of gestation will be discussed first, as that group of infants is the subject of interest in this review. With the exception of the results from the Collaborative Perinatal Project (CPP, see below), the rest of the studies comprising mixed subjects (preterm and term, diseased and non-diseased) will be categorized and discussed by outcome measures which include behavioral and neurologic outcomes, hearing impairment including sensorineural hearing loss, and intelligence measurements. CPP, with the largest number of subjects (54,795) in this review, has generated many follow-up studies with smaller number of subjects and those studies will be discussed together in a separate section.

One of the central tasks in pediatrics is to ascertain the effect of bilirubin on neurodevelopment in term healthy infants without perinatal or neonatal problems. Only four prospective and one retrospective studies have the requisite subject characteristics to address the above issue. A summary table of those studies will be presented first, then following by the discussion of the results of those studies (see Table 3.5 and Evidence Table 1).

Table 3.5 Effect of Serum Bilirubin Levels on Neurological or Behavioral Outcomes in Healthy Infants (GA ≥ 34 weeks of gestation)

Author, Year, UI # | Subjects N (Control) | Peak bilirubin Level (range) mg/dl | Outcomes | Confounders | Quality
Rapisardi, 1989 89213178 | 29 | 8.8 (2.3–18.5) | @50–71 hrs of life: CV of cry frequencies, as an indicator of “neurophysiological functioning” | PhotoRx, Age | B
| | | The correlation between the CV of F1 during phonation (PF1) and level of bilirubin was significant (r=0.37, p<0.05), suggesting that more variability in F1 was related to higher concentrations of bilirubin.
Escher-Gräub, 1986 87136731 | 76 ( 401) | 11.7–14.6 | @day 4–5 of life: BNBAS | None | B
| | | Jaundiced infants not requiring PhotoRx showed a less mature behavioral organization than the infants of the control group.
Soorani-Lunsing, 2001 11726727 | 20 (20) ^b^ | 18.3 (>12.9) | @3–8 days, 3 and 12 months of life: Neurological exams | PhotoRx; No TSB level available for control group | C
| | | Infants with TSB > 12.9 mg/dl had significantly higher prevalence of mild neurologic dysfunction.Controlling for other factors, the odds of developing mild neurologic dysfunction were 6.62 (95%CI 1.59–27.51), 3.75 (95%CI 1.03–14.53), and 9.47 (95%CI 1.67–53.65) at 3–8 days, 3 and 12 months of life respectively.
| | | @12 months of life: Behavioral Outcomes
| | | It didn't differ between study and control subjects according to the parental questionnaire.
Grimmer, 1999 99345621 | 16 (18) | 23.0 (20.1–28.69) | @61–187 months: Neurological Outcome (Touwen sub-scales) | PhotoRx | C
| | | None of the children studied had medical problems or overtly abnormal neurological findings.
| | | Cluster profiles did not differ significantly between formerly jaundiced children and controls, except for worse scores of formerly jaundiced children on the choreiform dyskinesia scale (P=0.028).
Paludetto, 1986 86296856 | 17 (17) ^a^ | 10.6 (8.4–14.3 ) | @3rd, 4th days of life, and 1 month of age: BNBAS | Not all controls had TSB measured | C
| | | There was no difference in any behavioral item of the BNBAS score at every observation.

a Only 4 controls had bilirubin measurement.

b No TSB level available for control group

BET = exchange transfusion; PhotoRx = phototherapy; BNBAS = Brazelton Neonatal Behavioral Assessment Scale; CV = coefficient of variation; F1 = formant frequency 1

Rapisardi, Vohr, Cashore, et al. (1989) studied and divided 29 healthy full-term infants into three different groups according to bilirubin level (less than or equal to 6 mg/dl, 6 to 12 mg/dl, greater than 12 mg/dl). Some of these infants received phototherapy. No further details were provided. There were no differences in mean values of acoustic measures (cry fundamental frequency, resonant frequency, energy and duration). There was a statistically significant difference between the three groups in the coefficient of variation (CV) of formant frequency-1 (frequency of resonance as determined by the filtering of vocal tract that is affected by the cross-sectional area and motor innervation of the supraglottal airway). Infants with the highest levels of bilirubin showed a greater CV of formant frequency-1 during phonation than infants with lower or medium levels of bilirubin (P<0.05). The authors suggested that “an increase in the variability of the first formant could be due to an increase in instability of the neural mechanisms controlling the cross-sectional area of the supraglottal airways.”

Escher-Graub and Fricker (1986) compared 76 term infants with maximum bilirubin of 11.7 to 14.6 mg/dl to 401 control term infants with bilirubin of less than 5.8 mg/dl using the Brazelton Neonatal Behavioral Assessment Scale (BNBAS). The BNBAS was done either on the fourth or fifth day of life. These term infants had no evidence of hemolysis and did not require phototherapy. The results showed that the two groups differed significantly (p<0.01 to 0.05) on 12 of the 28 scale items. Five of the six dimensions of newborn behavior were affected: habituation, orientation, motor performance, and regulation of state and autonomic stability. “Infants of the jaundice group showed a less mature behavioral organization than the infants of the control group.”

Soorani-Lunsing, Woltil, and Hadders-Algra (2001) assessed the neurologic condition of 20 healthy non-hemolytic term newborns with peak bilirubin of 13.6 to 26 mg/dl and 20 clinically non-jaundiced control infants. Ten of the jaundiced infants received phototherapy. A standardized neurologic examination similar to Prechtl's was carried out at the age of 12 months. “The examiner occasionally knew group membership of the children, but was never aware of the degree of hyperbilirubinemia of the study children.” Moderate hyperbilirubinemia was associated with a significant increase in minor neurologic dysfunction throughout the first year of life: newborn, 3 months of age and 12 months of age. Examples of minor neurologic dysfunction were mild abnormalities in postural behavior, the presence of high frequency tremors, mild deviancies in muscle tone regulation and mild asymmetries in infantile reactions and tendon reflexes. The odds of developing minor neurologic dysfunction at 12 months were 9.47 (95% CI 1.67 – 53.65). Neurologic outcome at 12 months was strongly related to the peak bilirubin level. The authors suggested that “total serum bilirubin levels of 335 micromole/liter (19.6 mg/dl) should be avoided.” The authors also noted that the behavior of the study and control children at age 12 months did not differ according to the parental questionnaires

Grimmer, Berger-Jones, Buhrer, et al. (1999) identified 29 non-hemolytic healthy term newborns with a total bilirubin between 20 and 30 mg/dl based on ten-year records of a referral center: Sixteen were available for a standardized, age-adjusted neurological examination (according to Touwen) at 61 to 187 months of age. All of them received phototherapy. Compared to 18 case controls with bilirubin less than 12 mg/dl, jaundiced children scored significantly (P=0.028) worse only on the choreiform dyskinesia scale. There was no difference in the other neurological subscales (fine and gross motor, sensorimotor apparatus and others).

Paludetto, Mansi, Rinaldi, et al. (1986), also using the Brazelton Neonatal Behavioral Scale, studied 17 jaundiced term 3-day-old infants (bilirubin of 8.4 to 14.3 with a mean of 10.6 mg/dl) not treated with phototherapy and 17 clinically non-jaundiced matched subjects; 14 four-day-old infants (8.4 to 12.9 with a mean of 10.4 mg/dl) and 14 clinically non-jaundiced matched subjects; 10 “ex-jaundiced” 1-month-old infants (9.1 to 15.9 with a mean of 11.5 mg/dl) and 10 clinically non-jaundiced matched subjects. No differences were found. The authors concluded “that moderate levels of hyperbilirubinemia not treated with phototherapy do not influence neonatal behavior.” Bilirubin levels were not measured in the control group.

The following group of studies consists of subjects who, in addition to healthy term newborns, might include newborns younger than 34-week gestation, neonatal complications such as sepsis, respiratory distress, hemolytic disorders and other factors. Nevertheless, some of the conclusions drawn might be applicable to a healthy term population. In these studies, greater emphasis will be placed on the reported results for the group of infants who were greater or equal to 34-week gestation or have birthweight greater or equal 2,500 grams.

### Studies Measuring Behavioral and Neurological Outcomes in Infants with Hyperbilirubinemia

A total of nine studies, in 11 publications, looked primarily at behavioral and neurological outcomes in patients with hyperbilirubinemia (see Table 3.6 and Evidence Table 1).

Table 3.6 Effect of Serum Bilirubin Levels on Neurological or Behavioral Outcomes in All Infants

Author, Year, UI # | Subjects N (Control) | Peak bilirubin Level (range) mg/dl | Outcomes | Confounders | Quality
Vohr, 1989 89328704 | 23 ^a^ (27) | 14.3±2.8 (10–20) | On day 1 to 2: BNBAS | PhotoRx | A
Vohr, 1990 90339225 | | | Jaundiced infants had significantly lower BNBAS scores in every behavioral item except autonomic stability.
| | | Significant correlations were found in increased levels of TSB with decreased scores on the individual BNBAS items. After controlling for PhotoRx by partial correlations, most correlations remained significant except for state regulation and autonomic stability.
Valaes, 1980 81031849 | 44 ^c^ (445) | 47% 16–20 | @61–81 months of age: Visual-Motor integration test (VMI) | Prematurity; BET; Phenobarbital | B
| | 29% 20–25 | Degree of jaundice was found not to be associated with neurologic scores.
| | 24% >25
Hyman, 1969 69132491 | 405 ^b^ | ≥ 15 | @4 years of age: CNS abnormalities | BET; streptomycin Rx; BW; Selection bias | B
| | | No significant difference in incidence of CNS abnormalities among infants exposed to different levels of bilirubin below 20 mg/dl. However, with TSB> 20 mg/dl, incidence of CNS abnormalities increased sharply.
Yilmaz, 2001 21125314 | 87 ^g^ | 11% 23-20 | @10–72 months: Neurological exam | PhotoRx; BET; Duration of jaundice | C
| | 49% 20–23.9 | Subjects with maximum TSB levels < 20 mg/dl didn't show any neurological abnormalities, whereas 9.3% of the subjects with TSB 20–23.9 mg/dl (N=43) had only dysconjugate gaze and 17.6% of the subjects with TSB ≥ 24 mg/dl had neurological manifestations.
| | 39% ≥ 24
Agrawal, 1998 99232291 | 30 ^f^ (25) | 22.4±2.7 | @1 year of age: DDST | PhotoRx; BET; lost to follow-up | C
| | | Neurological development was normal in all infants with TSB 15–20 mg/dl, in 89% of infants with TSB 21–25 mg/dl, and in 67% infants with TSB > 25 mg/dl.
Wolf, 1997 98030356 | 45 ^e^ @4 months | 28.5±6.3 | @4 months of age: Infant Motor Screening (IMS) | PhotoRx; BET; Prematurity; Illness | C
Wolf, 1999 99156393 | 35 @1 year | | Linear correlation showed an association of maximum TSB and test rating at 4 months (r=0.32, p<0.05) and test scores at 4 months (r=0.44, p<0.03)
| | | Mean TSB in the normal IMS group was 27.3±5.3 mg/dl; in the suspect and abnormal IMS group the mean TSB was 28±4 mg/dl and 33.7±10.3 mg/dl, respectively. These differences were not significant (p=0.06)
| | | @1 year of age: Bayley (BSID - PDI)
| | | 8 (23%) term infants, with mean TSB 33.4 mg/dl, had abnormal and suspect BSID and clinical diagnosis.
| | | 27 (77%) term infants, with mean TSB 26.5 mg/dl, scored normal on the BSID.
| | | “Correlation between Bayley motor score and TSB was 0.59 (p<0.01)”
Chen, 1995 96017937 | 72 (22) | 39% 10–15 | @1 year of age: DDST and Neurological exams | PhotoRx; BET | C
| | 32% 15–20 | None (0%) of the infants w/ TSB 10–20 mg/dl showed any abnormality in the DDST and neurological examination.
| | 29% >20 | Among infants w/ TSB > 20 mg/dl, 4 (22%) were abnormal in gross motor and fine motor skills of DDST.
Grunebaum, 1991 91231060 | 46 | 12.06±2.6 | @age 31.1±16.6 months: Growth, Neurological exam, DDST | PhotoRx; Lost to follow-up | C
| | | Growth and neurological examination were normal in all infants
| | | 2 (4%) had abnormal DDST, but all had normal DDST repeated 1 month later
Holmes, 1968 68310019 | 63 (17) ^d^ | 6.4–24 (46% 6.4–12.5; 54% 15–24) | @4 years 7 months - 7 years 8 months: Neurologic examination;s Motor development (Oseretsky test); Audiometric exams | Age; BET; Streptomycin | C
| | | In normal FT babies, mild to moderate hyperbilirubinemia is not associated with findings on Oseretsky motor development test.
| | | All had normal hearing, including subset with streptomycin Rx.

a 60% ABO incompatibility [56% of controls has ABO incompatibility as well]

b Including 10% preemies and some hemolytic diseases

c 29% ABO incompatibility; 2% G6PD deficiency; 69% unknown cause of jaundice

d All causes of jaundice were included in the study

e 43% term+ 57% preterm (mean GA 36.6±3.5 wk.). 44% LBW; 16% ABO incompatibility; 16% sepsis; 6% congenital syphilis

f 26.7% had ABO incompatibility and 63.3% had idiopathic hyperbilirubinemia

g 44% ABO incompatibility, 16% Rh incompatibility; 40% non-hemolytic jaundice

Vohr, Lester, Rapisardi, et al. (1989) or Vohr, Karp, O'Dea, et al. (1990) divided 50 term infants into either a group with low bilirubin of <8mg/dl or a group with moderate bilirubin of 10 mg/dl to 20 mg/dl. The Brazelton Neonatal Behavioral Assessment Scale (BNBAS) was administered between the second day and fifth day of life (mean ± S.D.; 65± 22 hours in moderate bilirubin group; 57 ± 13 hours in low bilirubin group, differences not significant). Some of these infants had positive Coombs test. None of the patients in the low bilirubin group received phototherapy. Seventeen of 23 patients in the moderate group received phototherapy. Partial correlation analysis controlling for phototherapy revealed that increased bilirubin concentration correlated negatively with BNBAS in state range (r= -0.28), orientation clusters (r= -0.42), and individual Brazelton items that involve auditory processing (r = -0.39 to -0.58).

Valaes, Kipouros, Petmezaki, et al. (1980), in a selective analysis of his maternal phenobarbital study, studied 44 term and preterm infants with peak bilirubin greater than 16 mg/dl. This group consisted of infants with ABO incompatibility, G6PD deficiency and nonspecific hyperbilirubinemia. Nine of them received exchange transfusion. These subjects had neurologic examination, Visual-Motor Integration test, Draw-a-Woman test and Georgas Vocabulary test at 61 to 82 months of age. No relationship between the level of bilirubin (from 16 mg/dl to >25 mg/dl) and test results was found.

Hyman, Keaster, Hanson, et al. (1969), from an original sample of 742 infants with hemolytic disease or indirect hyperbilirubinemia of ≥ 15 mg/dl (49 of whom died in the neonatal period), followed and studied 405 infants until 4 or more years of age. Analysis of the original group of 742 neonates as compared with the study group of 405 subjects showed that 70 percent of those with bilirubin ≥ 20 mg/dl as compared with 55 percent of those with bilirubin < 20 mg/dl were followed. Three hundred sixty-eight were term. Three hundred forty-eight had Rh and 48 had ABO incompatibility. Three hundred fifty-one received streptomycin and exchange transfusion. There was no significant difference in incidence of CNS abnormalities (sensorineural hearing loss, athetosis, strabismus, seizures, minimal cerebral dysfunction) among infants exposed to different levels of bilirubin below 20 mg/dl. Infants exposed to bilirubin above 20 mg/dl had a 20 percent incidence of CNS abnormalities vs. 7 percent incidence in the group with exposure below 20 mg/dl.

Yilmaz, Karadeniz, Yildiz, et al. (2001) studied 87 (out of a possible 755) children who were term newborns with jaundice. There were no control subjects in this study. Fourteen subjects had Rh and 38 had ABO incompatibility and 35 had non-hemolytic jaundice. 11.4 percent of subjects were treated with phototherapy; 11.5 percent were treated with phototherapy and exchange transfusion. Follow-up examinations were done from 10–72 months. Neurological dysfunction was observed in 11.5 percent (10/87) of cases. These patients had significantly higher peak bilirubin levels (26.1 ± 4.9 mg/dl vs. 23.2 ± 3.4 mg/dl) and longer duration of jaundice (6.1 ± 1.9 days vs. 4.7 ± 2.4 days) than those who were neurologically normal (p<0.05). There was no statistically significant relationship between the etiology of hyperbilirubinemia and the neurological prognosis.

Agarwal, Narayan, Kumari, et al. (1998) studied 30 term newborns with bilirubin > 15 mg/dl. Ten percent had Rh incompatibility, 26.7 percent had ABO incompatibility and 63.3 percent had idiopathic hyperbilirubinemia. Fourteen received exchange transfusion; the rest had phototherapy. Two subjects had kernicterus. At one year of age, screening by DDST showed that development was normal in 100 percent of infants with bilirubin of 15–20 mg/dl, 88.9 percent of infants with bilirubin of 21–25 mg/dl, and 66.7 percent of infants with bilirubin >25 mg/dl. No further statistical details were provided.

Wolf, Beunen, Casaer, et al. (1997) and Wolf, Wolf, Beunen, et al. (1999) studied the effect of maximum serum bilirubin in excess of 23.4 mg/dl on the neurodevelopmental outcome of 50 Zimbabwean neonates at four months and at one year of age. All received phototherapy, twenty-six were preterm infants, seven had sepsis without meningitis and seven received exchange transfusion. Out of 50 infants with serum bilirubin greater than 23.4 mg/dl, forty-five were evaluated at 4 months using the infant motor screen; six infants scored abnormal, six scored suspect. Forty-three were followed until one year of age, two died and five were lost to follow-up. Eleven scored within abnormal range on the Bayley Scales of Infant Development at 1 year of age and five developed the choreo-athetoid type of cerebral palsy. All of those infants were either preterm babies or had hemolytic diseases. All term infants without hemolysis and with bilirubin levels between 23.4 mg/dl and 29.2 mg/dl were normal at one year of age.

Chen and Kang (1995) studied Visual Evoked Potentials (VEP) in 72 term infants with hyperbilirubinemia and 22 control infants in four sessions for 8 weeks after birth. Reasons for jaundice were not stated. Infants with bilirubin >15 mg/dl were treated with phototherapy. Those with bilirubin ≥ 20 mg/dl also had exchange transfusion. The levels of maximum bilirubin found positively related to the wave latencies of first VEP. Within 8 weeks after birth, the wave latencies were significantly prolonged in infants in the severe (20 to 29.8 mg/dl) and moderate (15 to 18.6 mg/dl) groups than in the controls (4.8 to 8 mg/dl). Neurological examination and the Denver Developmental Screen Test (DDST) were performed on 62 of the term infants with neonatal hyperbilirubinemia at 1 year of age. Of the sixty-two, 24 infants belonged to the low (11.6 to 14.4 mg/dl), twenty to the moderate and 18 to the severe groups. None of the infants in the low and moderate groups showed any abnormality in the neurological examination and DDST. In the severe group, four of the 18 infants were abnormal in gross motor and fine motor skills of the DDST. One of these four infants showed general hypotonia, and his VEP's showed markedly low amplitudes and prolonged peak latencies for 8 weeks. Statistical analyses of the neurodevelopmental findings were not presented.

Grunebaum, Amir, Merlob, et al. (1991) enrolled 60 term and pre-term infants at 3 weeks of age into a breast milk jaundice study. Most infants were seen at out-patient clinic during the end of the second week of life (25 percent) or during the third week of life (28.3 percent). 13.3 percent were seen at an age of 5 weeks after birth or later. Infants, in whom the jaundice resolved within 3 weeks, were excluded from the study. Range of bilirubin at presentation was 4.2 mg/dl to 16.8 mg/dl. Fifteen infants received phototherapy. In 14 infants there was a brief interruption of nursing (in 13 cases for 24 hours and in one case for 48 hours). Forty-six subjects had neurodevelopmental examination between 10 and 60 months (mean age 31.1 ± 16.6 months). Their neurological examination was normal. All children had normal DDST except for two children. One had a delay in language ability and the other a delay in fine motor ability. A repeat DDST one month later was normal in both children.

Holmes, Miller, and Smith (1968) studied 63 children with neonatal bilirubin of 6.4 mg/dl to 24 mg/dl and 17 control children without neonatal clinical jaundice. These 80 children were selected out of a total of 195 available subjects. Only babies ≥ 2.5 Kg and who received more than one bilirubin determination were included in the experimental group. All causes of jaundice were included in the study. One case was excluded because he and his father displayed bizarre behavior. Another was excluded because he was mentally retarded; his bilirubin was in “low” range of 6–12 mg/dl. Eleven of 63 received exchange transfusion and 13 of 63 received streptomycin. A modified Oseretsky motor test and audiometry were performed in these children from 4 years 7 months to 7 years 8 months. The authors found no relationship between hyperbilirubinemia and the Oseretsky motor development test. Authors further noted that none of the subjects developed hearing impairment.

### Effect of Bilirubin on Brainstem Auditory Evoked Potential (BAEP)

This next group of studies primarily looks at the effect of bilirubin Brainstem Auditory Evoked Potential (BAEP) in eight studies, in nine publications; and, hearing impairment in six studies (see Tables 3.7, 3.8 and Evidence Table 1).

Table 3.7 Effect of Serum Bilirubin Levels on Auditory Brainstem Response & Hearing deficit in All Infants

Author, Year, UI # | Subjects N (Control) | Peak Bilirubin Level (range) mg/dl | Outcomes | Confounders | Quality
Tan, 1992 92139200 | 30 (31) | 16.7 | @0–3 days of Rx: BAER | PhotoRx | A
| | | In PhotoRx group, there was significant difference between the preexposure and postexposure values of latency V and IPL III–V and I–V.
| | | The correlation between the bilirubin levels and the BAER values during PhotoRx was significant r=0.967 and p<0.001 for latency V; r=0.999 and p< 0.001 for IPL I–V; and r=0.963 and p< 0.001 for IPL III–V.
Valaes, 1980 81031849 | 44 ^d^ (445) | 47% 16–20 | @61–81 months of age: Sensorineural hearing defect | Prematurity; BET; PB exposure | B
| | 29% 20–25 | Sensorineural hearing defect was significantly more common in children with moderate (bilirubin >12 mg/dl) or marked (bilirubin > 16 mg/dl) neonatal jaundice than in the children with slight or no jaundice (9.2% vs. 1.1%).
| | 24% >25
Hyman, 1969 69132491 | 351 ^b^ | ≥ 15 | @4 years of age: Hearing loss | BW | B
| | | Infants with TSB ≥ 20 mg/dl (N=108) had significantly higher prevalence of sensorineural hearing loss (10%), than infants with TSB < 20 mg/dl (N=243) (2%).
Johnston, 1967 67081206 | 129 ^c^ (95) | >20 | @5–6 years of age: Audiological assessment | BET; Prematurity | B
| | | Infants with TSB > 20 mg/dl had significantly more sensorineural hearing loss (7%), compared to infants with “low” bilirubin levels (0%).
Suresh, 1997 98374505 | 42 ^g^ | Neonatal: 26.6±5.8 | @2 months to 21 years old: Hearing loss | Rx for hyperbiliru-binemia; Prematurity | C
| | Postnatal: 20.5±5.5 | Hearing was normal in 94% patients. No sensorineural hearing loss (reported in 36 patients).
Boo, 1994 95018454 | 28 ^e^ (100) | 21.6±7.5 [18.4±7.4] | @11.6±3.9 days: Hearing loss | PhotoRx | C
| | | 16% (13/83) of subjects with bilirubin < 19.8 mg/dl vs. 33% (15/45) of subjects with bilirubin > 19.8 mg/dl had hearing loss. The difference was not significant.
| | | Logistic regression analysis showed that the significant risk factors associated with hearing loss in the term jaundiced neonates were exchange transfusion and age of onset of hyperbilirubinemia.
Esbjorner, 1991 91281442 | 9 ^a^ | 20.3 (16.4–25.6) | @4 (3.5–6) days, post Rx: ABR | PhotoRx | C
| | | Significant correlation between the latencies to wave I, III, V, IPL I–V and the reserve albumin concentration (r=-0.89, p<0.01), but no significant correlation between the latency to wave V and the total bilirubin concentration was found (r=0.02, p=0.95)
Rosta, 1971 72185033 | 84 ^f^ | ≥ 15 | @8 years of age: Hearing loss | BET, Streptomycin Rx | C
| | | Severe sensorineural hearing loss were detected in 5 (6%), a mild to moderate one in 9 (11%) patients. “The above incidence was surpassing the frequency of similar alterations in the normal population.”

a One infant had ABO incompatibility

b Including 10% preemies and some hemolytic diseases

c 71% iso-immunization; 20% ABO incompatibility

d 29% ABO incompatibility; 2% G6PD deficiency

e Non-physiologic causes of jaundice were known in 39 subjects but details were not provided

f “Nearly equal distribution Rh and ABO immune-hemolysis, and hyperbilirubinemia of unknown origin”

g All patients, age 2 months to 21 years old, were Crigler-Najjar syndrome type 1, resulting in life long jaundice.

Table 3.8 Mean Latencies and Interpeak Latencies of Brainstem Auditory Evoked Response (BAER) in All Infants (GA ≥ 34 weeks)

Author, Year, UI # | Sample N (Control) | Peak Bilirubin Level (range) mg/dl | Mean Latency (msec) | | | Mean Interpeak (msec) | | | Confounders | Quality
| | | I | III | (IV),V | I–III | III–V | I–V
Tan, 1992 92139200 | 30 (31) | 16.7 | 1.75 [1.77] | 4.56 [4.54] | 7.00 [6.75] | 2.80 [2.77] | 2.44 [2.25] | 5.25 [5.00] | None | A
Vohr, 1989 89328704 | 25 ^a^ (25) | 13.5±2.6 (10.2–19) | 1.8 [1.8] | 4.5 [4.3] | 7.5 [7.3] | 2.7 [2.6] | 3.0 [3.0] | 5.8 [5.5] | PhotoRx | A
Vohr, 1990 90339225
Gupta, 1998 98355379 | 15 (15) | 21.98 (18.4–26.4) | - | - | - | 2.94 [2.48] | 3.65 [3.20] | 6.00 [5.12] | sedation; hemolytic disease; (Unknown Rx effect) | B
| 30 (15) | 16.6 (15.8–18.0) | - | - | - | 2.65 [2.48] | 3.34 [3.20] | 5.83 [5.12]
| 45 ^c^ (15) | 18.4 (15.8–26.4) | - | - | - | 2.88 [2.48] | 3.50 [3.20] | 5.92 [5.12]
Sabatino, 1996 97171477 | 48 (42) | 4–25.8 | 1.9 [1.8] | 4.8 [4.0] | 8.1 [7.0] | 3.0 [2.3] | 3.1 [2.9] | 6.1 [5.2] | None | B
Perlman, 1983 84041257 | 24 ^b^ (19) | 18.7±2.7 | - | - | - | 2.77 [2.67] | 3.20 [3.09] | 5.97 [5.75] | PhotoRx; BET | B
Agrawal, 1998 99232291 | 30 ^e^ (25) | 22.4±2.7 | 1.8 [1.7] | 4.8 [4.5] | 7.3 [6.7] | 3.0 [2.8] | 2.4 [2.2] | 5.4 [5.1] | None | C
Gupta, 1990 91244386 | 25 ^d^ (20) | 20–35 | 1.98 [1.96] | 5.22 [5.01] | 7.34 [7.10] | - | - | 5.36 [5.14] | BET; | C

Bold = significantly different (p < .05)

n.s. = not significantly different

* = significantly different between pre- and post- treatment

a 60% ABO incompatibility [56% of controls has ABO incompatibility as well]

b 40% Rh incompatibility; 25% ABO incompatibility

c 38% G6PD deficiency; 20% ABO incompatibility

d 28% ABO incompatibility, 40% Rh incompatibility; 5% Subaponeurotic bleed

e 10% had Rh incompatibility, 26.7% had ABO incompatibility and 63.3% had idiopathic hyperbilirubinemia

[ ] Controls' value; Abn = abnormal = IPL I–V values > 4.34±0.15 msec; VEP =Visual Evoked Potential

Tan, Skurr, and Yip (1992) presented similar findings in a group of 30 healthy non-hemolytic term infants with mean bilirubin of 15 mg/dl and who had undergone phototherapy. When compared to control (bilirubin <8.2 mg/dl), this group of infants who had prolonged BAEP latency V (p<0.02) and interpeak latencies III–V (p<0.05). Concomitant improvement occurred in these values as the bilirubin levels declined in response to phototherapy.

Vohr, Lester, Rapisardi, et al. (1989), in a separate study of 50 term infants (some with ABO incompatibility, none with Rh incompatibility), found that moderate bilirubin group had significantly prolonged brain-stem conduction time. Correlation analysis showed that serum bilirubin values correlated positively with brain-stem conduction time (r = 0.36, p<0.01).

Vohr, Karp, O'Dea, et al. (1990), in the same study mentioned above, found increased bilirubin concentration correlated with an increased latency of brain-stem auditory evoked response in wave 4, 5 (latency of 7.50 ± 0.29 msec in the moderate bilirubin group vs. 7.32 ± 0.26 msec in the low bilirubin group, p<0.05).

In a similar study, Gupta and Mann (1998) performed BAEP's on 60 neonates (37–40 week gestation). Forty-five patients with bilirubin levels ranging from 15.8 mg/dl to 26.4 mg/dl were compared to 15 control patients who were either clinically non-jaundiced or had bilirubin < 12 mg/dl. Causes of hyperbilirubinemia included G6PD deficiency, ABO incompatibility and unknown reasons. Treatment information was not provided. A positive correlation was found between increasing levels of serum bilirubin and brain stem conduction time (P<0.01). Retest at one month of age showed 33.33 percent of cases with a mean serum bilirubin of 19.46 mg/dl and 80 percent with a mean bilirubin of 15.97 mg/dl showed total recovery. After 6 months, three cases with a mean bilirubin of 26.3 mg/dl and one case with a mean bilirubin of 17.7 mg/dl failed to show any improvement. The authors also concluded that neonates with distortion of normal wave patterns on BAEP's were found to have a poorer prognosis compared with those with delayed inter-peak (I-P) latencies.

Sabatino, Verrotti, Ramenghi, et al. (1996) studied brain stem auditory evoked potentials (BAEP) in 90 full-term newborns with jaundice. After enrolling only the subjects that showed the three major BAEP components (waves I, III and V), 48 full-term subjects with bilirubin from 13.9 to 25.8 mg/dl and without evidence of hemolysis were followed over a 3-year period. BAEP's were performed on day 3 and repeated 5–7 days post phototherapy or exchange transfusion until the bilirubin had decreased below 8 mg/dl. On day 3, latencies of waves III and V were significantly increased compared to control subjects. Recordings performed 5 to 7 days post therapy showed no significant differences during subsequent session. Serial neuropsychological evaluations at 6, 18 and 30 months using the Brunett-Lezine test showed no neurodevelopmental abnormality. Statistical analyses of the neuropsychological evaluations were not given.

Perlman, Fainmesser, Sohmer, et al. (1983) studied BAEP's in 24 neonates (37–41 week gestation) with bilirubin levels of 15 mg/dl to 25 mg/dl. Six had ABO incompatibility, one had Rh incompatibility, two had hemorrhage and the remainder had unknown reasons for jaundice. All 24 received phototherapy; three infants also received exchange transfusion. Nineteen neonates who were either clinically non-jaundiced or had bilirubin levels <12 mg/dl served as control. Hyperbilirubinemic infants had prolonged brainstem transmission time (P<0.01). Wave complex IV–V was present in all 19 control infants; it was absent in at least one recording of 10 of 24 jaundiced infants (P<0.001). Nine of 13 infants who had sequential studies over several days showed apparent improvement manifested by the subsequent appearance of waves that were initially absent or by shortening of initially prolonged latency.

Agrawal, Shukla, Misra, et al. (1998) in the previously mentioned study of 30 term newborns with bilirubin > 15 mg/dl, recorded BAEP's in these infants before and after phototherapy or exchange transfusion and at the age of 2 to 4 months. Seventeen of 30 infants showed abnormalities on initial BAEP's; these abnormalities correlated significantly with bilirubin level. After therapy, abnormalities reverted back to normal in 10 cases but persisted in seven out of 17. Follow-up BAEP's were done in 21of 30 cases at 14.4 ± 2.2 weeks. Of the 15 patients who had an initial abnormal BAEP, in only three were there persistent abnormalities. Two of them had kernicterus.

Gupta, Raj, and Anand (1990) studied 25 term infants with bilirubin > 20 mg/dl and who received exchange transfusion. Seven had Rh and 10 had ABO incompatibility; one had a subaponeurotic bleed; seven had undetermined cause for jaundice. Twenty normal term infants without jaundice served as control. BAEP's were performed at 10 ± 3 days, just before hospital discharge. Mean latencies (wave III, V) and I–V interpeak latency (brainstem conduction time) were significantly prolonged in jaundiced neonates as compared with controls (P<0.01). BAEP abnormalities were found with greater frequency in jaundiced neonates requiring a repeat exchange transfusion (P <0.001). However, all infants had normal BAEP's on follow-up retesting at 3 months.

Valaes, Kipouros, Petmezaki, et al. (1980) followed up 415 children (233 exposed to prenatal phenobarbital, 182 were not) at 61 to 82 months of age in a prenatal phenobarbital study. None of them received phototherapy. An unspecified number had exchange transfusion. Ten children were diagnosed with sensorineural hearing defect. It was significantly more common in children with moderate (bilirubin >12 mg/dl) or marked (bilirubin > 16 mg/dl) neonatal jaundice than in the children with slight or no jaundice (9.2 percent vs. 1.1 percent; P<0.05).

Hyman, Keaster, Hanson, et al. (1969), in the previously mentioned study of patients with hemolytic disease or hyperbilirubinemia, reported that in the 351 patients who received streptomycin, there was a significant association of sensorineural hearing loss and bilirubin ≥ 20 mg/dl as tested by audiometry after age 4 years. Eleven out of 108 patients (10.2 percent) with bilirubin ≥20 mg/dl vs. Five out of 243 patients (2.1 percent) with bilirubin <20 mg/dl developed sensorineural hearing loss (P<0.001).

Johnston, Angara, Baumal, et al. (1967) studied 129 children at 5 to 6 years of age with neonatal bilirubin >20 mg/dl. Ninety-two babies had Rh incompatibility, twenty-six had ABO incompatibility and 11 had other reasons for their hyperbilirubinemia. There were 24 premature babies in this group. Ninety-five percent of the cases received exchange transfusion. Seven children in this group (five of them are full term) had sensorineural hearing loss. In the control group of 95 children with low bilirubin (11 were premature babies), there was not a single case of sensorineural hearing loss (p=0.00128). Both groups of children received streptomycin when they were neonates.

Suresh and Lucey (1997) obtained information via returned questionnaires on 42 patients (2 months to 21-years-old) with Crigler-Najjar syndrome type-1 via returned questionnaires. Mean bilirubin was 19.8 ± 4.5 mg/dl (typical) in the neonatal period. The mainstay of therapy in these patients with Crigler-Najjar was home phototherapy for 10 to 16 hours a day. Hearing was reported to be normal in 34/36 patients. The two children with hearing loss had conductive loss from otitis media.

Boo, Oakes, Lye, et al. (1994) studied brain stem evoked response in 128 jaundiced term infants at a mean age of 11.6 days (S.D.=3.9). One hundred thirty-six were originally admitted to the nursery. Eight were excluded because of aminoglycoside treatment, cyanotic heart disease and congenital infection. Non-physiologic causes of jaundice were identified in 39 subjects but details were not provided. All subjects had phototherapy. Forty-three also had exchange transfusion. Sixteen percent (13/83) of subjects with bilirubin < 19.8 mg/dl vs. 33 percent (15/45) of subjects with bilirubin > 19.8 mg/dl had hearing loss. The difference was not significant. Logistic regression analysis showed that the significant risk factors associated with hearing loss in the term jaundiced neonates were exchange transfusion and age of onset of hyperbilirubinemia.

Esbjorner, Larsson, Leissner, et al. (1991) studied 9 healthy neonates (35 to 42 week gestation) with bilirubin from 16.4 mg/dl to 25.6 mg/dl. One case of jaundice was caused by ABO incompatibility; no underlying disease was found in the rest. All received phototherapy. No significant correlation between the BAEP latency to wave V and the total bilirubin concentration was found at 4 days of age. The authors did find a statistically significant correlation between the reserve albumin concentration (as measured by monoacetyldiaminodiphenyl sulphone analysis) and the latency to wave V (r = -0.89, p<0.001).

Rosta, Makoi, Bekefi, et al. (1971) studied 84 children with neonatal bilirubin of >15 mg/dl at 7 to 9 years of age. Etiologies of hyperbilirubinemia included ABO or Rh incompatibilities, and hyperbilirubinemia of unknown origin. All subjects had birthweight ≥2,500 grams. The authors did not specify exactly how many subjects received exchange transfusion and/or streptomycin. Five out of 84 had a severe sensorineural hearing loss and nine had a mild to moderate sensorineural hearing loss. There was no control group in this study.

### Effect of Bilirubin on Intelligence Outcomes

The following group of studies looks primarily at the effect of bilirubin on intelligence outcomes. A total of eight studies were reviewed (see Tables 3.9, 3.10, and Evidence Table 1).

Table 3.9 Effect of Serum Bilirubin Level on Intelligence Outcome in All Infants (GA ≥ 34 weeks)

Study, Year, UI # | Subjects N (Control) | Bilirubin Level (range) mg/dl | Outcomes | Confounders | Quality
Bengtsson, 1974 74170112 | 111 ^g^ (115) | 20.0–51.0 | @6.5–13 years old: IQ; Sensorineural hearing loss | BET | B
| | | No statistically significant correlation was found between I.Q. and maximal bilirubin values
| | | 3 (7%) children with ABO-incompatible hyperbilirubinemia had neurogenic hearing loss, while none was found in control (P>0.05).
Rosta, 1971 72185033 | 84 ^I^ | ≥ 15 | @8 years of age: IQ | BET, Streptomycin Rx | C
| | | Distribution of IQ was the same as in the normal population. 4 (5%) children had IQ below 0.70, 11 (13%) had an IQ between 0.70 and 0.80.
Hyman, 1969 69132491 | 29 ^h^ | ≥ 15 | @4 years of age: IQ; Auditory rote memory difficulties | BET; streptomycin Rx; BW; Selection bias | C
| | | No association was found between high bilirubin exposure and low IQ (N=38).
| | | No significant difference in the prevalence of auditory rote memory difficulties between infants with TSB ≥ 20 mg/dl (N=17) and infants with TSB < 20 mg/dl (N=21)

g All had negative Coombs' tests

h from original 405 subjects, Including 10% preemies and some hemolytic diseases

i “Nearly equal distribution of Rh and ABO immune-hemolysis, and hyperbilirubinemia of unknown origin”

Table 3.10 Mean Intelligence Quotient of Children with a History of Hyperbilirubinemia

Author, Year, UI # | Sample N (Controls) | Bilirubin Level (range) mg/dl | Mean IQ | | | Confounders | Quality
| | | Full | Verbal | Performance
Seidman, 1991 91375839 | 308 ^c^ (1,496) | Var1 | 103 | - | - | PhotoRx; BET | B
| 144 ^d^ (1,496) | Var2 | 103
Bengtsson, 1974 74170112 | 66 | 20–35 | 107 | - | - | BET | B
| 45 ^a^ | 20–51 | 106 | - | -
Culley, 1970 70266548 | 73 ^b^ (48) | 12–16 | 106 | - | - | Estimated TSB levels | B
| | > 16 | 107 | - | -
Ozmert, 1996 97154941 | 13 (27) | 17–20 | 102 | 102 | 102 | Possible selection bias (Unknown Rx effect) | C
| 26 (27) | 20–22 | 103 | 106 | 101
| 27 (27) | 22–25 | 99 | 101 | 95
| 19 (27) | > 25 | 102 | 103 | 101
| 17 ^g^ (27) | > 20 | 87 | 95 | 93
Odell, 1970 70075541 | 8 (6) ^f^ | > 19 | 94 | - | - | BET | C
| | | 25% < 80
Johnston, 1967 67081206 | 129 ^e^ (82) | > 20 | 105 | - | - | BET; Prematurity | C

a 100% ABO incompatibility

b Healthy infants (no hemolytic disease; no congenital malformations; no perinatal asphyxia; no neonatal illness or infections)

c Including some infants with Coombs positive tests

d Including infants with hemolytic disease (2% subjects had Coombs positive tests)

e 71% iso-immunization; 20% ABO incompatibility

f 43% Rh incompatibility; 14% ABO incompatibility; 14% Other blood incompatibility; 21% unknown cause of jaundice

g 65% Rh and 35% ABO incompatibility

st Var1 = 5–8 mg/dl on 1 day of life, 10–15 mg/dl on the 2^nd^ day of life, or 13–20 mg/dl thereafter

st Var2 = >8 mg/dl on the 1 day of life, >15 mg/dl on the 2^nd^ day of life, and >20 mg/dl thereafter

Bengtsson and Verneholt (1974) studied 111 children with neonatal bilirubin of 20 mg/dl to 51 mg/dl and 115 controls without visible jaundice. All were healthy full-term infants with negative Coombs' test. Forty-four of the hyperbilirubinemic group received exchange transfusion. Follow-up examinations were done between 6½ to 13 years of age. No statistically significant correlation was found between IQ and maximal bilirubin values. Out of the 111 children with hyperbilirubinemia, two had athetotic coordination disturbance and four had sensorineural hearing loss, while none of the 115 controls had such disorders. The differences were not statistically significant.

Rosta, Makoi, Bekefi, et al. (1971), in the previously mentioned uncontrolled study of 84 children with bilirubin >15 mg/dl and in whom follow-up examinations were done 7 to 10 years later, found that “the distribution of IQ was the same as in the normal population. Four children had IQ below 0.70; 11 had an IQ in the range between 0.70 –0.80.” Actual comparative data to the normal population was not provided.

Hyman, Keaster, Hanson, et al. (1969), in the previously mentioned study of infants with hemolytic disease and hyperbilirubinemia of other etiology, selected 29 available patients with either sensorineural hearing loss or Minimal Cerebral Dysfunction and nine control patients without CNS abnormality for further testing after age 4 years by one psychologist. These tests included Stanford-Binet, Wechsler Intelligence Scale for Children and others. “Based on the tests used, 29 patients (22 term and seven premature) were found to have normal mentality, five (four term and one premature) had subnormal mentality, and four (three term and one premature) were of superior mentality. Patients exposed to high bilirubin [≥ 20 mg/dl] and low bilirubin [< 20 mg/dl] during the neonatal period were almost equally represented in each mentality rating. Further analyses of the five patients with subnormal mentality showed that three had very high bilirubin exposure, 30 mg/dl or greater. No other correlation between bilirubin and mentality could be made.”

Seidman, Paz, Stevenson, et al. (1991) analyzed 1,948 17-year-olds (out of a total of 2,044 from a single hospital) who had neonatal records. Bilirubin values were available in 585 (30 percent of the 1,948) infants; subjects who had no clinical jaundice and for whom bilirubin levels were not obtained were included in the mild bilirubinemia group. Subjects' transformed intelligence test scores (from verbal Otis test and nonverbal matrices test results to values that correlated with Wechsler Adult Intelligence Scale) and medical examination findings performed at the military draft board at 17 years of age were stratified according to serum bilirubin levels. No direct linear association was found between neonatal bilirubin levels and intelligence test scores. However, the risk for IQ score less than 85 was found to be significantly higher (p=0.014) among full-term Coombs-negative male subjects with serum bilirubin greater than 20 mg/dl (odds ratio, 2.96; 95% CI 1.29–6.79).

Culley, Powell, Waterhouse, et al. (1970) studied Stanford-Binet intelligence quotient at 6 years of age in 169 neonates with non-hemolytic jaundice and 159 control neonates. These neonates' birthweight ranged from <1500 g to >3000 g. Treatment information was not provided. After adjusting for either birth weight or gestation in each jaundiced group, authors concluded that “in non-hemolytic jaundice there is no evidence of reduction in intelligence quotients with increasing jaundice up to the permitted level of around 20 mg/dl.”

Ozmert, Erdem, Topcu, et al. (1996) studied 102 (out of 416) children between 8 and 13 years of age. All these children had neonatal bilirubin >17 mg/dl (17–48 mg/dl), ≥ 37 week gestation and birthweight ≥ 3000 g. Seventeen children had positive direct Coombs' test (11 Rh, six ABO incompatibility). Treatment information was not provided. The control group consisted of 27 children of the same age but without neonatal hyperbilirubinemia. The Wechsler Intelligence Scale Revised for Turkish Children and other tests were performed in these children. Children who had positive direct Coombs tests and bilirubin >20 mg/dl had lower IQ scores and more prominent neurological abnormalities than the control group (P<0.05). IQ scores and prominent neurological abnormalities did not differ among the other groups of children with negative Coombs test and hyperbilirubinemia. The authors also noted an important risk factor for prominent neurological abnormalities was the duration that the infant's serum indirect bilirubin remained > 20 mg/dl.

Odell, Storey, and Rosenberg (1970) located 32 children between the ages of 4 and 7 years of age who had a history of neonatal jaundice. These 32 children represented only a third of the total population on whom bilirubin studies were performed during neonatal life. Twenty-four had exchange transfusion. Sixteen had either ABO or Rh incompatibility. Birthweight ranged from 1400 grams to 3827 grams. Fifteen patients had birth weight >2,500 grams. Maximum bilirubin level ranged from 11.4 mg/dl to 31.6 mg/dl with a median of 19 mg/dl. Stanford-Binet or Wechsler Intelligence Scale, and other visual-motor and short-term memory tests were given to this group of children. Six chi-square analyses were performed using IQ <80, ≥ 80 vs. maximum bilirubin of 20, 21, 22, 23, 24 mg/dl and values of bilirubin <19 mg/dl and ≥ 19 mg/dl. No statistical significant relationship was found. The authors further reported that there was a significant correlation (P <0.01) between the presence or absence of brain damage (measured by psychometric testing) and the degree to which the patient's sera had been saturated with bilirubin (as determined by the salicylate displacement technique).

Johnston, Angara, Baumal, et al (1967), in the previously mentioned study of 129 children with neonatal bilirubin >20 mg/dl, found the average IQ in this group was 104.8. The control group of 82 children had an average IQ of 102.8. No further statistical analysis was provided.

### Studies from Collaborative Perinatal Project (CPP)

The following six studies were all derived from Collaborative Perinatal Project (CPP) undertaken on 56,990 pregnancies and 54,795 live births in 12 centers in US from 1959 to 1966 (see Tables 3.11, 3.12, and Evidence Table 1).

Table 3.11 Effect of Serum Bilirubin on Neurodevelopmental Outcomes in Collaborative Perinatal Project Subjects

Author, Year, UI # | Subjects (N) | Outcomes | Confounders | Quality
Newman, 1993 94021217 | CPP subjects, born from 1959 to 1966, BW>2500 g (N=41,324; 33,272 had 7-year outcome data) | @7 yr. of age: Adjusted IQ, Neurologic exams; Hearing loss | BET | A
| | No significant difference in adjusted IQ between children with TSB < 20 mg/dl and ≥ 20 mg/dl in black and white subjects.
| | There was no significant association between peak TSB and IQ (r=0.13 in whites; r=0.34 in blacks, p>0.05).
| | Risk of abnormal or suspicious neurologic exam findings increased in stepwise manner from TSB <10 mg/dl to TSB ≥ 20 mg/dl. (P<0.001) Neurologic exam items most associated with bilirubin levels were mild and nonspecific motor abnormalities.
| | 2.2% of CPP subjects had hearing loss. Adjusted OR of hearing loss was 1.08 (95% CI 0.3–3.5)
Rubin, 1979 79153498 | Subjects (N=241) both in CPP and Educational Follow-up Study( EFS); plus a control group from EFS population (N=125) | @8 months of age: Bayley MDI & PDI | Lost to follow-up; BET | B
| | Infants with TSB 16–23 mg/dl (N=153) had significantly lower Bayley MDI and PDI scores at 8 months of age, compared to infants with TSB 11–15 mg/dl (N=66) and those with TSB ≤ 10 mg/dl (N=120). Controlling for GA, there was no longer a difference on MDI, but PDI remained significant.
| | @1 year of age: Neurological exams
| | Infants with TSB 16–23 mg/dl (N=153) had significantly more neurologic abnormalities at 1 year of age, compared to infants with TSB 11–15 mg/dl (N=69) and those with SB ≤ 10 mg/dl (N=120). Controlling for GA, the difference still remained significant.
| | @5 & 6 years of age: MRT & ITPA
| | No significant differences were found between groups.
| | @7 years of age: IQ; Neurological exams
| | No significant difference was found between groups.
Scheidt, 1977 77209363 | CPP subjects, born from 1959 to 1964, only term and FT infants (GA≥36 wk and BW>2500 g) were included for current review (original sample size=24,524) | @8 months of age: Bayley MDI & PDI (White infants): | None was found (Unknown Rx effect) | B
| | PDI score was significantly decreased with elevated TSB levels (≥10 mg/dl). However, significant decrease in Bayley MDI score only occurred in white term infants with TSB≥15 mg/dl.
| | @8 months of age: Bayley MDI & PDI (Black infants):
| | For black term (GA ≥ 36 wk and BW > 2500 g) infants, both Bayley MDI and PDI scores were significantly decreased with elevated TSB levels (≥10 mg/dl).
| | No association between TSB levels and Bayley MDI and PDI scores was found in black FT subjects (GA ≥ 37 wk and BW > 2500 g).
Boggs, 1967 67261091 | CCP subjects, born from 1959 to 1966, BW > 2500 g (N=18,484) | @8 months of age: Bayley MDI & PDI | Hemolytic disease; BET; Congenital malformation | B
| | For infants with BW 2501–3000 g (N=4,916), the estimated increase in percent of infants with a low PDI score was 1.2% for each 1 mg/dl rise in TSB level. The estimated increase in percent of infants with a low MDI score was 0.8% for each 1 mg/dl rise in TSB level.
| | For infants with BW ≥ 3000 g (N=13,568), the estimated increase in percent of infants with a low PDI score was 0.5% for each 1 mg/dl rise in total SB level. The estimated increase in percent of infants with a low MDI score was 0.3% for each 1 mg/dl rise in TSB level.
Naeye, 1978 79054333 | CPP subjects, born from 1959 to 1966, mixed term and preterm infants (N=41,444) | @4 yr. of age: IQ | Prematurity, Placental infection (Unknown Rx effect) | C
| | Increased frequency of mental impairment in subjects with peak bilirubin > 7 mg/dl
| | The frequency of low IQ with increasing bilirubin levels increased more rapidly in infected infants.
| | @7 yr. of age: Neurologic exam
| | An increase in the prevalence of abnormalities started at peak neonatal bilirubin levels of 12 to 13 mg/dl.
| | Neurologic abnormalities were more prevalent in subjects who had amniotic fluid infections.

MRT = metropolitan readiness tests

ITPA = Illinois test of psycholinguistic ability

Table 3.12 Mean Intelligence Quotient of Children from Collaborative Perinatal Project Cohort

Author, Year, UI # | Sample N (Controls) | Peak Bilirubin Level (range) mg/dl | Mean IQ | Confounders | Quality
Newman, 1993 94021217 | 41,324 ^a^ | < 10 | White:104; Black: 93 | BET | A
| | 10–15 | White: 103; Black: 93
| White: 21,375 | 15–20 | White: 104; Black: 93
| Black: 19,949 | 20–25 | White: 105; Black: 91
| | ≥ 25 | White: 106; Black: 90
Rubin, 1979 79153498 | 203 ^b^ (114) | 11–15 | 102 | Lost to follow-up; BET | B
| | 16–23 | 102
Upadhyay, 1971 71238892 | 20 ^c^ (20) | > 20 | 94 (10% < 80) | BET | C

Bold = below normal range

a Including infants with hemolytic disease (2% subjects had positive Coombs' tests)

b Subjects were from CPP, likely to include hemolytic jaundice and jaundice due to infections (not explicitly stated)

c 50% ABO incompatibility; 35% Rh incompatibility; 5% Septicemia with a gram-negative organism

From the CPP sample of 54,795 live-born infants, Newman and Klebanoff (1993) excluded infants who were not singletons, with birthweight < 2,500 grams or unknown, with race other than black or white, in whom no bilirubin measurement was recorded and the ones who died before their first birthday. This resulted in a study sample of 41,324 (or 75.4 percent of the original CPP sample) singleton black or white infants with birthweight ≥ 2,500 grams, who survived for at least 1 year and had at least one bilirubin level recorded. Outcome data at 7 years were available on approximately 80 percent (33,272 out of 41,324) of these infants. Neonatal bilirubin levels were not associated with loss to follow-up. IQ was measured using the Wechsler Intelligence Scale for children at age 7.1 ± 0.4 years (mean ± SD) in whites and 7.2 ± 0.8 years in blacks. Neurologic examinations were done at 1 and 7 years of age. Only results at age 7 years were presented; results at age 1 year were similar. The result was classified into normal, suspicious and abnormal. Hearing evaluations were done at 3 years ± 2 months and 8 years ± 3 months using pure-tone audiometry. Hearing examination at 8 years was “discontinued for administrative reasons” at six of the 12 centers. Thus, subjects for whom hearing data were available were not representative of the cohort as a whole. There was no consistent association between peak bilirubin level and IQ. To compare results with those of Naeye (see below) and Seidman et al (see above), IQ scores were dichotomized to <85 or ≥85. There was no association between bilirubin levels and dichotomized IQ in either race. The risk of abnormal or suspicious neurologic examination results increased in a stepwise manner from 14.9 percent (4,346 out of 29,258) in the group whose maximum bilirubin level was <10 mg/dl to 22.4 percent (60 out of 268) in the group whose maximum bilirubin was ≥ 20 mg/dl (P<0.001). Athetosis was not associated with peak bilirubin levels in this study. The proportion of children with sensorineural hearing loss at age 8 years was about 2 percent regardless of bilirubin level. However, authors noted that “because a comparatively small subset [16,886 out of 33,272 subjects at 8 years or 51 percent] of the CPP received hearing examinations and sensorineural hearing loss was uncommon, the power to detect an effect of very high bilirubin levels was limited."

Rubin, Balow, and Fisch (1979) enrolled all 241 subjects with maximum bilirubin of 11 mg/dl and above from the 1,613 participants both in the Educational Follow-up study (EFS) and the Minnesota section of the Collaborative Perinatal Project into a study trying to determine the relationship of neonatal hyperbilirubinemia to cognitive development at ages 4 through 7. One hundred and sixty-four subjects with bilirubin levels from 11 to 15 mg/dl were classified as the moderately elevated group; 77 subjects with bilirubin from 16 to 23 mg/dl were classified as the high bilirubin group. A control group of 125 subjects with bilirubin levels of 0–10 mg/dl was randomly drawn from the remainder EFS population and designated as the low bilirubin group. Nine subjects from the high and moderate bilirubin groups and one from the low bilirubin group had respiratory distress. Fourteen (18.2 percent) of the high bilirubin group had exchange transfusions. Bayley scales of Mental and Motor Development were administered at 8 months. IQ measures were obtained at age 4 using the Stanford-Binet, Short form L-M, and at age 7 using the Wechsler Intelligence Scale for Children. Neurologic examinations were administered at 1 year and 7 years. At age 8 months, high bilirubin group had a lower mean Bayley Motor Score the low bilirubin group (p<0.05). At age one year, high bilirubin group also has more neurologic abnormalities than the low bilirubin group (p=0.007). There were no significant differences found amongst bilirubin groups on the Stanford-Binet at age 4, Wechsler Intelligence Scale or the neurologic examinations at age 7.

Scheidt, Mellits, Hardy, et al. (1977), using the CPP population, analyzed the relationships between maximum bilirubin levels and neurodevelopment at 8 months and at 1 year of age. This study included white and black infants. Infants from multiple births, with Down syndrome, meningomyelocoele, hydrocephalus and congenital heart disease were excluded. Only those infants examined within a narrow time frame were included. 24,524 infants were examined at age 8 months ± 2 weeks and 27,720 were examined at age 12 months ± 4 weeks. The effects of bilirubin were evaluated within five birthweight/gestational age categories suggested by Yerushalmy. The two groups that are of particular interest to the present report are group 4 (>2,500 grams and ≥ 36 weeks) and group 5 (>2,500 grams and ≥ 37 weeks). A significant difference in Bayley motor score occurred with bilirubin ≤ 9 mg/dl vs. 15 to 19 mg/dl for white groups 3, 4 and 5 and for black groups 1, 2 and 4 (P≤0.05). A significant difference in motor scores also occurred with bilirubin ≤ 9 mg/dl vs. 10 to 14 mg/dl for white group 3, 4, 5 and black groups 1, 2, 3, 4 (P ≤ 0.02). Infants in group 2 (1,501 – 2,500 g, ≤ 36 weeks) had most variables in the 8 months Bayley and 1-year neurologic examination associated with increased level of bilirubin.

Boggs, Jr., Hardy, and Frazier (1967) compiled a preliminary report of approximately 23,000 subjects from the CPP and their 8-months standardized Bayley scores. The subjects were singletons; some had Coombs positive hemolysis, some had exchange transfusions and some had congenital malformations (analysis excluding infants with congenital malformations was essentially unchanged). Authors found that there was a significant (p<0.005) linear association between the maximum bilirubin levels and low motor score (<27) at 8 months. This trend was observed in all birthweight groups. The slope of the regression line was steeper in the low birthweight group. Similar findings were reported for the mental score.

From the CPP population, Naeye (1978) excluded subjects with multiple births, major congenital malformation, chromosomal disorders, lead intoxication, metabolic problems, CNS diseases, congenital syphilis and rubella. Subjects with mothers who had severe hypotension during labor or delivery or who were drug or alcohol addicted were also excluded. 45,347 infants were available for analysis regarding the relationship of hyperbilirubinemia, amniotic fluid infections, and neurodevelopmental outcomes at 1 year and 7 years. Neutrophil infiltration of the subchorionic plate of the placenta was taken as evidence of amniotic fluid infection. With or without amniotic infection, authors reported an increased frequency of IQ<90 at age 4 years with peak bilirubin ≥ 7 mg/dl. The incidence of IQ ≤ 90 with rising bilirubin levels increased more rapidly in infants with amniotic infection than in infants without. Authors also reported an increase in abnormal neurologic tests at 7 years of age, starting at peak bilirubin levels of 12 to 15 mg/dl.

In another study relating neonatal bilirubin to neurodevelopmental outcome, Upadhyay (1971), using the CPP subgroup from Johns Hopkins, identified 34 subjects (out of 4,195) with birthweight > 2,500 grams and maximum bilirubin > 20 mg/dl. Twenty subjects were evaluated. Fourteen out of 34 were excluded (five were evaluated prior to standardization of the bilirubin method, six were infants of high risk mothers, two were lost to follow-up and one child died at 14 months of kernicterus). Etiologies of hyperbilirubinemia included ABO and Rh incompatibility, sepsis and unknown reasons. Eleven had exchange transfusions. There were 20 matched control subjects with bilirubin less than 10 mg/dl. There was no difference in mean IQ at age 4 years between the two groups. However, in the psychological evaluation, eight out of 20 in the high bilirubin group vs. three out of 20 in the control were rated as non-normal (P<0.01).

## Question 2 What is the evidence for effect modification of the results in Question #1, by gestational age, hemolysis, serum albumin, and other factors?

There is only one paper that directly addressed the above question (See Evidence Table 1.A). Naeye, using the CPP population, found at age 4 years, the frequency of low IQ with increasing bilirubin levels increased more rapidly in infants with infected amniotic fluid. At age 7 years, neurologic abnormalities were also more prevalent in that subgroup of infants.

In the previously mentioned studies by Wolf, Beunen, Casaer, et al (1997) and Wold, Wolf, Beunen, et al. (1999) on 50 Zimbabwean infants with bilirubin > 23.4 mg/dl, the researchers found 11 infants with abnormal scores on the Bayley Scales at 1 year of age and five who developed choreo-athetoid cerebral palsy. All those infants were either preterm babies or had hemolytic diseases. All term infants without hemolysis and with bilirubin between 23.4 and 29.2 mg/dl were normal at one year of age.

When comparing the group of term/near-term infants with comorbid factors who had kernicterus to the group of infants with idiopathic hyperbilirubinemia and kernicterus, the overall mean bilirubin was 31.6 ± 9 mg/dl in the former vs. 35.4 ± 8 mg/dl in the latter (difference nonsignificant). Infants with G6PD deficiency, sepsis, ABO or Rh incompatibility had similar mean bilirubin levels. Infants with more than one comorbid factor had slightly lower mean bilirubin of 29.1 ± 16.1 mg/dl.

Eighteen of twenty-three (78 percent) term infants with idiopathic hyperbilirubinemia and who developed acute kernicterus survived the neonatal period with chronic sequelae. Thirty-nine of forty-one (95 percent) term infants with kernicterus and ABO or Rh incompatibility had chronic sequelae. Four of five (80 percent) infants with sepsis and kernicterus had chronic sequelae. And all four infants with multiple comorbid factors had sequelae.

There was no direct study concerning serum albumin level as an effect modifier of neurodevelopmental outcome in infants with hyperbilirubinemia. There was one report that found a significant association between reserve albumin concentration and latency to wave V in BAEP studies (Esbjorner, Larsson, Leissner, et al, 1991).

In addition, Ozmert, Erdem, Topcu et al. (1996) noted important risk factors for prominent neurological abnormalities were exchange transfusion and the duration that the infant's serum indirect bilirubin remained above 20 mg/dl.

All the above factors require further studies to understand the nature of neurodevelopment in relation to bilirubin physiology.

## Question 3 What are the quantitative estimates of efficacy of treatment at (1) reducing peak bilirubin levels (e.g., number needed to treat at 20 mg/dl to keep TSB from rising); (2) reducing the duration of hyperbilirubinemia (e.g., average number of hours by which time TSB greater than 20 may be shortened by treatment); and (3) improving neurodevelopmental outcomes?

### Description of Included Studies

A total of 21 publications are included in this section. Four publications addressed the efficacy of phototherapy for prevention of total serum bilirubin (TSB) levels exceeding 20 mg/dl, eight studies reported the treatment effect on decreasing serum bilirubin levels and changing auditory brainstem response of jaundiced infants (see Evidence Table 2), and nine studies examined the effects of treatments for hyperbilirubinemia on infants' neurodevelopmental outcomes (see Evidence Table 3). As described in Chapter 2, articles concerning only treatments for reducing peak bilirubin levels or the duration of hyperbilirubinemia without measures of neurodevelopmental outcomes were not included in our current review, with the exception of four studies concerning Number-Needed-to-Treat (NNT).

### Efficacy of Phototherapy for Prevention of TSB Exceeding 20 mg/dl

Four publications examined the clinical efficacy of phototherapy for prevention of TSB exceeding 20 mg/dl, shown in Tables 3.13 and 3.14. Of the four studies, three are randomized controlled trials (RCT) (Brown, Kim, Wu, et al., 1985; Martinez, Maisels, Otheguy, et al., 1993; Maurer, Kirkpatrick, McWilliams, et al., 1985) and one controlled trial was not randomized (John, 1975).

Table 3.13 Summary Individual Studies of Efficacy of Phototherapy for Prevention of TSB Exceeding 20 mg/dl, in Healthy ^a^, Term or Near-Term (GA≥34) Infants

Study, Year, UI# | Country | Subject Details | Phototherapy Protocol | Outcome | Study Design | Quality
Brown, 1985 85112402 | US | Racially diverse jaundiced infants with BW > 2500 g TSB > 13 mg/dl | Continuously PhotoRx began at the time the SB level reached 13 mg/dl in the first 96 hrs. Duration of PhotoRx was 96 hrs. Infants' eyes were covered. | ET: carried out when SB > 20 mg/dl in both groups | RCT | A
Maurer, 1985 85112404
Martinez, 1993 93141315 | US | FT breast-fed infants with SB ≥ 17 mg/dl | (I) Continue breast-feeding, administer PhotoRx | SB ≥ 20 mg/dl | RCT | A
| | | (II) Discontinue breast-feeding, substitute formula, and administer PhotoRx.
| | | Infants' eyes were covered.
John, 1975 75183114 | Australia | Mature infants who developed unexplained jaundice with SB > 15 mg/dl | Each course consisted of a continuously PhotoRx for 18 hrs, followed by a 6 hour break. 3 or 4 courses were given. Infants' eyes were covered. | ET: carried out when SB > 20 mg/dl in both groups | Non-RCT | C

a Healthy = no hemolytic disease; no congenital malformations; no perinatal asphyxia; no neonatal illness or infections

Non-RCT = nonrandomized control trial

ET = exchange transfusion

Table 3.14 Number Needed to Treat at TSB Level of 20 mg/dl to Keep TSB from Rising by Phototherapy in Healthy a Jaundiced Term or Near-term (GA≥34) Infants

Study, Year, UI# | Groups | No. of Infants whose SB>20 mg/dl (%) | Total number of Infants | Mean SB level at entry (range, mg/dl) | Follow-up | ARR | NNT (95%CI)
Brown, 1985 85112402 | Ctrl grp I ^b^ | 10 (17) | 60 | ≥ 13 | 144 hrs | +0.5% | -
| Rx grp I ^b^ | 12 (17) | 70
*sample from NICHD trial | Ctrl grp II | 13 (17) | 76 | ≥ 13 | 144 hrs | 14.3% | 7
| Rx grp II | 2 (3) | 70 | | | | (6–8)
Maurer, 1985 85112404 | Ctrl grp I ^c^ | 6 (20) | 30 | 15.8 (13–23) | 144 hrs | +0.6% | -
| Rx grp I ^c^ | 7 (21) | 34 | 16.5 (10–23)
*sample from NICHD trial | Ctrl grp II ^d^ | 17 (16) | 106 | 15.6 (10–24) | 144 hrs | 9.4% | 11
| Rx grp II ^d^ | 7 (7) | 106 | 15.5 (10–22) | | | (10–12)
Martinez, 1993 93141315 | Ctrl grp I | 6 (24) | 25 | 17.8 | 48 hrs | 10.1% | 10
| Rx grp I | 5 (14) | 36 | 18.0 | | | (8–11)
| Ctrl grp II | 5 (19) | 26 | 17.8 | 48 hrs | 16.6% | 6
| Rx grp II | 1 (3) | 38 | 17.9 | | | (5–7)
John, 1975 75183114 | Ctrl grp | 70 (18) | 381 | 15–18 | ND | 11.2% | 9
| Rx grp | 8 (7) | 111 | | | | (8–10)

a Healthy = no hemolytic disease; no congenital malformations; no perinatal asphyxia; no neonatal illness or infections

b Hemolytic disease group (infants with hemolysis, high risk group). BET were carried when infants' SB >18 mg/dl in the high risk group.

c Coombs' test positive (91% ABO incompatibility; 9% Rh incompatibility)

d Including some infants in the high-risk group. ET were carried when infants' SB >18 mg/dl in the high risk group.

ARR = absolute risk reduction rate; NNT = number needed to treat

Two studies (Brown, Kim, Wu, et al., 1985; Maurer, Kirkpatrick, McWilliams, et al., 1985) evaluated the same sample of infants. Both reports were derived from a RCT of phototherapy for neonatal hyperbilirubinemia commissioned by the National Institute of Child Health and Human Development (NICHD) between 1974 and 1976.

Because the phototherapy protocols differed significantly in the remaining studies, their results could not be statistically combined, and are reported separately here. A total of 893 term or near-term jaundiced infants (325 in the treatment group and 568 in the control group) were evaluated in the current review.

The development, design, and sample composition of NICHD phototherapy trial was reported in detail elsewhere (Bryla, 1985). NICHD's controlled trial of phototherapy for neonatal hyperbilirubinemia consisted of 672 infants who received phototherapy and 667 control infants. Of the 672 subjects in the treatment group, 140 had a birthweight ≥ 2,500 grams; all had gestational age (GA) ≥ 34 weeks. Of the 667 control infants, 136 had a birthweight ≥ 2,500 grams; all had a GA ≥ 34 weeks. The racial composition of the total 276 term/near-term subjects was 26 percent black, 38 percent Mexican-American, and 36 percent non-black/non-Mexican-American. Males represented 59 percent of the total sample.

Brown, Kim, Wu, et al. (1985) evaluated the efficacy of phototherapy for prevention of the need for blood exchange transfusion (BET) in NICHD's study population. For the purpose of current review, only the subgroup of 140 infants in the treatment and 136 in the control groups with BW ≥ 2,500 grams and GA ≥ 34 weeks were evaluated. The serum bilirubin level as criterion for BET in infants with BW ≥ 2,500 gram was 20 mg/dl at standard risk and 18 mg/dl at high risk. The high-risk criteria were described in detail in the Evidence Table 2. It was found that infants with hyperbilirubinemia secondary to non-hemolytic causes who received phototherapy had 14.3 percent risk reduction of BET than infants in no treatment group. NNT for prevention of the needs for exchange transfusion, or for TSB > 20 mg/dl, was seven (95 % CI 6 to 8). On the other hand, phototherapy didn't reduce the need for exchange transfusion for infants with hemolytic diseases or in the high risk group. In other words, no therapeutic effect on reducing the exchange transfusion rate in ≥ 34 weeks GA with hemolytic disease was observed (Brown, Kim, Wu, et al., 1985).

The same group of infants, 140 subjects in the treatment group and 136 controls with BW ≥ 2,500 grams and GA ≥ 34 weeks, were evaluated for the effect of phototherapy on the hyperbilirubinemia of Coombs' positive hemolytic disease in the study of Maurer, Kirkpatrick, McWilliams, et al. (1985). Of the 276 infants whose birthweight was 2,500 grams or more, 64 (23.1 percent) had positive Coombs' tests, 58 secondary to ABO and 6 secondary to Rh incompatibility. Thirty-four out of 64 in this group received phototherapy. The other 30 were placed in the control group. Of the 212 subjects who had negative Coombs' tests, 106 were in the treatment group and the same number was in the control group. No therapeutic effect on reducing the exchange transfusion rate was observed in infants with Coombs' positive hemolytic disease, but there was a 9.4 percent absolute risk reduction in babies who had negative Coombs' tests. In this group of infants, the NNT for prevention of the needs for exchange transfusion, or a TSB > 20 mg/dl, was 11 (95% CI, 10 to 12) (Maurer, Kirkpatrick, McWilliams, et al., 1985).

A more recent RCT compared the effect of four different interventions on hyperbilirubinemia (serum bilirubin concentration ≥ 291 μmole/l or 17 mg/dl) in 125 full-term breast-fed infants. Infants with any congenital anomalies, neonatal complications, hematocrit >65 percent, significant bruising or large cephalhematomas, or hemolytic disease were excluded. The four interventions in the study were (1) continue breast-feeding and observe (N=25); (2) discontinue breast-feeding, substitute formula (N=26); (3) discontinue breast-feeding, substitute formula and administer phototherapy (N=38); (4) continue breast-feeding, administer phototherapy (N=36). The interventions were considered failures if serum bilirubin levels reached 324 μmole/l or 20 mg/dl (Martinez, Maisels, Otheguy, et al., 1993). For the purpose of the current review, we re-grouped the subjects into treatment group or phototherapy group, and, control group or no phototherapy group. Therefore, the original group 4 and 3 became the treatment group I and II, and the original group 1 and 2 were the corresponding control group I and II. It was found that treatment I, phototherapy with continuing breast-feeding, had 10.1 percent ARR and the NNT for prevention of a serum bilirubin exceeding 20 mg/dl was 10 (95% CI 9 to 12). Compared to treatment I, treatment II (phototherapy with discontinuation of breast-feeding) was significantly more efficacious. It had 16.6 percent ARR and the NNT for prevention of a serum bilirubin exceeding 20 mg/dl was 6 (95% CI, 5 to 7).

John (1975) reported the effect of phototherapy in 492 full-term neonates born during 1971 and 1972 and who developed unexplained jaundice with bilirubin levels > 15 mg/dl. One hundred and eleven subjects received phototherapy. Three hundred and eighty-one infants did not. The author stated, “The choice of therapy was, in effect, random since two pediatricians approved of the treatment and two did not.” The results showed that phototherapy had a 11.2 percent risk reduction of exchange transfusion, performed in both treatment and control groups when serum bilirubin levels exceeded 20 mg/dl. Therefore, the NNT for prevention of a serum bilirubin exceeding 20 mg/dl was 9 (95% CI 8 to 10).

### Effectiveness of Reduction in Bilirubin Level on Brainstem Auditory Evoked Response (BAER) in Jaundiced Infants with GA ≥ 34 weeks

Eight studies that compared Brain Stem Auditory Evoked Responses (BAER) before and after treatments for neonatal hyperbilirubinemia are discussed in this section. Studies were categorized by treatments in Table 3.15. Of the eight studies, three studies treated jaundiced infants by administering phototherapy followed by BET according to different guidelines (Agrawal, Shukla, Misra, et al., 1998; Deorari, Singh, Ahuja, et al., 1994; Sabatino, Verrotti, Ramenghi, et al., 1996); four studies treated jaundiced infants with ET only (Funato, Teraoka, Tamai, et al., 1996; Hung, 1989; Kuriyama, Tomiwa, Konishi, et al., 1986; Nwaesei, Van Aerde, Boyden, et al., 1984); and, one study didn't specify what treatments jaundiced infants received (Bhandari, Narang, Mann, et al., 1993). In addition, subjects follow-up neurodevelopmental outcomes were summarized in Table 3.16 (see Evidence Table 2).

Table 3.15 Effectiveness of Decreasing Bilirubin Levels on Auditory Brainstem Response in Jaundiced Infants (GA ≥ 34 weeks)

Study, Year, UI # | Sample N (Control) | Mean Bili. Levels before Rx → After Rx (mg/dl) | Mean latency (msec) Before Rx → After Rx | | | Mean Interpeak (msec) Before Rx → After Rx | | | Follow-up (follow-up rate) | Quality
| | | I | (II), III | (IV),V8.1→7.0 [7.0] | I–III | III–V | I–V
Phototherapy and/or Exchange Transfusion
Sabatino, 1996 97171477 | 48 (42) | 14–25.8→ < 8 | 1.9→1.6 [1.8]→[1.6] | 4.8→4.0 [4.0]→[3.9] | 8.1 →7.0[7.0] [6.9] | 3.0→2.3 [2.3]→[2.2] | 3.1→2.9 [2.9]→[2.8] | 6.1→5.2 [5.2]→[5.0] | All normal (100%) | B
Deorari, 1994 95189280 | 7^a^ (20) | 24.6±1.6→14.8±2.1 | 2.1→1.8[1.9] | 5.5→5.4*[5.1] | 8.1→7.4*[7.0] | - | - | 6.0→5.6[5.1] | All normal (100%) | C
Agrawal, 1998 99232291 | 30^b^ (25) | 22.4±2.7→ ND | 1.8→1.7*[1.7] | 4.8→4.6*[4.5] | 7.3→6.9*[6.7] | 3.0→2.8*[2.8] | 2.4→2.3*[2.2] | 5.4→5.1*[5.1] | 10% ab-normal (100%) | C
Exchange Transfusion
Hung, 1989 90054139 | 6 ^c^ | 20.4→ 11.8 | 2.5→2.2* | 5.2→5.1* | 7.4→7.3* | - | - | - | n.d. | B
Kuriyama, 1986 89246798 | 6^d^ (8) | 21.5±4.6→11.6±3.5 | 1.9→1.7[1.8] | 5.0→7.8[4.6] | 7.4→7.0[6.9] | 3.1→3.0[2.8] | 2.4→2.3[2.3] | 5.5→5.3[5.1] | All normal (83%) | B
Funato, 1996 97104685 | 8^e^ (16) | 25.3±2.6→11.0±2.4 | 2.0→1.8*[1.8] | - | - | 2.9→2.9[2.7] | - | 5.3→5.2*[5.0] | All normal (100%) | C
Nwaesi, 1984 85037769 | 9 ^f^ | 22.3±1.4→15.3±3.2 | 1.9→1.9 | - | - | 3.0→2.8* | 3.4→3.1* | 6.4→5.8* | n.d. | C
Treatments (not specified)
Bhandari, 1993 94075016 | 30 ^g^ | 16.95±2.8→ ND | 1.8→1.7 | 4.6→4.4 | 6.7→6.7 | 2.7→2.7 | 2.2→2.1 | 4.8→5.0 | n.d. | B

Bold = significantly different than controls

* = significantly different between pre- and post- Rx

[ ] controls' value

n.d. = not done

a All underwent PhotoRx. ET was carried out when ABR was considered abnormal. Two ABO incompatibility, 1 Rh incompatibility, 1 G6PD deficiency; 3 Idiopathic.

b 10% had Rh incompatibility, 26.7% had ABO incompatibility and 63.3% had idiopathic hyperbilirubinemia

c Causes of jaundice was “mostly ABO, G6PD, and unknown factors”

d 83% Hemolytic disease; 17% Hemoperitoneum

e One ABO incompatibility, 3 Polycythemia, 1 Cephalhematoma, 5 Idiopathic jaundice

f 33% Rh incompatibility; 67% ABO incompatibility

g 20% ABO incompatibility, 7% Rh isoimmunization; 30% G6PD deficiency

Table 3.16 Follow-up Results of Effectiveness of Decreasing Bilirubin Levels on Auditory Brainstem Response in Jaundiced Infants (GA ≥ 34 weeks)

Study, Year, UI # | Follow-up Outcomes | Confounders | Quality
Phototherapy and/or Exchange Transfusion
Sabatino, 1996 97171477 | @1, 2, and 3 years of age: Brunett-Lezine test | PhtoRx; ET | B
| Neuropsychological evaluations performed in subjects showed scores similar to those of age-matched controls.
Deorari, 1994 95189280 | @1 year of age: DQ; Neurological sequelae | PhotoRx; ET | C
| Mean development motor quotient and mean development mental quotient in study and control groups were comparable and normal at 1 year of age
| None of the study or control group babies developed seizures, motor deficits or features of cerebral palsy
Agrawal, 1998 99232291 | @1 year of age: DDST | PhotoRx; ET; Lost to follow-up | C
| Neurological development was normal in all infants with SB 15–20 mg/dl, in 89% infants with SB 21–25 mg/dl, and in 67% infants with SB > 25 mg/dl
Exchange Transfusion
Kuriyama, 1986 89246798 | @25 days to 6 months: neurological development; hearing | ET | C
| All are normal development and not hearing abnormalities.
Funato, 1996 97104685 | @1.5–6 years of age: DQ/IQ | ET | C
| All had normal DQ/IQ > 85 except for 1 patient who developed borderline intelligence with IQ=77 at 6 years old

Sabatino, Verrotti, Ramenghi, et al. (1996) studied brain stem auditory evoked potentials (BAEP) in 90 full-term newborns with jaundice. After enrolling only the subjects who showed the three major BAEP components (waves I, III and V), 48 full-term subjects with bilirubin from 13.9 to 25.8 mg/dl and without evidence of hemolysis were followed over a 3-year period. BAEP's were performed on day 3 and repeated five to seven days post phototherapy or exchange transfusion until the bilirubin had decreased below 8 mg/dl. On day 3, latencies of waves III and V; and, interpeak latency III–V and I–V were significantly prolonged compared to control subjects. Recordings performed 5 to 7 days post therapy and during subsequent session showed no significant differences. Serial neuropsychological evaluations at 6, 18 and 30 months using the Brunett-Lezine test showed no neurodevelopmental abnormality. Statistical analyses of the neuropsychological evaluations were not given (Sabatino, Verrotti, Ramenghi, et al., 1996).

Infants with ABO incompatibility, Rh incompatibility, G6PD deficiency or idiopathic jaundice were treated with phototherapy and/or exchange transfusion in 7 studies (Agrawal, Shukla, Misra, et al., 1998; Bhandari, Narang, Mann, et al., 1993; Deorari, Singh, Ahuja, et al., 1994; Funato, Teraoka, Tamai, et al., 1996; Hung, 1989; Kuriyama, Tomiwa, Konishi, et al., 1986; Nwaesei, Van Aerde, Boyden, et al., 1984). The results consistently reported that treatments for jaundice significantly reduced the prolonged auditory brainstem response (ABR) latencies and interpeak latencies back to normal. The mean SB levels of the 96 infants also decreased from 20–25 mg/dl before treatments to 11–15 mg/dl after treatments. Of the 7 studies, four studies had follow-up results of neurological and intelligence outcomes. Three studies (Deorari, Singh, Ahuja, et al., 1994; Funato, Teraoka, Tamai, et al., 1996; Kuriyama, Tomiwa, Konishi, et al., 1986) with 14 jaundiced infants in the treatment group and 28 non-jaundiced infants in the control group, showed all normal developments at 25 days to 6 years of age. Moreover, Agarwal, Narayan, Kumari, et al. (1998) studied 30 term newborns with bilirubin > 15 mg/dl, recorded BAEP's in these infants before and after phototherapy or exchange transfusion and at the age of 2 to 4 months. Of the 30 infants, 10 percent had Rh incompatibility, 26.7 percent had ABO incompatibility and 63.3 percent had idiopathic hyperbilirubinemia. Seventeen out of the 30 infants showed abnormalities on initial BAEP's; these abnormalities correlated significantly with bilirubin level. After therapy, abnormalities reverted back to normal in 10 cases but persisted in 7 out of 17. Two subjects had kernicterus with bilirubin > 15 mg/dl. Follow-up BAEP's were done in 21/30 cases at 14.4 ± 2.2 weeks. Of the 15 patients who had an initial abnormal BAEP, in only 3 were there persistent abnormalities. At one year of age, screening by DDST showed that neurological development was normal in 100 percent of infants with bilirubin of 15–20 mg/dl; neurological development was normal in 88.9 percent of infants with bilirubin of 21 to 25 mg/dl; and neurological development was normal in 66.7 percent of infants with bilirubin >25 mg/dl. No further statistical details were provided (Agrawal, Shukla, Misra, et al., 1998).

### Effects of Treatments for Hyperbilirubinemia on Neurodevelopmental Outcomes

Nine studies examined the efficacy of treatment on neurodevelopmental outcomes, shown in Table 3.17 and 3.18. All the studies evaluated the efficacy of phototherapy. No study on the efficacy of exchange transfusion was identified. Of the nine studies, one was a randomized controlled trial, one a non-randomized controlled trial, six were prospective cohorts and one was a retrospective cohort (see Evidence Table 3).

Table 3.17 Effect of Serum Bilirubin Levels on Neurodevelopmental Outcomes in Infants with GA ≥ 34 weeks

Study, Year, UI # | Subject N (Controls) | Mean Bilirubin levels (mg/dl) | Outcomes | | | | | Bias/ Confounders | Quality
Behavioral Outcomes
Abrol, 1998 20235719 | 15 (15) | 12.1–15.0 (8.0–12.0) | Orientation cluster items | 24–48 h after initiation of Phototherapy | | 24–48 h after cessation of Phototherapy | | ND | A
| | | Visual animate | P<0.01 | | P<0.05
| | | Visual inanimate | P<0.01 | | P<0.05
| | | Animate visual and auditory | P<0.01 | | P<0.05
Ju SH, 1991 91289763 | 29 (14) | 12–15 (<12) | Orientation cluster | Before Rx | After Rx | 24 h after Rx | 2wks age | Incomplete binding since had mild or no clinically observable jaundice | B
| | | Mean | NS | P<0.01 | P<0.05 | NS | Large number of drop-outs at 2 week follow-up in the control group Small sample size
| | | Animate visual | NS | P<0.05 | P<0.05 | NS
| | | Animate visual & auditory | NS | P<0.05 | P<0.05 | NS | | B
| | | Inanimate visual & auditory | NS | P<0.05 | P<0.05 | NS
| | | Alertness | NS | P<0.05 | P<0.05 | NS
Paludetto, 1983 84057358 | 30 (30) | 13.3 | Orientation cluster | | 3^rd^ day | 4^th^ day | 1month | Loss of subject and matched control at each observation 30->14->12 at one month of age | B
| | 8.4–17.5 (9.6) | Animate visualP<0.01 | | | P<0.05 | NS
| | (3.5–14.5) | Inanimate visual P<0.05 | | | P<0.01 | P<0.05
| | | Inanimate visual P<0.005 and auditory | | | P<0.01 | P<0.05
| | | Alertness P<0.005 | | | P<0.05 | NS
| | | Motor performance Pull to sit P<0.001 | | | NS | NS
| | | Regulation of state Cuddliness P<0.001 | | | NS | NS
Telzrow, 1980 80225471 | 10 (10) | 17.07 | Mean cluster scores on Brazelton's scale | | | | | No bilirubin assessment made in control group | B
| | | | | Day 3 | Day 6 | Day 10
| | | Orientation | | P< 0.05 | P<0.05 | P=0.05
| | | Motor | | NS | P<0.01 | NS
Valkeakari 1981 81156354 | 41 (42) | - | Vineland social maturity scale | | Phototherapy | | Control | No information about the bilirubin levels of study or control group. Multiple analyses from small N. | B
| | | Self help general | | 12.56 ± 0.50 | | 12.64 ± 0.41
| | | Self help eating | | 8.61 ± 0.70 | | 8.67 ± 0.65
| | | Self help dressing | | 4.95 ± 1.75 | | 4.44 ± 1.52
| | | Locomotion | | 5.76 ± 0.92 | | 5.66 ± 1.07
| | | Occupation | | 7.51 ± 0.84 | | 7.31 ± 0.79
| | | Communication | | 5.98 ± 0.11 | | 5.94 ± 0.31
| | | Socialization | | 5.85 ± 0.79 | | 5.82 ± 0.82
| | | Social age | | 4.20 ± 0.51 | | 4.07 ± 0.48
| | | Bowel control | | 1.81 ± 0.54 | | 1.65 ± 0.46
| | | Bladder control | | 1.93 ± 0.56 | | 1.74 ± 0.47
| | | Speech score | | 1.41 ± 0.38 | | 1.45 ± 0.34
Neurological or Motor Outcomes
Seidman, 1994 94223372 | 42 (42) | 20.0 ± 0.4 (18.8 ± 0.3) | The phototherapy group showed an average IQ score of 108 ± 2 at 17 years which was not significantly different from the average IQ score of 107 ± 2 in the control group. | | | | | Retrospective study method used | B
Valkeakari 1981 81156354 | 41 (42) | ND | There were 2 infants with febrile convulsions in the PT group as compared to one in control group. There was only one infant with breath holding spells in PT group and none in control group. | | | | | No information about the bilirubin levels of study or control group | B
Misra, 1980 80203306 | 81 (60) | 10–30 (8.5) | Ten of the 81 subjects manifested some degree of mental retardation at some or the other time during follow-up while all the 60 controls were normal. But on long term follow-up 3 of the 31 subjects remained retarded with AQ<90 at their last examination and remaining 7 had become normal. | | | | | Large number of patients lost to follow-up 81→ 12 | C
| | | | | | | | Unable to sort out effect of phototherapy from higher bilirubin as control group had lower bilirubin

Table 3.18 Effect of Serum Bilirubin Levels on Visual Outcomes in Infants with GA ≥ 34 weeks

Study, Year, UI # | Subjects N (Controls) | Mean Bilirubin levels (Range) mg/dl | Outcomes | | | Bias/ Confounders | Quality
Granati, 1984 84283738 | 110 (110) | 19.2 ± 2.3 (14.2 –24.6) | Findings | PT group | Control group | Basic testing of vision and hearing may not have detected subtle measurements Bilirubin ranged from 14.0 –24.6 in subjects (mean 19.5) | B
| | [9.7 ± 1.7] [7.2–12.2] | Normal visual function | 77 ( 95.1%) | 84(94.5%)
| | | Reduced visual acuity | 3(3.7%) | 4(4.4%)
| | | Strabismus | 1(1.2%) | 1(1.1%)
Valkeakari, 1981 81156354 | 41 (42) | - | Findings | PT | Controls | No information about the bilirubin levels of study or control group | B
| | | Normal vision | 33 | 36
| | | Vision determination unsuccessful | 7 | 6
| | | Anisometry | 1 | -
| | | Phoria/Trophia | 10 | 12
| | | Changes in fundus (non specific) | 1 | 1
| | | changes in lens (physiological) | - | 2
| | | Nystagmus | - | -
Khanna, 1984 85103758 | 52 (52) | - | Retinoscopic finding | PT Group | Controls | Unclear how the total cohort of 112 was selected. | C
| | | Emmetropia | 7(13.4%) | 4(7.8%) | Wide age range at follow-up( 6 months to 7 years)
| | | Hypermetropia | 36(69.2%) | 39(76.4%) | Wide bilirubin range (15–69.2 mg/dl)
| | | Myopia | 6(11.5%) | 4(17.8%)
| | | Astigmatism | 3(5.7%) | 4(7.8%)
| | | Dyslexia test | - | -
| | | Fundus examination | 5 | 6
| | | Myopic discs | 3 | 2
| | | Pale discs | 2 | -
| | | Variations in size | 1 | -
| | | Dull macular reflex | - | 2
| | | Mottling/ greying around macula | - | 2

( ) Controls' value

#### Effect of Phototherapy on Behavioral and Neurological Outcomes

A total of seven studies looked at the effect of phototherapy on neurodevelopmental outcomes. Five of these studies looked at the effect of hyperbilirubinemia and phototherapy on behavior. Of the five studies, four used the Brazelton Neonatal Behavioral Assessment Scale (BNBAS) and one (Valkeakari, Anttolainen, Aurekoski, et al., 1981) used the Vineland Social maturity scale. No study evaluating neurodevelopmental outcomes of exchange transfusion was identified.

Abrol and Sankarasubramanian (1998) evaluated the effect of phototherapy on neonatal behavior using the BNBAS in 30 full term infants. Fifteen infants received phototherapy for TSB between 12 and 15 mg/dl. Phototherapy was discontinued when serum bilirubin levels were <12.0 mg/dl. Their outcomes were compared to a control group consisting of 15 infants who had TSB between 8–12 mg/dl at 48 hours. Only control infants were breast-fed during both assessments. Behavioral assessment done 24–48 hours after initiation of phototherapy showed that the study group performed significantly poorer in the orientation cluster as compared to the control group. A repeat assessment done 24–48 hours after cessation of phototherapy demonstrated no improvement in the study group. However there was no significant difference between the 2 groups in other clusters of the BNBAS scale.

Ju and Lin (1991) studied the effects of moderate non-hemolytic jaundice and phototherapy on newborn behavior in a randomized controlled trial. Initially 29 full term infants with TSB 12–15 mg/dl on 3^rd^ –5^th^ day of life were randomly assigned to phototherapy (N=14) and non-phototherapy (N=15) group. A third group of 14 infants with TSB < 12 mg/dl were recruited as control subjects. Phototherapy was given until TSB was < 12 mg/dl. The mean duration of phototherapy was 38 hours and no infant needed Exchange Transfusion. One infant in phototherapy group was excluded due to G6PD deficiency and evidence of hemolysis and four infants were excluded from control group when their serum bilirubin exceeded 12mg/dl and were put on phototherapy. Two infants were subsequently added to the non-phototherapy group to make a total of 13. Infant behavior was assessed by BNBAS 4 times: just before phototherapy, immediately after termination of phototherapy, 24 hours after phototherapy and at 2 weeks of age in phototherapy treatment group and at comparable age in other two groups. For analysis, 28 behavioral items were sub-categorized into six behavioral clusters. Twenty-one neurologic reflex items were used to generate a 7th reflex cluster. The results of seven cluster scores did not differ among the three groups at baseline examination. However, the treatment subjects performed poorly in several of the orientation cluster items as compared to the untreated and control groups (P<0.05). However, the untreated and control groups did not differ significantly. At 2 weeks of age no significant differences were found in the BNBAS scores among the three groups. The authors concluded that moderate non-hemolytic jaundice does not affect the behavior of full term infants and that phototherapy has short-term adverse effects on visual, auditory orientation and alertness, which may impair infant-caregiver interaction.

In 1983, Paludetto, Mansi, Rinaldi, et al. (1983) evaluated possible behavioral changes in healthy jaundiced infants treated with phototherapy. Thirty full term infants with TSB between 8.4–17.5 mg/dl and undergoing phototherapy for 6 hours or more were included the treatment group and 30 infants with TSB 3.5–14.5 mg/dl served as controls. The two groups were examined using the BNBAS at the age of 3days, 4 days and 1 month. On the 3rd and 4th day, the control group scored better than the study group, particularly in the orientation cluster. The visual cluster score appeared to be more compromised in the study group. Only 12 treatment and 12 control infants were assessed at the 1-month and the treatment group continued to perform poorly in some items of the orientation cluster.

Telzrow, Snyder, Tronick, et al. (1980) evaluated behavior of 10 healthy full term jaundiced infants during and after phototherapy. Ten non-jaundiced infants served as controls. Three evaluations were made using BNBAS on 3, 6 and 10 days of age. The treatment group had significantly lower scores on all three days for the orientation cluster and on day 6 for motor cluster scores. No significant correlation was found between level of jaundice and infant's behavior.

Seidman, Paz, Stevenson, et al. (1994) evaluated IQ at the age of 17 years, in 42 full term infants with severe hyperbilirubinemia who were treated with phototherapy, most of whom (31) also were treated with exchange transfusion. Forty-two infants who did not receive phototherapy were selected as controls. No significant difference in IQ between the two groups was found.

Valkeakari, Anttolainen, Aurekoski, et al. (1981) examined 41 subjects at age 3 years. All were full-term, had negative Coombs' tests and received prophylactic phototherapy for more than 100 hours during first week of life. A comparable control group of 42 infants who had not received phototherapy was also evaluated. Psychological assessment was done using Vineland social maturity scale. No significant difference could be demonstrated between the two groups in the physical, neurological, ophthalmologic and psychological examination conducted. The authors concluded that phototherapy is unlikely to cause harmful long-term developmental effects.

Misra, Srivastava, Bajpai, et al. (1980) followed 81 infants for a period of 36 months. All of them had phototherapy. Sixty non-exposed infants served as controls. All 81 subjects had immediate and 6-month follow-up up studies while only 31 subjects had follow-up studies from 6 to 36 months. Both groups showed a normal growth pattern comparable to Indian Council Medical Research standards. Ten of 81 subjects showed mental retardation at some point (either during the follow-up period or at other times) but all controls were normal. At the end of 36 months, three out of 31 study subjects had mental retardation with an Attainment Quotient (AQ< 90). The cause of jaundice in all three was unknown. Two had IQ between 70 to 89 and one had Attainment quotient between 50 to 69.

#### Effect of Phototherapy on Visual Outcomes

Three studies were identified that studied the effect of serum bilirubin and treatment on visual outcomes. Two were prospective cohorts and one was a retrospective cohort (Table 3.18).

Granati, Largajolli, Rubaltelli, et al. (1984) conducted a follow-up study of 110 full term infants treated with phototherapy. One hundred and ten matched non-icteric infants served as control. No significant difference was found in the visual function between the two groups. Three of 81 infants in phototherapy group and four of 89 infants in the control group had reduced visual acuity and one in each group had strabismus. In addition, an evaluation of growth, hearing, neurological and psychological function did not reveal significant difference between the two groups.

Khanna, Mehta, Matthews, et al. (1984) studied 56 full term children who had received phototherapy for indirect hyperbilirubinemia in the early neonatal period. They were compared with 56 matched controls with no jaundice or mild physiological jaundice not requiring phototherapy. A detailed ophthamological examination including tests for visual acuity, dyslexia tests, retinoscopy and fundoscopy revealed no significant differences between the two groups.

## Question 4 What is the accuracy of various strategies for predicting hyperbilirubinemia, including hour-specific bilirubin percentiles?

### Description of Included Studies

As shown in Summary Table 3.19, Part 1 and Part 2, 10 qualifying studies published from 1977 to 2001 examining five prediction methods of neonatal hyperbilirubinemia were included. A total of 8,167 multiple racial group neonates, the majority healthy near-term or term infants, were subjects. Four studies examined the accuracy of cord bilirubin level as a test for predicting the development of clinically significant neonatal jaundice (Carbonell, Botet, Figueras, et al., 2001; Knudsen, 1989; Knudsen, 1992; Risemberg, Mazzi, MacDonald, et al., 1977). Four studies investigated the test performance of serum bilirubin levels before 48 hours of life to predict hyperbilirubinemia (Awasthi and Rehman, 1998; Carbonell, Botet, Figueras, et al., 2001; Risemberg, Mazzi, MacDonald, et al., 1977; Seidman, Ergaz, Paz, et al., 1999). Carbonell, Botet, Figueras, et al. (2001) and Risemberg, Mazzi, MacDonald, et al. (1977) further compared the test performances of cord bilirubin to that of early serum bilirubin levels. The accuracy of end-tidal monoxide concentration as a predictor of the development of hyperbilirubinemia was examined in two studies (Okuyama, Yonetani, Uetani, et al., 2001; Stevenson, Fanaroff, Maisels, et al., 2001). Stevenson's study also examined the test performance of a combined strategy of end-tidal carbon monoxide concentration (ETCOc) and early serum bilirubin levels. Finally, two studies tested the efficacy of predischarge risk assessment, determined by a risk index model and hour-specific bilirubin percentile respectively, for predicting neonatal hyperbilirubinemia (Bhutani, Johnson, and Sivieri, 1999; Newman, Xiong, Gonzales, et al., 2000) (see Evidence Table 4).

Table 3.19 Part 1. Summary of Individual Studies of Prediction Strategies of Hyperbilirubinemia in Healthy, Term or Near-Term (GA≥34 weeks) Infants

Study,Year UI # | Country | Race (N) | Definition of Hyperbilirubinemia | Reference Standard: Laboratory-based assay of TSB | Quality
Prediction Method: Cord Bilirubin
Carbonell, 2001 21130776 | Spain | ND (585) | SB ≥ 17 mg/dl in the first 4 days of life | Bilirubinometer Bil-Red by direct reading at 461 mcm | A
Knudsen, 1992 92306741 | Denmark | ND (138) | SB > 11.7 mg/dl at day 3 | Standard direct spectroscopic method at 3^rd^ postnatal day | A
Knudsen, 1989 89189829 | Denmark | ND (291) | “Clinical jaundice” following by SB > 10 mg/dl | Standard method of Blom and Doumas | B
Risemberg, 1977 77156212 | US | ND (91) | SB > 10 mg/dl at 36 hrs of age | Laboratory-based assay | B
Prediction Method: Early Serum Bilirubin (mg/dl)
Awasthi, 1998 20234451 | India | ND (274) ^a^ | Peak SB > 15 mg/dl | Spectrophotometry on Toyo Bilirubin Analyzer | A
Carbonell, 2001 21130776 | Spain | ND (574+865) ^b^ | SB ≥ 17 mg/dl in the first 4 days of life | Bilirubinometer Bil-Red by direct reading at 461 mcm | A
Seidman, 1999 20110115 | Israel | Multiple race (1177) | TSB > 10 mg/dl at day 2, > 14 mg/dl at day 3; and, > 17 mg/dl at day 4 or 5 | Unitstat Bilirubinometer | A
Risemberg, 1977 77156212 | US | ND (91) | SB > 16 mg/dl at 36 hrs of age | Laboratory-based assay | B
Prediction Method: End-tidal Carbon-Monoxide Concentration (ETCOc, p.p.m)
Stevenson, 2001 21326594 | US + International | Multiple race (1370) | TSB ≥ 95^th^ %tile | Laboratory-based assay. Each sites used its own laboratory and method | A
Okuyama, 2001 21366215 | Japan | ND (51) | Peak SB ≥ 15 mg/dl | Laboratory-based assay | B
Prediction Method: Predischarge Risk Index
Newman, 2000 20529193 | US | (496) | TSB within the first 30 days of life ≥ 25 mg/dl | Data from the KPMCP integrated laboratory information system | B
Prediction Method: Predischage Risk Zone, Determined by Hour-Specific Bilirubin Percentile
Bhutani, 1999 99117600 | US | Multiple race (2840) | Subsequent TSB risk zone ≥ 95^th^ %tile | 2,5-DPH diazo mathod | A

SB = serum bilirubin; TSB = total serum bilirubin

All infants were healthy, term (GA≥34) infants, unless noted:

a 28% “Preterm”

b 574 infants in the phase I study; 865 infants in the phase II study. 90% infants were breast-fed exclusively.

Table 3.19 Part 2. Test Accuracy of Prediction Strategies of Hyperbilirubinemia in Healthy, Term or Near-Term (GA≥34 weeks) Infants

Study, Year, UI # | TP (n) | FN (n) | TN (n) | FP (n) | Sens (%) | Spec (%) | Thresholds
| | | | | | | Method | SB (mg/dl)
Prediction Method: Cord Bilirubin (μmol/l)
Carbonell, 2001 21130776 | 4 | 17 | 534 | 30 | 22 | 95 | 37 | 17
Knudsen, 1992 92306741 | 28 | 0 | 6 | 104 | 100 | 5 | 20 | 11.7
| 27 | 1 | 23 | 87 | 96 | 21 | 25 | 11.7
| 25 | 3 | 46 | 64 | 89 | 42 | 30 | 11.7
| 20 | 8 | 75 | 35 | 71 | 68 | 35 | 11.7
| 11 | 17 | 94 | 16 | 39 | 85 | 40 | 11.7
Knudsen, 1989 89189829 | 4 | 7 | 70 | 3 | 36 | 96 | 40 | 10 ^j^
Risemberg, 1977 77156212 | 12 | 16 | 63 | 0 | 43 | 100 | 68 | 10.0
Prediction Method: Early Serum Bilirubin (mg/dl)
Awasthi, 1998 20234451 | 24 | 11 | 157 | 82 | 69 | 66 | 3.99 ^f^ | 15
Carbonell, 2001 21130776 | 7 | 0 | 74 | 88 | 100 | 46 | 6 @24 hrs ^h^ | 17
| 11 | 0 | 102 | 56 | 100 | 64 | 9 @48 hrs ^h^ | 17
| 25 | 0 | 239 | 159 | 100 | 60 | 6 @24 hrs ^i^ | 17
| 45 | 1 | 348 | 426 | 98 | 45 | 9 @ 48 hrs ^i^ | 17
Seidman, 1999 20110115 | 49 | 11 | - | - | 82 | - | 5 @day 1 | HB ^g^
Risemberg, 1977 77156212 | 13 | 0 | 78 | 0 | 100 | 100 | 10 @12 hrs | 16
| 13 | 0 | 78 | 0 | 100 | 100 | 15 @24 hrs | 16
Prediction Method: End-tidal Carbon-Monoxide Concentration (ETCOc, p.p.m)
Stevenson, 2001 21326594 | 92 | 28 | 635 | 615 | 77 | 51 | 1.5 @36 hrs | ≥ 95^th^ %tile
| - | - | - | - | 90 | 65 | Comb | ≥ 95^th^ %tile
Okuyama, 2001 21366215 | 5 | 2 | 27 | 17 | 71 | 61 | 1.6 @36 hrs | 15
| 6 | 1 | 35 | 9 | 86 | 80 | 1.8 @42 hrs | 15
| 6 | 1 | 32 | 12 | 86 | 73 | 1.8 @48 hrs | 15
| 6 | 1 | 29 | 15 | 86 | 66 | 1.8 @60 hrs | 15
Prediction Method: Predischage Risk Index
Newman, 2000 20529193 | 58 | 1 | 129 | 273 | 98 | 32 | RI > 7 | 25
| 52 | 7 | 244 | 158 | 88 | 61 | RI >10 | 25
| 25 | 34 | 364 | 38 | 42 | 91 | RI > 15 | 25
| 8 | 51 | 399 | 3 | 14 | 99 | RI > 20 | 25
Prediction Method: Predischage Risk Zone, Determined by Hour-Specific Bilirubin Percentile
Bhutani, 1999 99117600 | 126 | 0 | 1756 | 958 | 100 | 65 | ≥ 40^th^ %tile | ≥ 95^th^ %tile
| 114 | 12 | 2300 | 414 | 91 | 85 | ≥ 75^th^ %tile | ≥ 95^th^ %tile
| 68 | 58 | 2610 | 104 | 54 | 96 | ≥ 95^th^ %tile | ≥ 95^th^ %tile

TP = true positive; FN = false negative; TN = true negative; FP = false positive; N = number of subjects; n = number of measurements; Sens = sensitivity; Spec = specificity; SB = serum bilirubin; r = regression coefficient between prediction method and SB; RI = risk index; HB = hyperbilirubinemia

Comb = combined ETCOc and TSB method (either an TSB between 75th and 95th %tile or an ETCOc ≥ population mean or both @ 36±6 hrs). Infants with TSB ≥ 95th %tile @ 30±6 hrs were excluded.

f mean SB at 18–24 hours of age

g TSB > 10 mg/dl at day 2, > 14 mg/dl at day 3; and, > 17 mg/dl at day 4 or 5

h Phase I study

i Phase II study

j “Clinical jaundice” following by SB > 10 mg/dl

### Accuracy of Various Strategies for Predicting Hyperbilirubinemia

#### Accuracy of Cord Bilirubin Level as a Test for Predicting Later Development of Hyperbilirubinemia

Carbonell, Botet, Figueras, et al. (2001) studied the predictive value of cord bilirubin in 585 healthy term newborns. A cord bilirubin ≥ 2.2 mg/dl predicted significant hyperbilrubinemia, defined as TSB ≥ 17 mg/dl between the 3^rd^ and 4^th^ days of life, with a sensitivity of only 22 percent and a specificity of 95 percent.

Knudsen studied cord bilirubin levels in two studies (Knudsen, 1989; Knudsen, 1992) comprised of 291 and 138 healthy term infants respectively. Different levels of cord blood bilirubin (CB) were tested for prediction of later development of hyperbilirubinemia, defined as TSB > 11.7 mg/dl or 200 umol/l. Phototherapy was required in 57 percent of newborns with CB > 40 umol/l, but only 9 percent if CB was ≤ 40 umol/l. In the second study, Knudsen (1992), the correlation of CB with TSB was 0.5 (Pearson's r). In both studies, sensitivity increased and specificity decreased directly as the threshold declined from CB > 40 umol/l to CB > 20 umol/l. Figure 3.6 shows the ROC curve from the Knudsen (1992) study.

Figure 3.6 Test Performance of Cord Bilirubin Levels

Data Source: Knudsen, 1992 [#92306741]

Risemberg, Mazzi, MacDonald, et al. (1977) studied cord bilirubin in 91 neonates from ABO incompatible pregnancies and 30 control infants to determine predictability for severe hyperbilirubinemia, defined as TSB > 16 mg/dl at 12 to 36 hours of age. A cord bilirubin level of greater than 4 mg/dl was found to indicate high risk, requiring frequent re-evaluation and therapy.

#### Accuracy of Early Serum Bilirubin Level as a Test for Predicting Later Development of Hyperbilirubinemia

Awasthi and Rehman (1998) studied 274 term (and preterm) infants to determine the usefulness of a serum bilirubin (SB) measurement at 18 to 24 hours of age in predicting peak SB > 15 mg/dl. The prevalence of peak SB >15 mg/dl in this population was 12.8 percent and a SB of > 3.99 mg/dl at 18 to 24 hours was predictive with a sensitivity of 69 percent. Further stratified analysis by feeding type within 12 hours of birth revealed a crude odds ratio for prediction test positive of 29 if breastfeeding and two if not breastfeeding.

In a study of 2,004 healthy term newborns, Carbonell, Botet, Figueras, et al. (2001) concluded that a TSB ≥ 6 mg/dl at 24 hours or ≥ 9 mg/dl at 48 hours is predictive of hyperbilirubinemia defined as >17 mg/dl with a sensitivity of 98 to 100 percent and a specificity of 45 to 64 percent.

Seidman, Ergaz, Paz, et al. (1999) defined severe hyperbilirubinemia in healthy term newborns as a TSB > 10.0 mg/dl at day 2, >14.0 mg/dl at day 3, and > 17.0 mg/dl at age 4 and 5 days. They studied 1177 infants and found odds ratios (OR) of 36.5 for TSB > 5 mg/dl on day 1, 3.1 for TSB on day 1 (per 1 mg/dl), and 2.4 for change in TSB from day 1 to day 2 (per 1 mg/dl). A multiple regression model, which also included selected maternal factors, was predictive of hyperbilirubinemia with sensitivity of 82 percent and a specificity of 83 percent.

As part of a study of the predictive value of cord bilirubin in 91 neonates from ABO incompatible pregnancies, Risemberg, Mazzi, MacDonald, et al. (1977) obtained TSB at 12, 24, 36 and 48 hours of life. A TSB of greater than 10 mg/dl at age 12 hours correlated perfectly with TSB greater than 16 mg/dl at 36 hours of life.

#### Accuracy of End-tidal Carbon-Monoxide (ETCO) Concentration as a Test for Predicting Later Development of Hyperbilirubinemia

Stevenson, Fanaroff, Martisels, et al. (2001) studied 1370 neonates from nine multinational sites to determine whether end tidal carbon monoxide (ETCOc), alone or in combination with TSB measurements, can predict hyperbilirubinemia, defined as an age-specific TSB ≥ 95 percentile, in the first week of life. Findings supported the measurement of TSB before discharge to predict hyperbilirubinemia, but measurement of ETCOc did not improve the predictability of age-specific TSB levels.

Okuyama, Yonetani, Uetani, et al. (2001) measured ETCOc every 6 hours during the first 72 hours of life among 51 healthy, full term newborns. Hyperbilirubinemia, defined as peak TSB ≥ 15 mg/dl, developed in seven of the 51 neonates. EDCOc at age 42 hours was most predictive of hyperbilirubinemia by ROC analysis, with sensitivity 86 percent and specificity 80 percent respectively.

#### Accuracy of Predischarge Risk Index as a Test for Predicting Later Development of Hyperbilirubinemia

Newman, Xiong, Gonzales, et al. (2000) reviewed the medical records of 73 neonates with maximum TSB of ≥ 25 mg/dl, compared with 423 randomly selected controls with TSB <25 mg/dl, in order to determine biological and health service predictors of extreme hyperbilirubinemia. The strongest predictors were found to be family history of jaundice in a newborn (OR=6.0), exclusive breastfeeding (OR=5.7), bruising (OR=4.0), Asian race (OR=3.5), cephalhematoma (OR=3.3), maternal age ≥ 25 years (OR=3.1), and lower gestational age (OR=0.6/wk). The authors developed a risk index with this data, assigning a numerical value to each characteristic. In the 32 percent of neonates with an index score of ≤ 7, the risk of developing a TSB level of ≥ 25 mg/dl was about 1 in 16,000. In the one percent of neonates with an index score of > 20, the risk of developing a TSB of ≥ 25 mg/dl was about two percent. If a score of ≤ 10 was used at a cutoff for low risk, 61 percent of newborns would be in the low risk group and about 1 in 4200 would develop a TSB ≥ 25 mg/dl. Even the remaining 39 percent classified as high risk would have only a 1 in 370 risk (0.27 percent) of developing a TSB ≥ 25 mg/dl. Figure 3.7 shows the ROC curve from the Newman, Xiong, Gonzales, et al. (2000) study.

Figure 3.7 Test Performance of Predischarge Risk Index

Data Source: Newman, 2000 [#20529193]

#### Accuracy of Predischarge Risk Zone, Determined by Hour-Specific Bilirubin Percentiles, as a Test for Predicting Later Development of Hyperbilirubinemia

Bhutani, Johnson, and Sivieri (1999) evaluated 2840 term and near term newborns to determine the efficacy of predischarge TSB in predicting clinically significant hyperbilirubinemia in the first week of life. Predischarge TSB was obtained at the time of routine metabolic screening and post discharge TSB was obtained at home or outpatient follow-up visits. Among the six percent of neonates with predischarge TSB in the high-risk zone (≥95 percentile) on an hour-specific nomogram, nearly 40% remained in that zone postdischarge. Of the 32% with TSB in the intermediate zone (40 to 95 percentile), 6 percent moved into the high-risk zone postdischarge. Among the 62 percent of newborns with TBS in the low-risk zone (<40%-ile), there was no subsequent risk for significant hyperbilirubinemia. The authors advocate predischarge TSB as a universal policy to target neonates for follow-up and intervention. Figure 3.8 shows the ROC curve from the Bhutani, Johnson, and Sivieri (1999) study.

Figure 3.8 Test Performance of Hour-Specific Bilirubin Percentile

Data Source: Bhutani and Johnson, 1999 [#99117600]

#### Comparison of the Accuracy of Various Strategies for Predicting Neonatal Hyperbilirubinemia

Based upon analysis of the receiver operating characteristic (ROC) curves developed for each of the predictive strategies described above, one can conclude that hour-specific bilirubin percentiles yield the greatest accuracy, with an area-under-the-curve (AUC) of 0.93, compared with 0.74 for cord bilirubin levels, and 0.80 for pre-discharge risk index.

## Question 5 What is the accuracy of transcutaneous bilirubin measurements?

### Description of Included Studies

A total of 47 qualifying studies in 50 publications examining the test performance of transcutaneous bilirubin measurements and/or the correlation of transcutaneous bilirubin (TcB) measurements to serum bilirubin levels were reviewed in this section. Of the 47 studies, the Minolta Airshields bilrubinometer was used in 41 studies (see Evidence Table 5.1), BiliCheck™ was used in three studies (see Evidence Table 5.2), Ingram Icterometer was used in four studies (see Evidence Table 5.3), and Colormate III in 1 study (see Evidence Table 5.4). Table 3.20 shows how the total 47 studies were distributed in this report.

Table 3.20 Description of Study Outcomes

Author, Year, UI # | Correlation Coefficient | Sensitivity and/or Specificity | Subgroup Analyses | Subgroups
AirShields Minolta bilirubinometer
Bhat, 1987 88085341 | Y | N | Y | GA/BW
Bhutta, 1991 92015688 | Y | Y | N | -
Bilgen, 1998 99123665 | Y | Y | N | -
Boo, 1984 85085660 | Y | N | Y | Race/Skin Color
Bourchier, 1987 88247126 | Y | N | Y | Race/Skin Color
Carbonell, 2001 21130776 | Y | Y | Y | Other: time
Christo, 1988 89253855 | Y | Y | Y | Phototherapy
Dai, 1996 97093944 | N | Y | N | -
Fok, 1986 86268743 | Y | Y | Y | Measurement site Phototherapy
Goldman, 1982 82241425 | Y | N | Y | Race/Skin Color
Hanneman, 1982 82105249 | Y | N | Y | GA/BW Race/Skin Color Phototherapy
Harish, 1998 98373176 | Y | Y | Y | GA/BW Phototherapy
Hegyi, 1981 81144434 | Y | N | Y | Measurement site
Karrar, 1989 89271698 | Y | Y | N | -
Kenny, 1984 89271698 | Y | N | Y | Measurement site Other: Feeding
Kivlaha, 1984 84296964 | Y | N | N | -
Knudsen, 1989 89189829 | Y | N | Y | Measurement sites
Knudsen, 1990 90242782
Knudsen, 1990 91196560 | Y | Y | N | -
Knudsen, 1992 92306741 | Y | Y | N | -
Knudsen, 1993 93333142 | Y | Y | N | -
Knudsen, 1995 93333142 | N | Y | N | -
Kumar, 1992 93084314 | Y | N | N | -
Laeeq, 1993 93267865 | Y | Y | N | -
Lin, 1993 93383693 | Y | Y | Y | Measurement site
Linder, 1994 94325008 | Y | Y | N | -
Maisels, 1982 82273864 | Y | Y | Y | Measurement site
Maisels, 1997 97247177 | Y | N | N | -
Schumacher, 1985 85241873 | Y | Y | N | -
Serrao, 1989 85241873 | Y | N | N | -
Sharma, 1988 89122266 | Y | N | Y | GA/BW
Sheridan-Pereira, 1982 83021365 | Y | Y | Y | Phototherapy
Smith, 1985 85112373 | Y | Y | N | -
Suckling, 1995 95327901 | Y | N | Y | GA/BW
Taha, 1984 85070990 | Y | Y | N | -
Tan, 1985 86101839 | Y | N | Y | Measure site Race/Skin Color
Tan, 1982 83044572
Tan, 1996 97017283 | Y | N | Y | Measurement site Race/Skin Color
Tsai, 1988 90177720 | Y | Y | Y | Measurement site
Yamauchi, 1989 89348834 | Y | N | Y | Measurement site
Yamauchi, 1990 90273849 | N | Y | N | -
Yamauchi, 1991 92188736 | Y | N | Y | Other: Time; Sunlight
Yamauchi, 1991 92188737 | Y | N | Y | Measurement site Other: Time
Yamauchi, 1988 89086035
BiliCheck™
Bhutani, 2000 20381429 | Y | Y | Y | Race/Skin Color
Lodha, 2000 20368382 | Y | Y | Y | Other: TSB > 13 mg/dl
Rubaltelli, 2001 21283339 | Y | Y | Y | Measurement site
Ingram Icterometer
Bilgen, 1998 99123665 | Y | Y | N | -
Chaibva, 1974 75018763 | Y | N | N | -
Gupta, 1991 92091059 | Y | Y | Y | GA/BW
Schumacher, 1985 85241873 | Y | Y | N | -
Colormate III
Tayaba 1998 98393764 | Y | N | Y | Race/Skin Color Phototherapy

Bold = Study reported more than one instrument

### Instruments

#### Minolta AirShields Bilirubinometer

The Minolta AirShields bilirubinometer (known in 2002 as the Minolta Airshields Jaundice Meter™) is a hand held instrument that employs fiberoptic techniques to illuminate the skin and subcutaneous tissue and then spectrophotometrically analyzes the intensity of the yellow color. The manufacturer recommends calibrating the instrument on a daily basis and each institution must generate its own correlation curves for TcB and TSB. The Minolta Airshields Jaundice Meter™ frequently described in the literature has changed manufacturer and its new manufacturer, listed as Minolta/Hill-Rom Air-Shield, Hatboro, Pennsylvania, does not catalog the model JM-102 in the product list on its company website.

#### BiliCheck™

The BiliCheck™ (SpectRX Inc., Norcross, GA) is a handheld noninvasive device that utilizes an in vivo multiwavelength spectral reflectance technique that allows for the device to determine the individual optical densities (ODs) attributed to bilirubin, hemoglobin, and melanin in the infant skin. The FDA cleared the BiliCheck™ for sale in 1999. The device is 12.4 × 7.6 × 12.1 cm dimensions (W × H × D), consisting of a light source, a microspectrophotometer, a fiberoptic probe, and a microprocessor control circuit that is used for analysis and interpretation of bilirubin measurement. The fiberoptic probe is placed on the infants' forehead skin and the light source is triggered after appropriate skin contact has occurred. Bilirubin related OD values are used to calculate the TcB algorithms. The BiliCheck™ theoretically improves upon previous transcutaneous measurement devices by accounting for skin thickness, blood content and flow, maturity and pigmentation (Bhutani, Gourley, Adler, et al., 2000).

#### Ingram Icterometer

The icterometer consists of a strip of transparent Plexiglas on which are painted five yellow transverse stripes of precise and graded hue. It has been used since 1925 (Schumacher, Thornbery, and Gutcher, 1985). The Plexiglas is pressed against the baby's nose until the skin blanches and then the color compared with the yellow stripes and a jaundice score applied. Advantages are the low cost compared to other transcutaneous methods.

#### Colormate III

The Colormate III manufactured by Chromatics Color Sciences International, Inc., New York, NY is a hand held colorimeter containing a Xenon flash tube and light sensors connected to a portable computer. The instrument measures over a band of wavelengths from 400 to 700 nm with specific filters used to assess the reflectance of light for specific wavelengths. The data are processed by the computer and reported as standard color coordinates (luminosity, redness and yellowness). The algorithm incorporated into the device examines the luminosity or lightness of the skin as well as the underlying color of normal skin and accounts for that in the baseline evaluation. The bilirubin estimate evaluates changes in the yellow component of the spectrum with a mathematical adjustment for the underlying lightness of the skin. The stability of the luminosity is included in the computer analysis. Measurements must be made on three of four sites (right or left cheek, back, chest, forehead). An early baseline measurement is made of the infants' skin prior to the onset of jaundice.

### Accuracy of Minolta AirShields Bilirubinometer

As shown in Table 3.21, Part 1, the accuracy of the Minolta AirShields bilirubinometer has been studied in diverse infant populations over the past 20 years comparing transcutaneous (TcB) measurements with a variety of assays of total serum bilirubin (TSB). Twenty-two studies reported the test performance, sensitivity, and specificity of TcB measurements. The study results are grouped by measurement site, the area of the infant's body where the TcB measurements were taken, with the majority of studies using the forehead, a few studies used the sternum site only or reported results from the sternum separately, and others used mixed sites.

Table 3.21 Part 1. Summary Studies of Minolta AirShields bilirubinometer in Healthy, Term or Near-Term (GA≥34) Infants not on phototherapy or Exchange Transfusion

Study, Year UI# | Country | Race (N) | Reference Standard: Laboratory-based Assay of TSB | Quality
Measurement site: At Forehead
Bhutta, 1991 92015688 | Pakistan | ND (63) | Autoanalyser (Astra, Beckman Instruments Inc.) using the modified Jendraasik-Grof method | A
Bilgen, 1998 99123665 | Turkey | ND (96) | Bilitron 444 direct spectrophotometric method | A
Knudsen, 1990 91196560 | Denmark | ND (207) | Standard diazo method | A
Knudsen, 1992 92306741 | Denmark | ND (138) | Standard direct spectroscopic method | A
Lin, 1993 93383693 | Taiwan | Chinese (305) | Spectro-photometric method with BB-meter-Model III | A
Schumacher, 1985 85241873 | US | White (106) | Dupont ACA III analyzer, a direct spectrophotometry method | A
Tsai, 1988 90177720 | Taiwan | Chinese (98) | BB-meter-Model III (O'hara Co. Ltd) | A
Fok, 1986 86268743 | Hong Kong | Chinese (202)^a^ | AO Unistat Bilirubinometer (American Optical, USA) | B
Harish, 1998 98373176 | India | ND (60) | Malloy and Evelyn method | B
Karrar, 1989 89271698 | Saudi Arabia | ND (155) | DuPont automatic clinical analyzer | B
Knudsen, 1993 93333142 | Denmark | Danish (73) | Standard diazo method | B
Knudsen, 1995 93333142 | Denmark | Danish (110) | Standard spectrophotometric method | B
Maisels, 1982 82273864 | US | White (157) | Automated modified diazo method | B
Smith, 1985 85112373 | US | Racial diverse (85)^b^ | Method was not report | B
Taha, 1984 85070990 | Saudi Arabia | ND (68) | AO Unistat Bilirubinometer (American Optical, USA) | B
Dai, 1996 97093944 | Canada | Racial diverse (38) | Jendrassik-Grof method on a Hitachi 717 analyzer (Boehringer Mannheim, Laral, Quebec) | C
Sheridan-Pereira, 1982 83021365 | Ireland | White (60)^c^ | Method of Jendrassik Grof. | C
Measurement site: At Mid-Sternum
Lin, 1993 93383693 | Taiwan | Chinese (305) | Spectro-photometric method with BB-meter-Model III | A
Fok, 1986 86268743 | Hong Kong | Chinese (202)^a^ | AO Unistat Bilirubinometer (American Optical, USA) | B
Linder, 1994 94325008 | Israel | Middle-eastern (123) | AO Unistat Bilirubinometer (American Optical, USA) | B
Maisels, 1982 82273864 | US | White (135) | Automated modified diazo method | B
Measurement site: Mixed Sites
Carbonell, 2001 21130776 | Spain | ND (574+865) | Bilirubinometer Bil-Red by direct reading at 461 mcm | A
Yamauchi, 1990 90273849 | Japan | Japanese (78) | AO Unistat Bilirubinometer (American Optical, USA) | A
Christo, 1988 89253855 | South India | ND (91) | Technicon RA1000 within 0.5 and 1 hour from serum blood sample drawn | B
Laeeq, 1993 93267865 | Pakistan | ND (105) | Standard diazo method | B

SB = serum bilirubin; TSB = total serum bilirubin

All infants were healthy, term (GA≥34), and not on phototherapy or exchange transfusion, unless noted:

a 1.5% G-6-PD deficiency; 11% ABO incompatible, but none of them show a positive Coomb's test

b 5% ABO incompatibility

c “Most were white and Mexican-American extractions”

Table 3.21, Part 2 shows 22 of the 40 studies reported test accuracy of the Minolta AirShields bilirubinometer as the sensitivity and specificity of a threshold of transcutaneous bilirubin index (TcB) to predict a threshold total serum bilirubin (TSB). Generally, TcB readings from the forehead or sternum have correlated well with TSB, although with a wide range of correlation coefficients from a low of 0.52 for a subgroup of infants < 37 weeks GA (Bhat, Srinivasan, Usha, et al., 1987) to as high as 0.94. Comparison of r-values across studies is difficult because of differences in study design and selection procedures.

Table 3.21 Part 2. Test Accuracy of Minolta AirShields bilirubinometer to Serum Bilirubin Levels in Healthy, Term or Near-Term (GA≥34) Infants not on phototherapy or Exchange Transfusion

Study, Year UI# | r | TP (n) | FN (n) | TN (n) | FP (n) | Sens (%) | Spec (%) | Thresholds
| | | | | | | | TcB | SB (mg/dl)
Measurement site: At Forehead
Bhutta, 1991 92015688 | 0.66 | 35 | 5 | 32 | 28 | 88 | 53 | 17 | 12.5
Bilgen, 1998 99123665 | 0.83 | 17 | 0 | 44 | 35 | 100 | 56 | 13 | 12.9
Knudsen, 1990 91196560 | 0.84 | 28 | 0 | 61 | 118 | 100 | 34 | 15 | 13
| | 28 | 0 | 93 | 86 | 100 | 52 | 16 | 13
| | 24 | 4 | 113 | 66 | 86 | 63 | 17 | 13
| | 22 | 6 | 134 | 45 | 79 | 75 | 18 | 13
| | 15 | 13 | 158 | 21 | 54 | 88 | 19 | 13
| 0.84 | 91 | 4 | 56 | 56 | 96 | 50 | 15 | 10.2
| | 83 | 12 | 81 | 31 | 87 | 72 | 16 | 10.2
| | 68 | 27 | 91 | 21 | 72 | 81 | 17 | 10.2
| | 56 | 39 | 101 | 11 | 59 | 90 | 18 | 10.2
| | 31 | 64 | 108 | 4 | 33 | 96 | 19 | 10.2
Knudsen, 1992 92306741 | 0.63 | 28 | 0 | 13 | 97 | 100 | 12 | 7 | 11.7
| | 27 | 1 | 29 | 81 | 96 | 26 | 8 | 11.7
| | 21 | 7 | 72 | 38 | 75 | 65 | 9 | 11.7
| | 16 | 12 | 48 | 62 | 57 | 81 | 10 | 11.7
| | 9 | 19 | 102 | 8 | 32 | 93 | 11 | 11.7
Lin, 1993 93383693 | 0.82 | 12 | 6 | 230 | 57 | 68 | 80 | Var | 12.9
Schumacher, 1985 85241873 | 0.74 | 16 | 1 | 69 | 20 | 94 | 78 | 20 | 12.9
Tsai, 1988 90177720 | 0.87 | 19 | 2 | 141 | 16 | 90 | 90 | 16 | 13
Fok, 1986 86268743 | 0.86 | 16 | 0 | 122 | 64 | 100 | 66 | 22 | 15
Harish, 1998 98373176 | 0.83 | 24 | 1 | 21 | 14 | 96 | 59 | 18 | 13
Karrar, 1989 89271698 | 0.82 | 36 | 13 | 95 | 11 | 74 | 90 | 21 | 12.5
Knudsen, 1993 93333142 | 0.85 | 30 | 0 | 5 | 38 | 100 | 11 | 13 | 13
| | 30 | 0 | 8 | 35 | 100 | 19 | 14 | 13
| | 30 | 0 | 15 | 28 | 100 | 35 | 15 | 13
| | 29 | 1 | 22 | 21 | 97 | 51 | 16 | 13
| | 28 | 2 | 32 | 11 | 93 | 74 | 17 | 13
Knudsen, 1995 ^g^93333142 | ND | 9 | 0 | 57 | 44 | 100 | 56 | 9 | 18
| | 8 | 1 | 67 | 34 | 89 | 66 | 9.5 | 18
| | 7 | 2 | 79 | 22 | 78 | 78 | 10 | 18
| | 3 | 6 | 93 | 8 | 33 | 92 | 11 | 18
Maisels, 1982 82273864 | 0.93 | 7 | 0 | 145 | 5 | 100 | 97 | 24 | 13
| | 20 | 2 | 121 | 14 | 91 | 90 | 20 | 10
Smith, 1985 85112373 | 0.90 | 6 | 1 | 64 | 14 | 86 | 82 | Comb | 12.9
Taha, 1984 85070990 | 0.88 | 11 | 5 | 96 | 8 | 69 | 92 | 22.5 | 12.9
Dai, 1996 97093944 | ND | 8 | 0 | 21 | 11 | 100 | 67 | 17 | 15.2
Sheridan-Pereira, 1982 83021365 | 0.70 | 4 | 0 | 40 | 13 | 100 | 75 | 20 | 14.5
Measurement site: Sternum
Lin, 1993 93383693 | 0.86 | 15 | 3 | 241 | 46 | 84 | 84 | Var | 12.9
Fok, 1986 86268743 | 0.91 | 10 | 6 | 158 | 28 | 63 | 85 | 22 | 15
Linder, 1994 94325008 | 0.96 | 19 | 4 | 136 | 3 | 86 | 96 | ND | 12.9
Maisels, 1982 82273864 | 0.93 | 4 | 0 | 126 | 5 | 100 | 96 | 23 | 13
| | 11 | 0 | 105 | 19 | 100 | 85 | 19 | 10
Measurement site: Mixed sites
Carbonell, 2001 21130776 | 0.92 | 15 | 3 | 368 | 188 | 83 | 66 | 11 ^h^ | 17
| | 17 | 1 | 287 | 269 | 94 | 52 | 13 ^j^ | 17
| | 45 | 1 | 262 | 557 | 98 | 32 | 13 ^k^ | 17
Yamauchi, 1990 90273849 | ND | 17 | 5 | 35 | 21 | 77 | 63 | 14 ^h^ | 15
| | 20 | 2 | 47 | 9 | 91 | 84 | 21 ^i^ | 15
Christo, 1988 89253855 | 0.90 | 16 | 0 | 65 | 10 | 100 | 87 | 17 | 13
| | 9 | 0 | 24 | 2 | 100 | 92 | 23 | 17
Laeeq, 1993 93267865 | 0.77 | - | - | - | - | 97 | 41 | ND | 6
| | - | - | - | - | 91 | 78 | ND | 9.92
| | - | - | - | - | 90 | 99 | ND | 15

TP = true positive; FN = false negative; TN = true negative; FP = false positive; N = number of subjects; n = number of measurements; Sens = sensitivity; Spec = specificity; TcB = transcutaneous bilirubin; SB = serum bilirubin; r = regression coefficient between TcB and SB

r = Pearson's correlation coefficient

Comb = Elevated TcB, Elevated ETco, or Elevated both TcB and Etco. “Elevated” was defined as more than 1 SD above the mean

Var = TcB ≥ 11, ≥ 16, or ≥ 20 on the 1st, 2nd, and following days of life

g Corrected TcB was use: TcB reading taken at median 21 hours of life was “corrected” by the difference in TcB readings obtained 6 hours later.

h TcB reading at 24 hours of life

i TcB reading on day 3 of life

j TcB reading at 48 hours of life in the phase I study

k TcB reading at 48 hours of life in the phase II study

An additional challenge to comparison across studies is that each instrument must be calibrated on a daily basis as recommended by the manufacturer and each institution must establish the relationship between the jaundice meter index, TcB, and the TSB, in part due to interlaboratory variations of TSB measurements (Schreiner and Glick, 1982). As can be seen in the table, the TcB index that correlates with a given level of TSB varies from center to center, and as discussed above, the manufacturer recommends that each site develop its own correlation curves.

TcB indices that correspond to various TSB levels vary from institution to institution, but appear to be internally consistent. Different TSB threshold levels were used across studies, therefore there is limited ability to combine data across the studies. The majority of the studies used TcB measurements taken at the forehead, several studies used multiple sites and combined results, one study used only the midsternum site, and in three studies, TcB measurement was taken at multiple sites. Within studies, it does appear that in many of the studies a threshold TcB index could be developed where there was high sensitivity to predict levels of serum bilirubin at preselected levels of TSB that could be clinically useful: for example TSB >12–13, TSB>15, TSB >17–18. However the threshold effect did not show in a SROC curve using TSB ≥ 13 (12.5–13) mg/dl as the gold standard (see Figure S1 in Meta-Analyses). Eleven studies of the test performance of Minolta AirShields bilirubinometer measuring at forehead to serum bilirubin cutoff point of 13 mg/dl were included in the following analysis (see Table S1 in Meta-Analyses). A total of 1560 paired TcB and serum bilirubin measurements were evaluated. The cutoff points of Minolta AirShields TcB measurements ranged from 13 to 24 for screening a serum bilirubin level ≥ 13 mg/dl. Threshold effect doesn't show in the SROC curve, indicating great heterogeneity between studies. The unweighted pooled estimates of sensitivity and specificity were 0.85 (0.77–0.91) and 0.77 (0.66–0.85) (see Table S1 in Meta-Analyses).

Three studies (see Table S2 in Meta-Analyses) with a total of 299 paired TcB and serum bilirubin measurements were evaluated for the SROC curve of Minolta AirShields bilirubinometer measuring at forehead as a screening tool for serum bilirubin level ≥ 15 (14.5–15.2) mg/dl. Since all three studies had a sensitivity of 100 percent, a SROC curve is not appropriate. The unweighted pooled estimates of sensitivity and specificity was 0.95 (0.77–0.99) and 0.67 (0.61–0.73) (see Table S2 in Meta-Analyses).

Another three studies (see Table S3 in Meta-Analyses) with a total of 502 paired TcB and serum bilirubin measurements were evaluated for the SROC curve (see Figure S2 in Meta-Analyses) of Minolta AirShields bilirubinometer measuring at forehead as a screening tool for serum bilirubin level ≥ 11 (10–11.7) mg/dl. The unweighted pooled estimates of sensitivity and specificity was 0.76 (0.64–0.85) and 0.80 (0.63–0.91) (see Table S3 in Meta-Analyses).

### Overall Meta-analysis of Correlation Coefficients for Minolta AirShields Bilirubinometer

In 38 of the 41 studies, linear regression analysis was performed generating Pearson's correlation coefficient (r) for TcB versus TSB. Overall, it does appear that a linear relationship between TcB as measured by Minolta AirShields bilirubinometer and the TSB in predominately term or near-term infants not on phototherapy. The pooled correlation coefficient was 0.84 (95% CI 0.81–0.87) (see Figure S3 in Meta-Analyses).

### Factors Affecting Test Accuracy of Minolta AirShields Bilirubinometer

As detailed in the Evidence Table 5.1, the study designs were varied as to study population: only jaundiced infants vs. all infants, racial background, measurement site, age at measurement, site of TcB measurement, and type of assay used for TSB reference standard. In many of the studies subgroup analysis was performed and details of the factors that were examined, which may affect test accuracy, are summarized in the following sections.

#### Measurement Sites

In the Table 3.22 below summarizing those studies that evaluated multiple measurement sites, the Minolta AirShields bilirubinometer appears to perform similarly well at the forehead site and the sternum, with the sternum site slightly better. Correlation coefficients were lower at the palm and sole. Meta-analysis of correlation coefficient (r) was performed for forehead (Sample N=1,936) and sternum sites (Sample N=1,815). The pooled r at forehead site was 0.87 (95%CI 0.82–0.90) and that at sternum site was 0.90 (95%CI 0.86–0.92) (see Figure S4 in Meta-Analyses).

Table 3.22 Overall Correlation Coefficient of Minolta AirShields Measurements to Serum Bilirubin Levels on Different Measurement Sites in Healthy Term Infants with (GA ≥ 34 weeks) not on Phototherapy

Study, Year UI # | Country | Race | Sample N | Correlation Coefficient (r) | | | | | | | Quality
| | | | Forehead | Sternum | Abdomen | Upper back | Lower back | Palm | Sole
Lin, 1993 93383693 | Taiwan | Chinese | 202 | 0.82 | 0.86 | - | - | - | - | - | A
Tsai, 1988 90177720 | Taiwan | Chinese | 98 | 0.87 | 0.78 | 0.76 | 0.69 | 0.69 | 0.49 | 0.47 | A
Yamauchi, 1991 92188737 | Japan | Japanese | 336 | 0.91 | 0.92 | 0.89 | 0.89 | 0.88 | - | 0.77 | A
Yamauchi, 1988 89086035
Fok, 1986 86268743 | Hong Kong | Chinese | 202 | 0.86 | 0.91 | - | - | - | - | - | B
Hegyi, 1981 81144434 | US | White | 43 | 0.77 | 0.90 | 0.88 | 0.87 | 0.86 | 0.72 | 0.72 | B
Kenny, 1984 89271698 | US | White | 18 | 0.85 | 0.93 | - | 0.83 | - | - | - | B
Knudsen, 1989 89189829 | Denmark | ND | 76 | 0.86 | - | 0.89 | - | - | - | - | B
Knudsen, 1990 90242782
Maisels, 1982 82273864 | US | White | 135 | 0.93 | 0.93 | - | - | - | - | - | B
Tan, 1985 86101839 | Singapore | Chinese | 224 | 0.93 | 0.94 | - | 0.86 | - | - | - | B
Tan, 1982 83044572 | | Malay | 303 | 0.87 | 0.90 | - | 0.87 | - | - | -
Tan, 1996 97017283 | Singapore | Racial diverse ^a^ | 542 | 0.80 | 0.75 | - | - | - | - | - | B
Yamauchi, 1989 89348834 | Japan | Japanese | 114 | 0.90 | 0.92 | - | - | - | - | - | B

a Chinese + Malay + Indian infants

#### Gestational Age or Birth Weight

In the five studies that gave separate correlation coefficients shown in Table 3.23 for test performance between term and near-term infants, there were no significant differences seen in the studies although a trend of lower correlation of the TcB with TSB in the near-term infants is seen. Meta-analysis of correlation coefficient (r) was performed for term infants with gestational age ≥ 37 weeks or infants with birth weight > 2,500 grams, and near-term infants with gestational age 34–37 weeks or term infants with a birth weight < 2,500 grams. Meta-analysis of correlation coefficient (r) was performed for term (N=425 pairs) and sternum sites (N=308 pairs). The pooled r was 0.81 (95% CI 0.75–0.86) and 0.74 (95% CI 0.64–0.82) for term and near-term infants respectively (see Figure S5 in Meta-Analyses).

Table 3.23 Summary of Studies on the Effects of Gestational Age or Birth Weight to the Accuracy of Minolta TcB measurements at Forehead in Term or Near-Term Infants not on Phototherapy

Study, Year UI # | Country | Race (N) | Subgroups | Pairs (N) | Coefficient (r) | Significance | Quality
Bhat, 1987 88085341 | India | ND (100) | GA ≥ 37 wk | 63 | 0.72 | P=.123 | B
| | | GA < 37 wk | 37 | 0.52
| | | BW > 2500 g | 37 | 1.03 ? | n.d
| | | BW ≤ 2500 g | 63 | 0.94
Hanneman, 1982 82105249 | US | White (57) | Infants GA≥38 wks | 35 | 0.90 | P=.739 | B
| | | Infants GA 34–37 wks | 22 | 0.88
Harish, 1998 98373176 | India | ND (33) | Term infants | 60 | 0.83 | P=.363 | B
| | | SGA term + Preterm infants | 40 | 0.76
Sharma, 1988 89122266 | India | ND (200) | Term infants | 120 | 0.74 | P=.485 | B
| | | Preterm infants | 80 | 0.69
| | | BW ≥ 2.5 Kg | 110 | 0.85 | P=.371
| | | BW < 2.5 Kg | 90 | 0.81
Suckling, 1995 95327901 | Scotland | White (55) | Term AGA | 37 | 0.802 | P=.33 | C
| | | Preterm or SGA | 39 | 0.702

n.d. = not done, because the correlation 1.03 is not valid

Bold = significantly different between subgroups (p < .10)

? = Unknown

#### Race (or Skin Color)

Tables 3.24 and 3.25 below summarize those studies that compared correlation coefficients across different races or skin color. Significant differences with p < 0.10 are highlighted in bold print with higher correlation of TcB with TSB in Malay (r=0.83) versus Indian infants (r=0.63) in one study (Boo and Bakar, 1984) but no difference in another (Tan, Chia, and Koh, 1996); white (r=0.88–0.90) versus black infants (r=0. 74) (Goldman, Penalver, and Penaranda, 1982; Hannemann, Schreiner, DeWitt, et al., 1982); Chinese (r=0.93) versus Malay (r=0.87) (Tan, 1982; Tan, 1985) although in the opposite direction in a subsequent study with Malay (r=0.84 at forehead, 0.87 at sternum) versus Chinese (r=0.73 at forehead, 0.78 at sternum) (Tan, Chia, and Koh, 1996).

Table 3.24 Summary of Studies on the Effects of Race / Skin Color to the Accuracy of Minolta TcB measurements at Forehead in Term or Near-Term Infants not on Phototherapy

Study, Year UI # | Country | Race (N) | Subgroups | Pairs (N) | Coefficient (r) | Significance | Quality
Boo, 1984 85085660 | Malaysia | Mixed (105) | Malay infants | 38 | 0.83 | M vs. C: P=.101 | B
| | | Chinese infants | 37 | 0.66 | M vs. I: P=.081
| | | Indian infants | 30 | 0.63 | C vs. I: P=.842
Bourchier, 1987 88247126 | New Zealand | Mixed (729) | Caucasian infants | 412 | 0.58 | P=.842 | B
| | | Maori infants | 317 | 0.57
| | | Black infants | 108 | 0.52
Hanneman, 1982 82105249 | US | Mixed (99) | White Infants GA≥34 wks | 57 | 0.88–0.90 | P=.025 | B
| | | Black infants GA≥34 wks | 42 | 0.74
Tan, 1985 86101839 | Singapore | Mixed (125) | Chinese infants | 102 | 0.93 | P=.018 | B
Tan, 1982 83044572 | | | Malay infants | 103 | 0.87
Tan, 1996 97017283 | Singapore | Mixed (542) | Chinese infants | 253 | 0.73 | M vs. C: P=.003 | B
| | | Malay infants | 169 | 0.84 | M vs. I: P=.435
| | | Indian infants | 120 | 0.81 | C vs. I: P=.077
Goldman, 1982 82241425 | US | Mixed (84) | White infants | 95 | 0.71 | P=.035 | C
| | | Black infants | 108 | 0.52

Bold = significantly different between subgroups (p < .10)

Table 3.25 Summary of Studies on the Effects of Race / Skin Color to the Accuracy of Minolta TcB measurements at Sternum in Term or Near-Term Infants not on Phototherapy

Study, Year UI # | Country | Race (N) | Subgroups | Pairs (N) | Coefficient (r) | Significance | Quality
Bourchier, 1987 88247126 | New Zealand | Mixed (729) | Caucasian infants | 412 | 0.67 | P=.253 | B
| | | Maori infants | 317 | 0.62
Tan, 1985 86101839 | Singapore | Mixed (125) | Chinese infants | 69 | 0.93 | P=.115 | B
Tan, 1982 83044572 | | | Malay infants | 103 | 0.90
Tan, 1996 97017283 | Singapore | Mixed (542) | Chinese infants | 253 | 0.78 | M vs. C: P=.004 | B
| | | Malay infants | 169 | 0.87 | M vs. I: P=.230
| | | Indian infants | 120 | 0.83 | C vs. I: P=.202

Bold = significantly different between subgroups (p < .10)

Meta-analysis of correlation coefficient (r) was performed for different races at forehead. A total of 564, 258, 392, 150, and 310 pairs of measurements were available for white, black, Chinese, Indian and Malay infants. At forehead, the pooled r for white infants was 0.65 (95%CI 0.59–0.69), for black infants was 0.56 (95%CI 0.47–0.64), for Chinese infants was 0.80 (95%CI 0.77–0.84), for Indian infants was 0.78 (95%CI 0.71–0.84), and for Malay infants was 0.85 (95%CI 0.82–0.88) (see Figure S6 in Meta-Analyses).

#### Phototherapy

In two of the four studies that analyzed test performance separately for those who had received phototherapy, there were significantly lower correlation coefficients for those who had received phototherapy with a similar trend seen in the other two studies. Fok, Lau, Hui, et al. (1986) found that the correlation coefficient between TcB indices and TSB levels dropped from 0.91 to 0.26 at the sternum with exposure to phototherapy and from 0.86 to 0.79 for those in the shaded area of the forehead.

Meta-analysis of correlation coefficient (r) was performed for infants not on phototherapy and those on phototherapy. The pooled r for infants on phototherapy was 0.78 (95% CI 0.72–0.83) and that was 0.85 (95% CI 0.79–0.89) for infants not on phototherapy (see Figure S7 in Meta-Analyses).

#### Other Factors

In the following two Tables 3.27 and 3.28, several studies reported comparisons of correlation coefficients of TcB to TSB for factors of age, sunlight exposure, and feeding (breast versus mixed formula/breast or formula only) and measurement site. Those studies that reported forehead measurements are summarized in Table 3.27, sternum in Table 3.28. Carbonell, Botet, Figueras, et al. (2001) found no significant differences in TcB/TSB correlation at the forehead measurement site, but significant improvement at the sternum site when comparing <24 hours to 24–48. Yamauchi and Yamanouchi (1991) and Yamauchi and Yamanouchi (1988) found that better correlation is found at the sternum than the forehead and that the sternum site appears less affected by sunlight exposure than the forehead.

Table 3.27 Summary of Studies on the Effects of Other Factors to the Accuracy of Minolta TcB measurements at Forehead in Term or Near-Term Infants not on Phototherapy

Study, year UI#; | Country | Race (N) | Subgroups | Pairs (N) | Coefficient (r) | Significance | Quality
Carbonell, 2001 21130776 | Spain | ND (574) | < 24 hrs | 120 | 0.77 | <24 vs. 24–48 hrs: P=.194 | A
| | | 24–48 | 126 | 0.83 | <24 vs. >48 hrs: P=.106
| | | < 48 hrs | 412 | 0.83 | 24–48 vs. >48 hrs: P=1.000
Yamauchi, 1991 92188736 | Japan | Japanese 107 | Infants days 1–5, Sunlight | 28 | 0.812 | Sunlight vs. no sunlight 1–5 day: P=.159 | A
| | | Infants days 1–5, No Sunlight | 53 | 0.901 | Sunlight 1–5 vs. 6–7 day: P=.018
| | | Infants days 6–7, Sunlight | 53 | 0.937 | No sunlight 1–5 vs. 6–7 day: P=.936
| | | Infants days 6–7, No sunlight | 52 | 0.903
Yamauchi, 1991 92188737 | Japan | Japanese (336) | Infants, days 0–3 | 68 | 0.922 | Days 0–3 vs. 4–5: P=.002 | A
Yamauchi, 1988 89086035 | | | Infants, days 4–5 | 159 | 0.814 | Days 0–3 vs. 6–12: P=.678
| | | Infants, days 6–12 | 349 | 0.930 | Days 4–5 vs. 6–12: P<0.0001
Kenny, 1984 89271698 | US | Caucasian (53) | Mixed-fed infants | 41 | 0.846 | M vs. B: P=.073 | B
| | | Breast-fed infants | 24 | 0.939 | M vs. F: P=.921
| | | Formula-fed infants | 17 | 0.837 | B vs. F: P=.133

Bold p < .10

Table 3.28 Summary of Studies on the Effects of Other Factors to the Accuracy of Minolta TcB measurements at Sternum in Term or Near-Term Infants not on Phototherapy

Study, Year, UI# | Country | Race (N) | Subgroups | Pairs (N) | Coefficient (r) | Significance | Quality
Carbonell, 2001 21130776 | Spain | ND (574) | < 24 hrs | 120 | 0.81 | <24 vs. 24–48 hrs: P=.1022 | A
| | | 24–28 hrs | 126 | 0.89 | <24 vs. >48 hrs: P<.00001
| | | >48 hrs | 412 | 0.94 | 24–48 vs. >48 hrs: P=.002
Yamauchi, 1991 92188736 | Japan | Japanese (107) | Infants days 1–5, Sunlight | 28 | 0.892 | Sunlight vs. no sunlight 1–5 day: P=.937 | A
| | | Infants days 1–5, No sunlight | 53 | 0.888 | Sunlight 1–5 vs. 6–7 day: P=.800
| | | Infants days 6–7, Sunlight | 53 | 0.904 | No sunlight 1–5 vs. 6–7 day: P=.280
| | | Infants days 6–7, No sunlight | 52 | 0.926
Yamauchi, 1991 92188737 | Japan | Japanese (336) | Infants, days 0–3 | 68 | 0.905 | Days 0–3 vs. 4–5: P=.134 | A
Yamauchi, 1988 89086035 | | | Infants, days 4–5 | 159 | 0.856 | Days 0–3 vs. 6–12: P=.067
| | | Infants, days 6–12 | 349 | 0.941 | Days 4–5 vs. 6–12: P<0.0001

Bold = p < .10

### Accuracy of BiliCheck™

Three studies (see Evidence Table 5.2 Part I – IV) examined the accuracy of the BiliCheck™ (multi-wavelength spectral reflectance device, MWSR) transcutaneous bilirubin measurements (TcB) to predict serum bilirubin (TSB) (“gold standard”). All studies were rated as high quality. Overall meta-analysis of correlation coefficients was performed for these three studies. Sample size was used to replace the number of pairs of measurements. The pooled correlation coefficient between BiliCheck™ bilirubin measurements and laboratory essay of serum bilirubin measurements was 0.88 (95% CI 0.83–0.92) (see Figure S8 in Meta-Analyses)

In the first study (Bhutani, Gourley, Adler, et al., 2000), 490 healthy term or near term U.S. infants, racially diverse (59 percent white, 29 percent black, 3 percent Hispanic, 4 percent Asian), received multiple TcB evaluations at the forehead site with two to four different devices each (a total of 11 devices) with near simultaneous measurement of TSB by high performance liquid chromatography (HPLC) for a total of 1788 paired measurements. The correlation of TcB to TSB (HPLC) was linear and significant (r = 0.91; P < 0.001). Similar correlation was found when categorized by race and gestational maturity, term versus near term (detailed in Evidence Table 6, Part 3). Intradevice precision of the BiliCheck™ was 0.59 mg/dl and interdevice precision was 0.68 mg/dl. Finally, as summarized in Table 3.29 below, when used as a “risk assessment” the BiliCheck™ TcB ≥ 75 percentile at 24 to 72 hours of age predicted a TSB ≥ 95 percentile track on the hour specific bilirubin nomagram (Bhutani, Gourley, Adler, et al., 2000) with 100 percent sensitivity and 88.1 percent specificity.

Table 3.29 Part 2. Test Accuracy of BiliCheck™ MMSR device in Healthy, Term or Near-Term (GA≥34) Infants not on Phototherapy or Exchange Transfusion

Study, Year, UI # | r | TP (n) | FN (n) | TN (n) | FP (n) | Sens (%) | Spec (%) | Thresholds
| | | | | | | | BiliC | SB (mg/dl)
Bhutani, 2000 20381429 | 0.91 | 23 | 0 | 349 | 147 | 100 | 88 | ≥ 75^th^ %tile | ≥ 95^th^ %tile
Lodha, 2000 20368382 | 0.83 | - | - | - | - | 69 | 89 | 13 | 13
| | - | - | - | - | 47 | 99 | 15 | 15
| | - | - | - | - | 20 | 100 | 18 | 18
Rubaltelli, 2001 21283339 | 0.87~0.89 | - | - | - | - | 97 | 64 | 10 | 13
| | - | - | - | - | 93 | 73 | 11 | 13
| | - | - | - | - | 86 | 85 | 12 | 13
| | - | - | - | - | 66 | 89 | 13 | 13
| | - | - | - | - | 92 | 71 | 12 | 15
| | - | - | - | - | 81 | 82 | 13 | 15
| | - | - | - | - | 63 | 92 | 14 | 15
| | - | - | - | - | 52 | 95 | 15 | 15
| | - | - | - | - | 90 | 87 | 14 | 17
| | - | - | - | - | 77 | 91 | 15 | 17
| | - | - | - | - | 63 | 96 | 16 | 17
| | - | - | - | - | 50 | 99 | 17 | 17

TP = true positive; FN = false negative; TN = true negative; FP = false positive; n / N = number of subjects; Sens = sensitivity; Spec = specificity; BiliC = BiliCheck measurement; SB = serum bilirubin; r = regression coefficient between BiliC and SB

All infants were healthy, term (GA≥34), and not on phototherapy or exchange transfusion, unless noted

Table 3.29 Part 1. Summary Studies of Bilicheck™ MMSR device in Healthy, Term or Near-Term (GA≥34) Infants not on Phototherapy or Exchange Transfusion

Study, Year UI # | Country | Race (N) | Reference Standard: Laboratory-based Assay of TSB | Quality
Bhutani, 2000 20381429 | US | Mixed race (517) | High-performance liquid chromatography (HPLC) | A
Lodha, 2000 20368382 | India | Indian (109) | Twin beam Microbilimeter (Ginevri Technologie Biomediche) | A
Rubaltelli, 2001 21283339 | Europe | Mixed race (210)^a^ | High-performance liquid chromatography (HPLC) | A

All infants were healthy, term (GA≥34), and not on phototherapy or exchange transfusion, unless noted:

a 20 percent infants ≤ 36 weeks

MMSR = multi-wavelength spectral reflectance

The second study (Lodha, Deorari, Jatana, et al., 2000) evaluated the BiliCheck™ accuracy in 109 term Indian infants with nonhemolytic jaundice (TSB > 8mg/dl). One hundred twenty-one paired estimations were performed, with TSB measured by “twin beam Microbilimeter” (Genevri Technologie Biomediche). In this sample, the BiliCheck™ performed less well, with r=0.8 overall and r=0.64 for the subgroup of 46 infants with TSB > 13 mg/dl. As shown in Table 3.26 Part 2 below, the sensitivity of the TcB to detect TSB > 13 mg/dl was 69 percent with a specificity of 89 percent which was similar to clinical assessment by experienced clinician of 52 percent sensitivity and 89 percent specificity. At higher threshold levels of TSB > 15 mg/dl sensitivity was 46.6 percent, specificity 99 percent and for TSB > 18 mg/dl, sensitivity was 20 percent and specificity 100 percent (only four infants had TSB > 18 mg/dl).

Table 3.26 Summary of Studies on the Effects of Phototherapy to the Accuracy of Minolta TcB measurements in Term or Near-Term Infants

Study | Country | Race (N) | Subgroups | Pairs (N) | Coefficient (r) | Significance | Quality
Christo, 1988 89253855 | India | ND (117) | Term infants w/o PhotoRx | 91 | 0.89 | P=.479 | B
| | | Infants on PhotoRx | 26 | 0.85
Fok, 1986 862687 43 | Hong Kong | Chinese (259) | Infants w/o PhotoRx | 605 | 0.86 | P=.043 | B
| | | Infants on PhotoRx | 100 | 0.79
Hanneman, 1982 82105249 | US | White (87) | Infants GA≥38 wks w/o PhotoRx | 35 | 0.90 | P=.736 | B
| | | Infants GA≥38 wks on PhotoRx | 7 | 0.86
| | | Infants GA 34–37 wks w/o PhotoRx | 22 | 0.88 | P=.387
| | | Infants GA 34–37 wks on PhotoRx | 23 | 0.80
Harish, 1998 98373176 | India | ND (33) | Term infants w/o PhotoRx | 60 | 0.83 | P=.067 | B
| | | Term infants on PhotoRx | 33 | 0.65
Sheridan-Pereira, 1982 83021365 | Ireland | White (60) | Term w/o PhotoRx | 57 | 0.65 | P=.39 | C
| | | Term on PhotoRx | 24 | 0.76

PhotoRx = phototherapy

Bold = significantly different between subgroups (p < .10)

The final study (Rubaltelli, Gourley, Loskamp, et al., 2001) was a multicenter study that attempted to evaluate the pooled performance of multiple BiliCheck™ devices in a diverse international population with multiple users and multiple laboratory methods of bilirubin determination compared to the “gold standard” of HPLC determination of bilirubin. Thirty-five infants undergoing TSB as part of their normal care were recruited from six different European hospitals (N=210) who underwent BiliCheck™ measurements at both forehead and sternum, TSB determinations by each hospital's usual laboratory method and HPLC TSB at a single reference laboratory. All infants were greater than 30 weeks GA, and 20 percent of the sample was less than 36 weeks GA. The correlation coefficient (r) for the combined BiliCheck™ TcB data was 0.89 at the forehead and 0.88 at the sternum compared with the gold standard TSB measured by HPLC. The correlation for TcB and laboratory TSB was similar, r=0.87. The intra-device coefficient of variation for BiliCheck™ forehead was 6.69 percent. HPLC TSB and standard laboratory measurements had high correlation (r=0.927). The BiliCheck™ TcB at the forehead and the laboratory TSB underestimated TSB measured by HPLC slightly. With a threshold TSB by HPLC of 13 and BiliCheck™ TcB of 11 the sensitivity was 93 percent and specificity 73 percent (similar to the performance of the laboratory TSB of 95 percent and 76 percent respectively). At a threshold TSB of 17 mg/dl, the TcB had 90 percent sensitivity and 87 percent specificity, slightly better than standard laboratory TSB of 87 percent and 83 percent. The authors conclude that the accuracy and precision of the TcB by BiliCheck™ was comparable to the standard laboratory TSB when compared to the gold standard TSB measurement by HPLC. Analysis of covariance found no differences in test performance by postnatal age, gestational age, birth weight or race; however, the majority of infants were white (66.7 percent) and only 4.3 percent were of African descent.

### Accuracy of Ingram Icterometer

Four studies (see Evidence Table 5.3 Part I – IV) evaluated the performance of the Ingram Icterometer TcB measurements to predict total serum bilirubin (TSB) in healthy, term infants with jaundice who were not receiving phototherapy. There was a linear relationship between the icterometer readings (TcB) and the serum bilirubin measurements (TSB). In two of the studies (Bilgen, Ince, Ozek, et al., 1998; Schumacher, Thornbery, and Gutcher, 1985) comparison was made with the Minolta Airshields Tc Bilirubinometer (see next section of report). The correlation coefficients (r) in the four studies were 0.96, 0.63, 0.97 and 0.78 respectively as summarized in Evidence Table 5.3 Part III. The pooled correlation coefficient between Ingram Icterometer measurements and laboratory essay of serum bilirubin measurements was 0.92 (95% CI 0.72–0.98) (see Figure S9 in Meta-Analyses). The three studies that provided results on the performance of the icterometer to predict serum bilirubin are summarized in the following two Tables, 3.30, Part 1 and Part 2. In term infants, the icterometer had an 82–100 percent sensitivity to predict a TSB > 12.9, with specificity of 48 and 74 percent respectively, and 97 percent sensitivity, 78 percent specificity to predict a TSB > 10 mg/dl. The disadvantage of the icterometer is the inter-observer variation to visually distinguish shades of color, but it has the advantage of low cost and maintenance (no calibration necessary).

Table 3.30 Part 1. Summary Studies of Ingram Icterometer at Tip of Nose in Healthy, Term or Near-Term (GA≥34) Infants not on Phototherapy or Exchange Transfusion

Study, Year, UI # | Country | Race (N) | Reference Standard: Laboratory-based assay of TSB | Quality
Bilgen, 1998 99123665 | Turkey | ND (96) | Bilitron 444 direct spectrophotometric method | A
Schumacher, 1985 85241873 | US | White (106) | Dupont ACA III analyzer, a direct spectrophotometry method | A
Gupta, 1991 92091059 | India | ND (88)^a^ | Type BM2-TOYO bilirubin analyser | B

All infants were healthy, term (GA≥34), and not on Phototherapy or exchange transfusion, unless noted:

a 77 term (GA≥37) infants; 11 preterm (GA 35–36) infants

Table 3.30 Part 2. Test Accuracy of Ingram Icterometer at Tip of Nose in Healthy, Term or Near-Term (GA≥34) Infants not on Phototherapy or Exchange Transfusion

Study, Year, UI # | r | TP (n) | FN (n) | TN (n) | FP (n) | Sens (%) | Spec (%) | Thresholds
| | | | | | | | Ict | SB (mg/dl)
Bilgen, 1998 99123665 | 0.78 | 17 | 0 | 38 | 41 | 100 | 48 | 3 | 12.9
Schumacher, 1985 85241873 | 0.63 | 14 | 3 | 66 | 23 | 82 | 74 | 3 | 12.9
Gupta, 1991 92091059 | 0.97 | Term infants (N=77) | | | | 97 | 71 | 3 | 10
| | Preterm (GA 35–36) infants (N=11) | | | | 50 | 86 | 3 | 10

TP = true positive; FN = false negative; TN = true negative; FP = false positive; n / N = number of subjects; Sens = sensitivity; Spec = specificity; Ict = Ictermeter Index; SB = serum bilirubin; r = regression coefficient between Ict and SB

All infants were healthy, term (GA≥34), and not on Phototherapy or exchange transfusion, unless noted

### Accuracy of the Chromatics Colormate III

One study (Tayaba, Gribetz, Gribetz, et al., 1998) was reviewed that evaluated the performance of the Colormate III transcutaneous bilirubinometer (see Evidence Table 5.4 Part I – IV). Consecutively born term and preterm infants born at one of two New York City hospitals were recruited, N=2441, and had TcB measurements taken within 30 hours of birth and every 6 to 8 hours until hospital discharge. Of these infants, 900 had subsequent measurements of TSB (1600 TcB/TSB pairs of measurements were taken) with a range of TSB values of 0.2 mg/dl to 21 mg/dl. Clinicians were blinded to TcB results. Linear regression analysis showed excellent correlation of the TcB measurements to TSB measurements by the standard laboratory determinations. The correlation coefficient, r, for the whole study group was 0.9563 and accuracy was not affected by race, weight, or phototherapy. The accuracy of the device is increased by the determination of an infant underlying skin type before the onset of visual jaundice; thus one drawback to the method when used as a screening device is that all infants would require an initial baseline measurement.

### Direct Comparison of the Accuracy of Different Instruments of TcB Measurements

#### Minolta AirShields Bilirubinometer (Jaundice Meter™) vs. BiliCheck™

One recent study, (Robertson, Kazmierczak, and Vos, 2002) compared the Jaundice Meter™ JM 102 (Minolta/Hill-ROM Air-Shields) to the SpectRx BiliCheck™. Jaundiced term infants not receiving phototherapy (n=101) had transcutaneous bilirubinometry (TcB) measurements taken at the forehead with both instruments and a serum bilirubin measurement (TSB) by the standard laboratory method (colorimetric diazonium salt method). In addition, skin pigmentation of the forehead was graded. The BiliCheck™ performed superiorly (r=.937) to the Jaundice Meter™ (r=0.704) in predicting TSB. With the BiliCheck™, skin color was not statistically significant in predicting TSB (p=0.890); however, skin color was significant with the Jaundice Meter™ (p=0.002).

#### Minolta AirShields Bilirubinometer vs. Ingram Icterometer

Two studies compared the performance or the Minolta AirShields bilirubinometer to the Ingram Icterometer in predicting serum bilirubin in healthy, jaundiced term infants (Bilgen, Ince, Ozek, et al., 1998; Schumacher, Thornbery, and Gutcher, 1985). In both studies, there was a linear relationship between the TcB and TSB with the Minolta AirShields bilirubinometer having higher correlation (r=0.74 and 0.83) than the icterometer (r=0.63 and 0.78). However, both devices performed similarly as screening devices with 100 percent sensitivity to predict TSB > 12.9 in the Bilgen study and no statistically significant difference between the two methods to predict TSB >12.9 in the Schumacher study (94 percent sensitivity, 77.5 percent specificity for the Minolta AirShields device and 82 percent sensitivity, 74 percent specificity for the Ingram icterometer).