# Appendix D. Contributors

The Evidence-based Practice Center staff acknowledges the collaboration of technical experts and Peer Reviewers in the preparation of this evidence report.

Technical Experts

American Academy of Family Physicians

William Hueston, MD

Department of Family Medicine

Medical University of South Carolina

Charleston, South Carolina

American Academy of Pediatrics

M. Jeffrey Maisels MD

Department of Pediatrics

William Beaumont Hospital

Royal Oak, Michigan

Thomas B. Newman, MD, MPH

Department of Epidemiology

University of California, San Francisco

San Francisco, California

David K. Stevenson, MD

Department of Pediatrics

Stanford University Medical School

Stanford, California

National Association of Pediatric Nurse Practitioners

Cheryl Aldridge MN, RN

Argyle, Texas

Center for Quality of Care Research and Education

R. Heather Palmer, M.B.B.Ch., S.M

Professor of Health Policy and Management,

Director, Center for Quality of Care Research and Education

Boston, Massachusetts

Parents of Infants and Children with Kernicterus

Ms. Sue Sheridan

Boise, Idaho

Peer Reviewers

American Academy of Family Physicians

Diane J. Madlon-Kay, MD

Minneapolis, Minnesota

Martin C. Mahoney, MD, PhD, FAAFP

Clarence, New York

American Academy of Pediatrics

Charlie Homer, MD, MPH, President and

National Initiative for Children's Healthcare Quality

Institute for Healthcare Improvement

Boston, Massachusetts

National Association of Pediatric Nurse Practitioners

Julie Novak, DNSc, RN, MA, CPNP

Lafayette, Indiana

Deborah Parks, DSN, RN, CPNP

Houston, Texas

Centers for Disease Control and Prevention

National Center for Birth Defects and Developmental Disabilities

Rachel Avchen, MS, PhD

Research Scientist

Atlanta, Georgia

National Institute for Child Health and Human Development

Pregnancy and Perinatology Branch

Tonse N.K. Raju, MD

Medical Officer, Neonatal Research

Rockville, Maryland