# Appendix C. Acronyms and Abbreviations

| Description
AAP | American Academy of Pediatrics
ABR | auditory brainstem response
AGA | birthweight was appropriate for gestational age
AHRQ | Agency for Healthcare Research and Quality
ARR | Absolute risk reduction
AUC | Areas under the ROC curve
BAER/BAEP | brainstem auditory evoked response / brainstem auditory evoked potential
BET | blood exchange transfusion
BMJ | Breast-milk jaundice
BNBAS | Brazelton neonatal behavioral assessment scale
BW | Birthweight
BSID | Bayley Scales of Infant Development
CB | Cord-blood bilirubin
CNS | Central nervous system
CPP | Collaborative Perinatal Project
C/S | cesarean section
DDST | Denver Developmental Screening Test
DQ | Developmental Quotient
ETCOc | End-tidal carbon-monoxide concentration
EEG | electroencephalograph
EFS | Educational Follow-up Study
EGA | Estimated gestational age
ET | Exchange Transfusion
GA | Gestational age
G6PD | glucose-6-phosphate dehydrogenase deficiency
HC | Head circumference
HPLC | High performance liquid chromatography
IMS | infant motor screening
IPL | interpeak latency
IQ | Intelligence Quotient
ITPA | Illinois test of Psycholinguistic Ability
Mo | Months
MR | mental retardation
MRT | Metropolitan Readiness Tests
NICHD | National Institute of Child Health and Human Development
ND | No data
NNT | Number Needed to Treat
OD | Optical densities
PB | Phenobarbital
PPV | Positive predictive value
PhotoRx | Phototherapy
Rh | Rhesus
ROC | Receiver operating characteristics
SB | Serum bilirubin
SROC | Summary receiver operating characteristics
TcB | Transcutaneous bilirubin
TSB | total serum bilirubin
VEP | visual evoked potentials
Wks | weeks
Yrs | years