# Appendix A. Search Strategy

[Titles Display] [Main Search Page]

------------------------------------------------------------------------

MEDLINE <1966 to September Week 3 2001>

------------------------------------------------------------------------

# | Search History | Results
1 | exp Hyperbilirubinemia/ | 15774
2 | exp Hyperbilirubinemia, Hereditary/ | 1234
3 | exp Bilirubin/ | 14754
4 | exp Jaundice, Neonatal/ | 4492
5 | exp Kernicterus/ | 547
6 | (bilirubin or hyperbilirubin$).tw | 16111
7 | kernicterus.tw. | 347
8 | jaundice.tw. | 13434
9 | neonat$.tw. | 98990
10 | 1 or 2 or 3 or 6 or 8 | 41610
11 | limit 10 to newborn infant | 7645
12 | (6 or 8) and 9 | 2900
13 | 4 or 5 or 11 or 12 | 8588
14 | limit 13 to human | 8431
15 | limit 14 to english language | 5746
16 | Case Report/ | 1022282
17 | 15 not 16 | 5063
| limit 17 to (addresses or bibliography or biography or comment
18 | or dictionary or directory or editorial or festschrift or interview or lectures or legal cases or letter or news or overall or periodical index) | 304
19 | 17 not 18 | 4759
| limit 19 to (guideline or meta analysis or practice guideline
20 | or review or review literature or review, academic or review multicase or review, tutorial) | 479
21 | 19 not 20 | 4280

[Titles Display] [Main Search Page]

------------------------------------------------------------------------

PREMEDLINE <September 24, 2001>

-------------------------------------

# | Search History | Results
1 | (bilirubin or hyperbilirubin$).tw. | 199
2 | kernicterus.tw. | 6
3 | jaundice.tw. | 156
4 | neonat$.tw. | 1541
5 | (1 or 3) and 4 | 49
6 | [Case Report/] | 0
7 | 2 or 5 | 51
8 | limit 7 to english language | 45
9 | limit 8 to review articles | 0
10 | from 8 keep 1–45 | 45