# Evidence Tables

Table I Evidence Table. SAMe for Treatment of Depression

| | | | | | | | Outcome Measurements**
1^st^ Author Year | Design Study Quality Population Diagnostic Criteria | | Arm # | Intervention Component Dose | | Sample Size | | Meta-Analysis Data***
Agnoli 1976 | Study Design: | RCT | 1 | Placebo | | n Entered: | 10 | Type of Outcome: Hamilton Depression
| Crossover Study: | No | | Dose: | N/A | n Analyzed: | 10
| Jadad Score: | 2 | | Route of Admin: | Intramuscular | | | Follow-ups (In Days): 3, 7, 15
| | | | Frequency: | 3 Per Day For 2–15 Days
| % Female: | 60 | 2 | SAMe | | n Entered: | 20 | Insufficient statistics for meta-analysis.
| % Under 18: | 0 | | Dose: | 15 mg | n Analyzed: | 20
| % Over 65: | N/A | | Route of Admin: | Intramuscular | | | HRSD:Comparison pre/post scores for Placebo (NS) and for SAMe (p<0.001). Treatment stopped as soon as clinically significant improvement noted (average 6.6 days).
| | | | Frequency: | 3 Per Day For 2–15 Days
| DSM 3 or 4: | No
Ancarnai 1993 | Study Design: | CCT | 1 | Placebo | | n Entered: | N/A | Type of Outcome: Hard Depression, IPAD-DS
| Crossover Study: | No | | Dose: | N/A | n Analyzed: | 10
| Jadad Score: | 1 | | Route of Admin: | Intravenous | | | Follow-ups (In Days): 10, 21
| | | | Frequency: | 1 Every Other Day
| % Female: | 43 | | | For 3 Weeks | | | Depression: Hamilton Rating Scale for Depression at 21 days
| % Under 18: | 0 | 2 | SAMe | | n Entered: | N/A
| % Over 65: | N/A | | Dose: | 400 mg | n Analyzed: | 41 | Arm 1 = 18.33 (8.60)
| | | | Route of Admin: | Intravenous | | | Arm 2 = 17.21 (8.58)
| DSM 3 or 4: | Yes | | Frequency: | 1 Every Other Day
| | | | | For 3 Weeks | | | Chronic Renal Failure patients. IPAT-DS scale:
| | | | | | | | Comparison pre/post scores for Placebo and SAMe (p<0.01).
Barberi 1978 | Study 1 of 2 | | 1 | Amitriptyline | | n Entered: | 10 | Type of Outcome: Hamilton Depression
| Study Design: | RCT | | Dose: | 50 mg | n Analyzed: | 10
| Crossover Study: | No | | Route of Admin: | N/A | | | Follow-ups (In Days): 7,20
| Jadad Score: | 1 | | Frequency: | 2 Per Day For 20 Days
| | | | | | | | Depression: Hamilton Rating Scale for Depression at 20 days
| % Female: | 60
| % Under 18: | 0 | | | | | | Arm 1 = 9.40 (2.85)
| % Over 65: | 0 | | | | | | 10 pts 25% improvement
| | | | | | | | 10 pts 50% improvement
| DSM 3 or 4: | No | 2 | SAMe | | n Entered: | 10
| | | | Dose: | 100 mg | n Analysed: | 10 | Arm 2 = 10.00 (1.58)
| | | | Route of Admin: | Intravenous | | | 10 pts 25% improvement
| | | | Frequency: | 2 Per Day For 20 Days | | | 10 pts 50% improvement
Barberi 1978 | Study 2 of 2 | | 1 | Placebo | | n Entered: | 10 | Type of Outcome: Hamilton Depression, PGA-Overall
| Study Design: | RCT | | Dose: | 100 mg | n Analized: | 10
| Crossover Study: | Yes | | Route of Admin: | Intravenous
| Jadad Score: | 2 | | Frequency: | 2 Per Day For 10 Days | | | Follow-ups (In Days): 10, 20
| | | 2 | SAMe | | n Entered: | 10
| % Female: | 45 | | Dose | 100 mg | n Analyzed: | 10 | Insufficient statistics for meta-analysis.
| % Under 18: | 0 | | Route of Admin: | Intravenous
| % Over 65: | 0 | | Frequency: | 2 Per Day For 10 Days | | | Hamilton Rating Scale for Depression: 57% of patients improved with SAMe; 15.3% improved with Placebo.
| DSM 3 or 4 | No
Bell 1988 | Study Design: | RCT | 1 | Imipramine | | n Entered: | 11 | Type of Outcome: Hamilton Depression, Beck, Symptoms, Somatic Symptoms Checklist
| Crossover Study: | No | | Dose: | 150 mg | n Analyzed: | 9
| Jadad Score: | 4 | | Route of Admin: | Oral
| | | | Frequency: | 1 Per Day For 14 Days | | | Follow-ups (In Days): 14
| % Female: | 72 | 2 | SAMe | | n Entered: | 11
| % Under 18: | N/A | | Dose: | 400 mg | n Analyzed: | 9 | Depression: Hamilton Rating Scale for Depression at 14 days
| % Over 65: | 0 | | Route of Admin: | Intravenous
| | | | Frequency: | 1 Per Day For 14 Days | | | Arm 1 = 31.20 (10.60)
| DSM 3 or 4: | Yes | | | | | | 2 pts 25% improvement
| | | | | | | | 2 pts 50% improvement
| | | | | | | | Arm 2 = 14.60 (9.30)
| | | | | | | | 9 pts 25% improvement
| | | | | | | | 6 pts 50% improvement
| | | | | | | | Beck Depression Scale: Comparison of improvement with SAMe vs. Imipramine (p<0.05) on day 14. Somatic Symptom Checklist: SAMe reported fewer side effects on days 10–14 compared to Imipramine (p<0.05).
Bell 1994 | Study Design: | RCT | 1 | Desipramine | | n Entered: | N/A | Type of Outcome: Hamilton Depression
| Crossover Study: | No | | Dose: | 250 mg | n Analyzed: | 6
| Jadad Score: | 2 | | Route of Admin: | Oral | | | Follow-ups (In Days): 28
| | | | Frequency: | 2 Per Day For 4 Weeks
| % Female: | 76 | 2 | SAMe | | n Entered: | N/A | Depression: Hamilton Rating Scale for Depression at 28 days
| % Under 18: | N/A | | Dose: | 800 mg | n Analyzed: | 11
| % Over 65: | N/A | | Route of Admin: | Oral | | | Arm 1:
| | | | Frequency: | 2 Per Day For 4 Weeks | | | 2 pts 50% improvement
| DSM 3 or 4: | Yes | | | | | | Arm 2:
| | | | | | | | 6 pts 50% improvement
| | | | | | | | Responders to treatment showed higher levels of SAMe in plasma (p<0.04).
Berlanga 1992 | Study Design: | RCT | 1 | Placebo | | n Entered: | 20 | Type of Outcome: Hamilton Depression
| Crossover Study: | No | | Dose: | N/A | n Analyzed: | 20
| Jadad Score: | 3 | | Route of Admin: | Intramuscular | | | Follow-ups (In Days): 2, 4, 6, 8, 10, 12, 14, 56
| | | | Frequency: | 1 Per Day For 2 Weeks
| % Female: | 80 | | Imipramine | | | | Exclude from meta-analysis as latency study.
| % Under 18: | 0 | | Dose: | 150 mg
| % Over 65: | 0 | | Route of Admin: | Oral | | | Combination of Imipramine and SAMe associated with earlier response. Hamilton Rating Scale for Depression: Combination vs. Imipramine alone Day 4 (p<0.05). No statistical difference by Day 14.
| | | | Frequency: | 1 Per Day For 8 Weeks
| DSM 3 or 4: | Yes | 2 | SAMe | | n Entered: | 20
| | | | Dose: | 200 mg | n Analyzed: | 20
| | | | Route of Admin: | Intramuscular
| | | | Frequency: | 1 Per Day For 2 Weeks
| | | | Imipramine
| | | | Dose: | 150 mg
| | | | Route of Admin: | Oral
| | | | Frequency: | 1 Per Day For 8 Weeks
Calandra 1979 | Study Design: | CCT | 1 | Chlorimipramine | | n Entered: | 12 | Type of Outcome: Hamilton Depression
| Crossover Study: | No | | Dose: | 50 mg | n Analyzed: | 12
| Jadad Score: | 0 | | Route of Admin: | Intravenous | | | Follow-ups (In Days): 15
| | | | Frequency: | 2 Per Day For 15 Days
| % Female: | N/A | 2 | SAMe | | n Entered: | 12 | Depression: Hamilton Rating Scale for Depression at 15 days
| % Under 18: | 0 | | Dose: | 75 mg | n Analyzed: | 12
| % Over 65: | N/A | | Route of Admin: | Intravenous | | | Arm 1 = 30.00 (3.74)
| | | | Frequency: | 2 Per Day For 15 Days | | | 12 pts 25% improvement
| DSM 3 or 4: | No | | | | | | 1 pt 50% improvement
| | | | | | | | Arm 2 = 38.25 (7.75)
| | | | | | | | 12 pts 25% improvement
| | | | | | | | 1 pt 50% improvement
Carney 1986 | Study Design: | RCT | 1 | Placebo | | n Entered: | 17 | Type of Outcome: Hamilton Depression, Beck, Newcastle
| Crossover Study: | No | | Dose: | N/A | n Analyzed: | 16
| Jadad Score: | 2 | | Route of Admin: | Intravenous
| | | | Frequency: | 1 Per Day For 14 Days | | | Follow-ups (In Days): 7, 14
| % Female: | 65 | 2 | SAMe | | n Entered: | 15
| % Under 18: | 0 | | Dose: | 200 mg | n Analyzed: | 12 | Depression: Hamilton Rating Scale for Depression at 14 days
| % Over 65: | N/A | | Route of Admin: | Intravenous
| | | | Frequency: | 1 Per Day For 14 Days | | | Arm 1 = 22.50 (6.10)
| DSM 3 or 4: | No | | | | | | Arm 2 = 20.10 (11.90)
| | | | | | | | Beck Depression Scale: Comparison pre/post scores for Placebo (p<0.01) and for SAMe (p<0.02) at Day 14.
Carrieri 1990 | Study Design: | RCT | 1 | Placebo | | n Entered: | 21 | Type of Outcome: Hamilton Depression, Beck
| Crossover Study: | Yes | | Dose: | N/A | n Analyzed: | 19
| Jadad Score: | 2 | | Route of Admin: | Oral or Intravenous | | | Follow-ups (In Days): 30
| | | | Frequency: | 1 or 2 Per Day For 30 Days
| % Female: | N/A | 2 | SAMe | | n Entered: | 21 | Depression: Hamilton Rating Scale for Depression at 30 days
| % Under 18: | N/A | | Dose: | 1000 mg | n Analyzed: | 19
| % Over 65: | N/A | | Route of Admin: | Oral or Intravenous | | | Arm 1 = 22.00 (5.29)
| | | | Frequency: | 1 Per 2 For 30 Days | | | Arm 2 = 14.00 (6.32)
| DSM 3 or 4: | No
| | | | | | | | Parkinson's disease patients. Parkinson's disease symptoms unchanged by treatment. Beck's Depression Scale: Comparison pre/post scores at first crossover for Placebo (p<0.01) and for SAMe (p<0.05) at Day 30.
Caruso 1987 | Study Design: | RCT | 1 | Placebo | | n Entered: | 30 | Type of Outcome: Hamilton Depression
| Crossover Study: | No | | Dose: | N/A | n Analyzed: | 29
| Jadad Score: | 3 | | Route of Admin: | Intramuscular | | | Follow-ups (In Days): 21
| | | | Frequency: | 1 Per Day For 21 Days
| % Female: | 86 | 2 | SAMe | | n Entered: | 30 | Depression: Hamilton Rating Scale for Depression at 21 days
| % Under 18: | 0 | | Dose: | 200 mg | n Analyzed: | 30
| % Over 65: | N/A | | Route of Admin: | Intramuscular | | | Arm 1 = 39.70 (5.80)
| | | | Frequency: | 1 Per Day For 21 Days | | | Arm 2 = 33.10 (7.20)
| DSM 3 or 4: | Yes
| | | | | | | | Rheumatoid Arthritis patients. Rheumatoid arthritis outcomes (Ritchie Index, stiffness, pain) unchanged by treatment.
Cerutti 1989 | Study Design: | RCT | 1 | Minaprine | | n Entered: | 10 | Type of Outcome: Hamilton Depression, Zung PGA, PGA-Overall
| Crossover Study: | Yes | | Dose: | 200 mg | n Analyzed: | 10
| Jadad Score: | 2 | | Route of Admin: | Oral
| | | | Frequency: | 1 Per Day For 21 Days | | | Follow-ups (In Days): 21, 42
| % Female: | 55 | 2 | SAMe | | n Entered: | 10
| % Under 18: | 0 | | Dose: | 800 mg | n Analyzed: | 10 | Depression: Hamilton Rating Scale for Depression at 21 days
| % Over 65: | 0 | | Route of Admin: | Oral
| | | | Frequency: | 1 Per Day For 21 Days | | | Arm 1 = 14.30 (3.74)
| DSM 3 or 4: | Yes | | | | | | Arm 2 = 14.50 (3.44)
| | | | | | | | Zung Rating Scale for Depression: Comparison pre/post scores in full crossover study SAMe vs. Imipramine (NS).
Cerutti 1993 | Study Design: | RCT | 1 | Placebo | | n Entered: | 30 | Type of Outcome: Kellners
| Crossover Study: | No | | Dose: | N/A | n Analyzed: | N/A
| Jadad Score: | 2 | | Route of Admin: | Oral | | | Follow-ups (In Days): 10, 30
| | | | Frequency: | 2 Per Day For 30 Days
| % Female: | 100 | 2 | SAMe | | n Entered: | 30 | Exclude from meta-analysis as not relevant outcome.
| % Under 18: | N/A | | Dose: | 800 mg | n Analyzed: | N/A
| % Over 65: | 0 | | Route of Admin: | Oral | | | Post-Partum patients. Kellner's Symptom Questionnaire (Italian version): Improvement SAMe vs. placebo (p<0.001) at Day 10. Comparison pre/post scores at Day 30, improvement Placebo and SAMe (p<0.01) with lower total scores for SAMe patients.
| | | | Frequency: | 2 Per Day For 30 Days
| DSM 3 or 4: | No
Chinchilla 1996 | Study Design: | CCT | 1 | Fluoxetine | | n Entered: | 30 | Type of Outcome: Hamilton Depression, Patient Assessment Scale-NOS, CGI
| Crossover Study: | N/A | | Dose: | 20 mg | n Analyzed: | 30
| Jadad Score: | 0 | | Route of Admin: | Intramuscular
| | | | Frequency: | 1 Per Day For 2 Weeks | | | Follow-ups (In Days): 14, 28
| % Female: | 83 | | SAMe
| % Under 18: | 0 | | Dose: | 100 mg | | | Exclude from meta-analysis as latency study.
| % Over 65: | N/A | | Route of Admin: | Intramuscular
| | | | Frequency: | 1 Per Day For 2 Weeks | | | Hamilton Rating Scale for Depression: Comparison of improvement in scores for Imipramine vs. Imiparamine + SAMe; At Baseline: Combination group had higher scores (p<0.05); At Day 14: Combination group had lower scores (p<0.01); At Day 28: Groups were equivalent (NS).
| DSM 3 or 4: | No | 2 | Fluoxetine | | n Entered: | 30
| | | | Dose: | 20 mg | n Analyzed: | 30
| | | | Route of Admin: | Intramuscular
| | | | Frequency: | 1 Per Day For 2 Weeks
| | | | | | | | Clinical Impression Scale (Patient & Practitioner): At Day 14: Combination group had lower scores (p<0.01); At Day 28: Groups were equivalent (NS).
De Leo 1987 | Study Design: | CCT | 1 | Placebo | | n Entered: | 20 | Type of Outcome: CGI, Zung
| Crossover Study: | No | | Dose: | N/A | n Analyzed: | 17
| Jadad Score: | 2 | | Route of Admin: | Intramuscular | | | Follow-ups (In Days): 15, 30
| | | | Frequency: | 1 Per Day For 30 Days
| % Female: | N/A | 2 | SAMe | | n Entered: | 20 | Depression: Zung at 15 days
| % Under 18: | N/A | | Dose: | 200 mg | n Analyzed: | 19 | Arm 1 = 54.53 (7.71)
| % Over 65: | N/A | | Route of Admin: | Intramuscular | | | Arm 2 = 47.79 (8.39)
| | | | Frequency: | 1 Per Day For 30 Days
| DSM 3 or 4: | Yes | | | | | | CGIS scale: Comparison SAMe vs. Placebo at 15 days (p<0.05) and 30 days (p<0.01).
De Vanna 1992 | Study Design: | RCT | 1 | Imipramine | | n Entered: | 15 | Type of Outcome: Hamilton Depression, Montgomery-Asberg, Hamilton Anxiety, Zung
| Crossover Study: | No | | Dose: | 35 mg | n Analyzed: | 11
| Jadad Score: | 3 | | Route of Admin: | Oral
| | | | Frequency: | 1 Per Day For 6 Weeks | | | Follow-ups (In Days): 10, 20, 42
| % Female: | 70 | 2 | SAMe | | n Entered: | 15
| % Under 18: | 0 | | Dose: | 400 mg | n Analyzed: | 12 | Depression: Hamilton Rating Scale for Depression at 20 days
| % Over 65: | N/A | | Route of Admin: | Oral
| | | | Frequency: | 1 Per Day For 6 Weeks | | | Arm 1 = 20.50 (6.63)
| DSM 3 or 4: | Yes | | | | | | Arm 2 = 22.00 (6.93)
| | | | | | | | Montgomery-Asberg Scale: Comparison pre/post rating scale for SAMe (p<0.001) at Day 10.
| | | | | | | | Hamilton Rating Scale for Anxiety: Comparison pre/post rating scale for SAMe (p<0.05) at Day 10.
| | | | | | | | Zung Self-rating Scale for Depression: No significant change.
Del Vecchio 1978 | Study Design: | RCT | 1 | Tricyclics (ns) | | n Entered: | 14 | Type of Outcome: Hamilton Depression
| Crossover Study: | No | | Dose: | 50 mg | n Analyzed: | 14
| Jadad Score: | 1 | | Route of Admin: | Intravenous | | | Follow-ups (In Days): 7, 21
| | | | Frequency: | 2 Per Day For 3 Weeks
| % Female: | N/A | 2 | SAMe | | n Entered: | 14 | Depression: Hamilton Rating Scale for Depression at 21 days
| % Under 18: | 0 | | Dose: | 75 mg | n Analyzed: | 14
| % Over 65: | N/A | | Route of Admin: | Intravenous | | | Arm 1 = 26.64 (2.71)
| | | | Frequency: | 2 Per Day For 3 Weeks | | | 5 pts 25% improvement
| DSM 3 or 4: | No | | | | | | 0 pts 50% improvement
| | | | | | | | Arm 2 = 30.07 (6.94)
| | | | | | | | 4 pts 25% improvement
| | | | | | | | 0 pts 50% improvement
Delle Chiaie 1997 | Study 1 of 2 | | 1 | Placebo | | n Entered: | N/A | Type of Outcome: Hamilton Depression
| Study Design: | RCT | | Dose: | N/A | n Analyzed: | 35
| Crossover Study: | No | | Route of Admin: | Intravenous | | | Follow-ups (In Days): 21
| Jadad Score: | 2 | | Frequency: | 1 Per Day For 3 Weeks
| | | 2 | SAMe | | n Entered: | N/A | Depression: Hamilton Rating Scale for Depression at 21 Days
| % Female: | N/A | | Dose: | 800 mg | n Analyzed: | 40
| % under 18: | N/A | | Route of Admin: | Intravenous | | | Arm 1 = 21.70 (9.70)
| % Over 65: | N/A | | Frequency: | 1 Per Day For 3 Weeks | | | Arm 2 = 17.70 (8.60)
| DSM 3 or 4: | No | | | | | | Montgomery-Asberg Depression Rating Scale after 4 weeks of treatment: SAMe vs Imipramine post treatment value (NS).
Delle Chiaie 1997 | Study 2 of 2 | | 1 | Chlorimipramine | | n Entered: | N/A | Type of Outcome: Hamilton Depression
| Study Design: | RCT | | Dose: | 100 mg | n Analyzed: | 65
| Crossover Study: | No | | Route of Admin: | Oral | | | Follow-ups (In Days): 21
| Jadad Score: | 2 | | Frequency: | 1 Per Day For 3 Weeks
| | | 2 | SAMe | | n Entered: | N/A | Depression: Hamilton Rating Scale for Depression at 21 Days
| % Female: | N/A | | Dose: | 800 mg | n Analyzed: | 57
| % under 18: | N/A | | Route of Admin: | Oral | | | Arm 1 = 15.00 (6.80)
| % Over 65: | N/A | | Frequency: | 1 Per Day For 3 Weeks | | | Arm 2 = 18.80 (8.20)
| DSM 3 or 4: | No | | | | | | Drug related adverse events and drop outs due to adverse events after 3 weeks of treatment: lower SAMe vs. Chloripramine (p<0.05)
Delle Chiaie 2000a | Study Design: | RCT | 1 | Imipramine | | n Entered: | 138 | Type of Outcome: Hamilton Depression, CGI, Montgomery-Asberg
| Crossover Study: | No | | Dose: | 150 mg | n Analyzed: | 138
| Jadad Score: | 2 | | Route of Admin: | Oral
| | | | Frequency: | 1 Per Day For 6 Weeks | | | Follow-ups (In Days): 42
| % Female: | 70 | 2 | SAMe | | n Entered: | 143
| % Under 18: | N/A | | Dose: | 1600 mg | n Analyzed: | 143 | Insufficient statistics for meta-analysis.
| % Over 65: | N/A | | Route of Admin: | Oral
| | | | Frequency: | 1 Per Day For 6 Weeks | | | Montgomery-Ashberg Depression Rating Scale, Clinical Global Impression Scale, Hamilton Depression Rating Scale after 6 weeks of treatment: SAMe vs Imipramine post treatment value (NS).
| DSM 3 or 4: | No
Delle Chiaie 2000b | Study Design: | RCT | 1 | Imipramine | | n Entered: | 148 | Type of Outcome: Hamilton Depression, Montgomery-Asberg
| Crossover Study: | No | | Dose: | 150 mg | n Analyzed: | N/A
| Jadad Score: | 2 | | Route of Admin: | Oral
| | | | Frequency: | 1 Per Day For 4 Weeks | | | Follow-ups (In Days): 28
| % Female: | 63 | | Placebo
| % Under 18: | N/A | | Dose: | N/A | | | Insufficient statistics for meta-analysis.
| % Over 65: | N/A | | Route of Admin: | Intramuscular
| | | | Frequency: | 1 Per Day For 4 Weeks | | | Montgomery-Asberg Depression Rating Scale. Clinical Global Impression Scale, Hamilton Depression Rating Scale after 4 weeks of treatment: SAMe vs Imipramine post treatment value (NS).
| DSM 3 or 4: | No | 2 | SAMe | | n Entered: | 147
| | | | Dose: | 400 mg | n Analyzed: | N/A
| | | | Route of Admin: | Intramuscular
| | | | Frequency: | 1 Per Day For 4 Weeks
| | | | Placebo
| | | | Dose: | N/A
| | | | Route of Admin: | Oral
| | | | Frequency: | 1 Per Day For 4 Weeks
Di Padova 2000 | Study 1 of 2 | | 1 | Imipramine | | n Entered: | N/A | Type of Outcome: Hamilton Depression, Montgomery-Asberg, CGI
| Study Design: | RCT | | Dose: | 150 mg | n Analyzed: | 148
| Crossover Study: | No | | Route of Admin: | Oral
| Jadad Score: | 2 | | Frequency: | 1 Per Day For 6 Weeks | | | Follow-ups (In Days): 14, 28, 42
| | | 2 | SAMe | | n Entered: | N/A
| % Female: | N/A | | Dose: | 1600 mg | n Analyzed: | 147 | Depression: Hamilton Rating Scale for Depression at 14 days
| % under 18: | N/A | | Route of Admin: | Oral
| % Over 65: | N/A | | Frequency: | 1 Per Day For 6 Weeks | | | Arm 1 = 19.90 (7.10*)
| | | | | | | | Arm 2 = 20.80 (7.10*)
| DSM 3 or 4 | No | | | | | | Montgomery-Asberg Depression Rating Scale after 4 weeks of treatment: SAMe vs Imipramine post treatment value (NS).
Di Padova 2000 | Study 2 of 2 | | 1 | Imipramine | | n Entered: | N/A | Type of Outcome: Hamilton Depression, Montgomery-Asberg, CGI
| Study Design: | RCT | | Dose: | 150 mg | n Analyzed: | 138
| Crossover Study: | No | | Route of Admin: | Oral
| Jadad Score: | 2 | | Frequency: | 1 Per Day For 4 Weeks | | | Follow-ups (In Days): 14, 28, 42
| | | 2 | SAMe | | n Entered: | N/A
| % Female: | N/A | | Dose: | 400 mg | n Analyzed: | 143 | Depression: Hamilton Rating Scale for Depression at 14 days
| % under 18: | N/A | | Route of Admin: | Intramuscular
| % Over 65: | N/A | | Frequency: | 1 Per Day For 4 Weeks | | | Arm 1 = 17.60 (7.10*)
| | | | | | | | Arm 2 = 18.60 (7.10*)
| DSM 3 or 4: | No | | | | | | Montgomery-Asberg Depression Rating Scale after 4 weeks of treatment: SAMe vs Imipramine post treatment value (NS).
Fava 1992 | Study Design: | CCT | 1 | Placebo | | n Entered: | 22 | Type of Outcome: Hamilton Depression, Laboratory values, CGI
| Crossover Study: | No | | Dose: | N/A | n Analyzed: | 21
| Jadad Score: | 2 | | Route of Admin: | Oral
| | | | Frequency: | 1 Per Day For 6 Weeks | | | Follow-ups (In Days): 42
| % Female: | 72 | 2 | SAMe | | n Entered: | 17
| % Under 18: | 0 | | Dose: | 1600 mg | n Analyzed: | 11 | Depression: Hamilton Rating Scale for Depression at 42 days
| % Over 65: | 0 | | Route of Admin: | Oral
| | | | Frequency: | 1 Per Day For 6 Weeks | | | Arm 1 = 15.20 (10.30)
| DSM 3 or 4: | Yes | | | | | | Arm 2 = 16.00 (11.40)
| | | | | | | | Patients with abnormal TSH response to TRH challenge had greater response to treatment after 6 weeks (p<0.02).
Fazio 1973 | Study Design: | CCT | 1 | Placebo | | n Entered: | 5 | Type of Outcome: Hamilton Depression
| Crossover Study: | No | | Dose: | N/A | n Analyzed: | 5
| Jadad Score: | 1 | | Route of Admin: | Oral | | | Follow-ups (In Days): Until symptoms resolve
| | | | Frequency: | 1 Per Day For Variable Days
| % Female: | 100 | 2 | SAMe | | n Entered: | 9 | Insufficient statistics for meta-analysis.
| % Under 18: | N/A | | Dose: | 45 mg | n Analyzed: | 9
| % Over 65: | N/A | | Route of Admin: | Oral | | | Hamilton Rating Scale for Depression (individual items): Comparison improvement in score Placebo vs. SAMe 7 items on Hamilton scale were not statistically significant, 7 items were significant (p<0.01 to 0.001), and 2 items were significantly improved in both groups.
| | | | Frequency: | 1 Per Day For Variable Days
| DSM 3 or 4: | No
Janicak 1988 | Study Design: | RCT | 1 | Placebo | | n Entered: | 5 | Type of Outcome: Hamilton Depression
| Crossover Study: | No | | Dose: | N/A | n Analyzed: | 3
| Jadad Score: | 3 | | Route of Admin: | Oral or Intravenous | | | Follow-ups (In Days): 15
| | | | Frequency: | 1 Per Day For 2 Weeks
| % Female: | 50 | 2 | Imipramine | | n Entered: | 3 | Depression: Hamilton Rating Scale for Depression at 15 days
| % Under 18: | 0 | | Dose: | 150 mg | n Analyzed: | 3
| % Over 65: | N/A | | Route of Admin: | Oral | | | Arm 1:
| | | | Frequency: | 1 Per Day For 2 Weeks | | | 0 pts 25% improvement
| DSM 3 or 4: | Yes | 3 | SAMe | | n Entered: | 12 | 0 pts 50% improvement
| | | | Dose: | 400 mg | n Analyzed: | 7
| | | | Route of Admin: | Intravenous | | | Arm 2:
| | | | Frequency: | 1 Per Day For 2 Weeks | | | 2 pts 25% improvement
| | | | | | | | 1 pt 50% improvement
| | | | | | | | Arm 3:
| | | | | | | | 5 pts 25% improvement
| | | | | | | | 1 pt 50% improvement
Kagan 1990a | Study Design: | RCT | 1 | Placebo | | n Entered: | 8 | Type of Outcome: Hamilton Depression, Caroll
| Crossover Study: | No | | Dose: | N/A | n Analyzed: | 6
| Jadad Score: | 5 | | Route of Admin: | Oral | | | Follow-ups (In Days): 3, 7, 14, 21
| | | | Frequency: | 2 Per Day For 21 Days
| % Female: | 0 | 2 | SAMe | | n Entered: | 10 | Depression: Hamilton Rating Scale for Depression at 21 days
| % Under 18: | 0 | | Dose: | 800 mg | n Analyzed: | 9
| % Over 65: | 0 | | Route of Admin: | Oral | | | Arm 1 = 23.70 (14.30)
| | | | Frequency: | 2 Per Day For 21 Days | | | 2 pts 25% improvement
| DSM 3 or 4: | No | | | | | | 1 pt 50% improvement
| | | | | | | | Arm 2 = 10.40 (6.90)
| | | | | | | | 7 pts 25% improvement
| | | | | | | | 6 pts 50% improvement
| | | | | | | | Carroll scale: Comparison improvement in score for SAMe vs. Placebo at 21 days (p<0.05).
Kufferle 1982 | Study Design: | RCT | 1 | Tricyclics (nos) | | n Entered: | 10 | Type of Outcome: Hamilton Depression, Zung, AMDP
| Crossover Study: | No | | Dose: | 50 mg | n Analyzed: | 9
| Jadad Score: | 3 | | Route of Admin: | Intravenous
| | | | Frequency: | 1 Per Day For 18 Days | | | Follow-ups (In Days): 6, 12, 18
| % Female: | 11 | 2 | SAMe | | n Entered: | 10
| % Under 18: | 0 | | Dose: | 150 mg | n Analyzed: | 9 | Depression: Hamilton Rating Scale for Depression at 18 days
| % Over 65: | 0 | | Route of Admin: | Intravenous
| | | | Frequency: | 1 Per Day For 18 Days | | | Arm 1 = 12.50 (10.50)
| DSM 3 or 4: | Yes | | | | | | Arm 2 = 13.5 (10.50)
| | | | | | | | Zung scale: Comparison pre/post scores improved for both Tricyclyic (p<0.01) and SAMe (p<0.01) at Day 6, 12, and 18. No significant difference between treatment groups noted on any scale.
Lo Russo 1994 | Study Design: | CCT | 1 | SAMe | | n Entered: | N/A | Type of Outcome: Pain scale: VAS/NOS, Zung, Hamilton Depression, Hamilton Anxiety, Fatigue, Pain, Sleep
| Crossover Study: | No | | Dose: | 400 mg | n Analyzed: | 14
| Jadad Score: | 1 | | Route of Admin: | Intravenous
| | | | Frequency: | 1 Per Day For 6 Days
| % Female: | 20 | | SAMe | | | | Follow-ups (In Days): 14, 28
| % Under 18: | 0 | | Dose: | 1000 mg
| % Over 65: | 0 | | Route of Admin: | Oral | | | Exclude from meta-analysis as latency study.
| | | | Frequency: | 1 Per Day For 1 Hour
| DSM 3 or 4: | Yes | | SAMe | | | | Opiate-dependent outpatients during detoxification with major depression. Hamilton Rating Scale for Depression, Hamilton Rating Scale for Anxiety, and Zung Depression Scale: Comparison pre/post improvement in all scores for Group 1 (SAMe concurrent w/detox) (p<0.01; p<0.01; p<0.01 respectively) at Day 14 and 28 and Group 2 (SAMe subsequent to detox) (p<0.01; p<0.01; p<0.01 respectively) at Day 14 and 28.
| | | | Dose: | 200 mg
| | | | Route of Admin: | Intramuscular
| | | | Frequency: | 2 Per Day For 6 Days
| | | | SAMe
| | | | Dose: | 400 mg
| | | | Route of Admin: | Oral
| | | | Frequency: | 3 Per Day For 1 Day
| | | 2 | SAMe | | n Entered: | N/A
| | | | Dose: | 400 mg | n Analyzed: | 11
| | | | Route of Admin: | Intravenous
| | | | Frequency: | 1 Per Day For 6 Day
| | | | SAMe
| | | | Dose: | 1000 mg
| | | | Route of Admin: | Oral
| | | | Frequency: | 1 Per Day For 1 Hour
| | | | SAMe
| | | | Dose: | 200 mg
| | | | Route of Admin: | Intramuscular
| | | | Frequency: | 2 Per Day For 6 Day
| | | | SAMe
Mantero 1975 | Study Design: | RCT | 1 | Imipramine | | n Entered: | 15 | Type of Outcome: Hamilton Depression,
| Crossover Study: | No | | Dose: | 25 mg | n Analyzed: | 14
| Jadad Score: | 2 | | Route of Admin: | Intramuscular | | | Follow-ups (In Days): 21
| | | | Frequency: | 3 Per Day For 3 Weeks
| % Female: | 65 | 2 | SAMe | | n Entered: | 16 | Depression: Hamilton Rating Scale for Depression at 21 days
| % Under 18: | 0 | | Dose: | 25 mg | n Analyzed: | 16
| % Over 65: | N/A | | Route of Admin: | Intramuscular | | | Arm 1:
| | | | Frequency: | 3 Per Day For 3 Weeks | | | 11 pts 25% improvement
| DSM 3 or 4: | No | | | | | | 9 pts 50% improvement
| | | | | | | | Arm 2:
| | | | | | | | 13 pts 25% improvement
| | | | | | | | 11 pts 50% improvement
Miccoli 1978 | Study Design: | CCT | 1 | Tricyclics (nos) | | n Entered: | 46 | Type of Outcome: Hamilton Depression
| Crossover Study: | No | | Dose: | 50 mg | n Analyzed: | 41
| Jadad Score: | 2 | | Route of Admin: | Intravenous | | | Follow-ups (In Days): 7, 21
| | | | Frequency: | 2 Per Day For 21 Days
| % Female: | 50 | 2 | SAMe | | n Entered: | 46 | Depression: Hamilton Rating Scale for Depression at 21 days
| % Under 18: | 0 | | Dose: | 100 mg | n Analyzed: | 45
| % Over 65: | N/A | | Route of Admin: | Intravenous | | | Arm 1 = 18.37 (4.69)
| | | | Frequency: | 2 Per Day For 21 Days | | | 41 pts 25% improvement
| DSM 3 or 4: | No | | | | | | 28 pts 50% improvement
| | | | | | | | Arm 2 = 18.29 (3.94)
| | | | | | | | 45 pts 25% improvement
| | | | | | | | 32 pts 50% improvement
| | | | | | | | Hamilton Rating Scale for Depression: Comparison between SAMe vs TCA (p<0.001) at Day 7.
Monaco 1979 | Study Design: | RCT | 1 | Amitriptyline | | n Entered: | 9 | Type of Outcome: Hamilton Depression
| Crossover Study: | No | | Dose: | 50 mg | n Analyzed: | 9
| Jadad Score: | 2 | | Route of Admin: | Intravenous | | | Follow-ups (In Days): 10, 15
| | | | Frequency: | 2 Per Day For 15 Days
| % Female: | 65 | 2 | SAMe | | n Entered: | 11 | Depression: Hamilton Rating Scale for Depression at 15 days
| % Under 18: | 0 | | Dose: | 1.5 mg/kg | n Analyzed: | 11
| % Over 65: | 5 | | Route of Admin: | Intravenous | | | Arm 1 = 17.20 (11.49)
| | | | Frequency: | 2 Per Day For 15 Days | | | 7 pts 25% improvement
| DSM 3 or 4: | No | | | | | | 3 pts 50% improvement
| | | | | | | | Arm 2 = 15.45 (5.70)
| | | | | | | | 11 pts 25% improvement
| | | | | | | | 5 pts 50% improvement
| | | | | | | | Hamilton Depression Rating Scale: Comparison pre/post improve in scores SAMe (p<0.001) and amitriptyline (p<0.1).
Muscettola 1982 | Study Design: | RCT | 1 | Placebo | | n Entered: | 10 | Type of Outcome: Hamilton Depression, CGI, BPRS
| Crossover Study: | No | | Dose: | N/A | n Analyzed: | 9
| Jadad Score: | 2 | | Route of Admin: | Intramuscular | | | Follow-ups (In Days): 5, 10, 15
| | | | Frequency: | 1 Per Day For 15 Days
| % Female: | 40 | 2 | SAMe | | n Entered: | 10 | Depression: Hamilton Rating Scale for Depression at 15 days
| % Under 18: | 0 | | Dose: | 150 mg | n Analyzed: | 9
| % Over 65: | N/A | | Route of Admin: | Intramuscular | | | Arm 1 = 23.00 (2.00)
| | | | Frequency: | 1 Per Day For 15 Days | | | 2 pts 25% improvement
| DSM 3 or 4 | No
| | | | | | | | Arm 2 = 14.00 (2.00)
| | | | | | | | 5 pts 25% improvement
| | | | | | | | Brief Psychiatric Rating Scale: Comparison pre/post percent change SAMe vs Placebo (p<0.02) for depressed mood after 15 days.
Pons Villegas 1983 | Condition: | Depression | 1 | No treatment | | n Entered: | 15 | Type of Outcome: Scale NOS, Transaminases
| Study Design: | CCT | | | | n Analyzed: | 15
| Crossover Study: | No | 2 | SAMe | | n Entered: | 15 | Follow-ups (In Days): 30
| Jadad Score: | 0 | | Dose: | 150 mg | n Analyzed: | 15
| | | | Route of Admin: | N/A | | | Exclude from meta-analysis as not relevant outcome.
| % Female: | N/A | | Frequency: | 1 Per Day For 10 Days
| % Under 18: | N/A | | SAMe | | | | Alcoholic patients with depression. Comparison SAMe vs. Placebo post treatment values after 15 days: Psychosomatic and Estado Timopatico scales (p<0.001). Percent of patients with normal GGT levels after 15 days: SAMe (53%) and Placebo (28%).
| % Over 65: | N/A | | Dose: | 100 mg
| | | | Route of Admin: | N/A
| DSM 3 or 4: | No | | Frequency: | 1 Per Day For 20 Days
Salmaggi 1993 | Study Design: | RCT | 1 | Placebo | | n Entered: | 40 | Type of Outcome: Hamilton Depression, CGI, RDI
| Crossover Study: | Yes | | Dose: | N/A | n Analyzed: | 30
| Jadad Score: | 3 | | Route of Admin: | Oral | | | Follow-ups (In Days): 10, 30
| | | | Frequency: | 1 Per Day For 30 Days
| % Female: | 100 | 2 | SAMe | | n Entered: | 40 | Depression: Hamilton Rating Scale for Depression at 30 days
| % Under 18: | 0 | | Dose: | 1600 mg | n Analyzed: | 30
| % Over 65: | 0 | | Route of Admin: | Oral | | | Arm 1 = 22.50 (16.43)
| | | | Frequency: | 1 Per Day For 30 Days | | | 20 pts 25% improvement
| DSM 3 or 4: | Yes | | | | | | 11 pts 50% improvement
| | | | | | | | Arm 2 = 16.60 (16.43)
| | | | | | | | 2 pts 25% improvement
| | | | | | | | 0 pt 50% improvement
| | | | | | | | Post-menopausal patients. Rome Depression Inventory: Comparison improvement in scores SAMe vs. Placebo (p<0.01) at 30 days. CGI Scale: Comparison improvement in scores SAMe vs. Placebo (p<0.01) at 30 days. MMPI scale: Comparison of improvement in depression and psychoasthenia scales SAMe vs. placebo (p<0.01 and p<0.05 respectively) at 30 days.
Scaggion 1982 | Study Design: | RCT | 1 | Nomifensine maleato | | n Entered: | 18 | Type of Outcome: Hamilton Depression, Labs-Bilirubin, Transaminases, Laboratory values
| Crossover Study: | No | | Dose: | 100 mg | n Analyzed: | 18
| Jadad Score: | 2 | | Route of Admin: | Oral
| | | | Frequency: | 2 Per Day For 14 Days | | | Follow-ups (In Days): 7, 14
| % Female: | 75 | 2 | SAMe | | n Entered: | 22
| % Under 18: | N/A | | Dose: | 150 mg | n Analyzed: | 22 | Depression: Hamilton Rating Scale for Depression at 14 days
| % Over 65: | N/A | | Route of Admin: | Intravenous
| | | | Frequency: | 2 Per Day For 14 Days | | | Arm 1 = 12.61 (3.63)
| DSM 3 or 4: | No | | | | | | 15 pts 25% improvement
| | | | | | | | 1 pt 50% improvement
| | | | | | | | Arm 2 = 9.45 (3.07)
| | | | | | | | 21 pts 25% improvement
| | | | | | | | 7 pts 50% improvement
Scarzella 1978 | Study Design: | RTC | 1 | Chlorimipramine | | n Entered: | 10 | Type of Outcome: Hamilton Depression
| Crossover Study: | No | | Dose: | 50 mg | n Analyzed | 10
| Jadad Score: | 2 | | Route of Admin: | Intravenous | | | Follow-ups (In days): 7, 15
| | | | Frequency: | 2 Per Day For 15 Days
| % Female: | N/A | 2 | SAMe | | n Entered: | 10 | Depression: Hamilton Rating Scale for Depression at 15 days
| % Under 18: | N/A | | Dose: | 125 mg | n Analyzed: | 10
| % over 65: | N/A | | Route of Admin: | Intravenous | | | Arm 1 = 13.90 (2.90)
| | | | Frequency: | 2 Per Day for 15 Days | | | 9 pts 25% improvement
| DSM 2 or 4: | No | | | | | | 7 pts 50% improvement
| | | | | | | | Arm 2 = 12.70 (7.90)
| | | | | | | | 9 pts 25% improvement
| | | | | | | | 9 pts 50% improvement
| | | | | | | | Hamilton Rating Scale for Depression: Comparison of improvement in pre/post scores SAMe (p<0.001) and Chloripramine (p<0.05) at day 7.
Schifano 1993 | Study Design: | RTC | 1 | Dothiepin | | n Entered: | 25 | Type of Outcome: Hamilton Depression, CGI
| Crossover Study: | No | | Dose: | 75 mg | n Analyzed | 19
| Jadad Score: | 1 | | Route of Admin: | Oral | | | Follow-ups (In Days): 14, 28
| | | | Frequency: | 1 Per Day For 28 Days | | | Follow-ups (In Days): 28
| % Female: | N/A | 2 | SAMe | | n Entered: | 26 | Insufficient statistics for meta-analysis
| % Under 18: | N/A | | Dose: | 400 mg | n Analyzed: | 20
| % over 65: | N/A | | Route of Admin: | Oral | | | Abstinent alcoholics. Hamilton Rating Scale for Depression: Higher baseline scores in Dothiepam group (p=0.03). Decrease in pre/post scores for both Dothiepam (p=0.00001) and SAMe p=0.0002) at 28 days. Clinical Global Impression Scale: Higher baseline scores in Dothiepam group (p=0.04). Decrease in pre/post scores for both Dothiepam (p=0.00001) and SAMe (p=0.0024) at 28 days.
| | | | Frequency: | 2 Per Day For 28 Days
| DSM 3 or 4: | No
Thomas 1987 | Condition: | Depression | 1 | Placebo | | n Entered: | 11 | Type of Outcome: Hamilton Depression, Laboratory values
| Study Design: | RTC | | Dose: | N/A | n Analyzed: | 11
| Crossover Study: | No | | Route of Admin: | Intravenous
| Jadad Score: | 2 | | Frequency: | 1 Per Day For 14 Days | | | Follow-ups (In Days): 14
| | | 2 | SAMe | | n Entered: | 9
| % Female: | 75 | | Dose: | 200 mg | n Analyzed: | 9 | Depression: Hamilton Rating Scale for Depression at 14 days
| % Under 18: | 0 | | Route of Admin: | Intravenous
| % Over 65: | N/A | | Frequency: | 1 Per Day For 14 Days | | | Arm 1 = 18.90 (8.90)
| | | | | | | | Arm 2 = 19.30 (7.50)
| DSM 3 or 4: | No
| | | | | | | | Comparison of fall in serum prolactin levels after 14 days of treatment: SAMe pre/post (p<0.01) and post levels SAMe vs. Placebo (p<0.05).

N/A = Not available or Not Applicable.

NOS = Not otherwise specified.

* Imputed standard deviation.

** See Appendix H for abbreviations for Outcomes Measurements.

***Mean (Standard Deviation) reported.

Table II Evidence Table. SAMe for Treatment of Osteoarthritis

ID | 1^st^Author Year | Design Study Quality Population Diagnostic Criteria | | Arm # | Intervention Component Dose | | Sample Size | | Outcome Measurements** Meta-analysis Data***
10360 | Bradley 1994 | Study Design: | RCT | 1 | Placebo | | n Entered: | 40 | Type of Outcome: VAS-disease status, PGA-Activity, HAQ, Pain scale: VAS/NOS
| | Crossover Study: | No | | Dose: | N/A | n Analyzed | 40
| | Jadad Score: | 2 | | Route of Admin: | Intravenous
| | | | | Frequency: | 1 Every Other Day For 5 Days | | | Follow-ups (In Days): 28
| | % Female: | N/A
| | % Under 18: | 0 | | Placebo | | | | [underlined: Site A]
| | % over 65: | N/A | | Dose: | N/A | | | Pain: VAS combined resting and walking pain 0–3 scale
| | | | | Route of Admin: | Oral
| | X-Ray: | Yes | | Frequency: | 3 Per Day For 23 Days | | | Arm 1 = 5.00 (0.75*)
| | | | 2 | SAMe | | n Entered: | 41 | Arm 2 = 3.00 (0.75*)
| | | | | Dose: | 400 mg | n Analyzed: | 41
| | | | | Route of Admin: | Intravenous | | | [underlined: Site B]
| | | | | Frequency: | 1 Every Other Day For 5 Days | | | Pain: VAS combined resting and walking pain 0–3 scale
| | | | | SAMe | | | | Arm 1 = 3.51 (0.75*)
| | | | | Dose: | 600 mg | | | Arm 2 = 3.04 (0.75*)
| | | | | Route of Admin: | Oral
| | | | | Frequency: | 3 Per Day For 23 Days | | | Site A and B not equivalent at baseline. Results not significant for HAQ disability, walking distance, acetaminophen consumed/day, or Beck's Depression Inventory
10125 | Capretto 1985 | Study Design: | RCT | 1 | NSAIDS | | n Entered: | 58 | Type of Outcome: PGA-Overall, ARA, Pain
| | Crossover Study: | No | | Dose: | 400 mg | n Analyzed: | 10
| | Jadad Score: | 2 | | Route of Admin: | Oral | | | Follow-ups (In Days): 15, 30
| | | | | Frequency: | 3 Per Day For 30 Days
| | % Female: | 67 | 2 | SAMe | | n Entered: | 53 | Pain: Total pain score for knee only 0 – 20 scale at 30 days
| | % Under 18: | N/A | | Dose: | 200 mg | n Analyed: | 11
| | % Over 65: | N/A | | Route of Admin: | Oral | | | Arm 1 = 5 (4.00)
| | | | | Frequency: | 3 Per Day For 30 Days | | | Arm 2 = 3.00 (2.50)
| | X-Ray | Yes | | | | | | X-ray changes at baseline were greater in the SAMe (p<0.025). Comparison of difference in pre/post scores between SAMe and Ibuprofen (NS).
10092 | Caroli 1980 | Study Design: | RCT | 1 | Aspirin | | n Entered: | 30 | Type of Outcome: Pain scale: VAS/NOS, Range of Motion, PGA, PGA-Overall
| | Crossover Study: | No | | Dose: | 1000 mg | n Analyzed: | 25
| | Jadad Score: | 4 | | Route of Admin: | Oral
| | | | | Frequency: | 3 Per Day For 6 Weeks
| | % Female: | 60 | 2 | SAMe | | n Entered: | 30
| | % Under 18: | 0 | | Dose: | 400 mg | n Analyzed: | 29 | Pain: VAS 0 – 5 scale at 28 days
| | % Over 65: | N/A | | Route of Admin: | Oral | | | Arm 1 = 2.41 (0.29)
| | | | | Frequency: | 3 Per Day For 6 Weeks | | | Arm 2 = 1.92 (0.22)
| | X-Ray: | Yes
| | | | | | | | | Range of Motion (Flexion/extension; Abduction/adduction; Internal/external rotation): Comparison pre/post measurements improvement SAMe (p<0.001 all) and ASA (p<0.001; p<0.05; p<0.01 respectively) at Day 14.
10086 | Caruso 1987 | Study Design: | RCT | 1 | Placebo | | n Entered: | 241 | Type of Outcome: VAS-disease status, Pain scale: VAS/NOS, Range of Motion, Tolerability, Efficacy.
| | Crossover Study: | No | | Dose: | N/A | n Analyzed: | 220
| | Jadad Score: | 2 | | Route of Admin: | Oral
| | | | | Frequency: | 3 Per Day For 30 Days
| | % Female: | 74 | 2 | Naproxen | | n Entered: | 245 | Follow-ups (In Days): 15, 30
| | % Under 18: | 0 | | Dose: | 250 mg | n Analyzed: | 229
| | % Over 65: | N/A | | Route of Admin: | Oral | | | Pain: Combined night and day pain 0 – 4 scale at 30 days
| | | | | Frequency: | 3 Per Day For 30 Days
| | X-Ray: | Yes | 3 | SAMe | | n Entered: | 248 | Arm 1 = 1.17 (1.00*)
| | | | | Dose: | 400 mg | n Analyzed: | 236 | Arm 2 = 0.96 (1.00*)
| | | | | Route of Admin: | Oral | | | Arm 3 = 0.97 (1.00*)
| | | | | Frequency: | 3 Per Day For 30 Days | | | Tolerability: SAMe vs. naproxen better according to patient (p<0.01) and physician's rating (p<0.025)
10094 | Cucinotta 1980 | Study Design: | RCT | 1 | Ibuprofen | | n Entered: | 20 | Type of Outcome: PGA, PGA-Overall, Muscle spasm, Range of Motion, Pain scale: VAS/NOS
| | Crossover Study: | No | | Dose: | 400 mg | n Analyzed | 17
| | Jadad Score: | 3 | | Route of Admin: | Oral
| | | | | Frequency: | 3 Per Day For 30 Days | | | Follow-ups (In Days): 16, 31
| | % Female: | 85 | 2 | SAMe | | n Entered: | 20
| | % Under 18: | N/A | | Dose: | 200 mg | n Analyzed | 19 | Exclude from meta-analysis as not pain
| | % Over 65: | N/A | | Route of Admin: | Oral
| | | | | Frequency: | 3 Per Day For 30 days | | | Severity of symptoms (patient report):
| | X-Ray: | Yes | | | | | | Comparison SAMe vs. Ibuprofen at 30 days for the hip joint (p<0.001 and p<0.01), at the knee joint (p<0.001 and p< 0.01) and cervical spine (p<0.025 and p<0.02) respectively. Range of motion (MD evaluation): Comparison SAMe vs. Ibuprofen at 30 days for the hip joint (p<0.001 and p<0.005), at the knee joint (p<0.001 and p< 0.01) and cervical spine (p<0.005 and p<0.02) respectively.
10250 | Domljan 1989 | Study Design: | CCT | 1 | Naproxen | | n Entered: | 20 | Type of Outcome: Functional scale-NOS, Laboratory values, PGA-Overall, Range of Motion
| | Crossover Study: | No | | Dose: | 250 mg | n Analyzed | 19
| | Jadad Score: | 2 | | Route of Admin: | Oral
| | | | | Frequency: | 3 Per Day For 7 Days
| | % Female: | N/A | 2 | SAMe | | n Entered: | 20 | Follow-ups (In Days): 28, 42
| | % Under 18: | 0 | | Dose: | 400 mg | n Analyzed | 18
| | % over 65: | N/A | | Route of Admin: | Oral | | | Pain: Osteoarthritic pain score 0 – 18 scale at 28 days
| | | | | Frequency: | 3 Per Day For 7 Days
| | X-Ray: | Yes | | | | | | Arm 1 = 5.74 (3.14)
| | | | | | | | | Arm 2 = 5.28 (2.70)
| | | | | | | | | No statistically significant difference in range of motion, walking time or global clinical score between the Naproxen and SAMe groups.
10091 | Glorioso 1985 | Study Design: | RCT | 1 | Ibuprofen | | n Entered: | 75 | Type of Outcome: Pain scale: VAS/NOS, Range of Motion, Overall effect, Muscle spasm, PGA, PGA-Overall
| | Crossover Study: | No | | Dose: | 400 mg | n Analyzed | 75
| | Jadad Score: | 3 | | Route of Admin: | Oral
| | | | | Frequency: | 3 Per Day For 30 Days
| | % Female: | 60 | 2 | SAMe | | n Entered: | 75 | Follow-ups (In Days): 16, 31
| | % Under 18: | 0 | | Dose: | 400 mg | n Analyed: | 75
| | % Over 65: | N/A | | Route of Admin: | Oral | | | Insufficient statistics for meta-analysis.
| | | | | Frequency: | 3 Per Day For 30 Days
| | X-Ray | Yes | | | | | | Pooled results for Symptoms (patient assessment): Comparison pre/post scores SAMe and Ibuprofen (p<0.01); Comparison between SAMe and Ibuprofen (NS).
10085 | Maccagno 1987 | Study Design: | RCT | 1 | Piroxican | | n Entered: | 24 | Type of Outcome: Joint pain scale, Range of Motion, Pain scale: VAS/NOS
| | Crossover Study: | No | | Dose: | 20 mg | n Analyzed | 23
| | Jadad Score: | 2 | | Route of Admin: | Oral
| | | | | Frequency: | 1 Per Day For 84 Days | | | Follow-ups (In Days): 14, 28, 56, 84
| | % Female: | 67 | 2 | SAMe | | n Entered: | 24
| | % Under 18: | 0 | | Dose: | 400 mg | n Analyed: | 22 | Pain: Total score of knee osteoarthritis 0 – 23 scale at 28 days
| | % Over 65: | N/A | | Route of Admin: | Oral
| | | | | Frequency | 3 Per Day For 84 Days | | | Arm 1 = 7.00 (2.40)
| | X-Ray | Yes | | | | | | Arm 2 = 9.70 (2.58)
| | | | | | | | | Pain, Morning Stiffness, Walking Distance: Comparison pre/post treatment SAMe and Piroxican at 28 days (p<0.01); Following active treatment: Pain and Walking distance scores better in SAMe than Prioxicam group (p<0.01).
10376 | Marcolongo 1985 | Study Design: | RCT | 1 | Ibuprofen | | n Entered: | 75 | Type of Outcome: Pain scale: VAS/NOS, Efficacy, Tolerability
| | Crossover Study: | No | | Dose: | 400 mg | n Analyzed | 75
| | Jadad Score: | 4 | | Route of Admin: | Oral
| | | | | Frequency: | 3 Per Day For 30 Days | | | Follow-ups (In Days): 16, 31
| | % Female: | 60 | 2 | SAMe | | n Entered: | 75
| | % Under 18: | 0 | | Dose: | 400 mg | n Analyed: | 75 | Pain: Symptom Pool 0 – 20 scale at 31 days
| | % Over 65: | N/A | | Route of Admin: | Oral | | | Arm 1 = 6.10 (3.60)
| | | | | Frequency: | 3 Per Day For 30 Days | | | Arm 2 = 5.90 (3.90)
| | X-Ray | Yes
| | | | | | | | | Comparison pre/post levels after 31 days: Symptom pool and Rigidity: SAMe (p<0.01) and Ibuprofen (p<0.01); SAMe vs. Ibuprofen (NS).
10114 | Montrone 1985 | Study Design: | CCT | 1 | Placebo | | n Entered: | 37 | Type of Outcome: Pain, ARA, Range of Motion
| | Crossover Study: | No | | Dose: | N/A | n Analyzed | N/A
| | Jadad Score: | 1 | | Route of Admin: | Oral | | | Follow-ups (In Days): 21
| | | | | Frequency: | 3 Per Day For 21 Days
| | % Female: | N/A | 2 | SAMe | | n Entered: | 39 | Insufficient statistics for meta-analysis.
| | % Under 18: | 0 | | Dose: | 400 mg | n Analyed: | N/A
| | % Over 65: | N/A | | Route of Admin: | Oral | | | Final evaluation (patient and physician):
| | | | | Frequency: | 3 Per Day For 21 Days | | | Preference for SAMe (p<0.025 and p<0.05 respectively). Comparison SAMe vs. Placebo (Patient assessment): Loading pain (p<0.03); Night pain (NS); Pain pool (p<0.03); Stairs (NS); Standing up from chair (p<0.003); Getting out of bed (NS); Difficulty with specific activities (p<0.03).
10083 | Muller-Fassbender 1987 | Study Design: | RCT | 1 | Ibuprofen | | n Entered: | 18 | Type of Outcome: Symptoms, Range of Motion, Pain scale: VAS/NOS
| | Crossover Study: | No | | Dose: | 400 mg | n Analyzed | 18
| | Jadad Score: | 2 | | Route of Admin: | Oral
| | | | | Frequency: | 3 Per Day For 4 Weeks | | | Follow-ups (In Days): 28
| | % Female: | 17 | 2 | SAMe | | n Entered: | 18
| | % Under 18: | 0 | | Dose: | 400 mg | n Analyed: | 18 | Pain: Total score of knee osteoarthritis 0 – 21 scale at 28 days
| | % Over 65: | N/A | | Route of Admin: | Oral
| | | | | Frequency: | 3 Per Day For 4 Weeks | | | Arm 1 = 9.20 (5.25*)
| | X-Ray | Yes
| | | | | | | | | Global Clinical Score: Comparison pre/post score SAMe (p<0.0001) and ibuprofen (p<0.0001) at 28 days.
10096 | Polli 1975 | Study Design: | RCT | 1 | Indomethicin | | n Entered: | N/A | Type of Outcome: Range of Motion, Muscle spasm, Functional scale-NOS, Laboratory values, VAS-drug response, Pain scale.
| | Crossover Study: | Yes | | Dose: | 50 mg | n Analyzed | 15
| | Jadad Score: | 2 | | Route of Admin: | Intramuscular
| | | | | Frequency: | 2 Per Day For 7 Days
| | % Female: | 50 | 2 | SAMe | | n Entered: | N/A | Follow-ups (In Days): 7, 17
| | % Under 18: | 0 | | Dose: | 30 mg | n Analyed: | 15
| | % Over 65: | 27 | | Route of Admin: | Intramuscular | | | Pain: VAS 0 – 3 scale at 14 days
| | | | | Frequency: | 2 Per Day For 7 Days | | | Arm 1 = 1.20 (0.75*)
| | X-Ray | Yes | | | | | | Arm 2 = 0.73 (0.75*)
| | | | | | | | | Muscle spasm: Comparison SAMe vs. indomethacin (p<0.05) at 17 days. Rigidity, Limitation of movement; Limitation of activities: Comparison SAMe vs. indomethacin (NS) at 17 days
10084 | Vetter 1987 | Study Design: | RCT | 1 | Placebo | | n Entered: | 18 | Type of Outcome: Symptoms, Pain scale: VAS/NOS, Range of Motion
| | Crossover Study: | No | | Dose: | N/A | n Analyzed | 17
| | Jadad Score: | 3 | | Route of Admin: | Oral
| | | | | Frequency: | 1 Per Day For 4 Weeks | | | Follow-ups (In Days): 28
| | % Female: | 58 | 2 | SAMe | | n Entered: | 18
| | % Under 18: | 0 | | Dose: | 1200 mg | n Analyed: | 18 | Pain: Total score of knee osteoarthritis 0 – 15 scale at 28 days
| | % Over 65: | N/A | | Route of Admin: | Oral
| | | | | Frequency: | 1 Per Day For 4 Weeks | | | Arm 1 = 5.90 (3.75*)
| | X-Ray | Yes | | | | | | Arm 2 = 8.90 (3.75*)
| | | | | | | | | Global Clinical Score: Comparison pre/post treatment SAMe (p<0.0007) and Indomethacin (p<0.0007) at 28 days. Tolerability: Patients with no reported side effects SAMe (89%) vs indomethacin (61%) at 28 days.

N/A = Not available or Not Applicable.

NOS = Not otherwise specified.

* Imputed standard deviation.

** See Appendix H for abbreviations for Outcomes Measurements

*** Mean (Standard Deviation) reported.

Table III Evidence Table. SAMe for Treatment of Cholestasis of Pregnancy

ID | 1^st^Author Year | Design Study Quality Population Diagnostic Criteria | | Arm # | Intervention Component Dose | | Sample Size | | Outcome Measurements** Meta-Analysis Data***
10032 | Floreani 1996 | Study Design: | RCT | 1 | Ursodeoxycholic acid | | n Entered: | 10 | Type of Outcome: Labs-Bilirubin, Transaminases, Pruritus, Outcome of pregnancy
| | Crossover Study: | No | | Dose: | 450 mg | n Analyzed: | 10
| | Jadad Score: | 0 | | Route of Admin: | Oral
| | | | | Frequency: | 1 Per Day Until Delivery | | | Follow-ups (In Days): 3, 7, 15, and 5 days post-delivery
| | % Female: | 100 | 2 | SAMe | | n Entered: | 10
| | % Under 18: | 0 | | Dose: | 1000 mg | n Analyzed: | 10
| | % Over 65: | 0 | | Route of Admin: | Intramuscular | | | Bilirubin: Total bile salts μmol/l at 15 days
| | | | | Frequency: | 1 Per Day Until Delivery | | | Arm 1 = 3.90 (3.10)
| | Biopsy: | No | | | | | | Arm 2 = 11.00 (10.01*)
| | | | | | | | | Pruritus: UDCA 10 patients pruritus disappeared within 3 days vs. SAMe no regression of pruritus until after pregnancy.
10151 | Frezza 1984 | Study Design: | RCT | 1 | Placebo | | n Entered: | 6 | Type of Outcome: Transaminases, Labs-Bilirubin, Pruritus
| | Crossover Study: | No | | Dose: | N/A | n Analyzed: | 6
| | Jadad Score: | 2 | | Route of Admin: | Intravenous
| | | | | Frequency: | 1 Per Day For 20 Days | | | Follow-ups (In Days): 10,20
| | % Female: | 100 | 2 | SAMe | | n Entered: | 6
| | % Under 18: | 0 | | Dose: | 200 mg | n Analyzed: | 6 | Bilirubin: mg/dl at 20 days
| | % Over 65: | 0 | | Route of Admin: | Intravenous | | | Arm 1 = 2.40 (1.22)
| | | | | Frequency: | 1 Per Day For 20 Days | | | Arm 2 = 1.80 (0.98)
| | Biopsy: | No | 3 | SAMe | | n Entered: | 6 | Arm 3 = 0.80 (0.49)
| | | | | Dose: | 800 mg | n Analyzed: | 6
| | | | | Route of Admin: | Intravenous | | | Pruritus: 0–4 scale at 20 days
| | | | | Frequency: | 1 Per Day For 20 Days | | | Arm 1 - 3.00 (1.96)
| | | | | | | | | Arm 2 - 2.80 (1.71)
| | | | | | | | | Arm 3 - 1.00 (1.96)
| | | | | | | | | Clinical response only noted in high dose SAMe group. SAMe group had significantly elevated alkaline phosphatase (p<0.01) at 10 and 20 days compared to the other groups.
10201 | Frezza 1987 | Study Design: | RCT | 1 | Placebo | | n Entered: | 15 | Type of Outcome: Transaminases, Labs-Bilirubin, Pruritus, Outcome of pregnancy
| | Crossover Study: | No | | Dose: | N/A | n Analyzed: | 15
| | Jadad Score: | 1 | | Route of Admin: | Intravenous
| | | | | Frequency: | 1 Per Day For 18 Days | | | Follow-ups (In Days):18
| | % Female: | 100 | 2 | SAMe | | n Entered: | 15
| | % Under 18: | N/A | | Dose: | 800 mg | n Analyzed: | 15 | Bilirubin: Total bile acids at mean time 18 days
| | % Over 65: | 0 | | Route of Admin: | Intravenous | | | Arm 1 = 40.00 (19.36)
| | | | | Frequency: | 1 Per Day For 18 Days | | | Arm 2 = 11.00 (7.75)
| | Biopsy: | No
| | | | | | | | | Same patient population as Frezza 1990 but different outcome reported.
10047 | Frezza 1990 | Study Design: | RCT | 1 | Placebo | | n Entered: | 15 | Type of Outcome: Transaminases, Labs-Bilirubin, Laboratory values, Pruritus, Outcome of pregnancy
| | Crossover Study: | No | | Dose: | N/A | n Analyzed: | 15
| | Jadad Score: | 0 | | Route of Admin: | Intravenous
| | | | | Frequency: | 1 Per Day Until Delivery
| | % Female: | 100 | 2 | SAMe | | n Entered: | 15 | Follow-ups (In Days): 1 day post-delivery
| | % Under 18: | 0 | | Dose: | 800 mg | n Analyzed: | 15
| | % Over 65: | 0 | | Route of Admin: | Intravenous | | | Pruritus: 10cm analogue scale at 18 days
| | | | | Frequency: | 1 Per Day Until Delivery | | | Arm 1 = 6.40 (5.81)
| | Biopsy: | No | | | | | | Arm 2 = 2.50 (3.87)
| | | | | | | | | Same patient population as Frezza 1987 but different outcome reported.
10150 | Lafuenti 1988 | Study Design: | CCT | 1 | Placebo | | n Entered: | 19 | Type of Outcome: Transaminases, Labs-Bilirubin, Laboratory values, Pruritus
| | Crossover Study: | No | | Dose: | N/A | n Analyzed: | 19
| | Jadad Score: | 0 | | Route of Admin: | N/A
| | | | | Frequency: | N/A | | | Follow-ups (In Days): Follow-ups measured until delivery
| | % Female: | 100 | 2 | SAMe | | n Entered: | 10
| | % Under 18: | N/A | | Dose: | 1800 mg | n Analyzed: | 10
| | % Over 65: | 0 | | Route of Admin: | Oral | | | Bilirubin: mg/dl at implied at delivery
| | | | | Frequency: | 1 Per Day For N/A Days | | | Arm 1 = 3.99 (2.01)
| | Biopsy: | No | 3 | SAMe | | n Entered: | 7 | Arm 2 = 1.65 (0.79)
| | | | | Dose: | 600 mg | n Analyzed: | 7 | Arm 3 = 1.75 (0.77)
| | | | | Route of Admin: | Oral
| | | | | Frequency: | 1 Per Day For N/A Days | | | Pruritus: 0–4 scale at implied at delivery
| | | | | | | | | Arm 1 = 3.40 (1.79)
| | | | | | | | | Arm 2 = 1.10 (1.17)
| | | | | | | | | Arm 3 = 1.40 (0.98)
| | | | | | | | | Baseline bilirubin: Higher in Placebo vs SAMe (600mg/d) (p=0.01) and vs. SAMe (1800mg/d) (p=0.0001). There was a decrease in premature birth in SAMe treated group (p=0.01).
10138 | Nicastri 1998 | Study Design: | RCT | 1 | Placebo | | n Entered: | 8 | Type of Outcome: Laboratory values, Pruritus, Transaminases, Labs-Bilirubin
| | Crossover Study: | No | | Dose: | N/A | n Analyzed: | 8
| | Jadad Score: | 3 | | Route of Admin: | Oral
| | | | | Frequency: | 2 Per Day For 20 Days | | | Follow-ups (In Days): 30
| | % Female: | 100 | 2 | SAMe | | n Entered: | 8
| | % Under 18: | 0 | | Dose: | 400 mg | n Analyzed: | 8 | Bilirubin: mg/dl at 20 days
| | % Over 65: | 0 | | Route of Admin: | Intravenous | | | Arm 1 = 1.80 (0.74*)
| | | | | Frequency: | 2 Per Day For 20 Days | | | Arm 2 = 0.90 (0.74*)
| | Biopsy: | No | 3 | Ursodeoxycholic acid | | n Entered: | 8 | Arm 3 = 1.00 (0.74*)
| | | | | Dose: | 300 mg | n Analyzed: | 8 | Arm 4 = 0.80 (0.74*)
| | | | | Route of Admin: | Oral
| | | | | Frequency: | 2 Per Day For 20 Days | | | Pruritus: Pruritus score 0–4 scale at 20 days
| | | | 4 | SAMe | | n Entered: | 8 | Arm 1 = 1.70 (1.00*)
| | | | | Dose: | 400 mg | n Analyzed: | 8 | Arm 2 = 1.50 (1.00*)
| | | | | Route of Admin: | Intravenous | | | Arm 3 = 2.00 (1.00*)
| | | | | Frequency: | 2 Per Day For 20 Days | | | Arm 4 = 1.20 (1.00*)
| | | | | Ursodeoxycholic acid
| | | | | Dose: | 300 mg | | | Pruritus Score: Comparision UDCA + SAMe vs UDCA (p<0.0003); UDCA + SAMe vs. SAMe (NS).
| | | | | Route of Admin: | Oral
| | | | | Frequency: | 2 Per Day For 20 Days
| | | | | | | | | Bilirubin: Comparision UDCA + SAMe vs UDCA (p<0.0021); UDCA + SAMe vs. SAMe (NS).
10045 | Ribalta 1991 | Study Design: | RCT | 1 | Placebo | | n Entered: | 10 | Type of Outcome: Transaminases, Pruritus, Labs-Bilirubin, Outcome of pregnancy
| | Crossover Study: | No | | Dose: | 100 mg | n Analyzed: | 9
| | Jadad Score: | 3 | | Route of Admin: | Intravenous
| | | | | Frequency: | 1 Per Day For 20 Days | | | Follow-ups (In Days): 5, 10, 15, 20
| | % Female: | 100 | 2 | SAMe | | n Entered: | 10
| | % Under 18: | 0 | | Dose: | 800 mg | n Analyzed: | 9 | Bilirubin: mg/dl at 20 days
| | % Over 65: | 0 | | Route of Admin: | Intravenous | | | Arm 1 = 1.37 (1.14)
| | | | | Frequency: | 1 Per Day For 20 Days | | | Arm 2 = 0.70 (0.60)
| | Biopsy: | No
| | | | | | | | | Pruritus: Severity of pruritus 0–4 scale at 20 days
| | | | | | | | | Arm 1 = 3.30 (0.30)
| | | | | | | | | Arm 2 = 2.80 (0.20)
| | | | | | | | | 7 out of 9 patients had a past history of recurrent cholestasis of pregnancy.
10172 | Roncaglia 2000 | Study Design: | RCT | 1 | Ursodeoxycholic acid | | n Entered: | N/A | Type of Outcome: Pruritus, Laboratory values, Labs-Bilirubin, Transaminases
| | Crossover Study: | No | | Dose: | 300 mg | n Analyzed: | 14
| | Jadad Score: | 2 | | Route of Admin: | Oral
| | | | | Frequency: | 2 Per Day Until Delivery | | | Follow-ups (In Days): 10 days post-delivery
| | % Female: | 100 | 2 | SAMe | | n Entered: | N/A
| | % Under 18: | N/A | | Dose: | 500 mg | n Analyzed: | 8 | Bilirubin: mg/dl at 10 days
| | % Over 65: | 0 | | Route of Admin: | Oral | | | Arm 1 = 0.50 (0.20)
| | | | | Frequency: | 2 Per Day Until Delivery | | | Arm 2 = 0.90 (0.40)
| | Biopsy: | No
| | | | | | | | | Pruritus: Pruritus score with scale not reported at 10 days
| | | | | | | | | Arm 1 = 1.10 (0.38*)
| | | | | | | | | Arm 2 = 0.50 (0.38*)
| | | | | | | | | Patients receiving UCDA had significantly lower serum levels of bile acids (p=0.02), bilirubin (p=0.001), and SGPT (p=0.03), but higher pruritus scores (p=0.02) than those receiving SAMe at baseline.

N/A = Not available or Not Applicable

NOS = Not otherwise specified.

* Imputed standard deviation.

** See Appendix H for abbreviations for Outcomes Measurements.

*** Mean (Standard Deviation) reported.

Table IV Evidence Table. SAMe for Treatment of Cholestasis (Liver Disease)

ID | 1^st^ Author Year | Design Study Quality Population Diagnostic Criteria | | Arm # | Intervention Component Dose | | Sample Size | | Outcome Measurements** Meta-Analysis Data***
10202 | Adachi 1986 | Study Design: | CCT | 1 | No treatment | | n Entered: | N/A | Type of Outcome: Transaminases, Labs-Bilirubin, Laboratory values
| | Crossover Study: | No | | | | n Analyzed: | 8
| | Jadad Score: | 0 | 2 | SAMe | | n Entered: | N/A
| | | | | Dose: | 600 mg | n Analyzed: | 9 | Follow-ups (In Days): 7, 14, 21, 28
| | % Female: | 35 | | Route of Admin: | Intravenous
| | % Under 18: | 0 | | Frequency: | 2 Per Day For 3 Weeks | | | Bilirubin (Chronic): mg/dl at 14 days
| | % Over 65: | 8 | 3 | Prednisone | | n Entered: | N/A | Arm 1 = 13.2 (14.1)
| | | | | Dose: | 30 mg | n Analyzed: | 6 | Arm 2 = 11.6 (6.5)
| | | | | Route of Admin: | Oral | | | Arm 3 = 13.1 (8.8)
| | | | | Frequency: | 3 Per Day For 7 Days
| | | | | Prednisone | | | | Intrahepatic cholestasis (various causes).
| | | | | Dose: | 20 mg | | | Bilirubin: Comparison pre/post level reduced in SAMe (p<0.05) and prednisolone (p<0.01).
| | | | | Route of Admin: | Oral
| | | | | Frequency: | 3 Per Day For 7 Days | | | Transaminases and alkaline phosphatase: No significant result in the three groups.
| | | | | Prednisone
| | | | | Dose: | 10 mg
| | | | | Route of Admin: | Oral
| | | | | Frequency: | 3 Per Day For 7 Days
10378 | Bombardieri 1985 | Study Design: | CCT | 1 | No treatment | | n Entered: | 12 | Type of Outcome: Labs-Bilirubin
| | Crossover Study: | No | | | | n Analyzed: | 9
| | Jadad Score: | 0 | 2 | SAMe | | n Entered: | 14 | Follow-ups (In Days): 10,20
| | | | | Dose: | 200 mg | n Analyzed: | 9
| | % Female: | 57 | | Route of Admin: | Intravenous | | | Bilirubin (Chronic): mg% at 20 days
| | % Under 18: | N/A | | Frequency: | 1 Per Day For 10 Days | | | Arm 1 = 1.9 (0.5)
| | % Over 65: | 0 | | SAMe | | | | Arm 2 = 1.6 (0.3)
| | | | | Dose: | 400 mg
| | | | | Route of Admin: | Oral | | | Gilbert's syndrome. Urinary DGA excretion
| | | | | Frequency: | 3 Per Day For 10 Days | | | SAMe vs. Placebo after 20 days treatment (p<0.05).
10375 | Bray 1991 | Study Design: | RCT | 1 | Ursodeoxycholic acid | | n Entered: | 12 | Type of Outcome: Labs-Bilirubin, Transaminases, Laboratory values, Labs-Bilirubin
| | Crossover Study: | Yes | | Dose: | 0.8–1.2 gm | n Analyzed: | 8
| | Jadad Score: | 2 | | Route of Admin: | Oral
| | | | | Frequency: | 1 Per Day For 8 Weeks | | | Follow-ups (In Days): 60, 150, 240
| | % Female: | 100 | 2 | Rifampicin | | n Entered: | 12
| | % Under 18: | 0 | | Dose: | 0.3 gm | n Analized: | 8 | Exclude from meta-analysis as crossover study.
| | % Over 65: | N/A | | Route of Admin: | Oral
| | | | | Frequency: | 1 Per Day For 8 Weeks | | | Primary biliary cirrhosis complicated with intrahepatic cholestasis. Comparison level after 2 months treatment GGT: UDCA vs. SAMe or Rifampicin (no p value given). Pruritus, Transaminases, Alkaline phosphatase: NS differences among groups.
| | | | 3 | SAMe | | n Entered: | 12
| | | | | Dose: | 2.4 gm | n Analyzed: | 8
| | | | | Route of Admin: | Oral
| | | | | Frequency: | 1 Per Day For 8 Weeks
10190 | Cacciatore 1989 | Study Design: | CCT | 1 | Placebo | | n Entered: | 18 | Type of Outcome: Pruritus
| | Crossover Study: | No | | Dose: | N/A | n Analyzed: | 18
| | Jadad Score: | 0 | | Route of Admin: | Intravenous | | | Follow-ups (In Days): 7, 14, 21
| | | | | Frequency: | 1 Per Day For 1 Weeks
| | % Female: | 44 | 2 | SAMe | | n Entered: | 18 | Exclude from meta-analysis as crossover study.
| | % Under 18: | N/A | | Dose: | 800 mg | n Analyzed: | 18
| | % Over 65: | N/A | | Route of Admin: | Intravenous | | | Chronic liver disease (various causes). Pruritus:
| | | | | Frequency: | 1 Per Day For 2 Weeks | | | Comparison of reduction in scores SAMe vs. placebo (p<0.05) at 1 wk and (p<0.01) at 2 wks.
10194 | Fiaccadori 1988 | Study Design: | RCT | 1 | Placebo | | n Entered: | 35 | Type of Outcome: Transaminases, Labs-Bilirubin
| | Crossover Study: | No | | Dose: | N/A | n Analyzed: | 33
| | Jadad Score: | 3 | | Route of Admin: | Oral | | | Follow-ups (In Days): 14
| | | | | Frequency: | 1 Per Day For 2 Weeks
| | % Female: | N/A | 2 | SAMe | | n Entered: | 34 | Insufficient statistics for meta-analysis.
| | % Under 18: | N/A | | Dose: | 1600 mg | n Analyzed: | 34
| | % Over 65: | N/A | | Route of Admin: | Oral | | | Chronic liver disease with cholestasis.
| | | | | Frequency: | 1 Per Day For 2 Weeks | | | Comparison of percentage of change pre/post levels after 2 weeks of treatment SAMe vs. Placebo: Bilirubin and Alkaline phosphatase (p<0.05). Comparison of decrease in pre/post levels after 2 weeks of treatment SAMe: Transaminases (p<0.01).
10199 | Frezza 1987 | Study Design: | RCT | 1 | Placebo | | n Entered: | 179 | Type of Outcome: Laboratory values, Transaminases, Pruritus, Labs-Bilirubin
| | Crossover Study: | No | | Dose: | N/A | n Analyzed: | 62
| | Jadad Score: | 2 | | Route of Admin: | Intravenous
| | | | | Frequency: | 1 Per Day For 2 Weeks | | | Follow-ups (In Days): N/A
| | % Female: | N/A | 2 | SAMe | | n Entered: | 186
| | % Under 18: | N/A | | Dose: | 800 μg | n Analyzed: | 18 | Pruritus (Chronic): Number of people who resolved pruritus at 14 days
| | % Over 65: | N/A | | Route of Admin: | Intravenous
| | | | | Frequency: | 1 Per Day For 2 Weeks | | | Arm 1 = 19.22 of 62 pts “decreased”
| | | | | | | | | Arm 2 = 69.99 of 81 pts “decreased”
| | | | | | | | | Chronic Liver Disease with cholestasis.
| | | | | | | | | Comparison of changes in pre/post treatment levels after 2 weeks SAMe vs. placebo: Pruritus (p<0.01); Bilirubin (p<0.001); Transaminases (p<0.001) and Alkaline phosphatase (p<0.001).
10053 | Frezza 1990 | Study Design: | RCT | 1 | Placebo | | n Entered: | 110 | Type of Outcome: Fatigue, Transaminases, Pruritus, Face Scale, Labs-Bilirubin
| | Crossover Study: | No | | Dose: | N/A | n Analyzed: | 101
| | Jadad Score: | 4 | | Route of Admin: | Oral
| | | | | Frequency: | 2 Per Day For 2 Weeks | | | Follow-ups (In Days): 7, 14, 44
| | % Female: | 56 | | H2 Blockers | | | | Bilirubin (Chronic): mu_mol/l at 14 days
| | % Under 18: | 0 | 2 | SAMe | | n Entered: | 110 | Arm 1 = 4.1 (2.0)
| | % Over 65: | N/A | | Dose: | 800 mg | n Analyzed: | 108 | Arm 2 = 2.7 (2.1)
| | | | | Route of Admin: | Oral
| | | | | Frequency: | 2 Per Day For 2 Weeks | | | Pruritus (Chronic): Number of people who resolved pruritus at 14 days
| | | | | H2 Blockers
| | | | | | | | | Arm 1 = 14 of 42 pts “>50% decrease”
| | | | | | | | | Arm 2 = 30 of 39 pts “>50% decrease”
| | | | | | | | | Chronic Liver Disease with cholestasis.
| | | | | | | | | Comparison pre/post treatment levels after 2 wks SAMe vs. placebo Bilirubin (p<0.01); Alkaline phosphatase (p<0.01); ALT (p<0.05); AST and GGT (NS); Pruritus (p<0.01).
10171 | Manzillo 1992 | Study Design: | RCT | 1 | Placebo | | n Entered: | N/A | Type of Outcome: Labs-Bilirubin, Transaminases, Pruritus
| | Crossover Study: | No | | Dose: | N/A | n Analyzed: | 108
| | Jadad Score: | 2 | | Route of Admin: | Intravenous
| | | | | Frequency: | 1 Per Day For 2 Weeks | | | Follow-ups (1 Days): 14
| | % Female: | 39 | 2 | SAMe | | n Entered: | N/A
| | % Under 18: | N/A | | Dose: | 800 mg | n Analyzed: | 119 | Bilirubin (Chronic): μmol/L at 14 days
| | % Over 65: | N/A | | Route of Admin: | Intravenous | | | Arm 1 = 27.4 (17.5)
| | | | | Frequency: | 1 Per Day For 2 Weeks | | | Arm 2 = 24.3 (16.1)
| | | | | | | | | Bilirubin (Acute): μmol/L at 14 days
| | | | | | | | | Arm 1 = 31.5 (27.6)
| | | | | | | | | Arm 2 = 21.3 (13.2)
| | | | | | | | | Pruritus (Acute & Chronic): Number of people who resolved pruritus at 14 days
| | | | | | | | | Arm 1 = 16 of 42 pts “relieved”
| | | | | | | | | Arm 2 = 54 of 63 pts “relieved”
| | | | | | | | | Intrahepatic cholestasis complicating either acute or chronic liver disease. Comparison SAMe vs. placebo: Chronic and Acute liver disease:
| | | | | | | | | Bilirubin and Transaminases: (p<0.05 and p<0.01 respectively); Pruritus: (p<0.001 both).
10185 | O'Donohue 1996 | Study Design: | RCT | 1 | No treatment | | n Entered: | 9 | Type of Outcome: Mortality, Transaminases, Labs-Bilirubin, Laboratory values
| | Crossover Study: | No | | | | n Analyzed: | 4
| | Jadad Score: | 2 | 2 | SAMe | | n Entered: | 8
| | | | | Dose: | 400 mg | n Analyzed: | 5 | Follow-ups (In Days): 4, 10
| | % Female: | 82 | | Route of Admin: | Intravenous
| | % Under 18: | N/A | | Frequency: | 2 Per Day For 5 Days | | | Insufficient statistics for meta-analysis.
| | % Over 65: | N/A | | | | | | Intrahepatic cholestasis following acute liver failure (various causes). Comparison decreases in mean bilirubin SAMe vs. no treatment (p<0.02 at 4 days; NS at 10 days). Survival: Longer in SAMe vs. no treatment (p<0.08).
10136 | Qin 2000 | Study Design: | RCT | 1 | Phosphate/Placebo | | n Entered: | 55 | Type of Outcome: Transaminases, Fatigue, Pruritus, Laboratory values
| | Crossover Study: | No | | Dose: | N/A | n Analyzed: | 55
| | Jadad Score: | 1 | | Route of Admin: | Intravenous
| | | | | Frequency: | 1 Per Day For 4 Weeks | | | Follow-ups (In Days): 14, 28
| | % Female: | N/A | 2 | SAMe | | n Entered: | 55
| | % Under 18: | N/A | | Dose: | 1000 mg | n Analyzed: | 55 | Bilirubin (Chronic): mu_mol/l at 14 days
| | % Over 65: | N/A | | Route of Admin: | Intravenous | | | Arm 1 = 90.2 (30.2)
| | | | | Frequency: | 1 Per Day For 4 Weeks | | | Arm 2 = 40.7 (24.2)
| | | | | | | | | Bilirubin (Acute): mu_mol/l at 14 days
| | | | | | | | | Arm 1 = 122.5 (46.3)
| | | | | | | | | Arm 2 = 68.3 (25.6)
| | | | | | | | | Pruritus (Chronic): Number of people who resolved pruritus at 14 days
| | | | | | | | | Arm 1 = 16 of 32 pts “effective”
| | | | | | | | | Arm 2 = 28 of 32 pts “effective”
| | | | | | | | | Viral hepatitis complicated by intrahepatic cholestasis. Comparison of improvement after 4 weeks of treatment SAMe vs. potassium phosphate/placebo: Albumin, Bilirubin, Alkaline phosphatase, Transaminases and Pruritus (p<0.05).

N/A = Not available or Not Applicable.

NOS = Not otherwise specified.

* Imputed standard deviation.

** See Appendix H for abbreviations for Outcomes Measurements.

*** Mean (Standard Deviation) reported.

Table V Evidence Table. SAMe for Treatment of Liver Disease (General)

ID | 1^st^Author Year | Design Study Quality Population Diagnostic Criteria | | Arm # | Intervention Component Dose | | Sample Size | | Outcome Measurements** Meta-Analysis Data***
10368 | Botero 1991 | Study Design: | RCT | 1 | Placebo | | n Entered: | 14 | Type of Outcome: Transaminases
| | Crossover Study: | No | | Dose: | N/A | n Analyzed: | 11
| | Jadad Score: | 2 | | Route of Admin: | Intravenous | | | Follow-ups (In Days): 10, 20, 30, 90
| | | | | Frequency: | 1 Per Day For 10 Days
| | % Female: | N/A | 2 | SAMe | | n Entered | 14 | Clinical heterogeneity precludes pooled analysis.
| | % Under 18: | N/A | | Dose: | 500 mg | n Analyzed: | 10
| | % Over 65: | 0 | | Route of Admin: | Intravenous | | | Acute viral hepatitis (A, B, and non A-non B). Transaminases: Decrease in Hepatitis A (p<0.001) at 10, 20 and 30 days and at 3 months for AST (p<0.05) compared to placebo. No differences were seen in Hepatitis B (4 patients) and in non A-non B group (3 patients).
| | | | | Frequency: | 1 Per Day For 10 Days
10062 | Bresci 1982 | Study Design: | CCT | 1 | Placebo | | n Entered: | 52 | Type of Outcome: Transaminases, Laboratory values,
| | Crossover Study: | No | | Dose: | N/A | n Analyzed: | 52
| | Jadad Score: | 0 | | Route of Admin: | Intramuscular
| | | | | Frequency: | 1 Per Day For 30 Days | | | Follow-ups (In Days): 30
| | % Female: | 38 | 2 | SAMe | | n Entered: | 52
| | % Under 18: | 0 | | Dose: | 100 mg | n Analyzed: | 52 | Clinical heterogeneity precludes pooled analysis.
| | % Over 65: | N/A | | Route of Admin: | Intramuscular
| | | | | Frequency: | 1 Per Day For 30 Days | | | Chronic Liver Disease (chronic persistent and alcoholic hepatitis). Transaminases: Improvement in pre/post levels at 30 days in chronic persistent hepatitis SAMe group (p<0.001); alcoholic hepatitis SAMe (p<0.01 for SGOT; p<0.001 for SGPT and GGT). Alkaline phosphatase:
| | | | | | | | | Improvement in pre/post levels at 30 days in chronic persistent hepatitis SAMe group (NS); alcoholic hepatitis SAMe (p<0.02).
10135 | Di Palma 1978 | Study Design: | CCT | 1 | Placebo | | n Entered: | 23 | Type of Outcome: Laboratory values, Transaminases, Labs-Bilirubin
| | Crossover Study: | No | | Dose: | N/A | n Analyzed: | 23
| | Jadad Score: | 0 | | Route of Admin: | N/A
| | | | | Frequency: | 1 Per Day For N/A | | | Follow-ups (In Days): 7, 14, 21, 28, 35
| | % Female: | 28 | 2 | SAMe | | n Entered: | 23
| | % Under 18: | 70 | | Dose: | Dose variable N/A | n Analyzed: | 23 | Clinical heterogeneity precludes pooled analysis.
| | % Over 65: | 0 | | Route of Admin: | N/A
| | | | | Frequency: | 1 Per Day For N/A | | | Viral hepatitis. Transaminases (GPT and GOT): Improvement in pre/post scores in both groups (p<0.001) at day 14. Bilirubin: Comparison of pre/post reductions SAMe (p<0.001) vs. placebo (p<0.05) and (p<0.01) at day 7 and 14 respectively.
10028 | Diaz Belmont 1996 | Study Design: | RCT | 1 | SAMe | | n Entered: | 23 | Type of Outcome: Laboratory values, Labs-Bilirubin, Transaminases, Laboratory values, PGA-Overall, Symptoms
| | Crossover Study: | No | | Dose: | 200 mg | n Analyzed: | 23
| | Jadad Score: | 2 | | Route of Admin: | Intravenous
| | | | | Frequency: | 1 Per Day For 15 Days
| | % Female: | 11 | 2 | Placebo | | n Entered: | 22 | Follow-ups (In Days): 8, 15
| | % Under 18: | 0 | | Dose: | N/A | n Analyzed: | 22
| | % Over 65: | 0 | | Route of Admin: | N/A | | | Clinical heterogeneity precludes pooled analysis.
| | | | | Frequency: | N/A
| | | | | | | | | Alcoholic hepatitis. Comparison pre/post levels SAMe group bili (p<0.0001), direct biliruben (p<0.0002), albumin (p<0.0055), alkaline phosphatase (p<0.0001) at 15 days.
10173 | Gentile 1990 | Study Design: | RCT | 1 | Placebo | | n Entered: | 18 | Type of Outcome: Transaminases, Labs-Bilirubin, Laboratory values
| | Crossover Study: | No | | Dose: | N/A | n Analyzed: | N/A
| | Jadad Score: | 1 | | Route of Admin: | Intravenous
| | | | | Frequency: | 1 Per Day For 10 Days | | | Follow-ups (In Days): 10
| | % Female: | N/A | 2 | SAMe | | n Entered: | 22
| | % Under 18: | 0 | | Dose: | 1200 mg | n Analyzed: | N/A | Clinical heterogeneity precludes pooled analysis.
| | % Over 65: | N/A | | Route of Admin: | Intravenous
| | | | | Frequency: | 1 Per Day For 10 Days | | | Chronic liver disease with cirrhosis. Comparison pre/post levels after 10 days Transaminases and Alkaline Phosphatase: SAMe (p<0.01) and placebo (NS). Bilirubin (Area Under the Curve) for Child’s Class A, B, C: SAMe (p<0.01) and placebo (NS).
10157 | Ideo 1975 | Study Design: | CCT | 1 | L-methionine | | n Entered: | 15 | Type of Outcome: Laboratory values, Transaminases, Labs-Bilirubin
| | Crossover Study: | No | | Dose: | 5 mg | n Analyzed: | 15
| | Jadad Score: | 2 | | Route of Admin: | Intravenous
| | | | | Frequency: | 4 Per Day For 30 Days | | | Follow-ups (In Days): 30
| | % Female: | N/A | | ATP
| | % Under 18: | 0 | | Dose: | 17 mg | | | Clinical heterogeneity precludes pooled analysis.
| | % Over 65: | 3 | | Route of Admin: | Intravenous
| | | | | Frequency: | 4 Per Day For 30 Days | | | Chronic hepatitis with cirrhosis. Improvements noted in pre/post levels for Bilirubin, Transaminases and Total Albumin. p values not given.
| | | | | L-methionine
| | | | | Dose: | 5 mg
| | | | | Route of Admin: | Intramuscular
| | | | | Frequency: | 4 Per Day For 30 Days
| | | | | ATP
| | | | | Dose: | 17 mg
| | | | | Route of Admin: | Intramuscular
| | | | | Frequency: | 4 Per Day For 30 Days
| | | | 2 | SAMe | | n Entered: | 15
| | | | | Dose: | 15 mg | n Analyzed: | 15
| | | | | Route of Admin: | Intravenous
| | | | | Frequency: | 4 Per Day For 30 Days
| | | | | SAMe
| | | | | Dose: | 15 mg
| | | | | Route of Admin: | Intramuscular
| | | | | Frequency: | 4 Per Day For 30 Days
10060 | Jorge 1985 | Study Design: | RCT | 1 | SAMe | | n Entered: | 15 | Type of Outcome: Laboratory values, Symptoms, Laboratory values, Transaminases
| | Crossover Study: | No | | Dose: | 200 mg | n Analyzed: | 15
| | Jadad Score: | 1 | | Route of Admin: | Intravenous
| | | | | Frequency: | 1 Per Day For 15 Days | | | Follow-ups (In Days): 7, 14, 21, 30
| | % Female: | 60 | | SAMe
| | % Under 18: | 33 | | Dose: | 200 mg | | | Clinical heterogeneity precludes pooled analysis.
| | % Over 65: | 0 | | Route of Admin: | Intramuscular
| | | | | Frequency: | 1 Per Day For 15 Days | | | Acute viral hepatitis (adults and children). Transaminases: Comparison of the rate of change in AST: SAMe vs. placebo (p<0.01) after 30 days. Improvements noted in PT, Alkaline phosphatase; Bilirubin after 30 days: No p values given.
| | | | | SAMe
| | | | | Dose: | 100 mg
| | | | | Route of Admin: | Intravenous
| | | | | Frequency: | 1 Per Day For 15 Days
| | | | | SAMe
| | | | | Dose: | 100 mg
| | | | | Route of Admin: | Intramuscular
| | | | | Frequency: | 1 Per Day For 15 Days
| | | | 2 | Customary care | | n Entered: | 15
| | | | | | | n Entered: | 15
10156 | Labo 1975 | Study Design: | RCT | 1 | Placebo | | n Entered: | 25 | Type of Outcome: Transaminases, Labs-Bilirubin, Laboratory values
| | Crossover Study: | No | | Dose: | N/A | n Analyzed: | 25
| | Jadad Score: | 3 | | Route of Admin: | Intravenous
| | | | | Frequency: | 2 Per Day For 30 Days | | | Follow-ups (In Days): 30
| | % Female: | N/A | | Vitamin B12
| | % Under 18: | 0 | | Dose: | 10000 μg | | | Clinical heterogeneity precludes pooled analysis.
| | % Over 65: | N/A | | Route of Admin: | Intravenous
| | | | | Frequency: | 2 Per Day For 30 Days | | | Chronic liver disease with cirrhosis. Comparison of improvement in levels in SAMe and B12 vs. B12 only at 30 days. Bilirubin (p<0.005); Albumin (p<0.05); Alkaline phosphatase (p<0.02) and Prothrombin time (p<0.005).
| | | | 2 | SAMe | | n Entered: | 28
| | | | | Dose: | 75 mg | n Analyzed: | 28
| | | | | Route of Admin: | Intravenous
| | | | | Frequency: | 2 Per Day For 30 Days
| | | | | Vitamin B12
| | | | | Dose: | 10000 μg
| | | | | Route of Admin: | Intravenous
| | | | | Frequency: | 2 Per Day For 30 Days
10167 | Loguercio 1993 | Study Design: | RCT | 1 | Placebo | | n Entered: | 10 | Type of Outcome: Laboratory values
| | Crossover Study: | No | | Dose: | N/A | n Analyzed: | 10
| | Jadad Score: | 1 | | Route of Admin: | Intravenous | | | Follow-ups (In Days): 15
| | | | | Frequency: | 1 Per Day For 15 Days
| | % Female: | 0 | 2 | SAMe | | n Entered: | 10 | Clinical heterogeneity precludes pooled analysis.
| | % Under 18: | 0 | | Dose: | 2 gm | n Analyzed: | 10
| | % Over 65: | 0 | | Route of Admin: | Intravenous | | | Alcoholic liver disease with cirrhosis (Child’s class A). Comparison of decrease in RBC cysteine after 15 days: Pre/post levels SAMe (p<0.01) or vs. placebo (p<0.01). Increase in RBC glutathione after 15 days: Pre/post levels SAMe (NS) or vs. placebo (p<0.01).
| | | | | Frequency: | 1 Per Day For 15 Days
10243 | Marchesini 1992 | Study Design: | CCT | 1 | Placebo | | n Entered: | 8 | Type of Outcome: Laboratory values
| | Crossover Study: | No | | Dose: | N/A | n Analyzed: | N/A
| | Jadad Score: | 0 | | Route of Admin: | Intravenous | | | Follow-ups (In Days): 1, 2, 3, 30
| | | | | Frequency: | 2 Per Day For 3 Days
| | % Female: | 38 | | Placebo | | | | Clinical heterogeneity precludes pooled analysis.
| | % Under 18: | 0 | | Dose: | N/A
| | % Over 65: | 0 | | Route of Admin: | Oral | | | Chronic Liver Disease with cirrhosis (Childs class B or C): In patients given SAMe, levels of taurine and cystine were increased (p<0.05), while levels of methionine, neutral amino acids, and polyamines were unchanged following the treatment period.
| | | | | Frequency: | 3 Per Day For 30 Days
| | | | 2 | SAMe | | n Entered: | 8
| | | | | Dose: | 600 μg | n Analyzed: | N/A
| | | | | Route of Admin: | Intravenous
| | | | | Frequency: | 2 Per Day For 3 Days
| | | | | SAMe
| | | | | Dose: | 400 μg
| | | | | Route of Admin: | Oral
| | | | | Frequency: | 3 Per Day For 30 Days
10066 | Mascio 1981 | Study Design: | CCT | 1 | Phosphatidylcholine | | n Entered: | 34 | Type of Outcome: Liver biopsy, Laboratory values
| | Crossover Study: | No | | Dose: | 1 gm | n Analyzed: | 34
| | Jadad Score: | 0 | | Route of Admin: | Intravenous
| | | | | Frequency: | 2 Per Day For 30 Days | | | Follow-ups (In Days): 30
| | % Female: | 34 | 2 | SAMe | | n Entered: | 34
| | % Under 18: | N/A | | Dose: | 250 mg | n Analyzed: | 34 | Clinical heterogeneity precludes pooled analysis.
| | % Over 65: | N/A | | Route of Admin: | Intravenous
| | | | | Frequency: | 2 Per Day For 30 Days | | | Chronic liver disease (various types). Chronic hepatitis: Improvement in pre/post scores in SAMe group after 30 days: Albumin (p<0.02), Prothrombin time (p<0.05), and Biopsy score (p<0.001). Cirrhosis: Improvement in pre/post scores in SAMe group: Albumin (NS), Prothrombin time (NS) and Biopsy score (p<0.001).
10027 | Mato 1999 | Study Design: | RCT | 1 | Placebo | | n Entered: | 61 | Type of Outcome: Mortality, Transaminases, Labs-Bilirubin, Laboratory values, Liver transplant
| | Crossover Study: | No | | Dose: | N/A | n Analyzed: | 46
| | Jadad Score: | 5 | | Route of Admin: | Oral
| | | | | Frequency: | 3 Per Day For 104 Weeks
| | % Female: | 14 | 2 | SAMe | | n Entered: | 62 | Follow-ups (In Days): 180, 270, 360, 450, 540, 630, 720
| | % Under 18: | 0 | | Dose: | 400 mg | n Analyzed: | 53
| | % Over 65: | N/A | | Route of Admin: | Oral
| | | | | Frequency: | 3 Per Day For 104 Weeks | | | Clinical heterogeneity precludes pooled analysis.
| | | | | | | | | Alcoholic liver cirrhosis (Childs class A, B and C). Mortality/liver transplantation over a 2 yr follow-up period: All study participants: SAMe vs. placebo (p=0.077); Childs Class A and B only: SAMe vs. placebo (p=0.025).
10065 | Micali 1983 | Study Design: | CCT | 1 | Placebo | | n Entered: | 25 | Type of Outcome: Laboratory values, Liver biopsy
| | Crossover Study: | No | | Dose: | N/A | n Analyzed: | 25
| | Jadad Score: | 1 | | Route of Admin: | Oral
| | | | | Frequency: | 3 Per Day For 4 Weeks | | | Follow-ups (In Days): 30
| | % Female: | 22 | 2 | SAMe | | n Entered: | 25
| | % Under 18: | 0 | | Dose: | 300 mg | n Analyzed: | 25 | Clinical heterogeneity precludes pooled analysis.
| | % Over 65: | N/A | | Route of Admin: | Oral
| | | | | Frequency: | 3 Per Day For 4 Weeks | | | Chronic liver disease (various causes). Steatosis: Improvement in biopsy results after 30 days:
| | | | | | | | | SAMe vs. placebo (p<0.01). Laboratory results improvement after 30 days SAMe vs. placebo: Transaminases (p<0.01); Prothrombin activity (p<0.01).
10155 | Miglio 1975 | Study Design: | RCT | 1 | Vitamin B12 | | n Entered: | 20 | Type of Outcome: Laboratory values, Transaminases, Labs-Bilirubin
| | Crossover Study: | No | | Dose: | 1000 μg | n Analyzed: | 20
| | Jadad Score: | 2 | | Route of Admin: | Oral
| | | | | Frequency: | 6 Per Day For 30 Days | | | Follow-ups (In Days): 30, 60
| | % Female: | N/A | 2 | SAMe | | n Entered: | 20
| | % Under 18: | N/A | | Dose: | 30 mg | n Analyzed: | 20 | Clinical heterogeneity precludes pooled analysis.
| | % Over 65: | N/A | | Route of Admin: | Oral
| | | | | Frequency: | 6 Per Day For 30 Days | | | Chronic hepatitis (various causes). Comparison of improvements in pre/post scores after 30 days treatment: SAMe and Vit B12: Total protein (p<0.02); Albumin (p<0.001); Transaminases (p<0.005); and Bilirubin (total (p<0.01) and indirect (p<0.005)). Vitamin B12 alone: All parameters (NS).
| | | | | Vitamin B12
| | | | | Dose: | 1000 μg
| | | | | Route of Admin: | Oral
| | | | | Frequency: | 6 Per Day For 30 Days
10153 | Musso 1980 | Study Design: | CCT | 1 | Milk thistle | | n Entered: | 10 | Type of Outcome: Transaminases, Labs-Bilirubin, Laboratory values
| | Crossover Study: | No | | Dose: | 12 mg/kg | n Analyzed: | 10
| | Jadad Score: | 0 | | Route of Admin: | N/A
| | | | | Frequency: | 1 Per Day For 30 Days | | | Follow-ups (In Days): 5, 10, 20, 30
| | % Female: | 59 | 2 | Milk thistle | | n Entered: | 7
| | % Under 18: | 100 | | Dose: | 12 mg/kg | | | Clinical heterogeneity precludes pooled analysis.
| | % Over 65: | 0 | | Route of Admin: | N/A
| | | | | Frequency: | 1 Per Day For 30 Days | | | Acute viral hepatitis (Pediatric patients). No improvement in Milk thistle/SAMe group compared to the milk thistle group.
| | | | | SAMe
| | | | | Dose: | 5 mg/kg
| | | | | Route of Admin: | N/A
| | | | | Frequency: | 1 Per Day For 30 Days
10067 | Pecoraro 1979 | Study Design: | CCT | 1 | Placebo | | n Entered: | 40 | Type of Outcome: Symptoms, Transaminases, Laboratory values, Labs-Bilirubin
| | Crossover Study: | No | | Dose: | N/A | n Analyzed: | 40
| | Jadad Score: | 0 | | Route of Admin: | Intravenous
| | | | | Frequency: | 1 Per Day Until symptoms resolve | | | Follow-ups (In Days): 10, 20, 25
| | % Female: | 44
| | % Under 18: | N/A | 2 | SAMe | | n Entered: | 40 | Clinical heterogeneity precludes pooled analysis.
| | % Over 65: | N/A | | Dose: | N/A | n Analyzed: | 40
| | | | | Route of Admin: | Intravenous | | | Acute viral hepatitis. Comparison of percentage of group which normalized values after 25 days SAMe vs. placebo: Bilirubin (p<0.01); SGOT (p<0.001); SGPT (p<0.001).
| | | | | Frequency: | 1 Per Day Until Symptoms Resolve
10176 | Persico 1990 | Study Design: | CCT | 1 | Placebo | | n Entered: | 18 | Type of Outcome: Transaminases, Labs-Bilirubin
| | Crossover Study: | No | | Dose: | N/A | n Analyzed: | N/A
| | Jadad Score: | 0 | | Route of Admin: | Intravenous | | | Follow-ups (In Days): 10
| | | | | Frequency: | 1 Per Day For 10 Days
| | % Female: | 33 | 2 | SAMe | | n Entered: | 30 | Clinical heterogeneity precludes pooled analysis.
| | % Under 18: | N/A | | Dose: | 1200 mg | n Analyzed: | N/A
| | % Over 65: | N/A | | Route of Admin: | Intravenous | | | Cirrhosis (Childs class A, B and C). Comparison of improvement pre/post levels after 10 days: SAMe: Transaminases and Alkalline phosphatase (p<0.001) and Placebo: all values (NS).
| | | | | Frequency: | 1 Per Day For 10 Days
10400 | Trespi 1997 | Study Design: | RCT | 1 | TUDCA | | n Entered: | N/A | Type of Outcome: Labs-Bilirubin, Transaminases, Laboratory values
| | Crossover Study: | No | | Dose: | 500 mg | n Entered: | 57
| | Jadad Score: | 1 | | Route of Admin: | Oral
| | | | | Frequency: | 1 Per Day For 24 Weeks | | | Follow-ups (In Days): 180
| | % Female: | 17 | 2 | Ursodeoxycholic acid | | n Entered: | N/A
| | % Under 18: | N/A | | Dose: | 600 mg | n Entered: | 51 | Alcoholic liver disease. Best results were obtained with TUDCA + SAMe.
| | % Over 65: | N/A | | Route of Admin: | Oral
| | | | | Frequency: | 1 Per Day For 24 Weeks
| | | | 3 | TUDCA | | n Entered: | N/A
| | | | | Dose | 500 mg | n Analyzed: | 51
| | | | | Route of Admin: | Oral
| | | | | Frequency: | 1 Per Day For 24 Weeks
| | | | | SAMe
| | | | | Dose: | 1500 mg
| | | | | Route of Admin: | Oral
| | | | | Frequency: | 1 Per Day For 24 Weeks
| | | | 4 | Ursodeoxycholic acid | | n Entered: | N/A
| | | | | Dose: | 600 mg | n Analyzed: | 51
| | | | | Route of Admin: | Oral
| | | | | Frequency: | 1 Per Day For 24 Weeks
| | | | | SAMe
| | | | | Dose: | 1500 mg
| | | | | Route of Admin: | Oral
| | | | | Frequency: | 1 Per Day For 24 Weeks
10149 | Vendemiale 1989 | Study Design: | CCT | 1 | No treatment | | n Entered: | 15 | Type of Outcome: Glutathione
| | Crossover Study: | No | | | | n Analyzed: | N/A
| | Jadad Score: | 0 | 2 | Placebo | | n Entered: | 8 | Follow-ups (In Days): 180
| | | | | Dose: | N/A | n Analyzed: | N/A
| | % Female: | 15 | | Route of Admin: | Oral | | | Clinical heterogeneity precludes pooled analysis.
| | % Under 18: | 0 | | Frequency: | 3 Per Day For 24 Weeks
| | % Over 65: | 0 | 3 | SAMe | | n Entered: | 16 | Chronic liver disease (alcoholic and non-alcoholic). Comparison pre/post increases in Total glutathione after 6 months (Alcholic and Non alcoholic liver disease): Placebo (NS); SAMe (p<0.05).
| | | | | Dose: | 400 mg | N Analyzed: | N/A
| | | | | Route of Admin: | Oral
| | | | | Frequency: | 3 Per Day For 24 Weeks
10163 | Wong 1998 | Study Design: | RCT | 1 | Placebo | | n Entered: | 5 | Type of Outcome: Laboratory values, Mortality,
| | Crossover Study: | No | | Dose: | N/A | n Analyzed: | 5
| | Jadad Score: | 2 | | Route of Admin: | N/A | | | Follow-ups (In Days): 1, 3, 7, 14
| | | | | Frequency: | For 14 Days
| | % Female: | N/A | 2 | SAMe | | n Entered: | 9 | Clinical heterogeneity precludes pooled analysis.
| | % Under 18: | N/A | | Dose: | N/A | n Analyzed: | 9
| | % Over 65: | N/A | | Route of Admin: | N/A | | | Liver transplantation (orthotopic). Comparison of normalization of Prothrombin times following transplantation over the first 3 post-operative days: SAMe vs. placebo (p=0.014). Survival after 3 months was similar in both groups.
| | | | | Frequency: | For 14 Days

N/A = Not available or Not Applicable.

NOS = Not otherwise specified.

* Imputed standard deviation.

** See Appendix H for abbreviations for Outcomes Measurements.

*** Mean (Standard Deviation) reported.