# References

Adachi Y, Nanno T, Kanbe A, et al. The effects of S-adenosylmethionine on intrahepatic cholestasis. Japanese Archives of Internal Medicine. 1986;33(6):185-92.
Agnoli A, Andreoli V, Casacchia M, et al. Effect of S-adenosyl-l-methionine (SAMe) upon depressive symptoms. J Psychiatric Research. 1976;13:43-54.
Agnoli A, Andreoli V, Casacchia M, et al. Results and possible developments of the clinical use of S-adenosyl-L-methionine (SAMe) in psychiatry. In: Andreoli A, Agnoli A and Fazio C, eds. Transmethylations and the Nervous System. New York: Springer-Verlag 1978:170–82.
Agnoli A, Fazio C, Andreoli V, et al. Disturbi neuropsichiatrici e transmetilazioni. Effetti terapeutici della s-adenosil-l-metionina. Clin Ter 1975;75:567–79. (Ita).
Almasio P, Bortolini M, Pagliaro L, et al. Role of S-adenosyl-L-methionine in the treatment of intrahepatic cholestasis. Drugs. 1990;40(suppl 3):111-23. [pmid: 2081476].
Ancarnai E, Biondi B, Bolletta A, et al. Major depression complicating hemodialysis in patients with chronic renal failure: a multicenter, double-blind, controlled clinical trial of s-adenosyl-l-methionine versus placebo. Curr Ther Res. 1993;54(6):680-6.
Angell M. Negative studies. N Engl J Med. 1989;321:464-6. [pmid: 2761580].
Annon. Launch this month for BASF's SAM-e in the USA. Nutraceuticals International 1999 Mar.
Bacq Y R, Sapey T. Intrahepatic cholestasis of pregnancy. Gastroenterol Clin Biol. Aug. 1998;22(N89):705-13. [pmid: 9823559].
Bailey J, Coppen A. A comparison between the Hamilton Rating Scale and the Beck Inventory in the measurement of depression. Br J Psychiatry. 1976;128:486-9. [pmid: 1276553].
Barberi A, Pusateri C. Sugli effetti clinici della S-adenosil-L-metionina (SAMe) nelle sindromi depressive. Minerva Psichiatr 1978;19:235–43. (Ita).
Bass N M. Is there any use for nontraditional or alternative therapies in patients with chronic liver disease?. Current Gastroenterol Reports. 1999;1:50-6.
Begg C B, Mazumdar M. Operating characteristics of a rank correlation test for publication bias. Biometrics. Dec. 1994;50(4):1088-101. [pmid: 7786990].
Bell K M, Plon L, Bunney Jr W E, et al. S-adenosylmethionine treatment of depression: a controlled clinical trial. Am J Psychiatry. Sept. 1988;145:1110-4. [pmid: 3046382].
Bell K M, Potkin S G. S-adenosylmethionine in the treatment of depression. Psychopharmacology (Berlin). 1988;96(Suppl):69. [pmcid: 161672].
Bell K M, Potkin S G, Carreon D, et al. S-adenosylmethionine blood levels in major depression: changes with drug treatment. Acta Neurol Scand. 1994;89(154):15-18. [pmid: 8178621].
Berlanga C, Ortega-Soto H, Ontiveros M, et al. Efficacy of S-adenosyl-L-methionine in speeding the onset of action of imipramine. Psychiatry Res. Dec. 1992;44(3):257-62. [pmid: 1289923].
Biggs J T, Wylie L T, Ziegler V F. Validity of the Zung Self-rating Depression Scale. Br J Psychiatry. 1978;132:381-5. [pmid: 638392].
Bombardieri G, Milani A, Bernardi L, et al. Effects of s-adenosyl-methionine (SAMe) in the treatment of Gilbert's syndrome. Curr Ther Res. 1985;37(3):580-5.
Bortoline M, Almasio P, Bray G, et al. Multicentre survey of the prevalence of intrahepatic cholestasis in 2520 consecutive patients with newly diagnosed liver disease. Drug Investigation. 1992;4(Suppl 4):83-9.
Botero R C, Delgado C. Placebo controlled trial of intravenous S-adenosylmethionine (SAMe) in patients with acute hepatitis A, B, and NANB. Abstract. Hepatology. 1991;14:199A.
Bottiglieri T, Chary C K, Laundy M, et al. Trans-methylation in depression. Alabama J Med Sci. 1988;25:296-301.
Bottiglieri T, Godfrey P, Flynn T, et al. Cerebrospinal-fluid s-adenosylmethionine in depression and dementia - effects of treatment with parenteral and oral s-adenosylmethionine. J Neurol Neurosurg Psychiatry. 1990;53(N12):1096-98. [pmid: 2292704].
Bradley J, Flusser D, Brandt K, et al. S-adenosyl methionine (SAMe) in the treatment of osteoarthritis (OA) of the knee. Arthritis Rheum. 1991;34(suppl 9):S86.
Bradley J D, Flusser D, Katz B P, et al. A randomized, double-blind, placebo-controlled trial of intravenous loading with s-adenosylmethionine (SAM) followed by oral SAM therapy in patients with knee osteoarthritis. J Rheumatol. May. 1994;21(N5):905-11. [pmid: 8064733].
Bray G P, Di Padova C, Tredger J M, et al. A comparison of s-adenosylmethionine (SAMe), rifampicin (R) and ursodeoxycholic acid (UDCA) in primary biliary cirrhosis (PBC): Interim results. Hepatology. 1991;13(suppl 2):S101.
Bresci G, Marchioro M. Effetti della SAMe sugli indici di funzionalità epatica in corso di epatopatia cronica. Confronto con placebo [Effects of SAMe on liver function tests in patients with chronic liver disease. A comparison with placebo]. Gazz Med Ital 1982;141(10):557–62. (Ita).
Bressa G M. S-adenosyl-l-methionine (SAMe) as antidepressant: meta-analysis of clinical studies. Acta Neurol Scand. 1994;89(suppl 154):7-14.
Brown R, Bottiglieri T, Coleman C et al. Stop Depression Now: SAM-e: The Breakthrough Supplement That Works As Well As Prescription Drugs, in Half the Time…With No Side Effects. Putnam Publishing Group; 2000.
Brown RP, Gerbarg PL. Herbs and nutrients in the treatment of depression, anxiety, insomnia, migraine, and obesity. Journal of Psychiatric Practice 2001 Mar.;75–91.
Brown R P, Gerbarg P L, Bottiglieri T. S-adenosylmethionine (SAMe) in the clinical practice of psychiatry, neurology and internal medicine. Clinical Practice of Alternative Medicine. 2000;1:230-41.
Cacciatore L, Varriale A, Cozzolino G, et al. S-adenosylmethionine SAMe in the treatment of pruritus in chronic liver disease. Acta Therapeutica. 1989;15(4):363-72.
Calandra C, Roxas M, Rapisarda V. Azione antidepressiva della SAMe a paragone della clorimipramina. Ipotesi interpretative del meccanismo d'azione. Minerva Psichiatr 1979;20:147–52. (Ita).
Cantonini C J. S-adenosyl-l-methionine: a new intermediate formed enzymatically from L methionine and adenosine triphosphate. J Am Chem Soc. 1952;74:29-42.
Capretto C, Cremona C, Canaparo L. A double-blind controlled study of s-adenosylmethionine (SAMe) v. ibuprofen in gonarthrosis, coxarthrosis and spondylarthrosis. Clin Trials J. 1985;22(1):15-24.
Carney M W P, Edeh J, Bottiglieri T, et al. Affective illness and s-adenosyl methionine: a preliminary report. Clin Neuropharmacol. 1986;9:379-85. [pmid: 2425961].
Carney M W P, Toone B K, Reynolds E H. S-adenosylmethionine and affective disorder. In: Schumacher HR, Moskowitz RW, Fassbender HG, editors. Symposium on osteoarthritis: the clinical picture, pathogenesis, and management with studies on a new therapeutic agent, s-adenosylmethionine, New York, NY, USA, April 29-May 4, 1986. Am J Med. 1987;83(5A):104-6. [pmid: 3318437].
Caroli A. Studio in doppio cieco SAMe (capsule) - Aspirina nell'osteoartrosi [Double-blind study of SAMe (capsules) and aspirin in osteoarthrosis]. G Clin Med 1980 Nov;61(11):844–57. (Ita).
Carrieri P B, Indaco A, Gentile S, et al. S-adenosylmethionine treatment of depression in patients with Parkinson's disease. Curr Ther Res. 1990;48(1):154-60.
Caruso I, Fumagalli M, Boccassini L, et al. Antidepressant activity of s-adenosylmethionine. Lancet. Apr. 1984;V(1):904. [pmid: 6143204].
Caruso I, Fumagalli M, Boccassini L, et al. Treatment of depression in rheumatoid arthritic patients; a comparison of s-adenosylmethionine (samyr) and placebo in a double-blind study. Clin Trials J. 1987;24(4):305-10.
Caruso I, Pietrogrande V. Italian double-blind multicenter study comparing S-adenosylmethionine, naproxen, and placebo in the treatment of degenerative joint disease. Am J Med. Nov. 1987;83(5A):66-71. [pmid: 3318442].
Cerutti PG, Savoini G, D'Avola G, et al. S-adenosilmetionina. Valutazione dell'efficacia della s-adenosil-metionina nel trattamento delle sindromi depressive: studio clinico controllato versus minaprina. Basi Razionali della Terapia 1989;19:591–5. (Ita).
Cerutti R, Sichel M P, Perin M, et al. Psychological distress during puerperium: A novel therapeutic approach using S-adenosylmethionine. Curr Ther Res Clin Exp. 1993;53(6):707-16.
Chavez M. SAMe: s-adenosylmethionine. Am J Health Syst Pharm. Jan. 2000;57:119-23. [pmid: 10688238].
Chawla R K, Bonkovsky H L, Galambos J T. Biochemistry and pharmacology of S-adenosyl-L-methionine and rationale for its use in liver disease. Drugs. 1990;40(suppl 3):98-110. [pmid: 2081485].
Chiang P, Gordon R, Tal J, et al. S-adenosyl-L-methionine and methylation. FASEB J 1996:471–80.
Chinchilla MA, Vega Pinero M, Cebollada Gracia A, et al. Latencia antidepresiva y S-Adenosil-Metionina [Antidepressive latency and S-adenosylmethionine]. Anales de Psiquiatria 1996;12(2):67–71. (Spa).
Cimino L, Dattilo M, Topa M, et al. Prevalence of intrahepatic cholestasis in a series of inpatients with chronic liver disease. J Hepatol. 1989;9:S139.
Clouatre D: All about SAM-e (faqs all about health series). Avery Penguin Putnam; 1999.
Coltorti M, Bortolini M, Di Padova C. A review of the studies on the clinical use of S-Adenosylmethionine (SAMe) for the symptomatic treatment of intrahepatic cholestasis. Methods Find Exp Clin Pharmacol. 1990;12(1):69-78. [pmid: 2179653].
Cook D J, Guyatt G H, Ryan G, et al. Should unpublished data be included in meta-analyses? Current convictions and controversies. JAMA. 1993;269:2749-53. [pmid: 8492400].
Cooney C, Lawren B, McCully K: Methyl magic: maximum health through methylation. Kansas City: Andrews McMeel Publishing; 1999.
Cowley G, Underwood A. What is SAMe? Newsweek; 1999.
Cucinotta D, Mancini M, Ceccato S, et al. Studio clinico controllato sull'attivita della SAMe somministrata per via orale nella patologia degenerativa osteo-articolare [Controlled clinical study of SAMe (S-adenosylmethionine) administered orally in degenerative osteoarticular pathology]. G Clin Med 1980 July;61(7):553–66. (Ita).
Davidson K. Intrahepatic cholestasis of pregnancy. Seminars in Perinatology. 1998;22:104-111. [pmid: 9638904].
De Leo D. S-adenosylmethionine as an antidepressant: double blind trial versus placebo. Curr Ther Res. June. 1987;41:865-70.
Del Vecchio M, Iorio G, Cocorullo M, et al. Has SAMe (Ado-Met) an antidepressant effect? A preliminary trial versus chlorimipramine. Rivista Sperimentale Freniatria. 1978;102:344-58.
Delle Chiaie R, Boissard G. Ademetionine (same) for the treatment of major depression. Meta-analysis of two european multicenter controlled trials. Pharmacol Res. 1997;35(Suppl):108.
Delle Chiaie R, Boissard G. Meta-analysis of 2 European multicenter controlled trials with ademetionine (SAMe) in major depression. Biol Psychiatry. July. 1997;42(suppl 1):245S.
Delle Chiaie R, Pancheri P, Scapicchio P. Mc4: multicentre, controlled efficacy and safety trial of intramuscular s- adenosyl-methionine (same) vs. Oral imipramine in the treatment of depression. International Journal of Neuropsycho pharmacology. July. 2000;3:S230.
Delle Chiaie R, Pancheri P, Scapicchio P. Mc3: multicentre, controlled efficacy and safety trial of oral s-adenosyl- methionine (same) vs. Oral imipramine in the treatment of depression. International Journal of Neuropsycho pharmacology. July. 2000;3:S230.
Depression in Primary Care. Clinical Practice Guideline, Vol. 1. Rockville (MD): U.S. Department of Health and Human Services, Agency for Health Care Policy and Research, 1993.
DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. Sep. 1986;7(3):177-88. [pmid: 3802833].
Di Padova C. S-adenosylmethionine in the treatment of osteoarthritis: Review of the clinical studies. Am J Med. 1987;83(Suppl 5A):60-5. [pmid: 3318441].
Di Padova C, Boissard G, Brunetti G. Ademetionine in the treatment of intrahepatic cholestasis in chronic liver diseases. Factors predicting better response. In: Methionine Metabolism Molecular. Mechanism and Clinical Implications. Proceedings of a workshop held at Sierra Nevada (Granada) on March 3–7, 1996;151–60.
Di Padova C, Giudici A, Boissard G. Ademetionine and depression. In: Mato JM, Caballero A, eds. V Workshop on Methionine Metabolism: Molecular mechanisms and clinical implications. Granada, Spain. Feb. 20–24. 2000;2000:295-9.
Di Palma D, Fiore M, Majoli M, et al. Prime acquisizioni sul trattamento delle epatiti acute con SAMe [First acquirements on the treatment of the acute hepatitis with SAMe]. G Mal Infett Parassit 1978;30(8):651–62. (Ita).
Domljan Z, Vrhovac B, Duerrigl T, et al. A double-blind trial of ademetionine vs. Naproxen in activated gonarthrosis. Int J Clin Pharmacol Ther Toxicol. 1989;27(7):329-33. [pmid: 2674027].
Drivdahl C E, Miser W F. The use of alternative health care by a family practice population. J Am Board Fam Prac. 1998;11:193-9.
Dunner N A, D N A. L. Acute and maintenance treatment of chronic depression. Journal Clin Psychiatry. 2001;62(suppl 6):10-16.
Egbebike JK, Calleja B: Fibromyalgia relief: the SAM-e solution. PTS Publishing Company; 2000.
Egger M, Davey Smith G, Schneider M, et al. Bias in meta-analysis detected by a simple, graphical test. BMJ. Sep. 1997;315(7109):629-34. [pmid: 9310563].
Eisenberg D, Davis R, Ettner S, et al. Trends in alternative medicine use in the United States, 1990-1997: results of a follow up survey. JAMA. 1998;280:1569-75. [pmid: 9820257].
Elders MJ. The increasing impact of arthritis on public health. J Rheumatol 2000;(suppl):60:6–8.
Ezzo J, Hadhazy V, Birch S, et al. Acupuncture for osteoarthritis of the knee: A systematic review. Arthritis & Rheum. 2001;44:819-25. [pmid: 11315921].
Fagan E A. Intrahepatic cholestasis of pregnancy. Clinics in Liver Disease. 1999;3(3):603-32. [pmid: 11291241].
Fava M, Rosenbaum J F, Birnbaum R, et al. The thyrotropin response to thyrotropin-releasing hormone as a predictor of response to treatment in depressed outpatients. Acta Psychiatr Scand. 1992;86:42-5. [pmid: 1414398].
Fazio C, Andreoli V, Agnoli A, et al. Effetti terapeutici e meccanismo d'azione della s-adenosil-l-metionina (SAM) nelle sindromi depressive [French Translation - Effets therapeutiques et mecanisme d'action de las-adenosyl-l-methionine (SAM) dans les syndromes depressifs]. Minerva Med 1973;64(29):1515–29. (Ita).
Felson D T, Lawrence R C, Hochberg M C, et al. Osteoarthritis: new insights, part 2: treatment approaches. Ann Intern Med. 2000;133:726-37. [pmid: 11074906].
Fiaccadori F, Frezza M, Di Padova C. Oral s-adenosylmethionine (SAMe) therapy in cholestatic patients with chronic liver disease: interim analysis of a placebo (P) controlled clinical trial. In: 23rd Meeting of the European Association for the Study of the Liver, Leuven, Belgium, August 25–27, 1988. J Hepatol (Amsterdam). 1988;7(suppl 1):S31.
Finkelstein J D. Homocysteine: A history in progress. Nutr Reviews. 2000;58:193-204.
Flora K, Rosen H R, Benner K G. Letter. Am J Gastroenterology. 1996;91:2654-5.
Floreani A, Paternoster D, Melis A, et al. S-adenosylmethionine versus ursodeoxycholic acid in the treatment of intrahepatic cholestasis of pregnancy: Preliminary results of a controlled trial. Eur J Obstet Gynecol Reprod Biol. Mar. 1996a;67(2):109-13. [pmid: 8841797].
Floreani A, Paternoster D, Melis A, et al. A controlled trial with s-adenosylmethionine versus ursodeoxycholic acid in intrahepatic cholestasis of pregnancy. J Hepatol. Aug. 1996b;25(suppl 1):136.
Frezza M. Metanalisi dei trial terapeutici con ademetionina nel trattamento della colestasi intraepatica [A meta-analysis of therapeutic trials with ademetionine in the treatment of intrahepatic cholestasis]. Ann Ital Med Int 1993 Oct;8(Suppl):48s–51s. (Ita).
Frezza M, Cammareri G, Di Padova C, et al. Beneficial effects of s-adenosylmethionine in pregnant women with cholestasis: results of a multicenter controlled clinical trial. In: 22nd Meeting Of The European Association For The Study Of The Liver, Torino, Italy, September 3–5, 1987. J Hepatol (Amsterdam). 1987;5(suppl 1):S27.
Frezza M, Centini G, Cammareri G, et al. S-adenosylmethionine for the treatment of intrahepatic cholestasis of pregnancy. Results of a controlled clinical trial. Hepatogastroenterology. 1990;37(suppl 2):122-5. [pmid: 2083923].
Frezza M, Di Padova C. Italian Study Group for SAMe in Liver Disease. Multicenter placebo controlled clinical trial of intravenous and oral s-adenosylmethionine same in cholestatic patients with liver disease. 38th Annual Meeting of the American Association for fhe Study of Liver Diseases, Chicago, Illinois, USA, October 25–28, 1987. Hepatology (Baltimore). 1987;7(5):1105. [pmcid: 64644].
Frezza M, Pozzato G, Chiesa L, et al. Reversal of intrahepatic cholestasis of pregnancy in women after high dose S-adenosyl-L-methionine administration. Hepatology 1984 Mar.-1984 Apr. 30;4(2):274–8.
Frezza M, Pozzato G, Pison G, et al. S-adenosylmethionine counteracts oral contraceptive hepatotoxicity in women. Am J Med Sci. 1987;293(4):234-8.
Frezza M, Surrenti C, Manzillo G, et al. Oral S-adenosylmethionine in the symptomatic treatment of intrahepatic cholestasis. A double-blind, placebo-controlled study. Gastroenterology. 1990;99(1):211-5. [pmid: 2188871].
Frezza M, Terpin M. Use of s-adenosyl-l-methionine in the treatment of cholestatic disorders: meta-analysis of clinical trials. Drug Investigation (New Zealand). 1992;4(suppl 4):101-8. [pmcid: 400670].
Friedel H A, Goa K L, Benfield P. S-adenosyl-L-methionine. A review of its pharmacological properties and therapeutic potential in liver dysfunction and affective disorders in relation to its physiological role in cell metabolism. Drugs. 1989;38(3):389-416. [pmid: 2680435].
Gaster B, Holroyd J. St. John's wort for depression: A systemic review. Nutr Reviews. 2000;58:193-204.
Gentile S, Persico M, Russo F S, et al. S-adenosylmethionine (SAMe) improves bilirubin handling in cirrhotic patients. Eur J Clin Invest. 1990;20(22):A8.
Giuldori P, Cortello M, Moreo G, et al. Pharmacokinetics of S-adenosymethionine in healthy volunteers. Eur J Clin Pharmacol. 1984;27:119-21. [pmid: 6489422].
Glorioso S, Todesco S, Mazzi A, et al. Double-blind multicentre study of the activity of S-adenosylmethionine in hip and knee osteoarthritis. Int J Clin Pharmacol Res. 1985;5(1):39-49. [pmid: 3888864].
Goodman JG, Gilman LE, eds. The Pharmacological Basis of Therapeutics, Ninth edition, New York: McGraw-Hill; 1996.
Grazi S, Costa M. SAMe (S-adenosyl-methionine): The European Arthritis and Depression Breakthrough. Rocklin, CA: Prima Publishing; 1999.
Greenberg P E, Stiglin L E, Finkelstien S N, et al. The economic burden of depression in 1990. J Clin Psychiatry. 1993;54:405-19. [pmid: 8270583].
Harmand M - F, Vilamitjana J, Maloche E, et al. Effects of S-adenosylmethionine on human articular chondrocyte differentiation: An in vitro study. Am J Medicine. 1987;83(Suppl 5A):48-54.
Hedges LV, Olkin I. Statistical Methods for Meta-Analysis. San Diego, CA: Academic Press, Inc.; 1985.
Hooper C L, Bakish D. An examination of the sensitivity of the six item Hamilton Rating Scale for Depression in a sample of patients suffering from major depressive disorder. Journal of Psychiatry and Neuroscience. 2000;25(2):178-84. [pmid: 10740991].
Horowitz S. SAMe for depression, arthritis, cirrhosis, and other disorders. Alternative & Complementary Therapies (England). Oct. 1999;5:266-70. [pmcid: 117436].
Hyman SE, Rudorfer MV. Depressive and Bipolar Mood Disorders. New York:Healtheon/Web MD; 2000.
Ideo G. S-adenosilmetionina: livelli plasmatici nella cirrosi epatica e primi risultati sul suo impiego clinico in epatologia. Studio in doppio cieco [S-Adenosylmethionine: plasma levels in hepatic cirrhosis and preliminary results of its clinical use in hepatology. Double-blind study]. Minerva Med 1975 May;66(33):1571–80. (Ita).
Information PC, 2000.
Ioannidis J P, Cappelleri J C, Lau J, et al. Early or deferred zidovudine therapy in HIV-infected patients without an AIDS-defining illness. Ann Intern Med. Jun. 1995;122(11):856-66. [pmid: 7741372].
Jadad A R, Moore R A, Carroll D, et al. Assessing the quality of reports of randomized clinical trials: is blinding necessary?. Control Clin Trials. 1996;17(1):1-12. [pmid: 8721797].
Janicak P G, Lipinski J, Davis J M, et al. S-Adenosylmethionine in depression: a literature review and preliminary report. Alabama J Med Sci. 1988;25:306-13.
Janicak P G, Lipinski J, Davis J M, et al. Parenteral S-adenosyl-methionine (SAMe) in depression: literature review and preliminary data. Psychopharmacology Bulletin. 1989;25(2):238-42. [pmid: 2690166].
Jellin JM, Batz F, Hitchens K. Pharmacit's letter/prescriber's letter: Natural Medicines Comprehensive Database. Stockton, CA: Therapeutic Research Facility; 2001.
Jorge AD. Accion terapeutica de la SAMe en hepatitis aguda [Therapeutic action of the S-adenosyl-L-methionine in acute hepatitis]. Prensa Med Argent 1985;72(11):373–379. (Spa).
Kagan BL, Sultzer D, Rosenlicht N, et al. Antidepressant Effect of Oral S-adenosyl-methionine. In: Stefanis et al., eds. Psychiatry: A World Perspective. Amsterdam: Elsevier Science B.V.; 1990, p. 428–33.
Kagan B L, Sultzer D L, Rosenlicht N, et al. Oral S-adenosylmethionine in depression: a randomized, double-blind, placebo-controlled trial. Am J Psychiatry. 1990;147(5):591-5. [pmid: 2183633].
Kaye G L, Blake J C, Burroughs A K. Metabolism of exogenous S-adenosyl-L-methionine in patients with liver disease. Drugs. 1990;40(suppl 3):124-8. [pmid: 2081477].
Konig B. A long-term (two years) clinical trial with S-adenosylmethionine for the treatment of osteoarthritis. Am J Med. Nov. 1987;83(5A):89-94. [pmid: 3318447].
Kufferle B, Grunberger J. Early clinical double-blind study with S-Adenosyl-l-methionine: a new potential antidepressant. In: Costa E, Racagni G (Eds.): Typical and Atypical Antidepressants: Clinical Practice. New York: Raven Press; 1982, p. 175–80.
Kupfer D J, Frank E, Perel J M, et al. Five-year outcome for maintenance therapies in recurrent depression. Arch of Gen Psychiatry. 1992;149:999-1010.
Labo G, Gasbarrini GB. Attivita terapeutiche della solfo-adenosilmetionina in alcune epatopatie croniche. [Therapeutic action of S-adenosylmethionine in some chronic hepatopathies]. Minerva Med 1975 May;66(33):1563–70. (Ita).
Lafuenti G, Plotti G, Nicolanti G, et al. Valutazione del rischio ostetrico in gravide con colestasi intraepatica in terapia con S-adenosyl-L-methionine [Evaluation of the obstetrical risk in pregnant women with intrahepatic cholestasis treated with S-adenosyl-L-methionine]. Recenti Prog Med 1988 Oct;79(10):420–3. (Ita).
Lawrence R C, Hochberg M C, Kelsey J L, et al. Estimates of the prevalence of selected arthritic and musculoskeletal diseases in the United States. J Rheumatol. 1989;16(4):427-41. [pmid: 2746583].
Lewis L J. A consumer perspective of diagnosis and treatment of chronic major depression. J Clin Psychiatry. 2001;62(suppl 6):30-4. [pmid: 11310817].
Lieber C S, Casini A, DeCarli L M, et al. S-adenosyl-L-methionine attenuates alcohol-induced liver injury in the baboon. Hepatology. 1990;11:165-72. [pmid: 2307395].
Linde K, Mulrow CD. St. John's wort for depression. Cochrane Database of Systematic Reviews 1999;4.
Linde K, Ramirez G, Mulrow C D, et al. St John's wort for depression--an overview and meta-analysis of randomized clinical trials. BMJ. 1996;313:253-8. [pmid: 8704532].
Loehrer F, Schwab R, Angst C, et al. Influence of oral S-adenosylmethionine on plasma 5-methyltetrahydrofolate, S-adenosylhomocysteine, homocysteine and methionine in healthy humans. J Pharmacology & Experimental Therapeutics. 1997;282:845-50.
Loguercio C, Del Vecchio Blanco C, Coltorti M. Effects of intravenous s-adenosyl-methionine (SAMe) on red blood cell content of glutathione and cysteine in alcoholic cirrhosis. Gastroenterology. 1993;104(suppl 4):A944.
Long L, Socken K, Ernst E. Herbal medicines for the treatment of osteoarthritis: A systematic review. Rheumatology. 2001;40:779-93. [pmcid: 120256].
Lo Russo A, Monaco M, Pani A, et al. Efficacy of s-adenosyl-l-methionine in relieving psychologic distress associated with detoxification in opiate users. Curr Ther Res. 1994;55(8):905-13.
Lu S C. S-adenosylmethionine. Int J Biochem & Cell Biology. 2000;32:391-5.
Maccagno A, Di Giorgio E, Caston O L, et al. Double-blind controlled clinical trial of oral S-adenosylmethionine versus piroxicam in knee osteoarthritis. Am J Med. Nov. 1987;83(5A):72-7. [pmid: 3318443].
Mantero M, Pastorino P, Carolei A, et al. Studio controllato in doppio cieco (SAMe-Imipramina) nelle sindromi depressive. Minerva Med 1975;66:4098–101. (Ita).
Manzillo G, Fiaccadori F, Frezza M, et al. Results of a placebo (P) controlled clinical trial with oral s-adenosylmethionine (SAMe) in cholestatic patients with chronic liver disease. In: 39th Annual Meeting and Postgraduate Course of the American Association for the Study of Liver Diseases, Chicago, Illinois, USA, November 5–8, 1988. Hepatology (Baltimore). 1988;8(5):1265. [pmcid: 64644].
Manzillo G, Frezza M, Fiaccadori F, et al. Symptomatic improvement of intrahepatic cholestasis after oral s-adenosylmethionine (SAMe) final results of a double-blind placebo controlled trial. In: 24th Meeting of the European Association for the Study of The Liver, Munich, West Germany, August 30-September 2, 1989. J Hepatol (Amsterdam). 1989;9(suppl 1):S188.
Manzillo G, Piccinino F, Surrenti C, et al. Multicentre double-blind placebo-controlled study of intravenous and oral s-adenosyl-l-methionine (SAMe) in cholestatic patients with liver disease. Drug Invest. 1992;4(suppl 4):90-100.
Marchesini G, Bugianesi E, Bianchi G, et al. Effect of S-adenosyl-L-methionine administration on plasma levels of sulphur-containing amino acids in patients with liver cirrhosis. Clin Nutr. 1992;11:303-8. [pmid: 16840013].
Marcolongo N, Giordano N, Colombo B, et al. Double-blind multicentre study of the activity of s-adenosyl-methionine in hip and knee osteoarthritis. Curr Ther Res. 1985;37(1):82-94.
Mascio G, Guida L, Ferbo U, et al. Trattamento della steatosi epatica pura o associata ad altre epatopatie. Risultati di una sperimentazione clinica controllata: solfo-adenosil-metionina (SAMe) versus fosfatidilcolina (PC) [Treatment of liver steatosis in pure form and associated with other liver diseases. Results of a controlled clinical experiment: Sulpho-adenosyl-methionine (SAMe) versus phosphatidylcholine (PC)]. Gazz Med Ital 1981;140(1–2):37–44. (Ita).
Mato J M, Alvarez L, Ortiz P, et al. S-adenosylmethionine synthesis: Molecular mechanisms and clinical implications. Pharmacol Ther. 1997;73(3):265-80. [pmid: 9175157].
Mato J M, Camara J, De Paz J F, et al. S-Adenosylmethionine in alcoholic liver cirrhosis: a randomized, placebo-controlled, double-blind, multicenter clinical trial. J Hepatol. 1999;30(6):1081-9. [pmid: 10406187].
McGill J M, Kwiatkowski A P. Cholestatic liver disease in adults. Am J Gastroenterol. 1998;93:684-91. [pmid: 9625109].
Micali M, Chiti D, Balestra V. Double-blind controlled clinical trial of SAMe administered orally in chronic liver diseases. Curr Ther Res Clin Exp. 1983;33(6 I):1004-13.
Miccoli L, Porro V, Bertolino A. Comparison between the antidepressant activity of S-adenosyl-l-methionine (SAMe) and that of some tricyclic drugs. Acta Neurol (Napoli). 1978;33:243-55. [pmcid: 397589]. [pmid: 371351].
Miglio F, Stefanini G, Corazza GR, et al. Sperimentazione in doppio cieco sull'attività terapeutica della SAMe, somministrata per os, nelle cirrosi epatiche ed in altre epatiti croniche [Double-blind studies of the therapeutic action of S-Adenosylmethionine (SAMe) in oral administration, in liver cirrhosis and other chronic hepatitis]. Minerva Med 1975 May;66(33):1595–9. (Ita).
Milliman W B, Samson D E, Brignall M S. Hepatitis C: A retrospective study, literature review, and naturopathic protocol. Alter Med Review. 2000;5:355-71.
Mitchell D. The SAM-e solution. New York, NY: Warner Books; 1999.
Moher D, Pham B, Jones A, et al. Does quality of reports of randomised trials affect estimates of intervention efficacy reported in meta-analyses?. Lancet. 1998;352(9128):609-13. [pmid: 9746022].
Monaco P, Quattrocchi F. Studio degli effetti antidepressivi di un transmetilante biologico (S-adenosil-metionina-SAMe). Riv Neurol 1979;49:417–39. (Ita).
Montrone F, Fumagalli M, Sarzi Puttini P, et al. Double blind study of s-adenosyl-methionine versus placebo in hip and knee arthrosis. Clin Rheumatol. Dec. 1985;4(4):484-5. [pmid: 3913558].
Moreno J, Ortiz P. Actividad antidepresiva de la S-adenosilmetionina (SAMe) [Antidepressive effect of S-adenosylmethionine(SAMe)]. Psiquis 1991;12(2):49–51. (Spa).
Moskowitz R W. Primary osteoarthritis: epidemiology, clinical aspects, and general management. Am J Med. 1987;83(suppl 5A):5-10. [pmid: 3318440].
Muller-Fassbender H. Double-blind clinical trial of S-adenosylmethionine versus ibuprofen in the treatment of osteoarthritis. Am J Med. Nov. 1987;83(5A):81-3. [pmid: 3318445].
Mulrow C, Lawrence V, Jacobs B, et al. Milk Thistle: Effects on Liver Disease and Cirrhosis and Clinical Adverse Effects. Evidence Report/Technology Assessment No. 21. Rockville (MD): Agency for Health Care Research and Quality, U.S. Department of Health and Human Services; 2000 Oct. AHRQ Publication No. 01-E025.
Murray CJL, Lopez AD, eds. The Global Burden of Disease: A Comprehensive Assessment of Mortality and Disability from Diseases, Injuries and Risk Factors in 1990 projected to 2020. Cambridge, Mass: Harvard University Press; 1996.
Muscettola G, Galzenati M, Balbi A. SAMe versus placebo: a double blind comparison in major depressive disorders. In: Costa E, Racagni G, eds. Typical and Atypical Antidepressants: Clinical Practice. New York: Raven Press; 1982. p. 151–6.
Musso A, Giacchino M, Vietti M, et al. Considerazioni sull'uso della Silimarina e della SAMe nel trattamento dell'epatite infettiva acuta dell'infanzia [The use of silymarin and SAMe in the treatment of acute infective hepatitis in childhood]. Minerva Pediatr 1980 Sept;32(17):1057–67. (Ita).
National Institute of Mental Health: Depression, 2000. NIMH Publication No. 00–3561.
Nicastri P, Diaferia A, Tartagni M, et al. A randomised placebo-controlled trial of ursodeoxycholic acid and S-adenosylmethionine in the treatment of intrahepatic cholestasis of pregnancy. Br J Obstet Gynaecol. Nov. 1998;105(11):1205-7. [pmid: 9853771].
Nierenberg A A. Long-term management of chronic depression. J Clin Psychiatry. 2001;62(suppl 6):17-21.
O'Donohue J W, Wendon J A, Williams R. S-adenosyl-l-methionine (SAM-e) in the treatment of cholestasis following acute liver failure: a randomised, controlled trial. Gastroenterology. May. 1996;110(suppl 4):A1282.
Ofman JJ, MacLean CH, Straus WL, Morton S, Berger ML, Roth EA, Shekelle PG. A meta-analysis of dyspepsia and nonsteroidal anti-inflammatory drugs. Unpublished report, RAND, 2001, Santa Monica CA.
Osman E, Owen J. S., Burroughs A.K. Review article: S-adenosyl-l-methionine - A new therapeutic agent in liver disease?. Aliment Pharmacol Ther. 1993;7(1):21-8. [pmid: 8439634].
Palmer D G. Eads J. Intrahepatic cholestasis of pregnancy: a critical review. Journal of Perinatal & Neonatal Nursing. 2000;14(1):39-51. [pmid: 11249293].
Pecoraro V, Bruno M, Giammona R. L'impiego terapeutico della SAMe (s-adenosil-l-metionina) nella epatite virale acuta [Therapy with SAMe (s-adenosyl-l-methionine) in acute viral hepatitis]. G Mal Infett Parassit 1979;31(6):390–4. (Ita).
Persico M, Gentile S, Di Padova C, et al. S-Adenosylmethionine (SAMe)-induced improvement of hepatic handling of organic anions in cirrhosis. Gastroenterology. 1990;98(52):A620.
Piccinino F, Sagnelli E, Pasquale G, et al. S-adenosyl-methionine in patients with chronic active hepatitis treated with steroids. Ital J Gastroenterol. 1982;14(3):186-187.
Pincus H A, Pettit A R. The societal costs of chronic major depression. J Clini Psychiatry. 2001;62(suppl 6):5-9.
Polli E, Cortellaro M, Parrini L, et al. Aspetti farmacologici e clinici della solfo-adenosil-metionina (SAMe) nella artropatia degenerativa primaria (osteoartrosi) [Pharmacological and clinical aspects of S-adenosylmethionine (SAMe) in primary degenerative arthropathy (osteoarthrosis)]. Minerva Med 1975 Dec;66(83):4443–59. (Ita).
Pons Villegas J. Efecto de la SAMe en pacientes alcoholicos [Effect of SAMe on alcoholic patients]. Actas Luso-Esp Neurol Psiquiatr 1983;11(2):385–9. (Spa).
Potkin S G, Bell K M. S-adenosylmethionine: overview of clinical and pharmacological effects. Psychopharmacology (Berlin). 1988;96(Suppl):69. [pmcid: 161672].
Potkin S G, Bell K, Plan L, et al. Rapid antidepressant response with SAMe - A double blind study. Ala J Med Sci. 1988;25(3):313-6. [pmid: 3052140].
Qin B, Guo S, Zhao Y, et al. A trial of ademetionine in the treatment of intrahepatic biliary stasis viral hepatitis. Zhonghua Gan Zang Bing Za Zhi. June. 2000;8(3):158-60. [pmid: 10880165].
Raidford D S. Pruritus of chronic cholestasis. QJM. 1995;88:603-607. [pmid: 7583073].
Ramsey S, Spencer A, Topoloski T, et al. Use of alternative therapies in older adults with osteoarthritis. Arthritis Care Res. 2001;45:222-7.
Ribalta J, Reyes H, Gonzalez M C, et al. S-adenosyl-L-methionine in the treatment of patients with intrahepatic cholestasis of pregnancy: A randomized, double-blind, placebo-controlled study with negative results. Hepatology. 1991;13(6):1084-9. [pmid: 2050326].
Rivera C S, Perez C R, Cao E S, et al. Use of three depression scales for evaluation of pretreatment severity and of improvement after treatment. Psychol Rep. 2000;87(2):389-94. [pmid: 11086582].
Roncaglia N, Locatelli A, Bellini P, et al. A randomized controlled trial of ursodeoxycholic acid and S-adenosyl-L-methionine in the treatment of gestational cholestasis. Am J Obstet Gynecol. 2000;182(12):S167.
Rosenlicht N Z, Kagan B L, Sultzer D L, et al. Oral s-adenosyl-methionine as an antidepressant. J Clin Pharmacol. 1989;29(9):839.
Rosenthal R. Meta-Analytic Procedures for Social Research. Newbury Park, CA: Sage Publications; 1991.
Salen G, Batta A K. Bile acids abnormalities in cholestatic liver diseases. Gastrol Clin. 1999;28:173-93.
Salmaggi P, Bressa G M, Nicchia G, et al. Double-blind, placebo-controlled study of s-adenosyl-l-methionine in depressed postmenopausal women. Psychotherapy & Psychosomatics. 1993;59(1):34-40. [pmid: 8441793].
Scaggion G, Baldan L, Domanin S, et al. Azione antidepressiva della SAMe a confronto con il nomifensine maleato. Minerva Psichiatr 1982;23:93–7. (Ita).
Scarzella R, Appiotti A. Confronto clinico in doppio cieco della SAMe versus clorimipramina nelle sindromi depressive. Rivista Sperimentale Freniatria 1978;102:359–65. (Ita).
Schifano F, Garofoli F. Dothiepin vs. S-adenosylmethionine (SAMe) for the treatment of major depression in weaned alcoholics: A pilot study. Eur Neuropsychopharmacol. 1993;3(3):330.
Schultz K F, Chalmers I, Hayes R J, et al. Dimensions of methodological quality associated with estimates of treatment effects in controlled trials. JAMA. 1995;273:408-12. [pmid: 7823387].
Schumacher H R. Osteoarthritis: the clinical picture, pathogenesis, and management with studies on a new therapeutic agent, S-adenosylmethionine. In Schumacher HR, Moskowitz RW, Fassbender H, eds, Symposium on Osteoarthritis: the Clinical Picture, Pathogenesis, and Management, with Studies on a New Therapeutic Agent, S-adenosylmethionine, April 29-May 4, 1986, New York, NY, USA. Am J Med. Nov. 1987;83(5A):1-4.
Selhub J, Miller J W. The pathogenesis of homocysteinemia: interruption of the coordinate regulation by S-adenosylmethionine of the remethylation and transsulfuration of homocysteine. Am J Clin Nutr. 1992;55:131-8. [pmid: 1728812].
Sherlock S, Dooley J. Diseases of the Liver and Biliary System, 10th ed. Oxford: Blackwell Science; 1997.
Stata Statistical Software: Release 6.0 [computer program]. Version 6.0. College Station, TX: Stata Corporation; 1999.
Stedman N: The SAM-e Handbook: The Fast, Natural Way to Relieve the Pain of Arthritis, Alleviate the Discomfort of Fibromyalgia, and Boost Your Energy. Three Rivers Publisher; 2000.
Stramentinoli G. Pharmacologic aspects of S-adenosylmethionine. Pharmacokinetics and pharmacodynamics. Am J Med. 1987;83:35-42. [pmid: 3318439].
Stramentinoli G, Catto E. Pharmacokinetic studies of SAMe in several animal species. Pharmacol Res Com. 1976;8:211-8.
Stramentinoli G, Pezzoli C, Galli-Kienle M. Intestinal absorption of S-adenosyl-l-methionine. J Pharmacol Exp Ther. 1979;209:323-36. [pmid: 439007].
Tambini R, Fracassetti O, Minola E, et al. S-adenosyl-l-methionine in the treatment of intrahepatic cholestasis of pregnancy: preliminary results of a meta-analysis study. J Hepatol. Apr. 1997;26(suppl 1):168.
Thase N A, ME N A, Sullivan L R. Relapse and recurrence of depression: a practical approach for prevention. CNS Drugs. 1995;4:261-277.
Thomas C S, Bottiglieri T, Edeh J, et al. The influence of s-adenosylmethionine (SAM) on prolactin in depressed patients. Int Clin Psychoparmacol. 1987;2:97-102.
Tramoni AV, Azorin JM. Indications thérapeutiques de la S-adénosyl méthionine (SAMe) en neuro-psychiatrie [Therapeutic aspects of S-adenosyl methionine(SAMe) in neuropsychiatry]. Encephale 1988;14(3):113–8. (Fre).
Trespi E, Vigoni R, Matti C, et al. TUDCA UDCA and ademetionine (Ade) in the treatment of alcohol-induced liver damage. J Hepatol. 1997;26(suppl):128.
Vanna M, Rigamonti R. Oral s-adenosyl-l-methionine in depression. Curr Ther Res. 1992;52(3):478-85.
Vendemiale G, Altomare B, Trizio T, et al. Effect of S-adenosyl-l-methionine on hepatic glutathione in patients with liver injury. Dig Dis Sci. 1986;31(suppl 10):92S.
Vendemiale G, Altomare E, Trizio T, et al. Effects of oral S-adenosyl-L-methionine on hepatic glutathione in patients with liver disease. Scand J Gastroenterol. 1989;24:407-15. [pmid: 2781235].
Vetter G. Double-blind comparative clinical trial with S-adenosylmethionine and indomethacin in the treatment of osteoarthritis. Am J Med. Nov. 1987;83(5A):78-80. [pmid: 3318444].
Wagner P J, Jester D, LeClaire B, et al. Taking the edge off: why patients choose St. Johns Wort. J Fam Pract. 1999;48:615-9. [pmid: 10496640].
Williams Obstetrics, 21st Ed. (2001), International Edition; New York: McGraw-Hill Medical Publishing Division; 2001.
Wong T, Tredger J M, Wendon J, et al. Double-blind, randomized trial of S-adenosylmethionine in orthotopic liver transplantation. Gastroenterology. 1998;114(42):A1366.
Yousef I M, Barnwell S G, Tuchweber B, et al. Effect of complete sulfation of bile acids on bile formation in rats. Hepatology. 1987;7(3):535-42. [pmid: 3570165].