# Conclusions

This evidence report assesses the evidence for the efficacy of SAMe as a treatment for three different disease conditions: depression, osteoarthritis, and cholestasis resulting from liver disease.

## Availability Of Study Reports

The body of relevant literature we identified was large, particularly for a CAM intervention, and the literature included a large number of controlled clinical trials. A significant proportion of these reports were published in non-English-language journals: for example, approximately one-fourth of the reports were in Italian. Most of the study reports were published in peer-reviewed literature and were available through traditional online library databases, but some reports could not be obtained, particularly those that were unpublished.

## Study Design

We are able to draw the following conclusions with regard to the study designs of the studies we included in our analyses:

- Interventions using SAMe were very heterogeneous with respect to both route of administration and dosage.
- Most studies enrolled small numbers of patients.
- The quality of the studies varied greatly, as judged by the Jadad criteria.
- Study populations also displayed considerable variability, especially those enrolled in liver disease studies.
- An adequate number of studies with sufficiently homogeneous outcomes and disease states was available to permit meta-analyses of the efficacy of SAMe for the treatment of depression and osteoarthritis. Despite the heterogeneity in the liver studies, sufficient numbers of studies with homogeneous outcomes were identified for cholestasis of pregnancy and intrahepatic cholestasis associated with liver disease to permit analysis.
- Studies of the effects of SAMe on a variety of other liver diseases were too heterogeneous with respect to disease state and/or outcomes to permit pooled analysis.
- The majority of studies included information on side effects, but in general, this information was not collected in a consistent or systematic way.

## The Use Of SAMe For The Treatment Of Depression

The data we analyzed in our review support the following conclusions regarding the use of SAMe for the treatment of depression:

- SAMe is likely more effective than placebo for relief of symptoms of depression.
- Compared to treatment with conventional antidepressant pharmacology, treatment with SAMe was not associated with a statistically significant difference in outcomes.

Possible publication bias was identified that may temper the strength of the conclusions we report.

## The Use Of SAMe For The Treatment Of Osteoarthritis

The data in our review support the following conclusions regarding the use of SAMe for the relief of pain due to osteoarthritis:

- A single large RCT reported SAMe to be more efficacious than placebo in relief of pain.
- Compared to treatment with nonsteroidal anti-inflammatory medication, treatment with SAMe was not associated with a statistically significant difference in outcomes.

## The Use Of SAMe For The Treatment Of Cholestasis

### Cholestasis Of Pregnancy

The data in our review support the following conclusions regarding the use of SAMe for the treatment of cholestasis of pregnancy:

- SAMe is likely more effective than placebo in reducing pruritus and bilirubin in women with cholestasis of pregnancy.
- SAMe appears no better than and may actually be worse than ursodeoxycholic acid, the conventional treatment for reducing pruritus and bilirubin in women with cholestasis of pregnancy.

### Intrahepatic Cholestasis Associated With Liver Disease

The data in our review support the following conclusions regarding the use of SAMe for the treatment of intrahepatic cholestasis associated with liver disease:

- SAMe is more efficacious than placebo in reducing pruritus and serum bilirubin in patients with intrahepatic cholestasis associated with liver disease.
- Because of an insufficient number of studies, no conclusions can be drawn about the efficacy of SAMe compared to conventional therapy in treating pruritus and bilirubin in patients with intrahepatic cholestasis associated with liver disease.

## Future Research

Additional studies are needed to assess fully the efficacy and safety of SAMe for treatment of depression, OA, and cholestasis. These studies should include review studies, those elucidating the pharmacology of SAMe, and clinical trials.

Further analysis of the literature on SAMe is indicated. For example, as mentioned, the cost-effectiveness, tolerability, and side-effect profile of SAMe may become clinically significant if SAMe is found to be equally as effective as conventional therapy. An additional review could focus on this topic. A further review of the literature could also be undertaken to determine if sufficient data exist to support the use of SAMe for any other disease states, such as fibromyalgia, but is not likely to produce stronger evidence than we found for the conditions studied.

The pharmacology of SAMe, especially that of the newer oral dosage forms, has not been well elucidated. Good dose escalation studies have not been performed using the oral formulation of SAMe for depression, osteoarthritis, or liver disease. Given the present state of knowledge, it would be difficult to design a large clinical trial with confidence that the best dosage form, amount, and route of administration have been chosen.

Once these issues have been settled, larger, multisite clinical trials are indicated for the use of SAMe for depression, osteoarthritis, and cholestasis. These trials need to enroll large numbers of patients with homogeneous diagnoses and clinically- relevant outcomes. The first such large multicenter trial should be undertaken for depression rather than for cholestasis. The largest number of clinical studies identified here assessed the effects of SAMe on depression, and a robust effect size for SAMe was demonstrated. Consideration should be given to testing SAMe not only against placebo but also against current standard therapy such as a selective serotonin reuptake inhibitor.

For liver disease other than cholestasis, additional smaller trials should be conducted to ascertain which patient populations would benefit most from SAMe and to identify the most effective interventions. Study populations should be more homogeneous with respect to diagnosis and disease stage to allow more specific conclusions regarding efficacy to be drawn. Clinical populations to consider for further investigation include viral hepatitis patients, particularly those with chronic active or chronic persistent viral hepatitis, as well as hepatitis C patients who have failed or refused conventional therapy and patients with cirrhosis. Additional populations of interest could include patients with acute alcoholic hepatitis, acute viral hepatitis, or drug-induced viral hepatitis. Special attention should be paid to the relative rates of side effects or adverse drug events in SAMe versus NSAIDs or aspirin.

For osteoarthritis, clinical trials should be performed rigorously using techniques standard to conventional drug research. Such standards would include inclusion criteria that are tighter than those currently in use and based on radiographic findings, standardized pain and function scales, as well as serial radiographic examination to assess whether SAMe affects disease progression.

Additional smaller clinical trials of an exploratory nature should be conducted to investigate other uses of SAMe. Such uses might include decreasing the latency of conventional antidepressants, treating postpartum depression, and treating fibromyalgia, or treating depression associated with a variety of chronic medical conditions. Any large clinical trial, especially one that compares SAMe to conventional therapy, should include a systematic assessment of side effects or adverse drug events. It would be difficult in anything but very large clinical trials to discriminate a difference in rates of rare events, such as gastrointestinal bleeding, but care should be taken to record such events when they do occur. All future studies should provide full disclosure regarding support, provision of product, and author affiliation, especially with manufacturers of SAMe.