# Results

## Description Of Evidence

We accepted 102 studies from the screening process and reviewed them for further analysis. Of those 102 studies, 47 focused on SAMe for the treatment of depression, 14 focused on the treatment of osteoarthritis, and 41 focused on the treatment of a variety of liver diseases. The details of these studies are presented in the evidence table located at the end of this report.

## Analysis Of Depression Studies

In order to perform meta-analyses of the studies that involved the use of SAMe for depression, we needed to identify clinically homogeneous and relevant follow-up times and outcomes across studies. Three different outcome measurements involving the Hamilton Rating Scale for Depression (HRSD) were identified as the most clinically relevant and frequently occurring outcome measures. The first measure was a risk ratio comparing the proportion of patients in the comparison group (e.g., placebo or other active drug) who had at least a 25 percent improvement in the HRSD (that is, at least a 25 percent drop in the HRSD measure at follow-up) with the proportion of patients in the SAMe group who exhibited the same outcome. A risk ratio of less than 1.0 indicates that a higher proportion of responders is associated with the use of SAMe. The second outcome measure was the risk ratio for the proportion of patients who had at least a 50 percent improvement in the HRSD score. The third outcome measure was an effect size for the continuous HRSD score. Therefore, risk ratios of less than 1.0 and effect sizes less than 0 favor treatment with SAMe.

A small number of studies did not report results using the HRSD. The equivalency of other available measurements of depression was considered. A high correlation has been demonstrated between the HRSD and the Zung Self-rating Depression Scale (ZSDS) (Biggs, Wylie, and Ziegler, 1978). A similar correlation was not reliably found between the Beck Depression Inventory (BDI) and the HRSD (Bailey and Coppen, 1976). Strong correlation is reported between the HRSD and the Montgomery-Asberg Scale (Hooper and Bakish, 2000; Riverera, Perez, Cao, et al., 2000). Therefore, if a study did not report an HRSD score as an outcome, a ZSDS score or a score on the Montgomery-Asberg Scale was considered appropriate for the analysis.

Ideally, we would have wanted to assess these outcomes at two different time points. First, we would have assessed the therapy's short-term results at about three to four weeks after subjects started therapy. Second, we would have assessed the durability of the therapy by studying results several months later. However, we could only analyze the data that were presented in the studies, most of which measured only short-term outcomes. Therefore, we were limited in this meta-analysis to assessing outcomes closest in time to 21 days after the subjects started therapy.

### Study Inclusion/Exclusion For The Depression Outcomes

We considered 47 studies for inclusion in the depression meta-analysis. All studies had two arms except for one that had three. Studies could be excluded if they represented data duplicated by another included study, could not be obtained, did not have an appropriate outcome measure, or were not clinically similar enough to be included in the analysis.

Five studies (Agnoli, Fazio, Andreoli, et al., 1975; Caruso, Fumagalli, Boccassini, et al., 1984; Salmaggi, Bressa, Nicchia, et al., 1991; Rosenlicht, Kagan, Sultzer, et al., 1989; Kagan, Sultzer, Rosenlicht, et al., 1990) were excluded from the meta-analysis because they contained data also contained in other studies (Agnoli, Andreoli, and Casacchia, 1976; Caruso, Fumagalli, Boccassini, et al., 1987; Salmaggi, Bressa, Nicchia, et al., 1993; Kagan, Sultzer, Rosenlicht, et al., 1990 respectively). Two studies (Bell and Potkin, 1988; Potkin, Bell, Plan, et al., 1988) contained the same data as a single other study (Bell, Plon, Burney, et al., 1988) that was included in the analysis. Another study (Bell, 1990) could not be obtained and so could not be included in the analysis.

Eleven additional studies that were considered for inclusion in the meta-analysis were also excluded. Two studies (Ceruti, Sichel, Perin, et al., 1993; Pons-Villegas, 1983) did not contain data on a relevant outcome. Six studies (Agnoli, Andreoli, and Casacchia, 1976; Barberi, and Pusateri, 1978; Schifano and Garoli, 1993; Fazio, Andreoli, and Agnoli, 1973; Delle Chiaie, Pancheri and Scapicchio, 2000a; and Delle Chiaie, Pancheri and Scapicchio, 2000b) were excluded because they did not include sufficient statistics for the calculations to be performed. The remaining studies involved clinical situations that we did not judge to be appropriate for a pooled analysis. Two studies (Chinchilla, Moreno, Piñero, et al., 1996; Berlanga, Ortega-Solo, Onitveros, et al., 1992) were excluded because they studied the effects of SAMe on the onset of action of a conventional antidepressant medication and thus were not considered clinically comparable to the other studies. A third study (Lo Russo, Monaco, Pani, et al., 1994) involved the treatment of depressive symptoms in patients undergoing opiate detoxification.

Studies excluded from the meta-analysis but presented in the evidence table will be discussed following the presentation of the meta-analysis results.

### Meta-Analysis For Depression

Twenty-eight studies were included in the meta-analysis. Ten studies were included in all three analyses, that is, the risk ratio and the effect size analyses. Fourteen studies were included in the effect size analysis only. Two were included in the risk ratio analyses only. One study was included in the effect size and a single risk ratio (greater than 25 percent improvement) analyses; and the final one was included only in the risk ratio greater than 50 percent improvement analysis.

#### Calculations For Depression

Two studies within the same article (Di Padova, Giudici, and Boissard, 2000) did not report standard deviations, so we imputed standard deviations using a simple average across all arms that measured a continuous outcome. One study (De Leo, 1987) reported only the ZSDS score. However, the results of this study were included in the effect size analysis due to the correlation between ZSDS and HRSD scores (Biggs, Wylie, and Ziegler, 1978).

For each study, we categorized SAMe dosage levels as low, medium, or high as described in the Methods section. Less variability was noted in the dosages of conventional antidepressants than in dosages of SAMe. The majority of conventional medications included as comparisons were tricyclic antidepressants and were given in doses described as “usual” by Goodman and Gilman (1996). One study (Bell, Potkin, Carreon, et al., 1994) used a higher-than-usual dose of desipramine, and one study (Mantero, Pastorino, Carolei, et al., 1975) used a lower-than-usual dose of imipramine. Three studies (Cerutti, Savoini, D'Avola, et al., 1989; Scaggion, Baldan, Domanin, et al., 1982; Schifano and Garfoli, 1993) used medications that are not currently prescribed in the United States; however, their dosages were presumed to be within the usual range. Therefore, stratification based on the dose of conventional antidepressants was not considered necessary.

### Meta-Analysis Of SAMe Versus Placebo

#### Risk Ratio Analysis: SAMe Versus Placebo

Three studies contained placebo arms and sufficient data to calculate risk ratios for either a 25 percent improvement in the HRSD, or a 50 percent improvement in the HRSD, or both. The results of this analysis are summarized in Table 5. In this and subsequent tables, the total n is the sum of the sample sizes in the SAMe and comparison (in this case, placebo) arms.

Table 5. SAMe versus placebo studies risk ratios

First Author & Year | SAMe Dose | Total N | RR 25% | 95% CI for RR 25% | RR 50% | 95% CI for RR 50%
Janicak (1988) | HIGH/ PO | 12 | 0.12 | (0.01, 1.79) | 0.44 | (0.02, 9.11)
Kagan (1990) | HIGH/ PO | 15 | 0.43 | (0.13, 1.40) | 0.25 | (0.04, 1.59)
Muscettola (1982) | MED/ IM | 18 | 0.40 | (0.10, 1.55) | NR | NA

CI: confidence interval; IM: intramuscular, NR: Not reported; NA: Not applicable; PO: oral administration; RR: risk ratio.

Since we could calculate the risk ratios for improvement from only three studies, we do not pool the results but discuss them only descriptively. All three of these studies report improvement, but none of the results reaches conventional statistical significance. Each of the studies is limited by the small number of subjects included. The studies ranged in size from about six patients in the SAMe and placebo groups respectively, to nine patients in each group. The risk ranged from about 25 percent to 75 percent across the two outcomes and across studies in the SAMe group. If we assume that the risk ratio is 0.4, which is about the average risk ratio observed, then the risk in the placebo group ranges from 10 percent to 30 percent. The power to detect differences in risk between the two groups for this range (25 percent versus 10 percent; 50 percent versus 20 percent; and 75 percent versus 30 percent) is extremely low for comparison groups of sizes six and nine. In fact, the power does not exceed 30 percent in any case. Even if the risk ratio is as low as the minimum observed (0.12) and assuming the sample sizes in that study (seven and five in each group respectively), the power is only 34 percent. Therefore, these studies are so limited in statistical power that no definitive conclusion can be drawn.

Both the intervention and the quality of the studies also vary somewhat. Kagan's study (Kagan, Sultzer, Rosenlicht, et al., 1990 Kagan, Sultzer, Rosenlicht, et al., 1990) was well designed and received a Jadad score of 5 (see Methods). However, the study design could not be fully implemented due to regulatory problems. Both the Janicak (Janicak, Lipinski, Davis, et al., 1988) and the Kagan (Kagan, Sultzer, Rosenlicht, et al., 1990) studies reported large numbers of dropouts (Biggs, Wylie, and Ziegler, 1978). Neither study included these patients in their final analyses; therefore, the results reported may be skewed towards a positive effect. Thus, the studies present evidence that supports an effect of SAMe relative to placebo (i.e., all of the risk ratios favor SAMe), but these findings are not conclusive (i.e., the differences between groups are not statistically significant and the studies have methods problems).

#### Effect Size Analysis: SAMe Versus Placebo

Eleven studies provided sufficient data to calculate an effect size for the HRSD measured continuously. The results of this analysis are summarized in Table 6 and Figure 2.

Table 6. SAMe versus placebo: depression effect size, pooled analysis

First Author & Year | SAMe Dose & Route of Administration | Total N | Effect Size | 95% CI
Ancarni (1993) | HIGH/IV | 51 | -0.13 | (-0.82, 0.56)
Carney (1986) | MED/ IV | 32 | -0.25 | (-0.94, 0.45)
Carrieri (1990) | HIGH/PO | 17 | -1.28 | (-2.34, 0.56)
Caruso (1987) | MED/ IM | 59 | -0.99 | (-1.54, -0.45)
Delle Chiaie (1997) | HIGH/IV | 75 | -0.43 | (-0.89, 0.03)
De Leo (1987) | Med/IM | 36 | -0.82 | (-1.50, -0.13)
Fava (1992) | HIGH/ PO | 39 | 0.07 | (-0.56, 0.71)
Kagan (1990) | HIGH/PO | 15 | -1.20 | (-2.32, -0.09)
Muscettela (1982) | MED/ IM | 18 | -4.29 | (-5.96, -2.61)
Salmaggi (1993) | HIGH/ PO | 60 | -0.35 | (-0.86, 0.16)
Thomas (1987) | HIGH/IV | 20 | 0.05 | (-0.84, 0.93)
Pooled Random Effects Estimate | | | -0.65 ^(1)^ | (-1.05, -0.25)

(1) Chi-squared test of heterogeneity p-value < 0.001.

CI: confidence interval; IM: intramuscular; IV: intravenous; PO: oral administration.

Figure 2. Depression Outcome: Continuous Hamilton Score SAMe Versus Placebo

The pooled estimate demonstrates a significant decrease of 65 percent of a standard deviation in the HRSD score, associated with SAMe treatment. However, the Chi-squared test of heterogeneity is also significant, with a p-value of less than 0.001.

Given the observed heterogeneity and the variability of dosage level and route of administration of SAMe, a further analysis was done to attempt to ascertain the effect of this variability on the reported effect sizes. When we stratified by SAMe dose and pooled the four medium-dose studies together and the seven high-dose studies together respectively, we obtained the following results. For the medium-dose studies, the pooled effect size is -1.28 (95% CI [-2.26, -0.31]) with a Chi-squared test of heterogeneity of p < 0.001. For the high-dose studies, the pooled effect size is -0.36 (95% CI [-0.66, 0.05]) with a Chi-squared test of heterogeneity of p = 0.22. Thus, stratification by total dose alone does not account for all of the heterogeneity observed. Further, no escalating dose-response relationship was demonstrated in the trials, based on total dose. Route of administration may be a potential confounding factor in assessing response based on dose. Four of the seven high-dose studies involve oral preparations. Thus, it is possible that the lower effect size is the result of the route of administration rather than the total dose.

Results of the pooled analysis summarized in Figure 2 show an effect size of -0.65 in favor of treatment with SAMe over the placebo. In order to assess the clinical importance of such an effect, we transformed this effect size back into a change in the score of the HRSD, assuming the average from all arms in the analysis as the standard deviation. Given this assumption, the pooled effect size is calculated to be equivalent to a drop of 5.6 points on the HRSD.

The clinical significance of a change in the HRSD can be assessed in two ways. First, if the score falls below a particular number (that number varies depending on which version of the score is used), then that patient is no longer considered to be significantly depressed. Second, for a change in the HRSD to represent a “response” to treatment, the score must change by 50 percent or more. A change of greater than 25 percent but less than 50 percent is taken to represent an improvement in symptoms but not a remission or complete response to treatment. However, since the actual number of possible points depends on which version of the test is being administered, the percentage of change represented by 5.6 points would vary as well. Versions of the HRSD used in studies included in our analysis varied from 11 items to 21 items. The versions used most often were the 17-question and the 21-question versions. In a recent study of a new antidepressant, the minimal initial HRSD score (using a 24-item version) for inclusion in the study was 20, and a change in score of 50 percent was defined as a significant clinical response. Thus, in this study, a raw score of 10 would be the minimal acceptable change for a clinically significant response (Keller, McCullough, Klein, et al., 2000). On this basis, it is unlikely that a change of 5.6 points would correspond to a highly significant clinical result such as complete remission of symptoms (greater than or equal to a 50 percent change). However, such a change is in the range of clinically significant improvement greater than or equal to a 25 percent change. Thus, the results of these studies support a clinically and statistically significant benefit of SAMe relative to placebo.

### Meta-Analysis Of SAMe Versus Other Drugs

#### Risk Ratio Analysis: SAMe Versus Other Drugs

We identified 11 studies that contained other drug arms and sufficient data to calculate risk ratios for either a 25 percent improvement in the HRSD, or a 50 percent improvement in the HRSD, or both. The results of this analysis are summarized in Table 7 and Figures 3 and 4.

Table 7. SAMe versus other drugs risk ratios pooled analyses

First Author & Year | Other Drug | Drug Dose | SAMe Dose & Route of Admin. | Total N | RR 25% | 95% CI for RR 25% | RR 50% | 95% CI for RR 50%
Barberi (1978) | Amitriptyline | Usual | MED / IV | 20 | 1.00 | (0.83, 1.20) | 1.00 | (0.83, 1.20)
Bell (1988) | Imipramine | Usual | HIGH /IV | 18 | 0.26 | (0.09, 0.78) | 0.33 | (0.09, 1.23)
Bell (1994) | Desipramine | Usual | HIGH / PO | 17 | NR | NA | 0.61 | (0.17, 2.14)
Calandra (1979) | Chlorimipramine | Usual | MED / IV | 24 | 1.00 | (0.86, 1.17) | 1.00 | (0.07, 14.21)
Del Vecchio (1978) | Chlorimipramine | Usual | MED / IM | 28 | 1.25 | 0.42, 3.70) | 1.00 | (0.02, 47.18)
Janicak (1988) | Imipramine | Usual | HIGH / IV | 10 | 0.93 | (0.37, 2.36) | 2.33 | (0.21, 26.23)
Mantero (1975) | Imipramine | Usual | LOW / IM | 31 | 0.90 | (0.61, 1.33) | 0.87 | (0.51, 1.48)
Miccoli (1978) | Chlorimipramine & Amitriptyline | Usual | MED / IV | 86 | 1.00 | (0.96, 1.04) | 0.96 | (0.73, 1.27)
Monaco (1979) | Amitriptyline | Usual | LOW / IV | 20 | 0.78 | (0.54, 1.14) | 0.73 | (0.24, 2.27)
Scaggion (1982) | Nomifensine | – | MED / PO | 40 | 0.87 | (0.70, 1.09) | 0.17 | (0.02, 1.29)
Scarzella (1978) | Chlorimipramine | Usual | MED / IV | 20 | 1.00 | (0.75, 1.34) | 0.78 | (0.49, 1.23)
| Pooled Random Effects Estimate | | | | 0.99^(1)^ | (0.95, 1.03) | 0.93^(2)^ | (0.82, 1.07)

CI: confidence intervals; IM: intramuscular; IV: intravenous; NR: Not reported; NA: Not applicable; PO: orally administered; RR: relative risk.

(1) Chi-squared test of heterogeneity p-value = 0.43 for RR 25% Change.

(2) Chi-squared test of heterogeneity p-value = 0.68 for RR 50% Change.

Figure 3. Depression Outcome: Number Greater than 50% SMAe Versus Other Drugs

Figure 4. Depression Outcome: Number Greater THan 25% SAMe Versus Other Drugs

The data reported in this group of studies do not demonstrate significant statistical heterogeneity. However, with risk ratios of approximately 1 (0.99 and 0. 93), these data do not support an effect of SAMe that is either superior or inferior to the comparison antidepressant drugs.

#### Effect Size Analysis: SAMe Versus Other Drugs

Fourteen studies that compared the efficacy of SAMe to that of other antidepressant drugs contained sufficient data to calculate an effect size in the HRSD measured continuously. The results of this analysis are summarized in Table 8 and in Figure 5.

Table 8. SAMe versus other drugs depression effect size pooled analysis

First Author & Year | Other Drug | Drug Dose | SAMe Dose & Route of Admin. | Total N | Effect Size | 95% CI
Barberi (1978) | Amitriptyline | Usual | MED / IV | 20 | 0.25 | (-0.63, 1.13)
Bell (1988) | Imipramine | Usual | HIGH / IV | 18 | -1.59 | (-2.64, -0.53)
Calandra (1979) | Chlorimipramine | Usual | MED / IV | 24 | 1.31 | ( 0.43, 2.19)
Cerutti (1989) | Minaprine | N/A | MED / PO | 20 | 0.05 | (-0.82, 0.93)
Del Vecchio (1978) | Chlorimipramine | Usual | MED / IV | 28 | 0.63 | (-0.13, 1.39)
Delle Chiaie (1997) | Chlorimipramine | Usual | HIGH / PO | 122 | 0.50 | (0.14, 0.86)
Di Padova (2000) | Imipramine | Usual | HIGH / IM | 295 | 0.13 | (-0.10, 0.36)
Di Padova (2000) | Imipramine | Usual | HIGH / PO | 281 | 0.13 | (-0.10, 0.36)
Kufferle (1982) | Chlorimipramine | Usual | MED / IV | 18 | 0.09 | (-0.83, 1.02)
Miccoli (1978) | Chlorimipramine & Amitriptyline | Usual | MED / IV | 86 | -0.02 | (-0.44, 0.40)
Monaco (1979) | Amitriptyline | Usual | LOW / IV | 20 | -0.19 | (-1.07, 0.69)
Scaggion (1982) | Nomifensine | N/A | MED / IV | 40 | -0.93 | (-1.58, -0.27)
Scarzella (1978) | Chlorimipramine | Usual | MED / IV | 20 | -0.19 | (-1.07, 0.69)
Vanna (1992) | Imipramine | Usual | MED / PO | 23 | 0.21 | (-0.61, 1.03)
| Pooled Random Effects Estimate | | | | 0.08 ^(1)^ | (-0.17, 0.32)

(1) Chi-squared test of heterogeneity p-value 0.001.

Figure 5. Depression Outcome: Continuous Hamilton Score SAMe Versus Other Drugs

Studies are heterogeneous as demonstrated by the Chi-squared test. Again, the pooled effect is not significant, indicating that the effects of SAMe and the other medications are approximately equivalent. The 95 percent confidence intervals are such that we cannot exclude a 20 percent of standard deviation difference in either direction.

#### Publication Bias

We assessed publication bias for four subgroups of studies included in the meta-analysis. The results are shown in Table 9.

Table 9. Publication bias test results

Study/Analysis | Number of Studies | Adjusted Rank Correlation Test | Regression Asymmetry Test
SAMe versus other drugs – 25% RR | 10 | p=0.15 | p=0.09
SAMe versus other drugs – 50% RR | 11 | p=0.44 | p=0.08
SAMe versus placebo – effect size | 11 | p=0.44 | p=0.07
SAMe versus other drugs – effect size | 14 | p=0.44 | p=0.54

The results of the regression asymmetry test approached statistical significance, raising the possibility of publication bias (i.e., unpublished studies that do not report favorable results). Visual inspection of the funnel plots was not conclusive (see Figures 6–9).

Figure 7. Depression Outcome: Continuous Hamilton Begg's Funnel Plot with Pseudo 95% Confidence Limits

Figure 8. Depression Outcome: Number Greater Than 50% Begg's Funnel Plot with Pseudo 95% Confidence Limits

Figure 6. Depression Outcome: Continuous Hamilton Begg's Funnel Plot with Pseudo 95% Confidence Limits

Figure 9. Depression Outcome: Number Greater Than 25% Begg's Funnel Plot with Pseudo 95% Confidence Limits

#### Depression Studies Not Included In The Meta-Analysis

There were eight studies excluded from the meta-analysis because they presented data duplicated in other included studies. The remaining 11 studies excluded from the meta-analysis are discussed here (they are included in the evidence table). Four (Agnoli, Andreoli, and Casacchia, 1976; Barberi and Pusateri, 1978; Fazio, Andreoli, Agnoli, et al., 1973; and Pons Villegas, 1983) involve a comparison between SAMe and placebo or usual and customary care for the treatment of depression, and three (Delle Chiaie, Pancheri and Scapicchio, 2000a; Delle Chiaie, Pancheri and Scapicchio, 2000b; and Schifano and Garofoli, 1993) involve a comparison between SAMe and another antidepressant. The patients in these first seven studies suffered from a variety of types of depression (e.g., endogenous, reactive, bipolar, etc.), and in an eighth study (Cerutti, Sichel, Perin, et al., 1993), patients were diagnosed with postpartum depression. The final three studies (Chinchilla, Moreno, Piñero, et al., 1996; Berlanga, Ortega-Solo, Onitveros, et al., 1992; Lo Russo, Monaco, Pani, et al., 1994) differed clinically from the rest of the studies of depression.

Agnoli (Agnoli, Andreoli, and Casacchia, 1976) did not report the total scores for the 17-item HRSD but did note 100 percent improvement in the treatment group versus placebo for the “depressive nucleus,” a subset of the HRSD that focuses most specifically on depressive symptoms. Treatment in this trial stopped as soon as a clinical effect was seen.

The article by Barberi and Pusateri (1978) contained two studies, both of crossover design. The first study, of SAMe versus amitriptyline, was included in the meta-analysis; therefore, only the second, placebo-controlled, study is discussed here. At the first crossover, SAMe was more effective than placebo for treating depression, as measured by a change in the “depressive nucleus” (p<0.001). By the end of the trial, the two groups demonstrated no significant difference. However, because no washout period was included, the group that took the placebo during the second half of the trial could have still been under the influence of the initial course of SAMe, thus biasing that half of the trial.

Fazio (Fazio, Andreoli, Agnoli, et al., 1973) did not demonstrate a significant difference between SAMe and placebo. However, the dose of SAMe was quite low (45 mg). Although the drug was given parenterally, a dose this low may not have been sufficient to demonstrate any clinical effect.

Pons Villegas (1983) conducted a trial in 30 depressed alcoholic patients half of whom received SAMe (150 mg per day for 10 days, then 100 mg per day for an additional 20 days). The other half of the patients received usual and customary care only. At the end of treatment, 53 percent of the SAMe group had full resolution of symptoms compared to 28 percent of the control group.

Delle Chiaie studied the efficacy of SAMe versus oral imipramine. In the first trial (Delle Chiaie, Pancheri and Scapicchio, 2000a), SAMe (1600 mg per day given orally) was compared to imipramine (150 mg per day given orally) for six weeks. Although no specific data were supplied, SAMe was reported to be as effective as imipramine with fewer side effects.

Delle Chiaie's second study (Delle Chiaie, Pancheri and Scapicchio, 2000b), compared the efficacy of intramuscular SAMe (400 mg per day) to oral imipramine (150 mg per day) for four weeks for depressed patients at 31 Italian medical centers. Again, no specific values were supplied, but SAMe was reported to be as effective as imipramine with fewer side effects.

Schifano and Garofoli (1993) reported on the difference between SAMe (800 mg/day) and dothiepin (a tricyclic antidepressant) (75 mg/day) in the treatment of 51 recovered alcoholics with depression. Both treatments showed significant effects after 28 days of treatment compared to baseline, but no significant differences between the two treatments were noted. The two treatments appeared to be equally effective, but the dothiepin group had higher HRSD scores at baseline and may have included sicker patients.

The trial by Cerutti and colleagues (Cerutti, Sichel, Perin, et al., 1993) studied the effect of SAMe in patients with postpartum depression (PPD). Treatment consisted of a high oral dose of SAMe (1600 mg), and the results were measured using a special Italian version of a validated scale for PPD, the Kellner Scale. By the tenth day of treatment, women in the SAMe group demonstrated a statistically significant improvement in their scores on the Kellner scale compared to the placebo group and to a control group receiving usual and customary care (p<0.01). By day 30, the difference compared with the placebo group was no longer statistically significant, but the difference compared with the usual-and-customary-care control group was significant (p<0.01). Thus, the benefit of treatment cannot be attributed to SAMe alone, because the placebo group improved as well.

In summary, those studies of depression not included in the meta-analyses are generally in agreement with our pooled estimates: a statistically significant short-term effect of SAMe relative to placebo, and no difference in effect between SAMe and conventional antidepressants.

The final three studies excluded from the meta-analysis all deal with clinical situations that were distinct enough to make the studies inappropriate for pooled analysis with the rest of the depression studies. Two of the studies (Chinchilla, Moreno, Piñero, et al., 1996; Berlanga, Ortega-Solo, Onitveros, et al., 1992) examined the ability of SAMe to decrease the latency of onset of action of conventional antidepressants. A third was concerned with treating depressive symptoms in patients undergoing opiate detoxification (Lo Russo, Monaco, Pani, et al., 1994). Berlanga and colleagues (Berlanga, Ortega-Solo, Onitveros, et al., 1992) demonstrated a significant effect of SAMe on the onset of action of imipramine. The combination of SAMe with imipramine for the relief of depressive symptoms was significantly more effective than imipramine alone by day 4 (p<0.05), as measured by the HRSD. By day 14, the two groups were equivalent. A similar improvement in the onset of action of fluoxetine was demonstrated by Chinchilla and colleagues (Chinchilla, Moreno, Piñero, et al., 1996). The final study, by Lo Russo (Lo Russo, Monaco, Pani, et al., 1994), tested the effects of SAMe on opiate detoxification. Although the dosage regimen was very complicated, which made assessment of the effect difficult, the authors believed that SAMe provided benefit by relieving symptoms of psychological distress during acute opiate withdrawal.

### Summary Of The Results Of SAMe Trials For Treatment Of Depression

All measures of the effect of SAMe versus placebo favored active treatment, although only the effect size analysis reached the level of conventional statistical significance. The clinical significance of the pooled estimate of effect (a 5.6 point improvement in the HSRD) is equivalent to an improvement, but not a total resolution, of symptoms.

Risk ratios and effect size calculations for SAMe compared to other antidepressants did not demonstrate a statistically significant difference. These findings suggest that both therapies were approximately equal in their effects. However, the possibility of publication bias requires tempering these conclusions.

## Analysis Of The Osteoarthritis Studies

For the osteoarthritis meta-analysis, we selected pain as the appropriate outcome for analysis, because it is clinically relevant and was the most frequently reported outcome. However, pain was not measured uniformly in all studies. Therefore, for each study, we made an attempt to identify the most general and comprehensive measure of pain that was used. Where possible, we chose the visual analogue scale (VAS) of total pain. In other studies, where pain was characterized by activity or time of day, categories were combined to form a more comprehensive, general measurement of pain. These combined scales were then used in the analysis. When pain was stratified by affected joints, we preferred the pain scales reported for the knee (the knee was the joint most often studied). We believe that the combined scales measured an equivalent clinical condition (global pain); thus, we considered them together for the analysis.

The follow-up times at which data were collected varied in the studies between 14 and 31 days. For each study, the follow-up measurement we chose for the analysis was the one closest to four weeks.

### Study Inclusion/Exclusion

We considered 14 studies for inclusion in the osteoarthritis meta-analysis. One study (Bradley, Flusser, Brandt, et al., 1991) was removed from the analysis and the evidence table because it was an abstract that reported the same data as another full-length publication (Bradley, Flusser, Katz, et al., 1994). Of the 13 remaining studies, 12 had two arms: a SAMe arm and either a placebo or a nonsteroidal anti-inflammatory drug (NSAID) arm. The remaining study (Caruso and Pietrogrande, 1987) had three arms: SAMe, placebo, and NSAID.

Two studies (Glorioso, Todesco, Mazzi, et al., 1985; Montrone, Fumagalli, Sarzi Puttini, et al., 1985) were excluded because they did not contain sufficient statistics for a calculation of effect size. We excluded another study (Cucinotta, Mancini, Ceccato, et al., 1980) because it did not report on a pain outcome.

A difficulty arose with the Bradley study (Bradley, Flusser, Katz, et al., 1994), which reported on two study sites (Sites A and B). The samples enrolled at the two sites were not equivalent at baseline and did not behave similarly during the trial, despite the fact that the interventions were identical. Because of these persistent differences, the authors analyzed and reported the results of the two groups separately. Therefore, we treated these sites separately in the meta-analysis as well; in the remaining discussion, we consider them separate studies. However, the results from the two sites appear in the evidence table as a single entry.

As a result of these exclusions and splitting of studies, we included 11 studies in the meta-analysis. These studies included 12 placebo or NSAID arms and 11 SAMe arms.

#### Calculations

We calculated the pain effect sizes as described previously. A negative effect size indicates that SAMe is associated with a lower pain measure at follow-up than is either the placebo or NSAID. As described previously, we categorized the SAMe doses as low, medium, and high, and the NSAID doses as low, medium, and high.

### Meta-Analysis Of SAMe Versus Placebo

Three studies compared the effect of SAMe to that of placebo. As we noted above, two of these reports presented data collected at separate sites using the same intervention (Bradley, Flusser, Katz, et al., 1994). The results of the studies and the pooled random effects estimate are shown in Table 10. We note the marked difference in the effect sizes reported for the two sites in the Bradley study. The total sample size reported in the table is the sum of the sample sizes in the two arms that were used to calculate the effect size.

Table 10. SAMe versus placebo: OA, pooled analysis

First Author & Year | SAMe Dose & Route of Administration | Total N | Effect Size | 95% CI
Bradley (1994) Site A | MED/ IV & PO | 48 | -0.40 | (-0.97, 0.17)
Bradley (1994) Site B | MED/ IV & PO | 33 | 0.60 | (-0.09, 1.30)
Caruso (1987) | HIGH/ PO | 458 | -0.20 | (-0.39, -0.02)
Pooled Random Effects Estimate | | | -0.07^(1)^ | (-0.52, 0.38)

(1) Chi-squared test of heterogeneity p-value = 0.064.

CI: confidence intervals; IV: intravenous; PO: oral administration.

We note that the fixed effects pooled estimate of -0.17 (95% CI [-0.34, 0.00]; p=0.044) is just barely significant. The Chi-squared test of heterogeneity, with a p-value of less than 0.10, indicates significant heterogeneity among the studies. In light of the considerable heterogeneity that exists across these studies, a pooled estimate may not be appropriate. Therefore, we discuss the studies separately. Two of the studies show a decrease in pain associated with placebo (a decrease of 20 percent and 40 percent of a standard deviation in the Caruso and colleagues study and at site A of the Bradley and colleagues study, respectively). Site B of the Bradley study does not show a placebo effect (an increase of 60 percent of a standard deviation).

The two sites of the Bradley study (Bradley, Flusser, Katz, et al., 1994) show opposite and almost equal effects. The populations at the two sites differed, with less severely ill patients at site A. In addition, site B had significant problems with randomization. Four of the eight measures of clinical status were significantly different between the sites at baseline, with the SAMe patients generally being more severely affected. Thus, at site B, the results may be affected by adverse assignment. It is likely that the results of the much larger study by Caruso and colleagues more closely represent the effect of SAMe relative to placebo (i.e., a modest but statistically significant effect of SAMe) than do the results of the Bradley study.

### Meta-Analysis Of SAMe Versus NSAID

Nine studies compared SAMe to NSAID. One of these was a large study that also included a SAMe versus placebo arm comparison. To identify appropriate comparisons to include in the analysis, we stratified the interventions by dose.

Table 11 shows the distribution of studies by NSAID and SAMe doses.

Table 11. Study distribution by NSAID dose and SAMe dose

| SAMe Dose
NSAID Dose | LOW | MED | HIGH | Total
LOW | 1 | 1 | 2 | 4
MED | 0 | 0 | 4 | 4
HIGH | 0 | 0 | 1 | 1
TOTAL | 1 | 1 | 6 | 9

For clinical reasons, we dropped the study that compared the effect of a low SAMe dose with that of a low NSAID dose (Polli, Cortellaro, Parrini, et al., 1975) from our pooled analysis. This study compared the effect of SAMe to that of Ibuprofen and had an effect size favoring SAMe of -0.61 (95% CI [-1.34, 0.12]), with a total of 30 patients for whom pain was measured at 14 days. However, we judged that the doses were subtherapeutic (indomethacin [Indocin], 50 mg and SAMe, 30 mg) and that, as a result, these findings were not applicable to clinical use.

The remaining eight studies and the pooled random effects estimate are shown in Table 12 and Figure 10.

Table 12. SAMe versus NSAID pooled analysis

First Author & Year | NSAID | NSAID Dose | SAMe Dose & Route of Administration | Total N | Effect Size | 95% CI
Capretto (1985) | Ibuprofen | LOW | MED/ PO | 21 | -0.58 | ( 1.46, 0.29)
Caroli (1980) | Aspirin | MED | HIGH/ PO | 54 | -1.90 | (-2.54, -1.25)
Caruso (1987) | Naproxen | MED | HIGH/ PO | 453 | 0.01 | (-0.17, 0.19)
Domljan (1989) | Naproxen | MED | HIGH/ PO | 37 | -0.15 | (-0.80, 0.49)
Maccagno (1987) | Piroxicam | HIGH | HIGH/ PO | 45 | 1.07 | ( 0.44, 1.69)
Marcolongo (1985) | Ibuprofen | LOW | HIGH/PO | 150 | -0.06 | (-0.38, 0.26)
Muller-Fassbender (1987) | Ibuprofen | LOW | HIGH/ PO | 36 | -0.11 | (-0.77, 0.54)
Vetter (1987) | Indocin | MED | HIGH/ PO | 35 | 0.78 | ( 0.09, 1.47)
| | Pooled Random Effects Estimate | | | -0.11^(1)^ | (-0.56, 0.35)

(1) Chi-squared test of heterogeneity p-value < 0.001.

CI: confidence intervals; PO: oral administration.

Figure 10. OA Outcome: Pain at Four Weeks Follow-up SAMe (Medium/High Dose) Versus NSAIDS

The heterogeneity among these eight studies is large, and the pooled estimate is not significant (p=0.65). A sensitivity analysis was undertaken to attempt to account for the observed variance.

#### Sensitivity Analyses

To explore the heterogeneity we had identified among the SAMe versus NSAID studies, we conducted two sensitivity analyses. In our first sensitivity analysis, we restricted our attention to the five SAMe versus NSAID studies, in which medium or high NSAID doses were administered. The Chi-squared test of heterogeneity for this analysis yielded a p-value of less than 0.001 with a pooled random effects estimate of -0.038 (95% CI [-0.84, 0.76]; p=0.93). Unfortunately, this sensitivity analysis did not explain the observed heterogeneity.

In our second sensitivity analysis, we excluded the large study by Caruso and Pietrorande (1987), which contained about two-thirds of the total patients, from the original pooling. The remaining seven studies retained significant heterogeneity (p<0.001), with a pooled random effects estimate of -0.13 (95% CI [-0.78, 0.52]; p=0.70). Again, this sensitivity analysis did not contribute to our understanding of the heterogeneity among studies.

It is interesting to note here that all of the studies included in this analysis used an oral dosage form of SAMe. It is possible that the modesty of the effects observed in these trials is due to the dosage formulation. However, parenteral therapy is not clinically feasible for this disease, because treatment is usually taken chronically.

#### Publication Bias

The number of SAMe versus placebo studies (three) was too small to allow a meaningful assessment of publication bias. Thus, we assessed publication bias only for the eight SAMe versus NSAID studies. Neither the adjusted rank correlation test (p=0.54), the regression asymmetry test (p=0.77), nor a visual inspection of the funnel plot (see Figure 11) indicated the presence of publication bias. The small number of available studies limited our ability to determine if publication bias did occur.

Figure 11. OA Outcome: Pain at Four Weeks Follow-up Begg's Funnel Plot with Pseudo 95% Confidence Limits

#### Osteoarthritis Studies Not Included In Meta-Analysis

One study was excluded because it presented data duplicated in another included study and the remaining three studies that were excluded from the meta-analysis are discussed here; Montrone and colleagues (Montrone, Fumagalli, Sarzi Puttini, et al., 1985), in a placebo-controlled study, compared the effect of SAMe (1200 mg per day for 21 days) to placebo for the treatment of hip and knee OA in 65 patients (32 SAMe and 34 placebo). Outcomes measured included pain and range of motion of the hip and knee. At the end of the trial, patients and physicians provided an overall rating of the effectiveness of therapy. All patients in the SAMe group improved on all measures compared to baseline. Compared to placebo, the trend favored SAMe, but only three of seven measurements achieved statistical significance.

Two additional studies compared SAMe to ibuprofen. The first (Cucinotta, Mancini, Ceccato, et al., 1980) compared SAMe (600 mg) with ibuprofen (1200 mg) for 30 days in 40 patients with OA of the knee, hip, and cervical spine. Patients in the SAMe arm reported significant improvement in overall symptoms for the hip and cervical spine at 31 days (p<0.001). Objective improvement in range of motion of the knee, hip, and cervical spine was documented by physician examination (p<0.001, p<0.001, p<0.005 respectively). These results were greater in magnitude than the results in the ibuprofen arm but did not reach statistical significance. Mild side effects were reported in 4 of 20 patients taking SAMe and in 17 of the 20 patients on ibuprofen. A similar trial (Glorioso, Todesco, Mazzi, et al., 1985) compared the effect of SAMe and ibuprofen (1200 mg each) on 150 subjects with hip and/or knee OA. At the end of the 30-day trial, SAMe was slightly more effective in both minutes of muscle rigidity following inactivity and a “pain pool average,” the summation of a variety of pain measurements. These results did not reach statistical significance. Three times fewer SAMe patients (5) than placebo patients (16) reported minor side effects during the trial.

In summary, the three OA studies not included in our meta-analysis support our results that SAMe has modest but significant benefit compared to placebo and no difference in efficacy between SAMe and NSAIDs.

## Analysis Of The Liver Disease Studies

We identified 41 studies that involved the use of SAMe for a variety of liver diseases. Cholestasis of pregnancy was the focus for nine studies, cholestasis from causes other than pregnancy for twelve studies, cirrhosis for seven studies, hepatitis for eight studies, other chronic liver disease for four studies, and transplantation for one study.

The studies that focused on the use of SAMe for cholestasis of pregnancy were judged sufficiently clinically similar to perform meta-analysis. For the cholestasis of pregnancy meta-analysis, two outcomes were chosen for pooling because they were reported most frequently and were the most clinically relevant. These outcomes, pruritus and bilirubin, are each discussed separately.

Twelve studies addressed intrahepatic cholestasis associated with a variety of liver disorders other than pregnancy. Because intrahepatic cholestasis is likely to be a “final common pathway” for many chronic liver conditions, we judged these studies sufficiently clinically similar to justify statistical pooling. Similar to the cholestasis of pregnancy meta-analysis, we chose pruritus and bilirubin as the two outcomes for pooling.

### Analysis Of Studies Of Cholestasis Of Pregnancy

#### The Pruritus Outcome

Study inclusion/exclusion. We considered nine studies for inclusion in the pruritus meta-analysis. One study had four arms (placebo, SAMe, ursodeoxycholic acid [UDCA], and SAMe plus UDCA). A second study had three arms (placebo and two SAMe arms of different doses). The remaining six studies had two arms (SAMe and placebo).

One study (Floreani, Paternoster, Melis, et al., 1996b) was removed from the analysis and the evidence table, because it was an abstract that contained the same data as another full-length study that was considered for the analysis (Floreani, Paternoster, Melis, et al., 1996a). However, the study itself was eventually excluded from the meta-analysis, because it did not contain sufficient statistics for an effect-size calculation. Two studies (Frezza, Centini, Cammareri, et al., 1990; Frezza, Cammareri, Di Padova, et al., 1987) reported the results of studies on the same study population, but each reported a different one of the two outcomes of interest; the study reporting pruritus (Frezza, Centini, Cammareri, et al., 1990), was included in this analysis. The other study was included in the bilirubin analysis.

As a result of these exclusions, six studies were included in the analysis. As mentioned above, one study (Nicastri, Diaferia, Tartagni, et al., 1998) had four arms: placebo, SAMe, UDCA, and SAMe plus UDCA. Two studies (Frezza, Pozzato, Chiesa, et al., 1984; Lafuenti, Plotti, Nicolanti, et al., 1988) had three arms: placebo and two SAMe arms of different doses. A fourth study (Roncaglia, Locatelli, Bellini, et al., 2000) had two arms: UDCA and SAMe. A fifth study (Frezza, Centini, Cammareri, et al., 1990) had placebo and SAMe arms, and a sixth study (Ribalta, Reyes, Gonzalez, et al., 1991) had mannitol (acting as a placebo) and SAMe arms. We sought outcome measurements closest to the time of delivery. Actual times of data collection ranged from the time of delivery (implied in one study) to 20 days post-delivery (reported in several studies).

Calculations for pruritus. Two studies that measured pruritus as an outcome did not report a measure of uncertainty. For the first study (Nicastri, Diaferia, Tartagni, et al., 1998), we assumed that the standard deviation equaled one-quarter of the theoretical range of the pruritus scale. For the second study (Roncaglia, Locatelli, Bellini, et al., 2000), we back-calculated the standard deviation from the reported p-value. The pruritus effect size was calculated as described previously. A negative effect size indicates that SAMe is associated with decreased pruritus as compared to the UDCA or placebo as appropriate. We categorized SAMe levels as low, medium, and high, as described previously.

Meta-analysis of SAMe versus placebo. Five studies compared the effect of SAMe to that of a placebo (or mannitol, which we considered equivalent to a placebo). Two of the five studies had more than one SAMe arm. To ensure that placebo patients within one study would not be double counted, we dropped the most disparate SAMe arm from the pooled analysis so that each study contributed only one effect size to our combined analysis. For the study by Frezza and colleagues (Frezza, Pozzato, Chiesa, et al., 1984), we dropped the SAMe arm that received 200 mg of SAMe, and for the study by Lafuenti and colleagues (Lafuenti, Plotti, Nicolanti, et al., 1988), we dropped the SAMe arm that received 1800 mg. The effect sizes for these two arms are shown in Table 13.

Table 13. Effect sizes for interventions excluded from SAMe versus placebo pooled analysis (pruritus)

First Author & Year | SAMe Dose | Total N | Effect Size | 95% CI
Frezza (1984) | MED | 12 | -0.10 | (-1.23, 1.03)
Lafuenti (1988) | HIGH | 29 | -1.39 | (-2.24, -0.55)

The pooled analysis for SAMe versus placebo is shown in Table 14 and in Figure 12.

Table 14. SAMe versus placebo pooled analysis (pruritus)

First Author & Year | Comparison Arm | SAMe Dose | Total N | Effect Size | 95% CI
Frezza (1990) | Placebo | HIGH | 30 | -0.77 | (-1.51, -0.03)
Frezza (1984) | Placebo | HIGH | 12 | -0.94 | (-2.13, 0.25)
Lafuenti (1988) | Placebo | MED | 26 | -1.18 | (-2.11, -0.26)
| No treatment
Nicastri (1998) | Placebo | HIGH | 16 | -0.19 | (-1.17, 0.79)
Ribalta (1991) | Mannitol | HIGH | 18 | -1.87 | (-2.98, -0.76)
| Pooled Random Effects Estimate | | | -0.95^(1)^ | (-1.45, -0.45)

(1) Chi-squared test of heterogeneity p-value = 0.25.

Figure 12. Cholestasis of Pregnancy Outcome: Pruritus SAMe Versus Placebo

The Chi-squared test of heterogeneity does not detect heterogeneity among these studies. However, given the low power of this test, we still report the pooled random effects estimate of -0.95 (p<0.001). This pooled estimate shows that, in these studies, SAMe is associated with a decrease of almost a full standard deviation in the appearance of pruritus as compared with placebo (or mannitol).

Meta-analysis of SAMe versus UDCA (pruritus). UDCA is the standard therapy for cholestasis of pregnancy. Two studies compared the effect of SAMe to that of this form of active therapy. One of these studies had three arms: SAMe alone, UDCA alone, and UDCA plus SAMe. The results of the analysis comparing UDCA alone to SAMe alone are shown in Table 15. The total sample size reported in the table is the sum of the sample sizes in the two arms that were used to calculate the effect size.

Table 15. SAMe versus ursodeoxycholic acid (pruritus)

First Author & Year | Comparison Arm | SAMe Dose | Total N | Effect Size | 95% CI
Nicastri (1998) | Ursodeoxycholic acid | HIGH | 16 | -0.47 | (-1.47, 0.52)
Roncaglia (2000) | Ursodeoxycholic acid | HIGH | 22 | -1.52 | (-2.50, -0.54)

Since we identified only two studies that compared UDCA with SAMe, we did not pool the studies and instead discuss the results descriptively. Data from both studies support significant benefit for SAMe and UDCA compared to baseline (although both studies showed a preference for UDCA over SAMe for treatment of elevated serum bilirubin, as we will discuss later). In the Roncaglia study (Roncaglia, Locatelli, Bellini, et al., 2000), SAMe appeared more effective than UDCA in treating pruritus (p=0.02). Further, the combination of SAMe and UDCA had a greater clinical effect on both outcomes than did UDCA alone; again, the effect on pruritus was larger than the effect on serum bilirubin (p<0.0003; p<0.002).

Publication bias. We assessed publication bias only for the five studies that entered our SAMe versus placebo pooled analysis. Neither the adjusted rank correlation test (p=0.81), the regression asymmetry test (p=0.58), nor a visual inspection of the funnel plot indicated publication bias (see Figure 13). However, the small number of studies limited our ability to determine if publication bias did occur.

Figure 13. Cholestasis of Pregnancy Outcome: Pruritus Begg's Funnel Plot with Pseudo 95% Confidence Limits

#### The Serum Bilirubin Outcome

Study inclusion/exclusion. We considered the same nine studies for inclusion in the cholestasis serum bilirubin meta-analysis as for the analysis of pruritus as an outcome. One publication (Floreani, Paternoster, Melis, et al., 1996b) was excluded, because it was an abstract that contained the same data as another full-length publication (Floreani, Paternoster, Melis, et al., 1996a); moreover, these data had been determined to be insufficient for effect size calculations. Two publications (Frezza, Centini, Cammareri, et al., 1990; Frezza, Cammareri, Di Padova, et al., 1987) reported on the same study population, but each reported only one of the two outcomes of interest. Thus, the study that reported the effects on serum bilirubin (Frezza, Cammareri, Di Padova, et al., 1987) was included in this analysis. As a result of these exclusions, seven studies were included in the analysis. One study (Nicastri, Diaferi, Tartagni, et al., 1998) had four arms: placebo, SAMe, UDCA, and SAMe plus UDCA. Two studies (Frezza, Pozzato, Chiesa, et al., 1984; Lafuenti, Plotti, Nicolanti, et al., 1988) had three arms each: placebo (no treatment) and two SAMe arms of different doses. Two studies (Floreani, Paternoster, Melis, et al., 1996a; Roncaglia, Locatelli, Bellini, et al., 2000) had two arms that consisted of UDCA and SAMe. One study (Frezza, Pozzato, Pison, et al., 1987) had two arms of placebo and SAMe. Finally, one study (Ribalta, Reyes, Gonzalez, et al., 1991) had two arms consisting of mannitol and SAMe.

Most studies reported total serum bilirubin in milligrams per deciliter (mg/dl), which was the preferred outcome. When results were not expressed in that way, other measures were considered. For two studies (Floreani, Paternoster, Melis, et al., 1996a; Frezza, Cammareri, Di Padova, et al., 1987), total bile salts and total bile acids both measured in millimicromoles per liter were used as the outcome, respectively. Although these outcomes are not equal, each varies proportionately with the total serum bilirubin. Therefore, they may be used to calculate a common effect size.

Calculations for serum bilirubin.Two studies did not report a measure of uncertainty. In one study, whose outcome measure was total bile salts (in μ-mol/l), one arm did not have an associated standard deviation, so we imputed the standard deviation from the other arm and another study (Frezza, Cammareri, Di Padova, et al., 1987) that did report a standard deviation for the same outcome measure in the same units. For the second study (Nicastri, Diaferi, Tartagni, et al., 1998), whose outcome measure was serum bilirubin (in mg/dl), we imputed the standard deviation from those four studies (Ribalta, Reyes, Gonzalez, et al., 1991; Lafuenti, Plotti, Nicolanti, et al., 1988; Frezza, Pozzato, Chiesa, et al., 1984; Roncaglia, Locatelli, Bellini, et al., 2000) that did report a standard deviation for serum bilirubin in the same units. The serum bilirubin effect size was calculated as described previously. A negative effect size indicates that SAMe is associated with decreased serum bilirubin as compared to the effect of UDCA, mannitol, or placebo, as appropriate. As described previously, we categorized SAMe levels as low, medium, and high.

Meta-analysis of SAMe versus placebo. Five studies compared the effect of SAMe to that of a placebo (or mannitol, which we considered equivalent to placebo). Two of the five studies had more than one SAMe arm. As in the pruritus analysis, we dropped the most disparate SAMe arm from the pooled analysis, so that our combined analysis would include only one effect size contributed by each study, to ensure that placebo patients in a study were not double-counted. For the study by Frezza, Pozzato, Chiesa, et al. (1984), we dropped the SAMe arm that received 200mg of SAMe, and for study by Lafuenti, Plotti, Nicolanti, et al. (1988), we dropped the SAMe arm that received 1800mg. The effect sizes for these two arms are shown in Table 16.

Table 16. Effect sizes for interventions excluded from SAMe versus placebo pooled analysis (serum bilirubin)

First Author & Year | SAMe Dose | Total N | Effect Size | 95% CI
Frezza (1984) | MED | 12 | -0.50 | (-1.65, 0.65)
Lafuenti (1988) | HIGH | 29 | -1.34 | (-2.18, -0.50)

The pooled analysis for SAMe versus placebo is shown in Table 17 and in Figure 14.

Table 17. SAMe versus placebo pooled analysis (serum bilirubin)

First Author & Year | Comparison Arm | SAMe Dose | Total N | Effect Size | 95% CI
Frezza (1984) | Placebo | HIGH | 12 | -1.58 | (-2.88, -0.29)
Frezza (1987) | Placebo | HIGH | 30 | -1.91 | (-2.78, -1.05)
Lafuenti (1988) | Placebo, No treatment | MED | 26 | -1.22 | (-2.15, -0.29)
Nicastri (1988) | Placebo | HIGH | 16 | -1.15 | (-2.21, -0.09)
Ribalta (1991) | Mannitol | HIGH | 18 | -0.70 | (-1.65, 0.25)
| Pooled Random Effects Estimate | | | -1.32^(1)^ | (-1.76, -0.88)

(1) Chi-squared test of heterogeneity p-value = 0.44.

Figure 14. Cholestasis of Pregnancy Outcome: Serum Bilirubin SAMe Versus Placebo

The Chi-squared test of heterogeneity does not detect heterogeneity among the studies. However, given the low power of this test, we still report the pooled random effects estimate of -1.32 (p<0.001). This pooled estimate shows that in these studies, SAMe is associated with a decrease of approximately 1.3 standard deviations in serum bilirubin as compared with placebo (or mannitol).

Meta-analysis of SAMe versus ursodeoxycholic acid. Three studies contained UDCA arms, including one study that had both an UDCA-only arm and a SAMe plus UDCA arm. The effect sizes for the UDCA-only arm are shown in Table 18. The total sample size reported in the table is the sum of the sample sizes in the two arms that were used to calculate the effect size.

Table 18. SAMe versus ursodeoxycholic acid (serum bilirubin)

First Author & Year | Comparison Arm | SAMe Dose | Total N | Effect Size | 95% CI
Floreani (1996) | Ursodeoxycholic acid | HIGH | 20 | 0.92 | ( 0.00, 1.84)
Nicastri (1998) | Ursodeoxycholic acid | HIGH | 16 | -0.13 | (-1.12, 0.85)
Roncaglia (2000) | Ursodeoxycholic acid | HIGH | 22 | 1.34 | ( 0.39, 2.30)

Since we identified only three studies that fit the criteria for inclusion, we did not pool the studies and instead discuss the results descriptively. One study reported no difference between SAMe and UDCA, and had very wide 95 percent confidence intervals. The other two studies reported UDCA as superior to SAMe, with an effect size favoring UDCA of about one standard deviation.

Sensitivity analysis. We conducted one sensitivity analysis on our SAMe versus placebo comparison. When we dropped the study that reported total bile acids (Frezza, Cammareri, Di Padova, et al., 1987) from the pooled analysis, the result was not significantly affected (pooled random effects estimate of -1.11 (95% CI [-1.62, -0.59]; p<0.001)).

Publication bias. We assessed publication bias for the five studies that entered our SAMe versus placebo pooled analysis. Neither the adjusted rank correlation test (p=0.81), the regression asymmetry test (p=0.87), nor a visual inspection of the funnel plot indicated publication bias (see Figure 15). However, the small number of studies limited our ability to determine whether publication bias did occur.

Figure 15. Cholestasis of Pregnancy Outcome: Serum Bilirubin Begg's Funnel Plot with Pseudo 95% Confidence Limits

### Analysis Of Studies Of Intrahepatic Cholestasis For Conditions Associated With Liver Disease (Other Than Pregnancy)

Twelve studies addressed intrahepatic cholestasis associated with a variety of liver disorders other than pregnancy. We judged that intrahepatic cholestasis is likely to be a “final common pathway” for many chronic liver conditions, and, therefore, that the studies were sufficiently clinically similar to justify statistical pooling. As we did for the previous cholestasis-of-pregnancy meta-analysis, the two outcomes we chose for pooling were pruritus and bilirubin. All outcomes were measured as closely as possible to 14 days, and follow-up times less than 10 days were considered too short to be included.

With respect to patient heterogeneity, we restricted our primary attention to the results for patients with chronic liver disease and excluded acute patients. Most studies either focused solely on chronic patients or presented results separately for the two groups. The single study that had a mix of patients whose disease status could not be discerned is noted below in the description of the results for the pruritus outcome. We report study-level data from two studies on acute patients, and discuss each outcome separately.

#### The Pruritus Outcome

Study inclusion/exclusion. Unlike the studies included in the cholestasis for pregnancy meta-analysis, only one of the twelve studies included in the cholestasis of chronic liver disease meta-analysis contained a mean pruritus score. Therefore, we used as our common statistic the risk ratio for resolved pruritus. For this statistic, the risk in the SAMe group is the number of patients in the SAMe group whose pruritus resolved divided by the number of patients in the SAMe group who began the study with pruritus. The risk in the comparison group, either placebo or other drug, is defined analogously. As a result, the risk ratio, which divides the risk in the comparison group by the risk in the SAMe group, is less than one if the risk of resolved pruritus is less in the comparison group, thereby indicating that SAMe is associated with a higher level of resolved pruritus. We defined the risk ratio in this manner so that a risk ratio less than one would indicate a better outcome associated with SAMe for all risk ratios across all conditions.

We considered 12 studies for inclusion in the intrahepatic cholestasis meta-analysis. Studies could be excluded if they represented data duplicated in another included study, did not have appropriate outcome measures, presented insufficient statistics, or had a crossover design.

Two studies (Manzillo, Frezza, Fiaccadori, et al., 1989); and Manzillo, Fiaccadori, Frezza, et al., 1988) were excluded, because they included duplicate data that were reported in another included study (Frezza, Surrenti, Manzillo, et al., 1990). Two studies (Adachi, Nanno, Kanbe, et al., 1986; and Bombardieri, Milani, Bernardi, et al., 1985) did not measure pruritus. Two studies (O'Donohue, Wendon and Williams, 1996; and Fiaccadori, Frezza and Di Padova, 1988) reported data that were insufficient for statistical analysis. Finally, one study had a crossover design (Cacciatore, Varriale, Cozzolino, et al., 1989): All patients were treated with a placebo before being switched to SAMe. Thus, this study was excluded. Another study (Bray, Di Padova, Tredger, et al., 1991) with a crossover design did not report data prior to the crossover and was also excluded. As a result of these exclusions, four studies were included in the analysis.

Meta-analysis of SAMe versus placebo. All four studies included in the analysis compared the effects of SAMe to that of placebo. The results of one study were presented only for a mix of chronic and acute patients (Manzillo, Piccinino, Surrenti, et al., 1992). We could extract data on chronic patients only for the other three studies. All four studies administered high doses of SAMe. The risk ratios and pooled analysis are shown in Table 19 and Figure 16.

Table 19. SAMe versus placebo pooled analysis for a mix of chronic and acute patients (pruritus)

Study | SAMe Dose | Total N | Risk Ratio | 95% CI RR
Frezza (1990) | HIGH | 81 | 0.43 | (0.27, 0.69)
Frezza (1987) | HIGH | 143 | 0.00 | (0.25, 0.53)
Manzillo (1992) | HIGH | 105 | 0.44 | (0.30, 0.66)
Qin (2000) | HIGH | 64 | 0.57 | (0.39, 0.83)
Pooled Random Effects Estimate | | | 0.45^(1)^ | (0.37, 0.55)

(1) Chi-squared test of heterogeneity p-value=0.40

Figure 16. Cholestasis Outcome: Pruritus SAMe Versus Placebo

The pooled estimate is significantly smaller than 1 (p<0.001), which indicates a higher risk of resolved pruritus associated with SAMe, as compared to the risk of resolved pruritus for placebo patients. Thus, SAMe was judged to be more effective than placebo in reducing pruritus.

Publication bias. Neither the adjusted rank correlation test (p=0.73), the regression asymmetry plot (p=0.76), nor a visual inspection of the funnel plot indicated a presence of publication bias (see Figure 17). However, the small number of studies limited our ability to determine if publication bias did occur.

Figure 17. Cholestasis Outcome: Pruritus Begg's Funnel Plot with Pseudo 95% Confidence Limits

#### The Serum Bilirubin Outcome

Study inclusion/exclusion for the serum bilirubin outcome. The serum bilirubin calculations for the analysis of studies of cholestasis of chronic liver disease were done as for the previous cholestasis of pregnancy analysis. Two studies (Manzillo, Frezza, Fiaccadori, et al., 1989; and Manzillo, Fiaccadori, Frezza, et al., 1988) were excluded because they included duplicate data that were reported in an included study (Frezza, Surrenti, Manzillo, et al., 1990). Two studies (Fiaccadori, Frezza, Di Padova, 1988; and O'Donohue, Wendon and Williams, 1996) reported insufficient statistics for the calculations to be performed. One study (Frezza and Di Padova, 1987) was excluded because it did not report the relevant outcome. One study (Cacciatore, Varriale, Cozzolino, et al., 1989) was excluded because it had a crossover design in which patients received the placebo prior to receiving SAMe. Finally, one study (Bray, Di Padova, Tredger, et al., 1991) was excluded because it included a crossover design and did not report data prior to the crossover. As a result of these exclusions, five studies were included in the analysis.

Meta-analysis of SAMe versus placebo. All five studies compared the effects of SAMe to that of placebo. We could extract data on chronic patients for all five studies, and all administered high doses of SAMe. The effect sizes and pooled analysis are shown in Table 20 and Figure 18.

Table 20. SAMe versus placebo pooled analysis for cholestasis in patients with chronic liver disease (serum bilirubin)

First Author & Year | SAMe Dose | Total N | Effect Size | 95% CI
Adachi (1986) | HIGH | 14 | -0.01 | (-1.07, 1.05)
Bombardieri | HIGH | 18 | -0.69 | (-1.64, 0.26)
Frezza (1990) | HIGH | 209 | -0.42 | (-0.70, -0.15)
Manzillo (1992) | HIGH | 227 | -0.18 | (-0.44, 0.08)
Qin (2000) | HIGH | 64 | -1.78 | (-2.36, -1.20)
Pooled Random Effects Estimate | | | -0.63^(1)^ | (-1.16, -0.10)

(1) Chi-squared test of heterogeneity p-value<0.001.

Figure 18. Cholestasis Outcome: Serum Bilirubin SAMe Versus Placebo

The pooled estimate is significantly smaller than 0 (p=0.02), indicating a statistically significant decrease of over one standard deviation in serum bilirubin associated with SAMe treatment. However, the studies are significantly heterogeneous.

Publication Bias. Neither the adjusted rank correlation test (p=0.81), the regression asymmetry plot (p=0.49), nor a visual inspection of the funnel plot indicated a presence of publication bias (see Figure 19). However, the small number of studies limited our ability to determine if publication bias did occur.

Figure 19. Cholestasis Outcome: Serum Bilirubin Begg's Funnel Plot with Pseudo 95% Confidence Limits

### Results For Acute Patients

Two studies presented data for acute patients only, and their individual effect sizes are shown in Table 21.

Table 21. SAMe versus placebo effect sizes for patients with acute liver disease (serum bilirubin)

First Author & Year | SAMe Dose | Total N | Effect Size | 95% CI
Manzillo (1992) | HIGH | 82 | -0.50 | (-0.95, -0.05)
Qin (2000) | HIGH | 46 | -1.42 | (-2.07, -0.78)

The results of the two studies, each of which administered a high SAMe dose, showed large, statistically significant benefits for SAMe compared to placebo.

One of the two studies that included only chronic patients compared the effects of SAMe versus those of prednisolone, and the effect size is shown in Table 22.

Table 22. SAMe versus prednisolone effect size for patients with chronic liver eisease (serum bilirubin)

First Author & Year | Drug | Drug Dose | SAMe Dose | Total N | Effect Size | 95% CI
Adachi (1986) | Prednisolone | MED | HIGH | 15 | 0.19 | (-0.85, 1.22)

This study has a small sample size and its power is extremely low. There is no statistically significant effect. The point estimate of the effect suggests at most a small difference.

### Liver Studies Not Considered For Meta-Analysis

Twenty studies that included patients with a wide variety of liver diseases were found to be too heterogeneous for inclusion in any pooled analysis. The number and variety of disease states included hepatitis of mixed etiology and acuteness (eight studies); cirrhosis of the liver from a variety of causes including viral infections, autoimmune disease, and alcohol (seven studies); chronic liver disease without cholestasis or cirrhosis (four studies); and liver transplant (one study). In addition, these studies showed some variation in the outcomes measured, such that no group of studies that shared a homogeneous disease state and outcome measure was large enough to justify a pooled analysis.

The majority of the remaining studies were small: 65 percent (13 studies) enrolled fewer than 25 patients per arm; 25 percent (five studies) enrolled between 25 and 50 subjects per arm; and 10 percent (two studies) enrolled 50 to 100 subjects. No study enrolled more than 100 subjects per arm. Therefore, most of these studies were not of sufficient power to detect any but the largest effect sizes. Likewise, the quality of these studies as measured according to the method of Jadad (Jadad, Moore, Carrol, et al., 1996) varied as well. Most (90 percent) were of low quality, having been assigned Jadad scores of 2 or less. The distribution of the Jadad scores by disease type is summarized in Table 23.

Table 23. Distribution of Jadad score in other liver studies

| Jadad scores
Diagnosis | 0 | 1 | 2 | 3 | 4 | 5
Cirrhosis | 2 | 2 | 1 | 1 | - | 1
Hepatitis | 4 | 1 | 3 | - | - | -
Chronic liver disease | 4 | - | - | - | - | -
Transplantation | - | - | 1 | - | - | -
TOTAL | 10 | 3 | 5 | 1 | 0 | 1

A brief summary of these studies is included here, organized by disease state, for the sake of completeness. Additional information about these studies is included in Evidence Table V.

#### Hepatitis

The effectiveness of SAMe to reduce laboratory values in patients with acute or chronic hepatitis was examined in eight studies (Botero and Delgado, 1991; Di Palma, Fiore, Majoli, et al., 1978; Diaz-Belmont, Dominguez Henke, and Uribe Ancira, 1996; Jorge, 1985; Miglio, Stefanini, Corazza, et al., 1975; Musso, Giacchino, Vietti, et al., 1980; Pecoraro, Bruno, Giammona, et al., 1979; Trespi, Vigoni, Matti, et al., 1997). Both the etiology of the hepatitis and the dosage of SAMe administered showed great clinical heterogeneity, although these studies generally reported favorable effects of SAMe over placebo on transaminases. Effects on clinical outcomes (mortality, quality of life, etc.) were not reported.

#### Cirrhosis

Seven studies focused on the effect of SAMe in patients with cirrhosis from a variety of causes including acute and chronic viral infection as well as alcohol abuse (Gentile, Persico, Russo, et al., 1990; Ideo, 1975; Labo and Gasbarrini, 1975; Loguercio, Del Vecchio, Blanco, et al., 1993; Marchesini, Bugianesi, Bianchi, et al., 1992; Mato, Camara, De Paz, et al., 1999; Persico, Gentile, Di Padova, et al., 1990). The largest study in this group (Mato, Camara, De Paz, et al., 1999), which treated patients with alcoholic cirrhosis, had the highest Jadad score of the seven studies (5). In addition to showing improvements in laboratory values, Mato and his colleagues demonstrated a significant increase in longevity in patients with Child's class A or B cirrhosis following two years of treatment with SAMe (p=0.025) compared to usual and customary care. The results from the remainder of the studies are summarized in Evidence Table V. Because these studies show considerable variation in interventions as well as outcomes measured, they are best considered on an individual basis.

#### Other Liver Disease

Four studies focused on SAMe treatment of chronic liver disease in patients who did not necessarily have cirrhosis or cholestasis (Bresci and Marchioro, 1982; Mascio, Guida, Ferbo, et al., 1981; Micali, Chiti, and Balestra, 1983; Vendemiale, Altomare, Trizio, et al., 1989). Another study (Wong, Tredger, Wendon, et al., 1998) followed patients who were treated with either SAMe or placebo for three months after orthotopic liver transplantation. Outcomes were very heterogeneous, and no single variable was assessed in all of these studies. The most consistently favorable results reported in these studies were decreases in transaminase in the SAMe treatment group.

## Side Effects

Appendix F lists the side effects or adverse events reported in the 90 RCTs included in the evidence tables. Side effects and adverse events were not mentioned at all in 31 reports (34 percent) and were described with considerable heterogeneity in the remainder of the reports. Many reports provided general statements such as, “SAMe was well tolerated and caused no side effects,” or provided statistical testing comparing the overall number of side effects among groups rather than data about specific side effects (“drug-related adverse events and dropouts for adverse events were significantly lower in SAMe than chloripramine (p<0.05)”). Only about half of the studies reported specific side effects separately for each arm of the study. Even in these cases, side effects were sometimes aggregated by organ system (“gastrointestinal”) and sometimes reported individually (nausea, vomiting, etc.). Unfortunately, all these limitations preclude quantitative synthesis of these data, and no definitive conclusions can be drawn. The most that can be said, based on these data, is that the side effects of SAMe seem relatively minor and not of a life-threatening nature. However, future RCTs and observational studies that include a rigorous reporting method will be necessary to adequately gauge the side effects and adverse events of SAMe and how these compare to those of other treatments for depression, osteoarthritis, and liver disease.

## Comparison With Results Of Other Systematic Reviews

A number of reviews and meta-analyses have assessed the effectiveness of SAMe for the four conditions we reviewed. We compare our findings with theirs here.

### Studies Of The Effects Of SAME On Depression

For depression, a systematic review with meta-analysis (Janicak, Lipinski, Davis et al., 1988 and 1989) and a prior systematic review (Bressa, 1994) were identified. Janicak (Janicak, Lipinski, Davis et al., 1988 and 1989) reviewed both case series and comparison trials and concluded that SAMe showed greater efficacy than placebo and a slight preference for or at least comparable efficacy with SAMe relative to tricyclic antidepressants. The systematic review by Bressa (Bressa, 1994) reached the same conclusion. Both studies analyzed percentage of partial and full responders, which corresponds to our risk-ratio analyses. In general, we were able to calculate risk ratios for fewer studies than Bressa or Janicak, because both reported on unpublished data that were not available to us (some of the unpublished data appeared to come from the manufacturer). In contrast to the analyses of Bressa and Janicak, we also calculated an effect size for the HRSD measured continuously. The results of this analysis supported conclusions similar to those noted above. Bressa (1994) also identified, as we did, significant heterogeneity in the studies pooled for analysis. Neither Bressa nor Janicak performed an analysis of the frequency of side effects of SAMe compared to either placebo or other active antidepressants.

Another study was identified as a “meta-analysis” (Delle Chaie and Boissard, 1997); however, it included data from only two clinical trials, which were included in our meta-analysis. Additional review articles were identified (Friedel, Goa, and Benfield, 1989; Carney, Toone, and Reynolds, 1987; Brown, Gerbarg, and Bottiglieri, 2000; Brown and Gerbarg, 2001; Moreno and Ortiz, 1991; Tramoni and Azorin, 1988) that reviewed the literature in a nonsystematic way and were generally supportive of SAMe as an effective treatment for depression.

### Studies Of The Effects Of SAMe On Osteoarthritis

Two reviews were identified that focused on the use of SAMe for osteoarthritis. A relatively limited review by Schumacher (1987) concentrated on the potential mechanism of action of SAMe, its effect on the gastrointestinal tract, and the apparently smaller number of side effects for SAMe than for standard NSAID medications, rather than the efficacy of the therapy. Our analysis is more congruent with a systematic review of controlled and uncontrolled trials performed by Di Padova (1987), which concluded that SAMe improved both subjective and objective symptoms of osteoarthritis. Further, he noted that SAMe had a slower onset of action than NSAIDs, with less efficacy for SAMe demonstrated at 2 weeks and equivalent efficacy at 4 weeks. He also asserted that SAMe is well tolerated, but no data are presented to support this assertion. In our analysis, we were able to pool data for subjective symptoms only, i.e., pain. We were able to demonstrate a modest preference for SAMe versus placebo; however the small number of studies and the marked heterogeneity within one study (Bradley, 1994) limit the assurance with which this conclusion may be asserted. In comparison with NSAIDs, SAMe appeared to be approximately equivalent in efficacy for pain, according to our analysis.

### Studies Of The Effects Of SAMe On Liver Disease

In our analysis of the effects of SAMe on cholestasis for liver disease, we treated studies involving the intrahepatic cholestasis of pregnancy separately from studies of cholestasis due to other liver diseases. This treatment allowed us to reduce the clinical heterogeneity of the studies as a group sufficient to justify pooled analyses. One other meta-analysis by Tambini (Tambini, Fracassetti, Minola et al., 1997) was identified that focused solely on the intrahepatic cholestasis of pregnancy. A pooled analysis of three studies concluded that SAMe may be an effective symptomatic treatment for intrahepatic cholestasis of pregnancy because it reduced both bilirubin levels and pruritus scores. Only placebo-controlled studies were included. Our analysis included more studies and also compared SAMe to active therapy (UDCA). We concluded, as did Tambini, that SAMe was more effective than placebo. In our analysis, SAMe was likely inferior to UDCA for the treatment of pruritus and reduction of bilirubin.

Two meta-analyses and one systematic review were identified that evaluated combined data on cholestasis in both pregnant and other liver disease patients. The review by Coltorti, Bortoline, and Di Padova (1990) considered both open and placebo-controlled trials and segregated trials involving cholestasis of pregnancy from other liver diseases. Cholestasis of pregnancy trials that included active treatment were not reviewed. These authors concluded that SAMe was efficacious for relieving subjective symptoms and laboratory abnormalities in all types of intrahepatic cholestasis. Meta-analyses by Frezza and Terpin (1992) and by Frezza (1993) pooled data from pregnancy and other liver disease studies. In addition, they focused on SAMe versus placebo studies only. Both analyses concluded that SAMe was superior to placebo for cholestasis in decreasing both pruritus and bilirubin as well as improving other biochemical parameters such as liver enzymes. Comparison of our analyses with these two meta-analyses is somewhat hampered by the differences in studies included. We did not combine the intrahepatic-cholestasis-of-pregnancy patients with other liver-disease patients. However, our general conclusion for both patient populations is similar to conclusions drawn by these authors: SAMe is superior to placebo both to relieve symptoms (pruritus) and to decrease bilirubin. A systematic analysis of side effects was not done in any of the analyses discussed.

We also identified two additional nonsystematic reviews (Almasio, Bortolini, Pagliaro, et al., 1990; Chawla, Bonkovsky and Galambos, 1990). Chawla principally focused on the likely mechanism of action of SAMe, while Almasio also described preclinical data. SAMe was considered by these authors to have utility in the treatment of liver disease in general (Chawla, Bonkovsky and Galambos, 1990) and intrahepatic cholestasis in particular (Almasio, Bortolini, Pagliaro, et al., 1990).

Di Padova (Di Padova, Boissard and Brunetti, et al., 1996) performed a multivariate logistic regression analysis of pooled data from five studies of patients with chronic liver disease. Their analysis favored SAMe over placebo. They also identified the presence of a history of alcohol abuse, ascites, prior treatment, and elevated bilirubin as predictors of a positive effect.

### Summary Of Comparisons With Other Analyses

Thus, the results of our meta-analyses for the four conditions examined are generally in alignment with previously published reviews and meta-analyses. In some instances, we made different choices regarding study inclusion or exclusion as well as which parameters to analyze, but these differences did not affect the broad consensus that SAMe appears to be more effective than placebo for the conditions studied and to be roughly equivalent to [standard therapy for depression and osteoarthritis]. No other analyses were identified that compared active therapy for cholestasis of pregnancy; thus, we have no comparison for our conclusion that SAMe is not preferred to standard therapy for that condition.

Further, our analysis for depression, osteoarthritis, and liver disease included studies which were published subsequent to the last systematic review. We also performed more analyses for depression (risk ratios of percent decrease in HRSD scores) than Janicak or Bressa did. We did not analyze pooled data on transaminase enzyme response to SAMe, but we did analyze both pruritus and serum bilirubin for the two liver conditions studied.

#### Meta-analysis

In addition, our meta-analysis stratified cholestatic liver disease into cholestasis of pregnancy and cholestasis associated with other liver diseases. This appeared to us to be a clinically relevant distinction.

## Limitations Of The Review

A number of factors prevent us from drawing any stronger conclusions from our data. Although we identified the possibility of publication bias, we were unable to obtain unpublished studies. However, we did include a number of conference proceedings in our analyses. Research by McAuley and colleagues (McAuley et al., 2000) has demonstrated that the exclusion of the so-called “gray literature” (unpublished data, conference proceedings, and abstracts) exaggerates the estimates of the effects of interventions that are being tested. No attempt has been made to replicate this finding in the CAM area, but it is reasonable to expect exclusion of the “gray literature” for CAM therapies would be associated with bias in pooled estimates of effect. Thus the effects that we reported may overestimate the effectiveness of SAMe.

Many of the studies we analyzed suffered from methodological shortcomings such as small numbers of subjects and poor designs, which resulted in low quality scores. Thus, the conclusions that could be drawn from those studies were limited. Heterogeneity in the route of administration and dose of SAMe made it difficult to draw conclusions about the preferred amount and route of administration for any of the diseases considered. For liver disease, many of the studies enrolled very heterogeneous populations with respect to both diagnosis and stage of disease, thus making it difficult to draw conclusions about efficacy in any liver disease or condition except cholestasis.

If SAMe is roughly equivalent in its effectiveness to conventional therapy for depression and osteoarthritis, then issues of cost effectiveness, tolerability, side-effect profile, and patient preference become significant. This review was not designed to address these issues.

In addition, a general limitation of these studies, which is similar to conventional literature limitations, is the relatively short intervention periods and follow-up times, especially in the depression studies.

Finally, manufacturer support has been identified as a potential source of publication bias (Cook, Guyatt, Ryan, et al., 1993; Angell, 1989). In order to examine this possibility, we collected information regarding support from the studies included in the evidence table. This information is included in Appendix G. A direct statement of support by a known manufacturer of SAMe was considered the strongest indication of manufacturer support. However, given the large number of studies that made no direct statement regarding support, we had to consider other data as a possible indication of support; we considered this information in a hierarchical fashion. After a direct statement of support, supply of product was noted, and finally, consideration was given to affiliation of an author with a manufacturer of SAMe. Additional information regarding support by drug manufacturers that did not produce SAMe as well as other funding sources were reported where available. Finally, it was noted if the study appeared in one of the pooled analyses. A summary of these data by disease state is presented below in Table 24.

Table 24. SAMe manufacturer support by disease state

Disease State | Studies Included n Analysis | Studies with Support | Studies with Support Included in Analysis | Studies with Support Excluded from Analysis
Depression | 39 | 6 (15%) | 5 (13%) | 2 (5%)
Osteoarthritis | 13 | 4 (33%) | 4 (44%) | 0
Cholestasis pregnancy | 8 | 1 (12.5%) | 1 (12.5%) | 0
Cholestasis liver disease | 10 | 5 (50%) | 3 (33%) | 4 (40%)
Other liver disease | 20 | 5 (20%) | N/A | N/A

The only disease state for which a majority of the studies showed some level of support was cholestasis associated with liver disease. Even in this group, as many supported studies were included in the analysis as were excluded. For osteoarthritis, only four studies showed support, but all of those were included in the meta-analysis. Given the large number of studies that made no statement of support, firm conclusions could not be drawn. Future research publications in this area should include disclosure of funding and other support.