# Introduction

## Purpose

This evidence report details the methodology, results, and conclusions of a comprehensive literature review and synthesis of evidence on the use of S-adenosyl-L-methionine (SAMe) for the treatment of depression, osteoarthritis, and liver disease. Meta-analysis was performed where appropriate. The results may be used to develop a research agenda as well as to assist clinicians in advising patients who desire to take SAMe.

## Scope Of Work

Following discussion with our expert advisory panel and with the agencies funding and administering the project (National Center for Complementary and Alternative Medicine [NCCAM] and Agency for Healthcare Research and Quality [AHRQ]) and considering the conditions for which SAMe is usually recommended, we narrowed the focus of this analysis to the use of SAMe for depression, osteoarthritis, and liver disease.

## S-Adenosyl-L-Methionine

S-adenosyl-L-methionine (SAMe), derived from the sulfur-containing amino acid methionine and adenosine triphosphate (ATP), functions in the body in a large number of critical biochemical pathways. Biochemical pathways that involve SAMe include polyamine synthesis, trans-methylation and trans-sulfuration (Chawla, Bonkovsky, and Galambos, 1990; Chiang, Gordon, Tal, et al., 1996). A recent review of the biochemical effects of SAMe (Lu SC, 2000) cited its widespread importance in tissue function as the rationale for its investigation as a possible therapeutic agent for a number of disease states. The use of purified SAMe as a dietary supplement has received a great deal of recent attention in the lay media (Cowley and Underwood, 1999) and is the subject of at least seven recent books (Brown, Bottiglieri, Coleman, et al., 2000; Clouatre, 1999; Cooney, Lawren, and McCully, 1999; Grazi and Costa, 1999; Mitchell, 1999; Stedman, 2000). SAMe supplements have been widely promoted as a remedy for depression, osteoarthritis, and liver disease (Horowitz, 1999; Chawla, Bonkovsky, and Galambos, 1990). As the 25th most popular supplement sold in health food stores, SAMe's sales are projected to exceed $40 million in the United States in the year 2001 (Information PC, 2000).

The chemical structure of SAMe was first reported by Cantoni in 1952 (Cantoni, 1952), but a commercially viable parenteral product, a stabilized p-toluene sulfate derivative, was not available until 1974 in Italy (Chavez, 2000). Several observations suggested a possible role for SAMe in the treatment of depression. SAMe had been found in various regions of the brain, and use of psychotropic drugs had been observed to increase the levels of SAMe in plasma (Bell, Plotkin, Carreon, et al., 1994). In addition, the results of earlier research with schizophrenic patients and normal volunteers suggested that SAMe positively affects some of the major symptoms of depression (Agnoli, Andreoli, Casacchia, et al., 1976). After a stable form of SAMe became available, it was tested in clinical trials for depression; one of the earliest of these tests was conducted by Agnoli and colleagues (Agnoli, Andreoli, Casacchia, et al., 1976), with promising results, suggesting effectiveness in reduction of the symptoms of depression.

While continuing the study of the biochemistry of SAMe, researchers discovered that SAMe was critical for glutathione synthesis. Glutathione is one of the principal antioxidants in the liver. The effect on glutathione synthesis suggested a potential role for SAMe in the treatment of liver disease and injury, which was confirmed in animal models (Chawla, Bonksovsky, and Galambos, 1990). Clinical trials for a variety of liver conditions followed; among these was, notably, cholestasis(blockage of the flow of bile through the liver) (Osman, Owen, and Burroughs, 1993; Chawla, Bonkovsky, and Galambos, 1990; Almasio, Bortolini, Pagliaro, et al., 1990).

Serendipitously, patients enrolled in clinical trials testing the effects of SAMe on depression who also had osteoarthritis reported a beneficial effect of SAMe on this condition (Agnoli, Andreoli, Casacchia, et al., 1976). Anti-inflammatory and analgesic activity has been attributed to SAMe (Brown, Gerbargand, Bottiglieri, 2000) and efficacy was further supported by a two-year, open study (Konig, 1987). Additional studies followed, which tested SAMe against both a placebo and a variety of standard anti-inflammatory medications. (See Evidence Table II.)

All of the early trials with SAMe used parenteral delivery, either intravenous or intramuscular, since no stable oral form was available. The lack of a preparation of SAMe that could be administered orally limited its development as a pharmaceutical agent. Recently, an enteric-coated form has been developed that provides adequate blood levels following oral ingestion and absorption. This new formulation opened the way for more widespread use of SAMe and for its introduction in February 1999 as a dietary supplement in the U.S. market (Cowley and Underwood, 1999). While no rigorous analysis of SAMe has been done from country to country, raw materials for the p-toluene salt are manufactured by BASF (BioResearch Group) in Italy and sold to the two largest US producers of SAMe, General Nutrition Centers and Nature Made (Annon, 1999).

### Pharmacology And Pharmacokinetics Of SAMe

SAMe functions primarily as a methyl donor. A wide variety of molecules accept SAMe's methyl groups; naturally occurring recipients include proteins, phospholipids, DNA, RNA, hormones, and the energy-transporting amino acid creatine (Lieber, Casini, DeCarli, et al., 1990). Methyl transfer is essential to the development of the phospholipid bilayer that makes up the outer membranes of normal cells and contributes to membrane fluidity. SAMe-mediated transmethylation is also critical for the formation of neurotransmitters in the central nervous system (Bottiglieri, Hyland, and Reynolds, 1994). Hepatic transmethylation is also important: 85 percent of total body transmethylation occurs in the liver (Lieber, Casini, DeCarli, et al., 1990).

After donating its methyl group, SAMe is converted to s-adenosylhomocysteine, which initiates the important trans-sulfuration pathway in the liver, resulting in the generation of glutathione, the most potent antioxidant in the liver (Stramentinoli, 1987). The generation of hepatic glutathione is an important step in hepatic detoxification (Friedel, Goa, and Benfield, 1989), and SAMe increases hepatic glutathione in alcoholic and non-alcoholic liver disease patients (Vendemiale, Altomare, Trizio, et al., 1986; Vendemiale, Altomare, Trizio, et al., 1989). Both folate and vitamin B12 are essential co-nutrients in the metabolism and replenishment of SAMe (Mato, Alvarez, Ortiz, et al., 1997).

Pharmacokinetic studies have established that SAMe is able to cross the intestinal wall, where it is rapidly metabolized, and its methyl group is incorporated into stable pools including those of plasma proteins and phospholipids (Chawla, Bonkovsky, and Galambos, 1990; Friedel, Goa, and Benfield, 1989; Stramentinoli, 1987). SAMe was found to be 80–90 percent bioavailable following an intramuscular injection (Stramentinoli and Catto, 1976; Osman, Ownes, and Burroughs, 1992). The half-life of an injected 100 mg dose was 81 ± 8 minutes,and that of a 500 mg dose was 101 ± 7 minutes, with volumes of distribution of 0.41 and 0.44 L/kg for doses of SAMe (100 mg and 500 mg), respectively (Giuldori, Cortellaro, Moreo, et al., 1984).

Because of the low bioavailability of orally administered SAMe in healthy volunteers, a significant first-pass effect (degradation in the gastrointestinal tract) and rapid metabolism in the liver are presumed (Stramentinoli, Pezzoli, and Galli-Kienle, 1979). Peak plasma concentrations obtained with an enteric-coated tablet formulation are dose related, with peak plasma concentrations of 0.5 to 1 mg/L achieved 3 to 5 hours after single doses ranging from 400 mg to 1000 mg (Giulidori, Cortellaro, Moreo, et al., 1990; Stramentinoli, 1987). Peak levels decline to baseline within 24 hours.

Sex differences in bioavailability have been reported in a single study (Stramentinoli, 1987). Women showed a 3- to 6-fold greater peak plasma value than men.

Plasma-protein binding of SAMe is less than or equal to 5 percent (Kaye, Blake, and Burroughs, 1990). SAMe crosses the blood-brain barrier, with slow accumulation in the cerebrospinal fluid (Friedel, Goa, and Benfield, 1989). Excretion of unmetabolized SAMe in humans is split between urinary excretion (15.5 ± 1.5 percent) and fecal excretion (23.5 ± 3.5 percent) (Kaye, Blake, and Burroughs, 1990).

No significant adverse events have been reported in the clinical-trial literature for the use of either parenteral or enteral SAMe, and it is generally considered to be safe (Jellin, Batz, and Hitchens, 2001). However, the involvement of SAMe in the re-methylation of methionine from homocysteine (an amino acid intermediate) raises a theoretical concern that disruption of the regulation of transmethylation could result in increased homocysteine, which has been identified as an independent risk factor for heart disease (Selub and Miller, 1992; Finklestein, 2000). However, a pharmacological study found that oral doses of SAMe decreased the levels of homocysteine in the blood and did not adversely affect the activity of 5-methyltetrahydrofolate, a major co-factor involved in the metabolism of homocysteine (Loehrer, Schwab, Angst, et al., 1997).

## Depression

Depression is characterized by disturbances in emotional, cognitive, behavioral, and somatic regulation. A diagnosis of major depressive disorder is made if an individual has five or more of these symptoms during the same two-week period. Major depression typically presents in discrete episodes that recur during a person's lifetime (National Institute of Mental Health Report, 2000; Diagnostic and Statistical Manual of Mental Disorders, fourth edition revised, 2000).

In the United States, major depression ranks first among all causes of disability and second after heart disease as a cause of healthy years lost to premature mortality and disability. In fact, major depression is projected to displace ischemic heart disease as the leading source of disease burden over the next 20 years (Murray and Lopez, 1996; Lewis, 2001). Patients with untreated or inadequately treated depressive disorders have significant role-functioning difficulties and poor perceived health, all at considerable direct and indirect cost (Lewis, 2001).

Depressive disorders cause serious morbidity and a substantial risk of death. Fifteen percent of patients with recurrent depression commit suicide. Patients with mood disorders also have higher-than-average mortality from accidents and other illnesses. Depression is now recognized as a serious risk factor for cardiovascular disease and for fatality following myocardial infarction (Kupfer, Frank, Perel, et al., 1992; Pincus and Pettit, 2000).

### Epidemiology

Depression is a risk for people of all ages, ethnicities, and education and income levels, regardless of marital status. An estimated 10 percent to 25 percent of women and 5 percent to 12 percent of men in the United States will experience a major depressive disorder in their lifetime. The point prevalence rates have been estimated at 5 percent to 9 percent for women and 2 percent to 3 percent for men (Pincus and Pettit, 2001). With few exceptions, this increased prevalence in women is observed worldwide. Approximately 10 to14 million people are depressed in any given year, with the largest group comprising women ages 18 to 45. Risk factors for depression include female gender, a history of depressive illness, and prior episodes of major depression (Hyman and Rudorfer, 2000; Pincus and Pettit, 2001). Most individuals with depression suffer from recurrent or chronic illness. Without prophylactic treatment, recurrence rates after two or three episodes may range from 60 to 85 percent (Thase and Sullivan, 1995).

### Economic

The annual cost of depression in the United States has been estimated at $43.7 billion to $52.9 billion, including costs due to health care, suicide, and losses in productivity. Workplace costs related to absenteeism and reduced productivity have been estimated at $23.8 billion (Greenberg, Stiglin, Finkelstein, et al., 1993). The tremendous negative impact of depression and the lack of effective prevention strategies make the identification of effective treatment of primary importance (Depression in Primary Care Clinical Practice Guideline, 1993).

### Conventional Treatment

The mainstays of treatment for depression are antidepressant drugs and short-term psychotherapies. Other treatments such as electroconvulsive therapy (ECT) are typically reserved for specific types of clinical presentation or failure to respond to other interventions.

Antidepressants are a heterogeneous group of compounds, nearly all of which have been effective in the treatment of unipolar and bipolar depression (Hyman and Rudorfer, 2000; Nierenberg, 2001). Antidepressants work acutely for depression in general and for chronic depression in particular. After acute remission, long-term continuation and long-term maintenance protect patients from depressive relapses and recurrences (Dunner, 2001).

### Complementary and Alternative Medicine (CAM) Therapies For Depression

A survey of psychiatric outpatients by Knaudt and colleagues (Knaudt, Conner, Weisler, et al., 1999) revealed that 47 percent of all psychiatric patients in the study and 34 percent of patients with major depression were using alternative therapies. In a recent overview, Ernst notes that 20 percent of depressed patients used a CAM therapy in the previous year (Ernst, Rand, and Stevenson, 1998). Depression was one of the 10 most common reasons indicated for CAM use, and a wide variety of therapies including herbs, supplements, exercise, and traditional Chinese medicine have been reported in the literature. Patient preferences drive the choice of CAM therapy for depression, as was demonstrated in a recent article focusing on use of St. John's wort (Wagner, Jester, LeClaire, et al., 1999). Patients cited the desire for personal control of their medical care, the perception of high risk associated with prescription medication, and the ease of access to St. John's wort as reasons for their use of this alternative therapy. All these factors make it quite likely that patients who are depressed will try over-the-counter alternative therapies.

CAM therapies most often cited for use in depression include St. John's wort, which has been the subject of systematic reviews (Linde, Ramirez, Mulrow, et al., 1996; Gaster and Holroyd, 2000) as well as a Cochrane Review (Linde and Mulrow, 1999). Other herbs have been studied for effectiveness in depression or mood alteration but not subjected to systematic review (Werbach and Murray, 2000).

### SAMe For Depression

SAMe is the primary methyl donor in the central nervous system. A number of neurotransmitters, fatty acids, phospholipids, and other chemicals must accept methyl groups from SAMe for activation. Thus, it is postulated that the observed antidepressant effect of SAMe is due to its influence on neurotransmitter metabolism and on membrane fluidity and receptor activity (Bottiglieri and Hyland, 1994). Both serum and cerebrospinal fluid levels of SAMe are reported to be low in depressed patients (Bottiglieri, Chary, Laundy, et al., 1988; Bottiglieri, Godfrey, Flynn, et al., 1990), although reports of depressed serum SAMe levels were not consistent (Bottiglieri and Hyland, 1994). However, an increase in SAMe serum levels has been shown to be positively correlated with responses to both SAMe and imipramine therapy (Bell, Potkin, Carreon, et al., 1994), as defined by a 50 percent lower score on the Hamilton Depression Rating Scale.

## Osteoarthritis

Osteoarthritis (OA) is the most common form of arthritis, affecting millions of people in the United States (Lawrence, Helmick, Arnett, et al., 1998). OA continues to be a major public health problem, causing pain, disability, loss of time from work, and adverse effects on the economy. An estimated 15 percent (40 million) of Americans reported some form of arthritis in 1995 (Lawrence, Hochberg, Kelsey, et al., 1989). By 2020, an estimated 18 percent (59.4 million) will be affected, thus increasing chronic disability and costs by more than 25 percent (MMWR, 1994). In fact, the incidence of osteoarthritis may be even higher than these figures suggest. If x-rays of hands and feet are examined, 37 percent of the adults in the United States show changes consistent with osteoarthritis, and the incidence increases to 85 percent by the eighth decade of life (Moskowitz, 1987). Osteoarthritis is the second most common cause cited in claims for social security disability benefits (Lawrence, Helmick, Arnett, et al., 1998). The annual cost to society in medical care and lost wages is currently estimated to be $65 billion, and was projected to escalate to $95 billion by the year 2000 (Elders, 2000).

Clinically, patients with arthritis report joint pain and decreased joint function. Typically, the pain worsens with weight-bearing and physical activity and improves with rest. Additionally, patients may report symptoms of joint instability, periarticular muscle weakness, and fatigue. The onset of these symptoms is almost invariably insidious, with episodes of pain that increase in frequency and duration until, in the most severe cases, the patient is in constant pain (Moskowitz, 1987).

### Etiology

Although the causes of OA are not completely understood, biomechanical stresses affecting the articular cartilage and subchondral bone and biochemical changes in both the articular cartilage and synovial membrane are all important in its pathogenesis. Evidence has been cited on the role of systemic factors such as genetics, diet, estrogen use, and bone density; and local biomechanical factors such as muscle weakness, obesity, and joint laxity (Moskowitz, 1987).

### Conventional Treatment

OA has no known cure. Goals of therapy include control of pain and improvement in function and health-related quality of life. Available treatment modalities include joint protection and muscle strengthening; pharmacological treatments; intra-articular injections; biomechanical interventions such as exercise and bracing; and surgical treatments (Felson, Lawrence, Hochberg, et al., 2000; Moskowitz, 1987). Surgical management, including total joint arthroplasty, is generally reserved for failed medical management that affects a patient's quality of life and functioning. Increasingly, appropriate treatment of osteoarthritis combines one or more oral agents with exercise and other biomechanical techniques.

### CAM Therapies For Osteoarthritis

Musculoskeletal pain is one of the most common complaints brought to alternative providers. In a survey of family practice patients who use CAM therapies, back pain and other musculoskeletal pain accounted for 36 percent and 17 percent of the visits respectively (Drivdahl and Miser, 1998). Eisenberg (1998) reported that arthritis was the fourth most common condition for which patients sought alternative care. Of the patients surveyed, 26.7 percent had used CAM therapies in the previous 12 months; 38.5 percent had used CAM therapies while also seeing a physician; and only 10 percent had actually seen a CAM practitioner. Thus, a significant portion of their alternative care was self-directed. Forty-seven percent of older adults reported using at least one alternative therapy in a 20-week period and out-of-pocket expenses were very similar for both CAM and conventional therapies at $1,127 versus $1,148 per year respectively (Ramsey, Spencer,Topolski, et al., 2001).

A wide variety of CAM therapies have been used to treat osteoarthritis, but have generally not been the subject of systematic reviews. A recent systematic review (Ezzo, Hadhazy, Birch, et al., 2001) of acupuncture treatment for osteoarthritis of the knee suggested benefit from this therapy. Long and colleagues (Long, Soeken, and Ernst, 2001) have systematically reviewed the literature on herbal medicines for osteoarthritis and found supportive evidence for a variety of herbs and some proprietary blends.

### SAMe For Osteoarthritis

SAMe has been shown to have anti-inflammatory and analgesic properties in animal models when given both orally and parenterally (Stramentinoli, 1987). The mechanism by which this effect is achieved is not clear, but it does not seem to be mediated via the prostaglandin system, as inferred from the finding that oral administration of a single dose or repeated doses of up to 1200 mg/kg for 30 days in rats did not affect the integrity of the gastric mucosa, which suggests that SAMe does not interfere with the cytoprotective function of prostaglandins in gastrointestinal tissues. Furthermore, SAMe does not influence platelet aggregation (Stramentinoli, 1987) and has not been demonstrated to affect the eicosanoid system (Di Padova, 1987).

A stimulatory effect of SAMe on chondrocytes has been suggested from studies using human chondrocyte cultures (Harmand, Vilamitjana, Maloche, et al., 1987), and SAMe has also been shown to increase the incorporation of sulfate into proteoglycans (Harnand, Vilamitjana, Maoche et al., 1987). In addition, SAMe does enter the synovial fluid following oral doses of 400 mg (Giulidori, Cortellaro, Moreo et al., 1984), which suggests a reasonable mechanism of action by which SAMe may affect osteoarthritis.

## Liver Disease

Chronic and acute liver disease can result from a wide variety of etiologies, ranging from toxic through infectious or genetic causes. The types of liver disease for which SAME has been tested is correspondingly broad. The condition of cholestasis, which is the result of physiologic changes in pregnancy and represents a “final common pathway” of injury in liver disease generally, was the condition most often studied.

### Cholestasis Of Pregnancy

Intrahepatic cholestasis of pregnancy (ICP) is a disease that is diagnosed most frequently in women in their third trimester of pregnancy and is primarily characterized by pruritus, liver enzyme elevations, and occasionally jaundice (Palmer and Eads, 2000). The incidence of ICP is probably about one in 500 to 1000 pregnancies (Williams Obstetrics, 21^st^ Ed., 2001), but the etiology is not clear, and the condition's occurrence is not predictable. It has been suggested that ICP may arise from an inherited increase in sensitivity to estrogens and progestogens. In addition, altered membrane composition and differences in the canalicular transport systems are implicated in the pathogenesis of this condition. As a result, the normal elevations in maternal levels of bile acids are exaggerated in ICP patients. Also, because the normal fetal-to-maternal transfer of bile acids across the trophoblast is impaired, the excess bile acids accumulate and are toxic to the fetus.

Although maternal pruritus can be severe, overall maternal morbidity and mortality associated with ICP are low (Fagan, 1999). However, fetal morbidity and mortality are significant, with associated risks for meconium-stained amniotic fluid, acute onset of fetal compromise, spontaneous preterm labor, and intrauterine fetal demise (Palmer and Eads, 2000).

The need to manage ICP is dictated by the increased risks of fetal distress, spontaneous preterm delivery, and sudden death, as well as by the desire to alleviate pruritus in the mother. Fetal risks increase progressively until delivery, regardless of serum levels of bile acids and alanine transaminase (a marker for liver function).

Recommended obstetric management includes frequent fetal surveillance and careful intra-uterine monitoring, with prompt delivery when fetal lung maturity has been established. As for conventional therapies, only ursodeoxycholic has been effective in treating maternal pruritus and normalizing the levels of bile acids and sulfated steroids in serum and other body fluids; however, the studies that demonstrated these effects were small (Fagan, 1999). Nicastri and co-workers (Nicastri, Diaferia, Tartagni, et al., 1998) reaffirmed these findings and further reported that S-adenosylmethionine increased the effects of ursodeoxycholic acid (Williams Obstetrics, 21^st^ Ed., 2001).

### Cholestasis In Chronic Liver Disease

Intrahepatic cholestasis (IHC) is defined as the impedance of bile formation and flow without the presence of an extrahepatic obstruction. It is a relatively common complication of a wide variety of chronic liver diseases, both those that result in parenchymal damage and those that do not (McGill and Kwiatkowsi, 1998). In a series of 867 Italian inpatients with cirrhosis (83 percent), chronic active hepatitis (15 percent) and primary biliary cirrohsis (2 percent), 35 percent were found to have intrahepatitic cholestasis (Cimino, Dattilo, Topa, et al., 1989). These results were confirmed in a second survey of 2520 newly diagnosed chronic liver patients (cirrhosis, 56 percent; chronic hepatitis, 27 percent; primary biliary cirrhosis, 6 percent), which demonstrated that 35 percent of these patients had IHC as well (Bortolini, Almasio, and Bray, 1992). Although it is difficult to assign an economic cost to this condition, it is the cause of significant morbidity for the affected patients when it leads to pruritus.

The etiology of IHC appears to vary and may include medications; conditions associated with excessive estrogen (such as the use of oral contraceptive agents or pregnancy); infectious hepatitis (especially viral); autoimmune liver diseases; and toxic liver damage, such as alcoholic liver disease (Sherlock and Dooley, 1997). The clinical presentation is characterized by pruritus, usually with jaundice, and malabsorption due to inadequate bile acids in the intestine. Long-term sequelae may include steatorrhea, hepatic osteodystrophy, and fat-soluble vitamin deficiencies, especially of vitamin K with concomitant coagulopathy and bleeding (Sherlock and Dooley, 1997).

Conventional therapy for this illness includes cholestyramine, ursodeoxycholic acid, steroids, antihistamines, opiate antagonists and rifampicin. However, none of the conventional therapies is markedly effective, and none is without side effects. Some authorities recommend SAMe as an accepted therapy, while others regard it as no more than an experimental therapy (Raidford, 1995; Sherlock and Dooley, 1997).

### CAM Therapies And Liver Disease

Flora and his group at the Oregon Health Sciences University report on the widespread use of herbal medications and supplements by their chronic liver disease patients (Flora, Rosen, and Benner, 1996). In a survey of 103 patients attending a hepatology clinic, they found that 31 percent were using such remedies. A wide variety of substances were cited by patients, and 19 patients were using multiple remedies. Milk thistle was the most frequently used remedy. The majority of patients obtained information from sources other than their medical doctors, relying instead on books, magazines, friends, or family.

CAM therapies for use in hepatitis C have been the subject of two recent reviews (Milliman, Lamson, and Brignall, 2000; Patrick, 1999). Milk thistle and its anti-oxidant complex, silymarin, are the herbal remedies most often cited for use in chronic liver disease and have been the subject of a systematic review by the Agency for Healthcare Research and Quality (Mulrow, Lawrence, Jacobs, et al., 2000). Despite the widespread use of herbal therapies for chronic liver disease, some experts call for caution, citing fear of hepatotoxicity (Bass, 1999).

### SAMe And Liver Disease

SAMe has been used to treat various types of acute and chronic liver diseases, including viral hepatitis (both B and C), alcoholic liver disease (including cirrhosis), Gilbert's syndrome and other disorders of bilirubin and porphyrin metabolism, as well as drug-induced cholestasis. Additionally, SAMe has been used preventively to protect the liver from the effects of a number of hepatotoxic drugs (Friedel, Goa, and Benefield, 1989). Thus, the focus of clinical trials in this area has been diffuse. However, a number of clinical trials have focused on the effect of SAMe on cholestasis from a variety of causes, including pregnancy.

SAMe may exert beneficial effects on the liver through a variety of mechanisms. Glutathione, the major anti-oxidant in the liver, plays a key role in detoxification and limiting oxidative damage. At customary therapeutic doses, SAMe has been shown to increase hepatic glutathione concentrations in patients with chronic liver disease (Chawla, Bonkovsky, and Galambos, 1990). Results of clinical trials have suggested that SAMe may decrease fatty deposition in the liver (Micali, Chiti, and Balestra, 1983), and SAMe's ability to protect against ethanol damage to the liver was demonstrated in baboons fed a diet high in alcohol (Lieber, Casini, De Carli, et al., 1990).

Effects on membrane fluidity and on the activity of the Na+, K+ ATPase-dependent pump are postulated to account in part for the beneficial effect of SAMe on intrahepatic cholestasis (Almasio, Bortolini, Pagliaro, et al., 1990). Hormones, estrogen in particular, are known to contribute to cholestasis, especially of pregnancy (Bacq and Sapey, 1998; Davidson, 1998; Reyes, 1992; Salen and Batta, 1999). SAMe has been demonstrated to decrease the negative effects of ethnylestradiol on bile flow and bile composition (Coltori, Bortolini, and Di Padova, 1990). SAMe's ability to increase the bioavailability of sulfates through transulfuration has been postulated to improve bile flow by favoring production of more soluble sulfurated bile salts (Yousef, Branswell, Tuchweber, et al., 1987). In fact, SAMe seems to exert its anticholestatic effect in a nonspecific manner, regardless of the etiology of the cholestatic liver injury (Coltori, Bortolini, and Di Padova, 1990).

## Summary

SAMe is a popular dietary supplement that has been recommended for treating a number of conditions. The burden of these conditions, in terms of both disability and decreased function, has in turn led many patients to try SAMe. For each of the three conditions selected — depression, osteoarthritis, and liver disease — evidence suggests a possible mechanism by which SAMe may be of benefit in treating either the symptoms or the pathophysiology. This evidence report presents the results of a systematic review of the clinical literature on SAMe for use in depression, osteoarthritis, cholestasis of pregnancy and intrahepatic cholestasis for conditions associated with liver disease.