# Appendix I Authors' Response to Reviewer Comments

Reviewer | Reviewers' Comments | Authors' Response To Comments
Bottiglieri | May include the following reference: Brown R, Gerbarg P, Bottiglieri T. S-Adenosylmethionine (SAMe) in the Clinical Practice of Psychiatry, Neurology, and Internal Medicine. In Press: Clinical Practice of Alternative Medicine 2000; 1(4):230–241. | Added to Evidence Report and Bibliography.
Bottiglieri | A reference should be provided for the following sentence: “SAM had been found in various regions of the brain, and the use of psychotropic drugs had been observed to increase the levels of SAMe in CSF”. | Statement corrected and reference added. See Introduction chapter, page 7.
Bottiglieri | The effect of SAMe administration on blood homocysteine is an important issue. In addition to the study mentioned (Loehrer, et al., 1997) there are 2 other studies that have looked at this. | Other reviews of homocysteine metabloism added but specific articles not identified by the reviewer.
Bottiglieri | May also mention that the non-adherence rate for patients taking antidepressants is high - those who do not tolerate side effects are likely to seek CAM therapies. | Noted; Not directly related to this review.
Bottiglieri | The elderly population may benefit greatly from antidepressant CAM therapies. This group does not generally tolerate very well standard antidepressant treatments. Important also because the incidence of depression is much greater in the aging population. | Noted. Average age of subjects in the studies generally less than 65 years old - two studies (Parkinson's disease) had older populations. Other than these studies, the data do not speak directly to this issue.
Bottiglieri | A list of drug interactions and/or adverse reactions in the studies would be useful. | See comments at the end of the Results chapter and Appendix F.
Bottiglieri | It would be useful for clinicians to have some account of the adverse reactions that can occur with SAMe. This is one of the most frequently asked questions by both physicians and patients. | See comments at the end of the Results chapter and Appendix F.
Bottiglieri | The section on Future Research could be expanded to suggest other patient groups that may benefit from SAMe treatment, i.e., depression associated with other neurological disorders or diseases. | Added to Future Research section.
Bottiglieri | Furthermore, anecdotal reports suggest that combinational treatment with SAMe and SSRIs can help to reduce the amount of SSRI needed. This can reduce the side effect profile and increase SSRI compliance. Future trials can be designed to evaluate this effect. | Note studies in Evidence Table that combine SAMe with a second anti-depressant. Labeled as latency studies in the evidence table. They examined the ability of SAMe to decrease the onset of action of the conventional anti-depressant. The issue of decreased dosage was not addressed in any of the controlled clinical trials found in this analysis.
Brown | The section on SAMe for osteoarthritis in the Draft Evidence Report could be developed more. There is information on the mechanisms of action in osteoarthritis including: anti-inflammatory; production of analgesic spermine and spermidine via the aminopropylation pathway; chondrocyte differentiation; and decreased tumor necrosis factor alpha. | Material added. See Introduction chapter, page 13.
Brown | The MRI study by Konig (1995) and one rabbit study demonstrating cartilage regeneration are significant. | Abstract for this study found. Did appear to be a study on osteoarthritis using SAMe, but did not address clinical outcomes, which was a requirement for inclusion in the Evidence Report.
Brown | What was the reason for exclusion of the De Vanna 1992 study? The reason did not appear in the SAMe Evidence Table. | This study was included in the meta-analysis (see Evidence Table I).
Brown | The 1988 study by Tora, et al., followed the effect of SAMe on liver enzyme elevations (GTT) in 1,418 patients for 3 to 6 months on psychtropic medications (including anticonvulsants which are considered psychotropic because of their increasing use in Bipolar Disorder and other neuropsychiatric conditions) and a subset with alcohol abuse. Drug induced hepatitis is a problem in the treatment of depression and many medical conditions. Thus the literature on SAMe's capacity to prevent or reverse hepatitis due to drugs, alcohol, infections and other hepatotoxicities deserves mention. | We agree that an exciting possible application of SAMe would be in the treatment and possible prevention of drug related elevations in liver enzymes. This study (Tora, et al., 1988) was screened in our original search. It was not included in the evidence report because it was not a controlled clinical trial, which was a condition for inclusion in the analysis.
Brown | Abnormal SAMe synthesis has been found in chronic liver disease from lead. Lead poisoning is a public health problem. SAMe could be a useful and safe treatment for adults and children. | Noted. No clinical literature found in our search, therefore this topic was not addressed in this review.
Brown | The fact that, in contrast to NSAI drugs, SAMe does not cause erosion of the gastric mucosa is important in view of the large numbers of patients who die yearly from gastrointestinal bleeding secondary to NSAIDS. | See statement in Introduction chapter, page 13. See also Appendix F for compilation of data on side effects. We included the available data from the RCTs of head to head comparisons of NSAIDs and SAMe. Future RCTs are need to establish the relative risk/benefit ratio of SAMe and NSAIDs. See our comment in Future Research section.
Brown | Furthermore, there is a significant co-morbidity of depression and arthritis that is under recognized (Brown et al. 2001). | Only one study had RA and depression; Note the OA studies that included measures of depression (Evidence Table).
Brown | The findings from 3 recent large multi-center double-blind comparison trials by Delle Chiale, et al do not appear in your report. | Came in after the draft report and are included in the final report (see Evidence Table I).
Brown | Clinicians frequently use combinations of antidepressants with mood stabilizers for treatment resistant depression. SAMe is particularly easy to use because it does not interact adversely with any other psychotropic medications. | See studies labeled latency studies in the Evidence Table. Comment made in Results chapter and in Future Research section.
Brown | SAMe has very few side effects, particularly in comparison to other medications. For a discussion of SAMe side effects reported in the literature and observed in clinical practice see Brown et al. 2001, pgs 81–82. | See comments at the end of the Results chapter and Appendix F.
Coeytaux | [underlined: Osteoarthritis]. You state that the knee was the joint most often studied. But, you don't say much more in the rest of the report. | Comment removed.
Coeytaux | I recommend providing a better rationale for why the three seemingly unrelated conditions (OA, depression and liver disease) were? Selected. You simply state, at that point, that AHRQ was interested in those three conditions for which SAMe has been reported. I'd like to know more. | See material added to Introduction and Methods chapters.
Coeytaux | As a clinician, I'd like to know a little more about the various preparations of SAMe. I'd like to know how and where it is currently available (e.g., sold in health-food stores? Tablets? Capsules? In Solution? Cost range? Available/recommended dosage? Potentially toxic dose?) | See Introduction chapter, pages 7–8.
Coeytaux | [underlined: Introduction.] Do you have any information re: how many people have used SAMe, or how much was sold worldwide or in the US? | See Introduction chapter, pages 7–8.
Coeytaux | I recommend being more precise and consistent when discussing liver disease. | Noted and terminology as precise as possible.
Coeytaux | You may want to do a better job of describing Jadad's system of rating the quality of clinical trials. You might also include the form used for that purpose in the Appendix. | See material added to Methods chapter and Appendix E.
Diehl | Other liver conditions which had a reasonably large number of studies, such as cirrhosis, cholestatic liver disease not associated with pregnancy, and acute hepatitis were summarily dismissed with the phrase “clinical heterogeneity precludes pooled analysis.” …This I believe is a grave error…. Analysis for cirrhosis, acute hepatitis or cholestatic liver disease would have been very useful. | Analysis performed intrahepatic cholestasis associated with liver disease- see Evidence Table IV and Results section starting at page 40. Attempts to perform additional pooled analyses did not have sufficient studies for cirrhosis or hepatitis. Studies which were sufficiently homgeneous clinically did not have poolable outcomes. These studies were discussed qualitatively. Additional information on all trials not included in a meta-analysis, was included in the Evidence Tables.
Diehl | Practicing hepatologists and gastroenterologists would be very interested in the results of a SAMe drug trial, for example, in the treatment of cirrhosis, from whatever cause. | See Future Research section.
Diehl | Similarly, a drug that can improve cholestatic liver disease, from whatever cause, would be of real interest to anyone managing liver disease. | See Future Research section.
Fong | Although the main objective of this report was to delineate the efficacy of SAMe in these three categories of diseases, there were little or no data on potential side effects of SAMe. | See material added at the end of the Results chapter and Appendix F.
Fong | More data regarding the sources of SAMe (manufacturers) in these various studies should be provided. | Available data on manufacturer funding and provision of product, which was available in the published studies, is summarized in Appendix G.
Fong | Many of these studies were conducted in Europe and this reviewer questions whether a similar purity of SAMe would be available in the US. | See Introduction chapter, page 8.
Fong | It would be useful to provide more detailed background for the rationale for the different dosages used in the various studies. | Not provided in the studies and there was no dose escalation studies identified.
Fong | The limitation is in the quality of studies and the inherent shortcomings of meta-analysis. | See Limitations section at end of Results chapter.
Nagata | In regard to pharmacology and pharmacokinetics, the chemistry and physiology of SAMe should be mentioned in more detail to explain why these three categories, (such as depression) were chosen. For example, citing the review paper published by Dr. Lu might be useful (Lu, SC. Int J Biochem Cell Biol 2000. 32:391). | Material added to Introduction chapter. Reference cited was included in Introduction chapter, page 7.
Nagata | As mentioned on page 7 (“the result may be used to develop a research agenda…”), the purpose of this evidence report is to give recent information to scientists and clinicians for additional clinical study and advice to patients. Therefore, the dose of SAMe, length of treatment and when effectiveness can be seen should be stated. Although side effects are not written in detail in papers, information on adverse effects and the reason for dropouts should be described in as much detail as possible. | See Evidence Table for the length of treatment. See end of the Results chapter and Appendix F for discussion of side effects.
Pizzorno | Is the efficacy of SAMe dependent on the degree of depression (mild or severe)? This will be very important for clinicians to know as they work with clients and the public. | We agree that this is an important point. Unfortunately, most of the studies did not classify their patients in this manner. Additional studies should be done to assess which types and severity of depression would be most effectively treated with SAMe. See Future Research section.
Pizzorno | The most serious problem is the lack of assessment of SAMe toxicity and potential for drug interaction. Reporting only positive clinical results without the potential risks and interactions is problematic. | See end of the Results chapter and Appendix F for discussion of side effects.
Pizzorno | There is inadequate discussion of dosage. While there is some commentary, the report needs a more in-depth discussion of the criteria for determining the dosage classification, how the minimum likely effective dosage was determined and recommendations for, at least, an optimal dosage range. | This is a very important point, which unfortunately the literature we found could not answer. We did not find a single dose ranging RCT. Only 2 studies compared more than one dose of SAMe. Therefore we stated the need for this work in the Future Research section.
Pizzorno | The listing of CAM interventions for these three diseases is superficial and incomplete. If common CAM interventions are to be listed, then the discussion needs to be more complete | Additional material added so that this discussion is commensurate with the discussion of conventional therapies. Preference was given to systematic reviews of CAM therapies for the conditions discussed. Beyond the material included, this report was not meant to be an exhaustive review of CAM therapies but to provide a context for the use of SAMe.
Pizzorno | “CAM Therapies for Osteoarthritis” is quite incomplete. It only describes CAM use, but leaves out discussion of the many CAM therapies used, e.g., glucosamine sulfate, niacinamine, Harpagophytum procumbens, Boswellia serrata, etc. | See above and material added to the Introduction chapter, pages 12–13.
Pizzorno | SAMe has very few side effects, particularly in comparison to other medications. For a discussion of SAMe side effects reported in the literature and observed in clinical practice see Brown et al. 2001, pgs 81–82. | See material added to the end of the Results chapter and Appendix F.
Pizzorno | Surprisingly, there is no discussion of CAM therapies for liver disease. The CAM professions utilize a diverse array of nutritional, botanical and dietary interventions. | See response above and material added to the Introduction chapter, pages 14–15.
Pizzorno | Discussion of mechanism is fairly weak. Much more is understood about the mechanism of action of SAMe, especially the dietary and lifestyle factors which impact its availability and utilization. | Additional material added to the discussion of mechanism of action, especially for osteoarthritis. Information on mechanism of action was not meant to be exhaustive, but rather to put the clinical literature in context.
Pizzorno | Finally, the make-up of the Technical Expert Panel is a bit surprising. None of the panel members appears to be an expert in biochemistry or nutrition. I applaud the inclusion of CAM professionals in the panels of this nature. However, acupuncturists typically do not have expertise in nutritional medicine and no naturopathic doctor or holistic medical doctor with a known level of expertise in nutritional medicine has been included. | Because of the nature of the EPC contracts for CAM reviews, we have a single Technical Expert Panel (TEP) that provides input across all the topics we are assigned. It was not possible to constitute the TEP with a practitioner for each type of CAM. We use the peer review process to help ensure that we receive adequate input for each topic we assess. See Appendix J for our list of outside reviewers for this report.
Weisman | With regard to osteoarthritis, the area with which I am most familiar, it would be worth pointing out that the studies you cite fall short of using methodologies that are now being considered standard. These methodologies include composite indices such as the WOMAC as well as quality of life instruments that are now becoming quite appropriate surrogate markers for outcome in osteoarthritis. | Note this comment and include this in the consideration for Future Research section.
Weisman | Further, the field of outcome studies in osteoarthritis is growing rapidly in terms of disease modification, that is, radiographic or other imaging measures of true disease progression. Consideration of an agent as merely pain relief may not be the future direction for osteoarthritis therapy. | Note this comment and include this in the consideration for Future Research section.
Weisman | I do not necessarily agree that further exploratory studies should be done to investigate uses of this agent before more definitive studies are undertaken. You might consider making the recommendation for a large, multi-center, placebo and active controlled clinical trial such as what is being undertaken for glucosamine/chondroitin sulfate by the NIH. | Noted and this will be considered in the future research. For example, once the dosage issues are settled, a large multi-center trial is likely ready for depression.