# Appendix H Abbreviations for Outcomes in the Evidence Tables

AMDP | AMDP Rating Scale for Somatic Symptoms
ARA | ARA Functional Classification
BECK | Beck Self-Rating Depression Inventory
BPRS | Brief Psychiatric Rating Scale
CARROLL | Carroll Rating Scale for Depression
CI | Confidence Interval
CGI | Clinical Global Impression Scale
HRSD | Hamilton Rating Scale for Depression
HRSA | Hamilton Rating Scale for Anxiety
HAQ | Stanford Health Assessment Questionnaire
IPAD-DS | Institute for Personality and Testing Depression Scale
MMPI | Minnesota Multiphasic Personality Inventory
NOS | Not Otherwise Specified
PGA | Physician Global Assessment
RDCS | Research Diagnostic Criteria Spitzer
RDI | Rome Depression Inventory
VAS | Visual Analog Scale