# Appendix G Support Table

DEPRESSION

ID YEAR | Study | Support | Not Stated | Manufacturer SAMe | Manufacturer Not SAMe | Supplied Product | Other Funding | Author Affiliation | In Analysis
10008 | Agnoli 1976 | Not stated | X | | | | | | -
10278 | Ancarnai, 1993 | Bioresearch/BASF | | X | | | | | YES
10023 | Barberi 1978 | Not stated | X | | | | | | YES
10023 | Barberi 1978 | Not stated | X | | | | | | YES
10270 | Bell 1998 | Foundation | | | | | P | | YES
10353 | Bell 1994 | Not stated | X | | | | | | YES
10336 | Berlanga 1992 | Not stated | X | | | | | | -
10012 | Calandra 1979 | Not stated | X | | | | | | YES
10009 | Carney 1986 | Not stated | X | | | | | | YES
10284 | Carrieri 1990 | Not stated | X | | | | | | YES
10124 | Caruso 1987 | | X | | | | | | YES
10015 | Cerutti 1989 | Not stated | X | | | | | | YES
10314 | Cerutti 1993 | BioResearch/ BASF | | X | | | | | -
10301 | Chinchilla 1996 | Not stated | X | | | | | | -
10331 | De Leo 1987 | Not stated | X | | | | | | YES
10282 | De Vanna, 1992 | Supported in part BioResearch/BASF | | X | | | | | YES
10011 | Del Vecchio 1978 | Not stated | X | | | | | | YES
10261 | Delle Chiaie 1997 (Study 1) | Authors affiliated w/ BASF | X | | | | | X | YES
10261 | Delle Chiaie 1997 (Study 2) | Authors affiliated w/ BASF | X | | | | | X | YES
10265 | Delle Chiaie 2000 (Study 1) | Authors prior affiliation w/ BASF; Current affiliation not BASF | X | | | | | | YES
10264 | Delle Chiaie 2000 (Study 2) | Authors prior affiliation w/ BASF; Current affiliation not BASF | X | | | | | | YES
10382 | Di Padova 2000 (Study 1) | Published by Knoll Farmaceutici Spa | | X | | | | | YES
10382 | Di Padova 2000 (Study 2) | Published by Knoll Farmaceutici Spa | | X | | | | | YES
10018 | Fava 1992 | Not stated | X | | | | | | YES
10345 | Fazio 1973 | Not stated | X | | | | | | -
10017 | Janicak 1988 | Foundation | | | | | P | | YES
10340 | Kagan 1990a | Pfizer, VA, NIMH | | | X | | G | | YES
10014 | Kufferle 1982 | Not stated | X | | | | | | YES
10350 | Lo Russo 1994 | BioResearch/ BASF | X | X | | | | | -
10010 | Mantero 1975 | Not stated | X | | | | | | YES
10019 | Miccoli 1978 | Not stated | X | | | | | | YES
10021 | Monaco 1979 | Not stated | X | | | | | | YES
10016 | Muscettola 1982 | Not stated | X | | | | | | YES
10370 | Pons Villegas 1983 | Not stated | X | | | | | | -
10355 | Salmaggi 1993 | One author BioResearch/BASF | X | | | | | X | YES
10013 | Scaggion 1982 | Not stated | X | | | | | | YES
10020 | Scarzella 1978 | Not stated | X | | | | | | YES
10312 | Schifano 1993 | Boots Italia Spa (?) | X | | | | | | -
10394 | Thomas 1987 | Not stated | X | | | | | | -

OSTEOARTHRITIS

ID YEAR | 1st Author | Support | Not stated | Manufacturer SAMe | Manufacturer Not SAMe | Supplied Product | Other Funding | Author Affiliation | In Analysis
10360 | Bradley 1994 | Asta Medica AG/Germany | | | X | | | | YES
10125 | Capretto 1985 | Not stated | X | | | | | | YES
10092 | Caroli 1980 | Not stated | X | | | | | | YES
10086 | Caruso 1987 | Product supplied BioResearch/BASF | | | | X | | | YES
10094 | Cucinotta 1980 | Not stated | X | | | | | | -
10250 | Domljan 1989 | Product donated Astra Pharma Germany | | | X | | | | YES
10091 | Glorioso 1985 | Not stated | X | | | | | | -
10085 | Maccagno 1987 | Product supplied BioResearch/BASF | X | | | X | | | YES
10114 | Montrone 1985 | Not stated | X | | | | | | -
10376 | Marcolongo 1985 | Not stated | X
10083 | Muller-Fassbender 1987 | Product supplied BioResearch/BASF | X | | | X | | | YES
10096 | Polli 1975 | Not stated | X | | | | | | YES
10084 | Vetter 1987 | Product supplied BioResearch/BASF | X | | | X | | | YES

CHOLESTASIS OF PREGNANCY

ID YEAR | 1st Author | Support | Not stated | Manufacturer SAMe | Manufacturer Not SAMe | Supplied Product | Other Funding | Author Affiliation | In Analysis
10032 | Floreani 1996 | Ministerial Grant | | | | | G | | YES
10151 | Frezza 1984 | Not stated | X | | | | | | YES
10201 | Frezza 1987 | Not stated | X | | | | | | YES
10047 | Frezza 1990 | Di Padova associated with BASF | | | | | | X | YES
10150 | Lafuenti 1988 | Not stated | X | | | | | | YES
10138 | Nicastri 1998 | Not stated | X | | | | | | YES
10045 | Ribalta 1991 | University/ FONDECYT | | | | | G/U | | YES
10172 | Roncaglia 2000 | Not stated | X | | | | | | YES

CHOLESTASIS LIVER DISEASE

ID YEAR | 1st Author | Support | Not stated | Manufacturer SAMe | Manufacturer Not SAMe | Supplied Product | Other Funding | Author Affiliation | In Analysis
10202 | Adachi 1986 | SAMe supplied by BASF; | X | | | X | | | YES
10378 | Bombardieri 1985 | | X | | | | | | YES
10375 | Bray 1991 | One author affiliated with BioResearch (Di Padova) | | | | | | X | -
10190 | Cacciatore 1989 | Two authors identified as BASF (LeGrazie & Bortolini); Corresponding author Bortolini associated w/BASF | X | | | | | X | -
10194 | Fiaccadori 1988 | Not stated | X | | | | | | -
10199 | Frezza 1987 | Not stated | X | | | | | | YES
10053 | Frezza 1990 | One author identified as BASF (Di Padova); Partially supported by grant from BioResearch Co. | | X | | | | X | YES
10171 | Manzillo 1992 | One author identified as BASF (Giudici) | X | | | | | X | YES
10185 | O'Donohue 1996 | Not stated | X | | | | | | -
10136 | Qin 2000 | Not stated | X | | | | | | YES

OTHER LIVER DISEASE

ID YEAR | 1st Author | Support | Not stated | Manufacturer SAMe | Manufacturer Not SAMe | Supplied Product | Other Funding | Author Affiliation | In Analysis
10368 | Botero 1991 | Not stated | X | | | | | | -
10062 | Bresci 1982 | Not stated | X | | | | | | -
10135 | Di Palma 1978 | Not stated | X | | | | | | -
10028 | Diaz Belmont 1996 | Not stated | X | | | | | | -
10173 | Gentile 1990 | One author identified as BASF (Di Padova) | X | | | | | X | -
10157 | Ideo 1975 | Not stated | X | | | | | | -
10060 | Jorge 1985 | Not stated | X | | | | | | -
10156 | Labo 1875 | Not stated | X | | | | | | -
10167 | Loguercio 1993 | Not stated | X | | | | | | -
10243 | Marchesini 1992 | Product supplied BioResearch/BASF; 40% Ministry University Scientific & Technology Research | | | | X | G/U | | -
10066 | Mascio 1981 | Not stated | X | | | | | | -
10027 | Mato 1999 | BoehringerIngelheim; Knoll Pharmaceutical; Government grants (Spain); Di Padova Knoll Pharmaceutical reviewed the manuscript | | X | | | G | | -
10065 | Micali 1983 | Not stated | X | | | | | | -
10155 | Miglio 1975 | Not stated | X | | | | | | -
10153 | Musso 1980 | Not stated | X | | | | | | -
10067 | Pecoraro 1979 | Not stated | X | | | | | | -
10176 | Persico 1990 | One author affiliated with BioResearch (Di Padova) | X | | | | | X | -
10400 | Trespi | Not stated | X | | | | | | -
10149 | Vendemiale 1989 | One author affiliated with BioResearch (Di Padova) | X | | | | | X | -
10163 | Wong 1998 | Knoll Pharmaceutical | | X | | | | | -