# Appendix F Side Effects

DEPRESSION

ID YEAR | 1st Author | Information Regarding Side Effects Given | Psychiatric Side Effects | Gastrointestinal Side Effects | Other Side Effects (SAMe) | Details
10008 | Agnoli 1976 | Not stated
10278 | Ancarnai, 1993 | Yes | X | | Rash | Groups not reported separately
10023 | Barberi 1978 (Study 1) | Yes | X | X | Headache, Vertigo, Tachycardia | Groups reported separately; Studies not reported separately; SAMe: 4/50; Placebo: 4/20; Amitriptylline: 8/10
10023 | Barberi 1978 (Study 2)
10270 | Bell 1998 | Yes | | X | | Trend towards fewer side effects with SAMe than imipramine (p<0.06)
10353 | Bell 1994 | Not stated
10336 | Berlanga 1992 | Yes | | | | No psychiatric side effects reported
10012 | Calandra 1979 | Not stated
10009 | Carney 1986 | Yes | X | | | Numbers not specific; Placebo side effects not reported
10284 | Carrieri 1990 | Yes | | X | Headache, Insomnia | Did not exacerbate Parkinson's symptoms; Crossover study: 6 during SAMe treatment
10124 | Caruso 1987 | Not stated
10015 | Cerutti 1989 | Yes | | X | | 2 patients in miniprine group had mild GI side effects; No SAMe patients reported side effects
10314 | Cerutti 1993 | Not stated
10301 | Chinchilla 1996 | Yes | | X | | A 28 days, Fluoxetine: Mild-10 report/30 patients; Moderate-1 report/ 30 patients; Fluoxetine + SAMe: Mild — 1 report/ 30 patients; Moderate - 0 reports/ 30 patients
10331 | De Leo 1987 | Yes | X | | | 5 patients reported increased anxiety; No placebo side effects reported
10282 | De Vanna, 1992 | Yes | X | X | Dry mouth | SAMe: 6 nausea, 1 dry mouth, 1 mania, 3 patients withdrew; Imipramine: 1 nausea, 1 excessive sweating, 3 mouth dryness, 1 glaucoma, drowsiness, 1 dizziness, 4 patients withdrew
10011 | Del Vecchio 1978 | Yes | X | | | Non specific statement: “SAMe sporadic symptoms of easily controlled anxiety”; Chloripramine patients “presented the known considerable side effects of this drug”
10261 | Delle Chiaie 1997 (Study 1) | Not stated
10261 | Delle Chiaie 1997 (Study 2) | Yes | | | | Drug-related adverse events and drop-outs for adverse events significantly lower in SAMe than choloripramine (p<0.05)
10265 | Delle Chiaie 2000 (Study 1) | Yes | | | | “Adverse events were less in patients treated with SAMe compared to those treated to imipramine.”
10264 | Delle Chiaie 2000 (Study 2) | Yes | | | | “Adverse events were less in patients treated with SAMe compared to those treated to imipramine.”
10382 | Di Padova 2000 (Study 1) | Yes | | | | “Adverse events likely related to to study medication SAMe (7) vs. Imipramine (28) (p<0.001)”
10382 | Di Padova 2000 (Study 2) | Yes | | | | “Adverse events likely related to to study medication SAMe (14) vs. Imipramine (48) (p<0.001)”
10018 | Fava 1992 | Not stated
10345 | Fazio 1973 | Not stated
10017 | Janicak 1988 | Yes | X | | | SAMe: 1 psychotic decompensation
10340 | Kagan 1990a | Yes | X | | Skin, Headaches | SAMe: 5 patients (1 mania); Placebo: 6 patients
10328 | Kagan 1990b | Yes | X | | | SAMe: 1 mania
10014 | Kufferle 1982 | Yes | | X | | SAMe: 3/30 patients with GI side effects, 3 withdrawals; Placebo: 6/30 patients GI side effects, 2 withdrawals
10350 | Lo Russo 1994 | Not stated
10010 | Mantero 1975 | Yes | | | | Cholinergic side effects reported for imipramine group
10019 | Miccoli 1978 | Yes | X | X | Tachycardia, Restlessness | SAMe: 11 reports, None severe, No withdrawals; Tricyclic: 54 reports, 6 severe, 4 withdrawals
10021 | Monaco 1979 | Yes | | | | No adverse events noted
10016 | Muscettola 1982 | Yes | X | | | SAMe: I patient with anxiety
10370 | Pons Villegas 1983 | Not stated
10355 | Salmaggi 1993 | Yes | | | | SAMe: 2/40; Placebo: 3/40 minor side effects both group
10013 | Scaggion 1982 | Yes | | | | No adverse effects found in either group
10020 | Scarzella 1978 | Yes | | | | No adverse effects found in either group
10312 | Schifano 1993 | Yes | | | | No differences were found in side effects in either group
10394 | Thomas 1987 | Not stated

OSTEOARTHRITIS

ID YEAR | 1st Author | Information Regarding Side Effects Given | Psychiatric Side Effects | Gastrointestinal Side Effects | Other Side Effects (SAMe) | Details
10125 | Capretto 1985 | Yes | | X | Itch | SAMe: 3 mild, 1 moderate, 2 severe, 1 withdrawal; Ibuprofen: 9 mild, 3 moderate, 4 severe, 3 withdrawals
10092 | Caroli 1980 | Yes | X | | Allergy | SAMe: 4 patients; ASA: 16 patients
10086 | Caruso 1987 | Yes | X | X | | SAMe: 73 total reports, 62 GI effects, 8 CNS, 6 occult blood in stool; Naproxen: 117 total reports, 91 GI effects, 9 CNS, 14 occult blood in stool; Placebo: 60 total reports, 46 GI reports, 5 CNS reports, 3 occult blood in stool
10094 | Cucinotta 1980 | Yes | X | | Insomnia | SAMe: 4 patients (3 GI, 1 insomnia); Ibuprofen: 17 patients (10, GI, 3 depression, 1 insomnia, 1 pruritis)
10250 | Domljan 1989 | Yes | X | | Rash | SAMe: 4 total, 1 withdrawal; Naproxen: 3 total
10091 | Glorioso 1985 | Yes | | X | | SAMe: 5 total, all GI (4 moderate, 1 severe); Iburofen: 16 total, mainly GI (7 mild, 6 moderate, 3 severe)
10085 | Maccagno 1987 | Yes | | X | | SAMe: 4 total, all GI; Prioxicam: 9 total, 1 withdrawal. Not evaluated statistically
10114 | Montrone 1985 | Yes | | X | | SAMe: I patient with mild constipation; Choloripramine: “the usual side-effects like dry mouth and others were found.”
10083 | Muller-Fassbender 1987 | Yes | | | | No withdrawals from either group; “Both treatments were well tolerated.”
10096 | Polli 1975 | Yes | | X | | SAMe: 2 patients nausea; Indomethacin: 10 patients total (8 GI, 4 headaches)
10084 | Vetter 1987 | Yes | | X | | SAMe: 11% total, Nausea; Indomethacin: 39% total, 1 withdrawal

CHOLESTASIS OF PREGNANCY

ID YEAR | 1st Author | Information Regarding Side Effects Given | Psychiatric Side Effects | Gastrointestinal Side Effects | Other Side Effects (SAMe) | Details
10032 | Floreani 1996 | Not stated
10151 | Frezza 1984 | Yes | | | | “SAMe was well tolerated and caused no side effects”
10201 | Frezza 1987 | Yes | | | | No side effects reported in either group
10047 | Frezza 1990 | Yes | | | | No side effects reported in either group
10150 | Lafuenti 1988 | Not stated
10138 | Nicastri 1998 | Yes | | | | “No side effects treated in mothers or babies”
10045 | Ribalta 1991 | Yes | | | | “No adverse reactions attributable to SAMe or placebo were detected in mothers”
10172 | Roncaglia 2000 | Not stated

CHOLESTASIS LIVER DISEASE

ID YEAR | 1st Author | Information Regarding Side Effects Given | Psychiatric Side Effects | Gastrointestinal Side Effects | Other Side Effects (SAMe) | Details
10202 | Adachi 1986 | Yes | | | | “No adverse events were noted from administration of SAMe or prednisolone”
10378 | Bombardieri 1985 | Yes | | | | No side effects to SAMe treatments either IV or PO
10375 | Bray | Yes | | | | SAMe: No withdrawals; UDCA: 1 withdrawals; Rifampicin: 2 withdrawals
10190 | Cacciatore 1989 | Yes | | | | No dropouts for side effects in either group
10194 | Fiaccadori 1988 | Yes | | | | No side effects recorded
10199 | Frezza 1987 | Not stated
10053 | Frezza 1990 | Yes | | X | Insomnia, Headache | SAMe: 15/110 total (11 GI, 1 headache); Placebo: 11/110 (10 GI. 1 headache).
10171 | Manzillo 1992 | Yes | | | | “Intravenous and oral SAMe tolerated as well as placebo”
10195 | Manzillo 1988 | Yes | | X | Superficial phlebitis, sweating | SAMe: 16 total (5 insomnia, 3 GI, 7 phlebitis); Placebo: 10 total (4 GI, 3 superficial phlebitis, 1 rash)
10193 | Manzillo 1989 | Yes | | | | SAMe: 15 total; Placebo: 11 total; Minor and non-specific
10185 | O'Donohue 1996 | Yes | | | | No adverse events recorded in the SAMe group
10136 | Qin 2000 | Not stated

OTHER LIVER DISEASE

ID YEAR | 1st Author | Information Regarding Side Effects Given | Psychiatric Side Effects | Gastrointestinal Side Effects | Other Side Effects (SAMe) | Details
10368 | Botero 1991 | Yes | | | | No adverse side effects seen in either group
10062 | Bresci 1982 | Yes | | | | “No side effects were observed in the SAMe group”
10135 | Di Palma 1978 | Not stated
10028 | Diaz Belmont 1996 | Yes | | | | “SAMe group had no bad effects and was well tolerated”
10173 | Gentile 1990 | Not stated
10157 | Ideo 1975 | Not stated
10060 | Jorge 1985 | Not stated
10156 | Labo 1875 | Not stated
10167 | Loguercio 1993 | Not stated
10243 | Marchesini 1992 | Not stated
10066 | Mascio 1981 | Not stated
10027 | Mato 1999 | Yes | | X | | SAMe: No adverse events reported in the treatment group; Withdrawal: SAMe 5 (3 nausea, 1 diarrhea, 1 pyrosis); Placebo 1 (1 nausea)
10065 | Micali 1983 | Not stated
10155 | Miglio 1975 | Not stated
10153 | Musso 1980 | Not stated
10067 | Pecoraro 1979 | Yes | | | | No side effects reported in the SAMe group
10176 | Persico 1990 | Not stated
10400 | Trespi | Not stated
10149 | Vendemiale 1989 | Not stated
10163 | Wong 1998 | Not stated