# Appendix E The Jadad Score

A Method for assessing the quality of controlled clinical trials

Basic Jadad Score is assessed based on the answer to the following 5 questions.

The maximum score is 5.

Question | Yes | No
1. Was the study described as random? | 1 | 0
2. Was the randomization scheme described and appropriate? | 1 | 0
3. Was the study described as double-blind? | 1 | 0
4. Was the method of double blinding appropriate? (Were both the patient and the assessor appropriately blinded?) | 1 | 0
5. Was there a description of dropouts and withdrawals? | 1 | 0

## Quality Assessment Based on Jadad Score

Range of Score | Quality
0–2 | Low
3–5 | High