# Appendix B

## Articles Not Obtainable

1. Antun F. Open study of SAMe in depression. Symposium on transmethylations. Trieste, Italy 1987;
2. Bell MB, Carreon D, Plon L, et al. Oral S-adenosylmethionine in the treatment of depression: a double-blind comparison with desipramine. Study Report. BioResearch file 1990;
3. Hubrich P, Ecker S, Reiff J, et al. Ademetionine versus clomipramine in the treatment of major depression. 10th World Congress of Psychiatry 1996 Aug.;2(285.
4. Labriola FR, Kalina E, Glina H, et al. Accion de la SAMe en depressiones endogenas. V Congreso Nacional de la Sociedad Mexicana de Psiquiatria Biologica y II Symposium de la Federacion Latinoamericana de Psiquiatria Biologica. Cd. de Pueble Mexico 1986;