# Appendix J Acknowledgments

## Reviewers

We gratefully acknowledge the following individuals who reviewed the initial draft of this report and provided us with constructive feedback. Acknowledgments are made with the explicit statement that this does not constitute endorsement of the report.

Teodoro Bottiglieri, M.Sc., Ph.D.

Baylor Institute of Metabolic Disease

Dallas, TX

Richard Paul Brown, M.D.

Columbia University

Department of Psychiatry

New York, NY

Francesco Chiappelli, Ph.D.^*^

* Also a member of the technical expert panel

University of California, Los Angeles

Laboratory of Human Oral & Molecular

Immunology

School of Dentistry

Los Angeles, CA

Carlos Di Padova, M.D.

Knoll Famaceutical Spa

Research & Development

Milan, Italy

David Diehl, M.D.

New York University Medical Center

Department of Medicine

Division of Gastroenterology

New York, NY

Remy Coeytaux, M.D.

University of North Carolina

Department of Family Medicine

Chapel Hill, NC

Tse-Ling Fong, M.D.

University of Southern California

Division of Gastroenterology

Los Angles, CA

Patricia L. Gerbarg, M.D.

Kingston, NY

Submitted in review concert with Dr. Richard Paul Brown.

Yasuo Nagata, Ph.D.

Pharmavite Corporation

Director, Scientific Affairs

Mission Hills, CA

Joseph Pizzarno, N.D.

Bastyr University

President Emeritus

Kenmore, WA

Michael Weisman, M.D.

Cedars-Sinai Medical Center

Director, Division of Rheumatology

Los Angeles, CA

Note: Dr. Mary Hardy wishes to disclose that she serves on the Scientific Advisory Board of Pharmavite Corporation.

## Technical Expert Panel

We wish to acknowledge the work of our technical expert panel:

Betty L. Chang, DNSc, FNP-C, FAAN

Professor, School of Nursing

University of California, Los Angeles

Los Angeles, CA

Seigward-Markus Elsas, M.D.

Clinical Fellow in Neurophysiology

University of California, Los Angeles

Los Angeles, CA

Glenn Clark, DDS

School of Dentistry

University of California, Los Angeles

Los Angeles, CA

Deborah Glik, Ph.D.

Associate Professor, School of Public Health

University of California, Los Angeles

Los Angeles, CA

Michael Goldstein, Ph.D.

Professor, School of Public Health

University of California, Los Angeles

Los Angeles, CA

Eric Hurwitz, D.C., Ph.D.

Assistant Professor, Department of Epidemiology, School of Public Health,

University of California

Los Angeles, CA

Ka Kit Hui, M.D., FACP

Director, UCLA Center for East-West Medicine

University of California

Los Angeles, CA

Simon Mills, MA, MCPP, FNIMH

Director for the Center of Complementary Medicine

University of Exeter

Exeter, England

Lakshmi C. Mishra, BIMS, M Pharm, Ph.D .

Professor of Research

Southern California University of Health Science

Whittier, CA

Shri K. Mishra, M.D., MS, Doctor of Ayurveda

Professor of Neurology and Coordinator

Integrative Medicine

USC School of Medicine

USC Keck School of Medicine

Los Angeles, CA

Lucy Postolov, LAc

Postolova Acupuncture Group

Los Angeles, CA

David Riley, M.D.

Clinical Associate Professor

University of North West Medical School,

Director, Integrative Medicine Research

Santa Fe, NM

Betsy B. Singh, PhD

Dean of Research

Southern California University of Health Sciences

Whittier, CA

George Solomon, M.D.

Professor Emeritus, UCLA School of Medicine, Dept. of Psychiatry and Biobehavioral Medicine

University of California

Los Angeles, CA

Hitoshi Tomizawa, M.D.

Director, Japanese Executive Medical Services, Cedars-Sinai Medical Center

Los Angeles, CA

Xiao-Ping Xu, LAc

Burns and Allen Research Institute

Cedars Sinai Medical Center

Los Angeles CA

## Others

We would also like to acknowledge and thank the following individuals:

Pamela Elfenbaum, M.P.H.

University of Southern California

Los Angeles, CA

Greg Orshansky, M.D.

Cedars-Sinai Medical Center

Los Angeles, CA

Jay Udani, M.D.

Northridge Community Hospital

Director

Program of Integrative Medicine

Northridge, CA

Shannon Rhodes, MSA

Staff Assistant

Evidence-Based Practice Center

RAND

Santa Monica, CA