# Appendix A Search Methods

## SAM-e SEARCH #1

Date Performed: 10/3/2000

Databases searched and time periods covered:

Medline | 1966-2000
HealthSTAR | 1975-2000
Embase | 1974-2000
Biosis Previews | 1969-2000

Search Concepts:

S-ADENOSYLMETHIONINE? OR SADENOSYLMETHIONINE? OR S ADENOSYL METHIONINE? OR SAM(2W)E AND ARTHRITIS OR OSTEOARTHRITIS OR HEPAT? OR LIVER OR DEPRESSION OR DEPRESSIVE DISORDER OR AFFECTIVE NEUROSIS OR ANTIDEPRESSIVE AGENTS AND DOCUMENT TYPE = RANDOMIZED CONTROLLED TRIAL OR RANDOMI? OR RANDOM ALLOCAT? OR META ANALYS? OR SYSTEMATIC REVIEW? OR CASE SERIES OR CASE STUD?

Results of Titles Search By Topic:

Arthritis | 16
Hepatitis/Liver | 21
Depression | 31
| 68

Titles generated from search: 68

## SAM-e SEARCH #2A

Date Performed: 10/03/2000

Databases searched and time periods covered:

MANTIS | 1880-2000
Allied & Alternative Medicine (AMED) | 1984-2000

Search Concepts:

S-ADENOSYLMETHIONINE? OR SADENOSYLMETHIONINE? OR S ADENOSYL METHIONINE?

Results of Title Search: 6

## SAM-e SEARCH #2B

Date Performed: 10/05/2000

Databases searched :

Cochrane Library | 1922-2000/December

Search Concepts:

S-ADENOSYLMETHIONINE OR SADENOSYLMETHIONINE OR (S-ADENOSYL AND METHIONINE) OR (S AND ADENOSYLMETHIONINE) OR (SADENOSYL AND METHIONINE OR (S AND ADENOSYL AND METHIONINE)

Titles generated from search: 117

## SAM-e SEARCH #2C

Date Performed: 07/30/2001

Databases searched and time period covered:

CINAHL | 1982-2000 (June)

Terms searched:

S ADENOSYLMETHIONINE OR SADENOSYLMETHIONINE OR S ADENOSYL METHIONINE OR SADENOSYL METHIONINE OR ADEMETHIONINE OR ADEMETIONINE

Titles generated from search: 39

## SAM-e SEARCH #3A

Date Performed: 11/7/00

Databases searched and time period covered:

MEDLINE | 1966-2000
HealthSTAR | 1975-2000
EMBASE | 1974-2000
Biosis Previews | 1969-2000
MANTIS | 1880-2000 (March)
Allied & Alternative Medicine (AMED) | 1984-2000

[Note - in the following search, MANTIS had no hits and AMED only had one hit.]

Terms searched:

S ADENOSYLMETHIONINE- OR SADENOSYLMETHIONINE- OR S ADENOSYL METHIONINE- OR SADENOSYL METHIONINE-

and

ARTHRITIS(EXPLODED) OR ARTHRITIS OR OSTEOARTHRITIS OR JOINT DISEASES(EXPLODED) OR ARTHROPATHY(EXPLODED) OR JOINT DISEASE- OR JOINT INFLAM-

and

HUMAN

Titles generated from search: 88

## SAM-e SEARCH #3B

Date Performed: 11/7/2000

Databases searched and time period covered:

MEDLINE | 1966-2000
HealthSTAR | 1975-2000
EMBASE | 1974-2000
Biosis Previews | 1969-2000
MANTIS | 1880-2000 (March)
Allied & Alternative Medicine (AMED) | 1984-2000

Terms searched:

S ADENOSYLMETHIONINE- OR SADENOSYLMETHIONINE- OR S ADENOSYL METHIONINE- OR SADENOSYL METHIONINE-

and

LIVER DISEASE(S)(EXPLODED) OR CHOLESTASIS(EXPLODED) OR OBSTRUCTIVE BILE DUCT DISEASE(EXPLODED) OR CHOLESTASIS OR HEPAT- OR LIVER

and

HUMAN

Titles generated from search: 469

## SAM-e SEARCH #3C

Date Performed: 11/9/2000

Databases searched:

MEDLINE

HealthSTAR

EMBASE

Biosis Previews

MANTIS

Allied & Alternative Medicine (AMED)

Time period covered: 1992-2000

Terms searched:

S ADENOSYLMETHIONINE- OR SADENOSYLMETHIONINE- OR S ADENOSYL METHIONINE- OR SADENOSYL METHIONINE-

and

DEPRESSIVE DISORDER(EXPLODED) OR DEPRESSION IN TITLE OR SUBJECT HEADING OR DEPRESSIVE DISORDER- IN TITLE OR SUBJECT HEADING OR AFFECTIVE NEUROSIS(EXPLODED) OR ANTIDEPRESSIVE AGENTS(EXPLODED) OR ANTIDEPRESSANT AGENT(EXPLODED) OR ANTIDEPRESSANT- OR ANTIDEPRESSIVE- OR ANTI DEPRESS-

and

HUMAN

Titles generated from search: 124

Note -the following search was actually part of search #3c, but because the databases searched specialize in psychology and mental health, the concepts for depression were not included in the search.

Databases searched:

PSYCINFO

MENTAL HEALTH ABSTRACTS

Time period covered: 1992-2000

Terms searched:

S ADENOSYLMETHIONINE- OR SADENOSYLMETHIONINE- OR S ADENOSYL METHIONINE- OR SADENOSYL METHIONINE-

and

HUMAN

Titles generated from search: 39

## SAM-e SEARCH #4A

Date Performed: 11/15/2000

Databases searched and time period covered:

Inside Conferences | 1993-2000
ELSEVIER BIOBASE | 1994-2000
International Pharmaceutical Abstracts | 1970-2000
Conference Papers Index | 1973-2000
Pascal | 1973-2000
CAB HEALTH | 1983-2000
Pharm-Line | 1978-2000
Derwent Drug File | 1983-2000
SciSearch (Current) | 1990-2000
Pharmaceutical News Index | 1974-2000
Adis LMS Drug Alerts | 1983-2000
Drug News & Perspectives | 1992-2000
Gale Group Newsletter DB | 1987-2000
Health News Daily | 1990-2000
TGG Health&Wellness DB | 1976-2000
IMSWorld R&D Focus | 1991-2000

Terms searched:

S ADENOSYLMETHIONINE- OR SADENOSYLMETHIONINE- OR S ADENOSYL METHIONINE- OR SADENOSYL METHIONINE-

and

ARTHRITIS OR OSTEOARTHRITIS OR JOINT DISEASE- OR JOINT INFLAM-

and

HUMAN

Titles generated from search: 107

## SAM-e SEARCH #4B

Performed 11/15/00:

Databases searched and time period covered:

Inside Conferences | 1993-2000
ELSEVIER BIOBASE | 1994-2000
International Pharmaceutical Abstracts | 1970-2000
Conference Papers Index | 1973-2000
Pascal | 1973-2000
CAB HEALTH | 1983-2000
Pharm-Line | 1978-2000
Derwent Drug File | 1983-2000
SciSearch (Current) | 1990-2000
Pharmaceutical News Index | 1974-2000
Adis LMS Drug Alerts | 1983-2000
Drug News & Perspectives | 1992-2000
Gale Group Newsletter DB | 1987-2000
Health News Daily | 1990-2000
TGG Health&Wellness DB | 1976-2000
IMSWorld R&D Focus | 1991-2000

Terms searched:

S ADENOSYLMETHIONINE- OR SADENOSYLMETHIONINE- OR S ADENOSYL METHIONINE- OR SADENOSYL METHIONINE-

and

HEPATI- OR LIVER OR CHOLESTASIS

and

HUMAN

Titles generated from search: 260

## SAM-e SEARCH #4C

Date Performed: 11/20/2000

Databases searched and time period covered:

Inside Conferences | 1993-2000
ELSEVIER BIOBASE | 1994-2000
International Pharmaceutical Abstracts | 1970-2000
Conference Papers Index | 1973-2000
Pascal | 1973-2000
CAB HEALTH | 1983-2000
Pharm-Line | 1978-2000
Derwent Drug File | 1983-2000
SciSearch (Current) | 1990-2000
Pharmaceutical News Index | 1974-2000
Adis LMS Drug Alerts | 1983-2000
Drug News & Perspectives | 1992-2000
Gale Group Newsletter DB | 1987-2000
Health News Daily | 1990-2000
TGG Health&Wellness DB | 1976-2000
IMSWorld R&D Focus | 1991-2000
Adis Newsletters (Current) | Latest 4 weeks
Adis Newsletters (Archive) | 1982-latest 4 weeks

Terms searched:

S ADENOSYLMETHIONINE- OR SADENOSYLMETHIONINE- OR S ADENOSYL METHIONINE- OR SADENOSYL METHIONINE-

and

DEPRESSION OR DEPRESSIVE OR ANTIDEPRESS- OR ANTI-DEPRESS-

and

HUMAN

Titles generated from search: 234

## SAM-e SEARCH #5

Date Performed: 07/25/2001

Databases searched and time period covered:

MEDLINE | 1966-2000
HealthSTAR | 1975-2000
EMBASE | 1974-2000
Biosis Previews | 1969-2000
MANTIS | 1880-2000
Inside Conferences | 1993-2000
ELSEVIER BIOBASE | 1994-2000
International Pharmaceutical Abstracts | 1970-2000
Conference Papers Index | 1973-2000
Pascal | 1973-2000
CAB HEALTH | 1983-2000
Pharm-Line | 1978-2000
Derwent Drug File | 1983-2000
SciSearch (Current) | 1990-2000
Pharmaceutical News Index | 1974-2000
Adis LMS Drug Alerts | 1983-2000
Drug News & Perspectives | 1992-2000
Gale Group Newsletter DB | 1987-2000
Health News Daily | 1990-2000
TGG Health&Wellness DB | 1976-2000

Terms searched:

ADEMETHIONINE

Titles generated from search: 11