# Appendixes

Appendix A Search Methods

Appendix B

Appendix C Article Screening Form

Appendix D

Appendix E The Jadad Score

Appendix F Side Effects

Appendix G Support Table

Appendix H Abbreviations for Outcomes in the Evidence Tables

Appendix I Authors' Response to Reviewer Comments

Appendix J Acknowledgments