# Appendixes

Appendix A Peer Reviewers

Appendix B Journals Searched

Appendix C Search Strategies

Appendix D Abstract Review Form

Appendix E Quality Assesment Form

Appendix F Reproducibility of White-Coat Hypertension