# Bibliography

Arch Intern Med 1997 157(21):2413 46 9385294
Abe H, Yokouchi M, Saitoh F, Deguchi F, Kimura G, Kojima S, Yoshimi H, Ito K, Kuramochi M, Ikeda M and others Hypertensive complications and home blood pressure: comparison with blood pressure measured in the doctor's office J Clin Hypertens 1987 3(4):661 9 2969039
Ahmed W, Oriaku O, and Pickering TG. The prevalence of white-coat hypertension in African American. Ethn Dis. 1998;8.
Aihara A, Imai Y, Sekino M, Kato J, Ito S, Ohkubo T, Tsuji I, Satoh H, Hisamichi S, and Nagai K Discrepancy between screening blood pressure and ambulatory blood pressure: a community-based study in Ohasama Hypertens Res 1998 21(2):127 36 9661809
Amar J, Vernier I, Rossignol E, Bongard V, Arnaud C, Conte JJ, Salvador M, and Chamontin B Nocturnal blood pressure and 24-hour pulse pressure are potent indicators of mortality in hemodialysis patients Kidney Int 2000 57(6):2485 91 10844617
Andersen AR and Nielsen PE Home readings of blood pressure in hypertension Scand J Prim Health Care 1985 3(2):71 7 4059703
Antivalle M, Lattuada S, Paravicini M, Rindi M, and Libretti A Twenty-four hour non-invasive ambulatory blood pressure monitoring in the assessment of early hypertension J Hypertens 1986 4(Suppl 5):S322 S324
Antivalle M, Lattuada S, Salvaggio A, Paravicini M, Rindi M, and Libretti A Placebo effect and adaptation to noninvasive monitoring of BP J Hum Hypertens 1990 4(6):633 7 2096204
Appel LJ The role of diet in the prevention and treatment of hypertension Curr Atheroscler Rep 2000 2(6):521 8 11122788
Appel LJ and Stason WB Ambulatory blood pressure monitoring and blood pressure self- measurement in the diagnosis and management of hypertension Ann Intern Med 1993 118(11):867 82 8093115
Asagami T, Kushiro T, Inoue J, and Kanmatsuse K Long-term reproducibility and usefulness of daytime recording of noninvasive 24-hour ambulatory blood pressure monitoring in borderline hypertension: a two-year follow-up study Clin Exp Hypertens 1996 18(5):637 57 8781751
Asmar RG, Girerd XJ, Brahimi M, Safavian A, and Safar ME Ambulatory blood pressure measurement, smoking and abnormalities of glucose and lipid metabolism in essential hypertension J Hypertens 1992 10(2):181 7 1313482
Ayala DE, Hermida RC, Mojon A, Fernandez JR, and Iglesias M Circadian blood pressure variability in healthy and complicated pregnancies Hypertension 1997 30(3 Pt 2):603 10 9322989
Ayala DE, Hermida RC, Mojon A, Fernandez JR, Silva I, Ucieda R, and Iglesias M Blood pressure variability during gestation in healthy and complicated pregnancies Hypertension 1997 30(3 Pt 2):611 8 9322990
Aylett M Use of home blood pressure measurements to diagnose "white coat hypertension' in general practice J Hum Hypertens 1996 10(1):17 20 8642185
Aylett M, Marples G, and Jones K Home blood pressure monitoring: its effect on the management of hypertension in general practice Br J Gen Pract 1999 49(446):725 8 10756615
Ayman D and Goldshine AD. Blood pressure determinations by patients with essential hypertension, I: The difference between clinic and home readings before treatment. Am J Med Sci. 1940;200:465-74.
Baba S, Ozawa H, Nakamoto Y, Ueshima H, and Omae T Enhanced blood pressure response to regular daily stress in urban hypertensive men J Hypertens 1990 8(7):647 55 2168455
Baguet JP, De Gaudemaris R, Antoniadis A, Tremel F, Siche JP, and Mallion JM Use of ambulatory blood pressure monitoring data to predict left ventricular mass in hypertension Blood Press Monit 2001 6(2):73 80 11433127
Baguet JP, Mallion JM, Moreau-Gaudry A, Noirclerc M, Peoc'h M, and Siche JP Relationships between cardiovascular remodelling and the pulse pressure in never treated hypertension J Hum Hypertens 2000 14(1):23 30 10673727
Bailey B, Carney SL, Gillies AA, and Smith AJ Antihypertensive drug treatment: a comparison of usual care with self blood pressure measurement J Hum Hypertens 1999 13(2):147 50 10100064
Baker B, Paquette M, Szalai JP, Driver H, Perger T, Helmers K, O'Kelly B, and Tobe S The influence of marital adjustment on 3-year left ventricular mass and ambulatory blood pressure in mild hypertension Arch Intern Med 2000 160(22):3453 8 11112239
Bald M, Kubel S, and Rascher W Validity and reliability of 24h blood pressure monitoring in children and adolescents using a portable, oscillometric device J Hum Hypertens 1994 8(5):363 6 7695689
Bang LE, Buttenschon L, Kristensen KS, and Svendsen TL Do we undertreat hypertensive smokers? A comparison between smoking and non-smoking hypertensives Blood Press Monit 2000 5(5-6):271 4 11153050
Bang LE, Holm J, and Svendsen TL Retinol-binding protein and transferrin in urine. New markers of renal function in essential hypertension and white coat hypertension? Am J Hypertens 1996 9(10 Pt 1):1024 8 8896656
Bar J, Maymon R, Padoa A, Wittenberg C, Boner G, Ben-Rafael Z, and Hod M White coat hypertension and pregnancy outcome J Hum Hypertens 1999 13(8):541 5 10455476
Barton JR, Stanziano GJ, and Sibai BM Monitored outpatient management of mild gestational hypertension remote from term Am J Obstet Gynecol 1994 170(3):765 9 8141198
Basler HD, Brinkmeier U, Buser K, Haehn KD, and Molders-Kober R Psychological group treatment of essential hypertension in general practice Br J Clin Psychol 1982 21(Pt 4):295 302 6756521
Battig B, Steiner A, Jeck T, and Vetter W Blood pressure self-measurement in normotensive and hypertensive patients J Hypertens Suppl 1989 7(3):S59 63
Bauduceau B, Genes N, Chamontin B, Vaur L, Renault M, Etienne S, and Marre M Ambulatory blood pressure and urinary albumin excretion in diabetic (non-insulin-dependent and insulin-dependent) hypertensive patients: relationships at baseline and after treatment by the angiotensin converting enzyme inhibitor trandolapril Am J Hypertens 1998 11(9):1065 73 9752891
Baumgart P, Walger P, Jurgens U, and Rahn KH Reference data for ambulatory blood pressure monitoring: what results are equivalent to the established limits of office blood pressure? Klin Wochenschr 1990 68(14):723 7 2391953
Beckman M, Panfilov V, Sivertsson R, Sannerstedt R, and Andersson O Blood pressure and heart rate recordings at home and at the clinic. Evidence for increased cardiovascular reactivity in young men with mild blood pressure elevation Acta Med Scand 1981 210(1-2):97 102 7293832
Beevers G, Lip GY, and O'Brien E Blood pressure measurement. Part ii-conventional sphygmomanometry: technique of auscultatory blood pressure measurement BMJ 2001 322(7293):1043 7 11325773
Bellomo G, Narducci PL, Rondoni F, Pastorelli G, Stangoni G, Angeli G, and Verdecchia P Prognostic value of 24-hour blood pressure in pregnancy JAMA 1999 282(15):1447 52 10535435
Benedetto C, Marozio L, Giarola M, Chiarolini L, Maula V, and Massobrio M Twenty-four hour blood pressure monitoring in early pregnancy: is it predictive of pregnancy-induced hypertension and preeclampsia? Acta Obstet Gynecol Scand 1998 77(1):14 21 9492711
Berenson GS, Dalferes E Jr, Savage D, Webber LS, and Bao W Ambulatory blood pressure measurements in children and young adults selected by high and low casual blood pressure levels and parental history of hypertension: the Bogalusa Heart Study Am J Med Sci 1993 305(6):374 82 8506897
Bergbrant A, Hansson L, and Jern S Borderline hypertension. A 24-hour abnormality Am J Hypertens 1993 6(8):713 8 8217035
Berglund G, De Faire U, Castenfors J, Andersson G, Hartford M, Liedholm H, Ljungman S, Thulin T, and Wikstrand J Monitoring 24-hour blood pressure in a drug trial. Evaluation of a noninvasive device Hypertension 1985 7(5):688 94 4040887
Bianchi S, Bigazzi R, Baldari G, Sgherri G, and Campese VM Diurnal variations of blood pressure and microalbuminuria in essential hypertension Am J Hypertens 1994 7(1):23 9 8136107
Bieniaszewski L, Staessen JA, Polfliet J, Thijs L, and Fagard R Treatment of hypertensive patients according to the conventional or ambulatory pressure: a progress report on the APTH trial. APTH Investigators. Ambulatory Blood Pressure and Treatment of Hypertension Acta Cardiol 1996 51(3):243 51 8817007
Binstock ML and Franklin KL A comparison of compliance techniques on the control of high blood pressure Am J Hypertens 1988 1(3 Pt 3):192S 4S 3415798
Biswas A, Choolani MA, Anandakumar C, and Arulkumaran S Ambulatory blood pressure monitoring in pregnancy induced hypertension Acta Obstet Gynecol Scand 1997 76(9):829 33 9351407
Bjorklund K, Lind L, and Lithell H Twenty-four hour ambulatory blood pressure in a population of elderly men J Intern Med 2000 248(6):501 10 11155143
Bongiovi S, Palatini P, Macor F, Visentin P, and Pessina AC Age and blood-pressure-related changes in left ventricular diastolic filling J Hypertens Suppl 1992 10(2):S25 30
Bottini PB, Carr AA, Rhoades RB, and Prisant LM Variability of indirect methods used to determine blood pressure. Office vs mean 24-hour automated blood pressures Arch Intern Med 1992 152(1):139 44 1728909
Braun HJ, Rabouw H, Werner H, van Montfrans GA, de Stigter C, and Zwinderman AH Measurements of blood pressure with various techniques in daily practice: uncertainty in diagnosing office hypertension with short-term in-hospital registration of blood pressure Blood Press Monit 1999 4(2):59 64 10450115
Brown MA, Buddle ML, Cario GM, and Whitworth JA Ambulatory blood pressure monitoring during pregnancy. Comparison with mercury sphygmomanometry Am J Hypertens 1993 6(9):745 9 8110427
Brown MA, Robinson A, and Jones M The white coat effect in hypertensive pregnancy: much ado about nothing? Br J Obstet Gynaecol 1999 106(5):474 80 10430198
Brueren MM, Schouten HJ, de Leeuw PW, van Montfrans GA, and van Ree JW A series of self-measurements by the patient is a reliable alternative to ambulatory blood pressure measurement Br J Gen Pract 1998 48(434):1585 9 9830184
Brueren MM, van Limpt P, Schouten HJ, de Leeuw PW, and van Ree JW Is a series of blood pressure measurements by the general practitioner or the patient a reliable alternative to ambulatory blood pressure measurement? A study in general practice with reference to short-term and long-term between-visit variability Am J Hypertens 1997 10(8):879 85 9270082
Burt VL, Whelton P, Roccella EJ, Brown C, Cutler JA, Higgins M, Horan MJ, and Labarthe D Prevalence of hypertension in the US adult population. Results from the Third National Health and Nutrition Examination Survey, 1988-1991 Hypertension 1995 25(3):305 13 7875754
Campbell NR, Myers MG, and McKay DW Is usual measurement of blood pressure meaningful? Blood Press Monit 1999 4(2):71 6 10450116
Campo C, Fernandez G, Gonzalez-Esteban J, Segura J, and Ruilope LM Comparative study of home and office blood pressure in hypertensive patients treated with enalapril/HCTZ 20/6 mg: the ESPADA study Blood Press 2000 9(6):355 62 11212065
Cannella G, Paoletti E, Ravera G, Cassottana P, Araghi P, Mulas D, Peloso G, Delfino R, and Messa P Inadequate diagnosis and therapy of arterial hypertension as causes of left ventricular hypertrophy in uremic dialysis patients Kidney Int 2000 58(1):260 8 10886571
Canter D, Texter M, and McLain R Screening out 'white coat' hypertensives from clinical trials PHARM. MED 1993 7(3):229 37
Canter DA, Texter MJ, and McLain RW Ambulatory blood pressure monitoring can play an integral role in patient selection, dosage adjustment and efficacy assessment in clinical trials of antihypertensive agents J Hypertens Suppl 1994 12(7):S33 8
Cardillo C, De Felice F, Campia U, and Folli G Psychophysiological reactivity and cardiac end-organ changes in white coat hypertension Hypertension 1993 21(6 Pt 1):836 44 8500864
Cardillo C, De Felice F, Campia U, Musumeci V, and Folli G Relation of stress testing and ambulatory blood pressure to hypertensive cardiac damage Am J Hypertens 1996 9(2):162 70 8924266
Carnahan JE and Nugent CA The effects of self-monitoring by patients on the control of hypertension Am J Med Sci 1975 269(1):69 73 1130437
Carr AA, Bottini PBand Prisant LM Ambulatory blood pressure monitoring for evaluation and management of hypertensives: effect on outcome and cost effectiveness J Clin Pharmacol 1992 Jul 32(7):610 3
Cartwright W, Dalton KJ, Swindells H, Rushant S, and Mooney P Objective measurement of anxiety in hypertensive pregnant women managed in hospital and in the community Br J Obstet Gynaecol 1992 99(3):182 5 1606113
Casadei B Use of ambulatory blood pressure monitoring in pharmacological trials J Hum Hypertens 1991 5Suppl 2:31 4 1791617
Cavallini MC, Roman MJ, Pickering TG, Schwartz JE, Pini R, and Devereux RB Is white coat hypertension associated with arterial disease or left ventricular hypertrophy? Hypertension 1995 26(3):413 9 7649575
Celis H, De Cort P, Fagard R, Thijs L, and Staessen JA For how many days should blood pressure be measured at home in older patients before steady levels are obtained? J Hum Hypertens 1997 11(10):673 7 9400910
Cerasola G, Cottone S, Mule G, Nardi E, Mangano MT, Andronico G, Contorno A, Li Vecchi M, Galione P, Renda F, Piazza G, Volpe V, Lisi A, Ferrara L, Panepinto N, and Riccobene R Microalbuminuria, renal dysfunction and cardiovascular complication in essential hypertension J Hypertens 1996 14(7):915 20 8818932
Cerasola G, Cottone S, Nardi E, D'Ignoto G, Volpe V, Mule G, and Carollo C White-coat hypertension and cardiovascular risk J Cardiovasc Risk 1995 2(6):545 9 8665373
Cerasola G, D'Ignoto G, Cottone S, Nardi E, Grasso L, Zingone F, and Volpe V Blood pressure pattern importance in the development of left ventricular hypertrophy in hypertension G Ital Cardiol 1991 21(4):389 94 1834509
Cerrai T, Benedetti I, Della Scala F, Gori M, Nicolini S, Pampaloni S, Paolini R, Piccioli GC, Righi M, Romoli R, and Torricelli S Blood pressure measurement in haemodialysis patients EDTNA ERCA J 1999 25(2):9 11
Chamorro A, Saiz A, Vila N, Ascaso C, Blanc R, Alday M, and Pujol J Contribution of arterial blood pressure to the clinical expression of lacunar infarction Stroke 1996 27(3):388 92 8610300
Chase HP, Garg SK, Icaza G, Carmain JA, Walravens CF, and Marshall G 24-h ambulatory blood pressure monitoring in healthy young adult Anglo, Hispanic, and African-American subjects Am J Hypertens 1997 10(1):18 23 9008244
Chatellier G, Battaglia C, Pagny JY, Plouin PF, and Menard J Decision to treat mild hypertension after assessment by ambulatory monitoring and World Health Organisation recommendations BMJ 1992 305(6861):1062 6 1467686
Chatellier G, Dutrey-Dupagne C, Vaur L, Zannad F, Genes N, Elkik F, and Menard J Home self blood pressure measurement in general practice. The SMART study. Self-measurement for the Assessment of the Response to Trandolapril Am J Hypertens 1996 9(7):644 52 8806976
Chaturvedi N, Athanassopoulos G, McKeigue PM, Marmot MG, and Nihoyannopoulos P Echocardiographic measures of left ventricular structure and their relation with rest and ambulatory blood pressure in blacks and whites in the United Kingdom J Am Coll Cardiol 1994 24(6):1499 505 7930282
Chau NP, Bauduceau B, Vilar J, and Gautier D Ambulatory blood pressure is still elevated in treated hypertensive diabetic subjects compared with untreated diabetic subjects with the same office blood pressure J Hum Hypertens 1992 6(2):91 4 1597851
Chau NP, Bauduceau B, Vilar J, and Gautier D Relationship between autonomic dysfunction and BP variability in subjects with diabetes mellitus J Hum Hypertens 1993 7(3):251 5 8345492
Chau NP, Chanudet X, Berardi L, and Larroque P Ambulatory blood pressure in young subjects with familial history of hypertension Clin Exp Hypertens [A] 1991 13(1):103 15
Chau NP, Chanudet X, and Larroque P A method to define reference profiles for ambulatory blood pressure, with application to blood pressure profiles in 158 young subjects Clin Exp Hypertens [A] 1988 10(6):951 69
Chazot C, Charra B, Laurent G, Didier C, Vo Van C, Terrat JC, Calemard E, Vanel T, and Ruffet M Interdialysis blood pressure control by long haemodialysis sessions Nephrol Dial Transplant 1995 10(6):831 7 7566612
Chen CH, Ting CT, Lin SJ, Hsu TL, Chou P, Kuo HS, Wang SP, Yin FC, and Chang MS Relation between diurnal variation of blood pressure and left ventricular mass in a Chinese population Am J Cardiol 1995 75(17):1239 43 7778547
Christen Y, Ganslmayer M, Waeber B, Burnier M, Nussberger J, and Brunner HR Use of non-invasive ambulatory blood pressure monitoring to screen for high-risk hypertensive patients J Hypertens Suppl 1990 8(6):S119 24 2081993
Churchill D and Beevers DG Differences between office and 24-hour ambulatory blood pressure measurement during pregnancy Obstet Gynecol 1996 88(3):455 61 8752258
Churchill D, Perry IJ, and Beevers DG Ambulatory blood pressure in pregnancy and fetal growth Lancet 1997 349(9044):7 10 8988114
Ciaroni S, Cuenoud L, and Bloch A Clinical study to investigate the predictive parameters for the onset of atrial fibrillation in patients with essential hypertension Am Heart J 2000 139(5):814 9 10783214
Clark S, Fowlie S, Pannarale G, Bebb G, and Coats A Age and blood pressure measurement: experience with the TM2420 ambulatory blood pressure monitor and elderly people Age Ageing 1992 21(6):398 403 1471576
Clement DL and De Buyzere M Office versus Ambulatory (OvA) recording of blood pressure, a European multicenter study: inclusion and early follow-up characteristics Blood Press Monit 1998 3(3):167 72 10212349
Coats AJ Reproducibility or variability of casual and ambulatory blood pressure data: implications for clinical trials J Hypertens Suppl 1990 8(6):S17 20 2081995
Coats AJ, Conway J, Somers VK, Isea JE, and Sleight P Ambulatory pressure monitoring in the assessment of antihypertensive therapy Cardiovasc Drugs Ther 1989 3Suppl 1:303 11 2487802
Coats AJ, Radaelli A, Clark SJ, Conway J, and Sleight P The influence of ambulatory blood pressure monitoring on the design and interpretation of trials in hypertension J Hypertens 1992 10(4):385 91 1316405
Cocchi R, Esposti ED, Fabbri A, Lucatello A, Sturani A, Quarello F, Boero R, Bruno M, Dadone C, Favazza A, Scanziani R, Tommasi A, and Giangrande A Prevalence of hypertension in patients on peritoneal dialysis: results of an Italian multicentre study Nephrol Dial Transplant 1999 14(6):1536 40 10383021
Collins R, Peto R, MacMahon S, Hebert P, Fiebach NH, Eberlein KA, Godwin J, Qizilbash N, Taylor JO, and Hennekens CH Blood pressure, stroke, and coronary heart disease. Part 2, Short-term reductions in blood pressure: overview of randomised drug trials in their epidemiological context Lancet 1990 335(8693):827 38 1969567
Colombo F, Catarame S, Cossovich P, Fundaro C, Perilli E, Fiorini T, and Libretti A Isolated office hypertension: are there any markers of future blood pressure status? Blood Press Monit 2000 5(5-6):249 54 11153047
Conway J and Coats A Value of ambulatory blood pressure monitoring in clinical pharmacology J Hypertens Suppl 1989 7(3):S29 32
Corsi V, Germano G, Appolloni A, Ciavarella M, de Zorzi A, and Calcagnini G Fully automated ambulatory blood pressure in the diagnosis and therapy of hypertension Clin Cardiol 1983 6(3):143 50 6851276
Covic A, Goldsmith DJ, and Covic M Reduced blood pressure diurnal variability as a risk factor for progressive left ventricular dilatation in hemodialysis patients Am J Kidney Dis 2000 35(4):617 23 10739781
Covic A, Goldsmith DJ, Farmer CK, Cox J, Dallyn P, Sharpstone P, and Kingswood JC How reproducible is diurnal blood pressure rhythm in patients with secondary (renal) hypertension? Rev Med Chir Soc Med Nat Iasi 1999 103(1-2):88 93 10756891
Cox J, Amery A, Clement D, De Cort P, Fagard R, Fowler G, Iranzo RM, Mancia G, O'Brien E, O'Malley K and others Relationship between blood pressure measured in the clinic and by ambulatory monitoring and left ventricular size as measured by electrocardiogram in elderly patients with isolated systolic hypertension J Hypertens 1993 11(3):269 76 8387084
Cox J, O'Malley K, Atkins N, and O'Brien E A comparison of the twenty-four-hour blood pressure profile in normotensive and hypertensive subjects J Hypertens Suppl 1991 9(1):S3 6
Cox JP, Atkins N, O'Malley K, and O'Brien E Does isolated systolic hypertension occur with ambulatory blood pressure measurement? J Hypertens Suppl 1991 9(6):S100 1 1818899
Csiky B, Kovacs T, Wagner L, Vass T, and Nagy J Ambulatory blood pressure monitoring and progression in patients with IgA nephropathy Nephrol Dial Transplant 1999 14(1):86 90 10052483
Cunha DM, Cunha AB, Martins Wd W, Pinheiro LA, Romeo LJ, Moraes AV A, and Morcerf FP Echocardiographic assessment of the different left ventricular geometric patterns in hypertensive patients Arq Bras Cardiol 2001 76(1):22 8
Cuspidi C, Lonati L, Sampieri L, Macca G, Michev I, Salerno M, Fusi V, Leonetti G, and Zanchetti A Impact of blood pressure control on prevalence of left ventricular hypertrophy in treated hypertensive patients Cardiology 2000 93(3):149 54 10965085
Cuspidi C, Lonati L, Sampieri L, Macca G, Valagussa L, Zaro T, Michev I, Fusi V, Leonetti G, and Zanchetti A Impact of nocturnal fall in blood pressure on early cardiovascular changes in essential hypertension J Hypertens 1999 17(9):1339 44 10489113
Cuspidi C, Lonati L, Sampieri L, Macca G, Valagussa L, Zaro T, Michev I, Salerno M, Leonetti G, and Zanchetti A Blood pressure control in a hypertension hospital clinic J Hypertens 1999 17(6):835 41 10459882
Cuspidi C, Lonati L, Sampieri L, Michev I, Macca G, Rocanova JI, Salerno M, Fusi V, Leonetti G, and Zanchetti A Prevalence of target organ damage in treated hypertensive patients: different impact of clinic and ambulatory blood pressure control J Hypertens 2000 18(6):803 9 10872567
Cuspidi C, Marabini M, Lonati L, Sampieri L, Comerio G, Pelizzoli S, Leonetti G, and Zanchetti A Cardiac and carotid structure in patients with established hypertension and white-coat hypertension J Hypertens 1995 13(12 Pt 2):1707 11 8903637
Czarnecka D, Kawecka-Jaszcz K, Lubaszewski W, Rajzer M, and Curylo A Circadian blood pressure changes and cardiac geometry in essential arterial hypertension J Hum Hypertens 1996 10Suppl 3:S95 8 8872837
Daniels SR, Loggie JM, Burton T, and Kaplan S Difficulties with ambulatory blood pressure monitoring in children and adolescents J Pediatr 1987 111(3):397 400 3625408
de Faire U, Lindvall K, and Nilsson B Noninvasive ambulatory 24 h blood pressures and basal blood pressures predict development of sustained hypertension from a borderline state Am J Hypertens 1993 6(2):149 55 8471234
De Gaudemaris R, Camaleonte A, Dimitriou R, Debru JL, and Mallion JM Interest of ambulatory blood pressure, exercise test recordings and echocardiographic measurements, in borderline arterial hypertension Clin Exp Hypertens [A] 1985 7(2-3):371 9
de Gaudemaris R, Chau NP, and Mallion JM Home blood pressure: variability, comparison with office readings and proposal for reference values. Groupe de la Mesure, French Society of Hypertension J Hypertens 1994 12(7):831 8 7963513
de Gaudemaris R, Mallion JM, and Battistella P Ambulatory blood pressure and variability by age and sex in 200 normotensive subjects: reference population values J Hypertens 1987 5(Suppl 5):S429 S430
de la Sierra A, Bragulat E, Sierra C, Gomez-Angelats E, Antonio MT, Aguilera MT, and Coca A Microalbuminuria in essential hypertension: clinical and biochemical profile Br J Biomed Sci 2000 57(4):287 91 11204857
Del Torre M, Mormino P, Roman E, Michieletto M, and Palatini P Comparison between office and ambulatory blood pressure in young and elderly subjects with isolated systolic hypertension Blood Press Monit 1996 1(6):457 62 10226275
des Combes BJ, Porchet M, Waeber B, and Brunner HR Ambulatory blood pressure recordings. Reproducibility and unpredictability Hypertension 1984 6(1):110 4 6693140
Devereux RB, Alonso DR, Lutas EM, Gottlieb GJ, Campo E, Sachs I, Reichek N Echocardiographic assessment of left ventricular hypertrophy: comparison to necropsy findings Am J Cardiol 1986 Feb 15 57(6):450 8
Devereux RB, James GD, and Pickering TG What is normal blood pressure? Comparison of ambulatory pressure level and variability in patients with normal or abnormal left ventricular geometry Am J Hypertens 1993 6(6 Pt 2):211S 5S 8347321
Devereux RB, Pickering TG, Harshfield GA, Kleinert HD, Denby L, Clark L, Pregibon D, Jason M, Kleiner B, Borer JS, and Laragh JH Left ventricular hypertrophy in patients with hypertension: importance of blood pressure response to regularly recurring stress Circulation 1983 68(3):470 6 6223721
Diamond JA, Krakoff LR, Martin K, Wallenstein S, and Phillips RA Comparison of ambulatory blood pressure and amounts of left ventricular hypertrophy in men versus women with similar levels of hypertensive clinic blood pressures Am J Cardiol 1997 79(4):505 8 9052361
Dickersin K, Manheimer E, Wieland L, Robinson K, Lefebvre C, and McDonald S Development of a centralized register of controlled clinical trials: The Cochrane Collaboration's CENTRAL Evaluation and the Health Professions Supplement Issue: The Cochrane Collaboration 2002 25(1):38 64
Donner-Banzhoff N, Chan Y, Szalai JP, and Hilditch J 'Home hypertension': exploring the inverse white coat response Br J Gen Pract 1998 48(433):1491 5 10024708
Donner-Banzhoff N, Chan Y, Szalai JP, and Hilditch JR Is the 'clinic-home blood pressure difference'associated with psychological distress? A primary care-based study J Hypertens 1997 15(6):585 90 9218176
Drayer JI and Weber MA Definition of normalcy in whole-day ambulatory blood pressure monitoring Clin Exp Hypertens [A] 1985 7(2-3):195 204
Drayer JI and Weber MA Reproducibility of blood pressure values in normotensive subjects Clin Exp Hypertens [A] 1985 7(2-3):417 22
Dukat A, Balazovjech I, Lietava J, and Gavornik P Follow-up of outpatients with essential hypertension. A comparison of three methods of blood pressure measurement Cor Vasa 1992 34(4):322 8 1308724
Dupont AG, Vanderniepen P, Volckaert A, Finne E, and Six RO Noninvasive ambulatory monitoring of blood pressure in essential hypertension. Effect of age on variability and disparity J Clin Hypertens 1986 2(3):278 84 3783191
Dzien A, Pfeiffer K, Dzien-Bischinger C, Hoppichler F, and Lechleitner M The correlation of office blood pressure and 24-hour ambulatory measurements in hypertensive patients - comparison between non-pharmacological treatment and antihypertensive medication Eur J Med Res 2000 5(6):268 72 10882643
Earp JA, Ory MG, and Strogatz DS The effects of family involvement and practitioner home visits on the control of hypertension Am J Public Health 1982 72(10):1146 54 7114339
Eison H, Phillips RA, Ardeljan M, and Krakoff LR Differences in ambulatory blood pressure between men and women with mild hypertension J Hum Hypertens 1990 4(4):400 4 2258884
Elijovich F and Laffer CL Bayesian analysis supports use of ambulatory blood pressure monitors for screening Hypertension 1992 19(2 Suppl):II268 72 1735591
Elijovich F and Laffer CL Magnitude, reproducibility, and components of the pressor response to the clinic Hypertension 1990 15(2 Suppl):I161 5 2298472
Emelianov D, Thijs L, Staessen JA, Celis H, Clement D, Davidson C, Gasowski J, Gil-Extremera B, Fogari R, Jaaskivi M, Lehtonen A, Nedogoda S, O'Brien E, Palatini P, Parati G, Salvetti A, Vanhanen H, Webster J, and Fagard R Conventional and ambulatory measurements of blood pressure in old patients with isolated systolic hypertension: baseline observations in the Syst-Eur trial Blood Press Monit 1998 3(3):173 80 10212350
Engel BT, Gaarder KR, and Glasgow MS Behavioral treatment of high blood pressure. I. Analyses of intra- and interdaily variations of blood pressure during a one-month, baseline period Psychosom Med 1981 43(3):255 70 7255637
Engfeldt P, Danielsson B, Nyman K, Aberg K, and Aberg H 24-hour ambulatory blood pressure monitoring in elderly normotensive individuals and its reproducibility after one year J Hum Hypertens 1994 8(8):545 50 7990078
Enstrom-Granath I. Ambulatory blood pressure monitoring. A tool for more comprehensive assessment. Blood Press Suppl. 1992;5:1-27. [pmid: 1345260].
Enstrom I, Burtscher IM, Eskilsson J, Holm K, Holtas S, Pennert K, and Thulin T Organ damage in treated middle-aged hypertensives compared to normotensives: results from a cross-sectional study in general practice Blood Press 2000 9(1):28 33 10854005
Enstrom I and Lindholm LH Blood pressure in middle-aged women: a comparison between office-, self-, and ambulatory recordings Blood Press 1992 1(4):240 6 1345221
Enstrom I, Thulin T, and Lindholm L How good are standardized blood pressure recordings for diagnosing hypertension? A comparison between office and ambulatory blood pressure J Hypertens 1991 9(6):561 6 1653295
Equiluz-Bruck S, Schnack C, Kopp HP, and Schernthaner G Nondipping of nocturnal blood pressure is related to urinary albumin excretion rate in patients with type 2 diabetes mellitus Am J Hypertens 1996 9(11):1139 43 8931842
Fagard RH, Staessen JA, and Thijs L Prediction of cardiac structure and function by repeated clinic and ambulatory blood pressure Hypertension 1997 29(1 Pt 1):22 9 9039075
Fagard RH, Staessen JA, and Thijs L Relationships between changes in left ventricular mass and in clinic and ambulatory blood pressure in response to antihypertensive therapy J Hypertens 1997 15(12 Pt 1):1493 502 9431857
Fagard RH, Staessen JA, Thijs L, Gasowski J, Bulpitt CJ, Clement D, de Leeuw PW, Dobovisek J, Jaaskivi M, Leonetti G, O'Brien E, Palatini P, Parati G, Rodicio JL, Vanhanen H, and Webster J Response to antihypertensive therapy in older patients with sustained and nonsustained systolic hypertension. Systolic Hypertension in Europe (Syst-Eur) Trial Investigators Circulation 2000 102(10):1139 44 10973843
Farmer CK, Goldsmith DJ, Cox J, Dallyn P, Kingswood JC, and Sharpstone P An investigation of the effect of advancing uraemia, renal replacement therapy and renal transplantation on blood pressure diurnal variability Nephrol Dial Transplant 1997 12(11):2301 7 9394315
Feola M, Boffano GM, Procopio M, Reynaud S, Allemano P, and Rizzi G Ambulatory 24-hour blood pressure monitoring: correlation between blood pressure variability and left ventricular hypertrophy in untreated hypertensive patients G Ital Cardiol 1998 28(1):38 44 9493044
Ferguson JH and Shaar CJ The effective diagnosis and treatment of hypertension by the primary care physician: impact of ambulatory blood pressure monitoring J Am Board Fam Pract 1992 5(5):457 65 1414446
Fernandez-Gonzalez R, Gomez-Pajuelo C, Gabriel R, de La Figuera M, Moreno E, and of The Verapamil-Frequency Res Effect of verapamil on home self-measurement of blood pressure and heart rate by hypertensive patients. Verapamil-Frequency Research Group Blood Press Monit 2000 5(1):23 30 10804447
Ferrara AL, Pasanisi F, Crivaro M, Guida L, Palmieri V, Gaeta I, Iannuzzi R, and Celentano A Cardiovascular abnormalities in never-treated hypertensives according to nondipper status Am J Hypertens 1998 11(11 Pt 1):1352 7 9832179
Ferrara LA, Guida L, Pasanisi F, Celentano A, Palmieri V, Iannuzzi R, Gaeta I, Leccia G, and Crivaro M Isolated office hypertension and end-organ damage J Hypertens 1997 15(9):979 85 9321745
Fiedler N, Favata E, Goldstein BD, and Gochfeld M Utility of occupational blood pressure screening for the detection of potential hypertension J Occup Med 1988 30(12):943 8 3230445
Floras JS, Jones JV, Hassan MO, Osikowska B, Sever PS, and Sleight P Cuff and ambulatory blood pressure in subjects with essential hypertension Lancet 1981 2(8238):107 9 6113479
Fogari R, Corradi L, Zoppi A, Lusardi P, and Poletti L Repeated office blood pressure controls reduce the prevalence of white-coat hypertension and detect a group of white-coat normotensive patients Blood Press Monit 1996 1(1):51 4 10226202
Fogari R, Zoppi A, Malamani GD, Lazzari P, Destro M, and Corradi L Ambulatory blood pressure monitoring in normotensive and hypertensive type 2 diabetes. Prevalence of impaired diurnal blood pressure patterns Am J Hypertens 1993 6(1):1 7 8427656
Fotherby MD and Potter JF Reproducibility of ambulatory and clinic blood pressure measurements in elderly hypertensive subjects J Hypertens 1993 11(5):573 9 8390530
Fotherby MD and Potter JF Twenty-four-hour ambulatory blood pressure in old and very old subjects J Hypertens 1995 13(12 Pt 2):1742 6 8903644
Fotherby MD and Potter JF Variation of within visit blood pressure readings at a single visit in the elderly and their relationship to ambulatory measurements J Hum Hypertens 1994 8(2):107 11 8207736
Fotherby MD, Robinson TG, and Potter JF Clinic and 24h blood pressure in elderly treated hypertensives with postural hypotension J Hum Hypertens 1994 8(9):711 6 7807502
Frattola A, Parati G, Cuspidi C, Albini F, and Mancia G Prognostic value of 24-hour blood pressure variability J Hypertens 1993 11(10):1133 7 8258679
Fredrikson M, Blumenthal JA, Evans DD, Sherwood A, and Light KC Cardiovascular responses in the laboratory and in the natural environment: is blood pressure reactivity to laboratory-induced mental stress related to ambulatory blood pressure during everyday life? J Psychosom Res 1989 33(6):753 62 2621677
Fredrikson M, Tuomisto M, Lundberg U, and Melin B Blood pressure in healthy men and women under laboratory and naturalistic conditions J Psychosom Res 1990 34(6):675 86 2290140
Friedman RH, Kazis LE, Jette A, Smith MB, Stollerman J, Torgerson J, and Carey K A telecommunications system for monitoring and counseling patients with hypertension. Impact on medication adherence and blood pressure control Am J Hypertens 1996 9(4 Pt 1):285 92 8722429
Galderisi M, Petrocelli A, Alfieri A, Garofalo M, and de Divitiis O Impact of ambulatory blood pressure on left ventricular diastolic dysfunction in uncomplicated arterial systemic hypertension Am J Cardiol 1996 77(8):597 601 8610609
Garg SK, Chase HP, Icaza G, Rothman RL, Osberg I, and Carmain JA 24-hour ambulatory blood pressure and renal disease in young subjects with type I diabetes J Diabetes Complications 1997 11(5):263 7 9334907
Gellermann J, Kraft S, and Ehrich JH Twenty-four-hour ambulatory blood pressure monitoring in young children Pediatr Nephrol 1997 11(6):707 10 9438648
Gerber LM, Schnall PL, and Pickering TG Body fat and its distribution in relation to casual and ambulatory blood pressure Hypertension 1990 15(5):508 13 2332242
Gerber LM, Schwartz JE, Schnall PL, Devereux RB, Warren K, and Pickering TG Effect of body weight changes on changes in ambulatory and standardized non-physician blood pressures over three years Ann Epidemiol 1999 9(8):489 97 10549882
Gerc V, Favrat B, Brunner HR, and Burnier M Is nurse-measured blood pressure a valid substitute for ambulatory blood pressure monitoring? Blood Press Monit 2000 5(4):203 9 11035861
Gerin W, Rosofsky M, Pieper C, and Pickering TG A test of reproducibility of blood pressure and heart rate variability using a controlled ambulatory procedure J Hypertens 1993 11(10):1127 31 8258678
Gharavi AG, Lipkowitz MS, Diamond JA, Jhang JS, and Phillips RA Deletion polymorphism of the angiotensin-converting enzyme gene is independently associated with left ventricular mass and geometric remodeling in systemic hypertension Am J Cardiol 1996 77(15):1315 9 8677872
Giaconi S, Palombo C, Genovesi-Ebert A, Marabotti C, Volterrani D, and Ghione S Long-term reproducibility and evaluation of seasonal influences on blood pressure monitoring J Hypertens Suppl 1988 6(4):S64 6 3241275
Giordano U, Matteucci MC, Calzolari A, Turchetta A, Rizzoni G, and Alpert BS Ambulatory blood pressure monitoring in children with aortic coarctation and kidney transplantation J Pediatr 2000 136(4):520 3 10753251
Glen SK, Elliott HL, Curzio JL, Lees KR, and Reid JL White-coat hypertension as a cause of cardiovascular dysfunction Lancet 1996 348(9028):654 7 8782756
Goldstein IB, Shapiro D, and Thananopavaran C Home relaxation techniques for essential hypertension Psychosom Med 1984 46(5):398 414 6387759
Gosse P, Ansoborlo P, Lemetayer P, and Clementy J Left ventricular mass is better correlated with arising blood pressure than with office or occasional blood pressure Am J Hypertens 1997 10(5 Pt 1):505 10 9160760
Gosse P, Bougaleb M, and Clementy J Long term reproducibility of ambulatory blood pressure monitoring Therapie 1996 51(1):5 9 8762214
Gosse P, Campello G, Aouizerate E, Roudat R, Broustet JP, and Dallochio M Left ventricular hypertrophy in hypertension: correlation with rest, exercise and ambulatory systolic blood pressure J Hypertens 1986 4(Suppl 5):S297 S299
Gosse P, Campello G, Roudaut R, and Dallocchio M High night blood pressure in treated hypertensive patients: not harmless Am J Hypertens 1988 1(3 Pt 3):195S 8S 3415799
Gosse P, Gasparoux P, Ansoborlo P, Lemetayer P, and Clementy J Prognostic value of ambulatory measurement of the timing of Korotkoff sounds in elderly hypertensives: a pilot study Am J Hypertens 1997 10(5 Pt 1):552 7 9160767
Gosse P, Jullien V, Jarnier P, Lemetayer P, and Clementy J Reduction in arterial distensibility in hypertensive patients as evaluated by ambulatory measurement of the QKD interval is correlated with concentric remodeling of the left ventricle Am J Hypertens 1999 12(12 Pt 1-2):1252 5 10619589
Gosse P, Lamaison C, Roudaut R, and Dallocchio M Ambulatory blood pressure monitoring. Values in normotensive patients and suggestions for interpretation Therapie 1991 46(4):305 9 1948806
Gosse P, Promax H, Durandet P, and Clementy J 'White coat' hypertension. No harm for the heart Hypertension 1993 22(5):766 70 8225536
Gosse P, Roudaut R, Herrero G, and Dallocchio M beta-Blockers vs. angiotensin-converting enzyme inhibitors in hypertension: Effects on left ventricular hypertrophy J CARDIOVASC PHARMACOL 1990 16(SUPPL. 5):S145 S150 11527119
Gosse P, Roudaut R, Reynaud P, Jullien E, and Dallocchio M Relationship between left ventricular mass and noninvasive monitoring of blood pressure Am J Hypertens 1989 2(8):631 3 2528359
Gould BA, Kieso HA, Hornung R, Altman DG, Cashman PM, and Raftery EB Assessment of the accuracy and role of self-recorded blood pressures in the management of hypertension Br Med J (Clin Res Ed) 1982 285(6356):1691 4
Gourlay SG, McNeil JJ, Marriner T, Farish SJ, Prijatmoko D, and McGrath BP Discordance of mercury sphygmomanometer and ambulatory blood pressure measurements for the detection of untreated hypertension in a population study J Hum Hypertens 1993 7(5):467 72 8263887
Grandi AM, Broggi R, Zanzi P, Gaudio G, Santillo R, Lamponi M, Bertolini A, Guasti L, and Venco A Individualized versus standardized analysis of ambulatory blood pressure profile: relationship with left ventricular characteristics Blood Press Monit 1999 4(1):7 11 10362885
Grossman E, Alster Y, Shemesh J, Nussinovitch N, and Rosenthal T Left ventricular mass in hypertension: correlation with casual, exercise and ambulatory blood pressure J Hum Hypertens 1994 8(10):741 6 7837210
Grune S, Weisser B, Kraft K, Del Bufalo A, Binswanger B, Mengden T, Spuhler T, Greminger P, Moccetti T, Vetter H and others Comparison of casual ambulatory and self-measured blood pressure in a long-term study with cilazapril and atenolol Am J Med 1993 94(4A):71S 4S 8488866
Guagnano MT, Pace-Palitti V, Murri R, Marchione L, Merlitti D, and Sensi S The prevalence of hypertension in gynaecoid and android obese women J Hum Hypertens 1996 10(9):619 24 8953208
Gualdiero P, Niebauer J, Addison C, Clark SJ, and Coats AJ Clinical features, anthropometric characteristics, and racial influences on the 'white-coat effect' in a single-centre cohort of 1553 consecutive subjects undergoing routine ambulatory blood pressure monitoring Blood Press Monit 2000 5(2):53 7 10828890
Hall CL, Higgs CM, and Notarianni L Home blood pressure recording in mild hypertension: value of distinguishing sustained from clinic hypertension and effect on diagnosis and treatment. Bath Health District Hypertension Study Group J Hum Hypertens 1990 4(5):501 7 2283640
Hall CL, Higgs CM, and Notarianni L. Value of patient-recorded home blood pressure series in distinguishing sustained from office hypertension: effects on diagnosis and treatment of mild hypertension. Bath District Hypertension Study Group. J Hum Hypertens. 1990;4 Suppl 2:9-13.
Hanninen JA, Takala JK, and Keinanen-Kiukaanniemi SM Blood pressure control in subjects with type 2 diabetes J Hum Hypertens 2000 14(2):111 5 10723117
Hansen KW Ambulatory blood pressure in insulin-dependent diabetes: the relation to stages of diabetic kidney disease J Diabetes Complications 1996 10(6):331 51 8972385
Hansen KW, Christensen CK, Andersen PH, Pedersen MM, Christiansen JS, and Mogensen CE Ambulatory blood pressure in microalbuminuric type 1 diabetic patients Kidney Int 1992 41(4):847 54 1513107
Hansen KW, Schmitz A, and Pedersen MM Ambulatory blood pressure measurement in type 2 diabetic patients: methodological aspects Diabet Med 1991 8(6):567 72 1832358
Harshfield GA, James GD, Schlussel Y, Yee LS, Blank SG, and Pickering TG Do laboratory tests of blood pressure reactivity predict blood pressure changes during everyday life? Am J Hypertens 1988 1(2):168 74 3401355
Harshfield GA, Treiber FA, Davis H, Johnson M, Slavens GA, and Thompson W Temporal stability of ambulatory blood pressure and heart rate in youths Blood Press Monit 1999 4(2):87 90 10450118
Hata Y, Ichimaru Y, Kodama Y, Adachi M, Sato Y, Yokoi T, and Yanaga T. Relationship between circadian rhythm of blood pressure and left ventricular function in hypertensive patients. Prog Clin Biol Res. 1990;341A:339-45. [pmid: 2217251].
Helmers KF, Baker B, O'Kelly B, and Tobe S Anger expression, gender, and ambulatory blood pressure in mild, unmedicated adults with hypertension Ann Behav Med 2000 22(1):60 4 10892529
Hermida RC and Ayala DE Diagnosing gestational hypertension and preeclampsia with the 24-hour mean of blood pressure Hypertension 1997 30(6):1531 7 9403578
Hermida RC, Ayala DE, Mojon A, Fernandez JR, Alonso I, Silva I, Ucieda R, and Iglesias M Blood pressure patterns in normal pregnancy, gestational hypertension, and preeclampsia Hypertension 2000 36(2):149 58 10948070
Hermida RC, Ayala DE, Mojon A, Fernandez JR, Silva I, Ucieda R, and Iglesias M High sensitivity test for the early diagnosis of gestational hypertension and preeclampsia. I. Predictable variability of cardiovascular characteristics during gestation in healthy and hypertensive pregnant women J Perinat Med 1997 25(1):101 9 9085211
Hermida RC, Ayala DE, Mojon A, and Iglesias M High sensitivity test for the early diagnosis of gestational hypertension and preeclampsia. II. Circadian blood pressure variability in health and hypertensive pregnant women J Perinat Med 1997 25(2):153 67 9189835
Hernandez-delRey R, Armario P, Martin-Baranera M, Sanchez P, Cardenas G, and Pardell H Target-organ damage and cardiovascular risk profile in resistant hypertension. Influence of the white-coat effect Blood Press Monit 1998 3(6):331 7 10212374
Hietanen E and Wendelin-Saarenhovi M Ambulatory blood pressure reproducibility and application of the method in a healthy Finnish cohort Scand J Clin Lab Invest 1996 56(5):471 80 8869670
Higgins JR, Walshe JJ, Halligan A, O'Brien E, Conroy R, and Darling MR Can 24-hour ambulatory blood pressure measurement predict the development of hypertension in primigravidae? Br J Obstet Gynaecol 1997 104(3):356 62 9091016
Hinderliter AL, Light KC, and Willis PW 4th Racial differences in left ventricular structure in healthy young adults Am J Cardiol 1992 69(14):1196 9 1575191
Hoegholm A, Bang LE, Kristensen KS, Nielsen JW, and Holm J Microalbuminuria in 411 untreated individuals with established hypertension, white coat hypertension, and normotension Hypertension 1994 24(1):101 5 8020997
Hoegholm A, Kristensen KS, Bang LE, and Gustavsen PH White coat hypertension and blood pressure variability Am J Hypertens 1999 12(1O Pt 1):966 72 10560782
Hoegholm A, Kristensen KS, Bang LE, and Nielsen JW White coat hypertension and target organ involvement: the impact of different cut-off levels on albuminuria and left ventricular mass and geometry J Hum Hypertens 1998 12(7):433 9 9702928
Hoegholm A, Kristensen KS, Bang LE, Nielsen JW, Nielsen WB, and Madsen NH Left ventricular mass and geometry in patients with established hypertension and white coat hypertension Am J Hypertens 1993 6(4):282 6 8507447
Hoegholm A, Kristensen KS, Madsen NH, and Svendsen TL White coat hypertension diagnosed by 24-h ambulatory monitoring. Examination of 159 newly diagnosed hypertensive patients Am J Hypertens 1992 5(2):64 70 1550667
Holl RW, Pavlovic M, Heinze E, and Thon A Circadian blood pressure during the early course of type 1 diabetes. Analysis of 1,011 ambulatory blood pressure recordings in 354 adolescents and young adults Diabetes Care 1999 22(7):1151 7 10388981
Hornsby JL, Mongan PF, Taylor AT, and Treiber FA 'White coat' hypertension in children J Fam Pract 1991 33(6):617 23 1744607
Howes LG, Reid C, Bendle R, and Weaving J The prevalence of isolated systolic hypertension in patients 60 years of age and over attending Australian general practitioners Blood Press 1998 7(3):139 43 9758082
Hozawa A, Ohkubo T, Nagai K, Kikuya M, Matsubara M, Tsuji I, Ito S, Satoh H, Hisamichi S, and Imai Y Factors affecting the difference between screening and home blood pressure measurements: the Ohasama Study J Hypertens 2001 19(1):13 9 11204293
Hozawa A, Ohkubo T, Nagai K, Kikuya M, Matsubara M, Tsuji I, Ito S, Satoh H, Hisamichi S, and Imai Y Prognosis of isolated systolic and isolated diastolic hypertension as assessed by self-measurement of blood pressure at home: the Ohasama study Arch Intern Med 2000 160(21):3301 6 11088093
Ijiri H, Kohno I, Yin D, Iwasaki H, Takusagawa M, Iida T, Osada M, Umetani K, Ishihara T, Sawanobori T, Ishii H, Komori S, and Tamura K Cardiac arrhythmias and left ventricular hypertrophy in dipper and nondipper patients with essential hypertension Jpn Circ J 2000 64(7):499 504 10929777
Imai Y, Nagai K, Sakuma M, Sakuma H, Nakatsuka H, Satoh H, Minami N, Munakata M, Hashimoto J, Yamagishi T and others Ambulatory blood pressure of adults in Ohasama, Japan Hypertension 1993 22(6):900 12 8244523
Imai Y, Nakatsuka H, Ikeda M, Nagai K, Abe K, Minami N, Munakata M, Sakuma H, Hashimoto J, Sekino H and others A cross-sectional survey of home blood pressure in a rural community in northern Japan Clin Exp Hypertens [A] 1990 12(6):1095 106
Imai Y, Nihei M, Abe K, Sasaki S, Minami N, Munakata M, Yumita S, Onoda Y, Sekino H, Yamakoshi K and others A finger volume-oscillometric device for monitoring ambulatory blood pressure: laboratory and clinical evaluations Clin Exp Hypertens [A] 1987 9(12):2001 25
Imai Y, Nishiyama A, Sekino M, Aihara A, Kikuya M, Ohkubo T, Matsubara M, Hozawa A, Tsuji I, Ito S, Satoh H, Nagai K, and Hisamichi S Characteristics of blood pressure measured at home in the morning and in the evening: the Ohasama study J Hypertens 1999 17(7):889 98 10419061
Imai Y, Ohkubo T, Hozawa A, Tsuji I, Matsubara M, Araki T, Chonan K, Kikuya M, Satoh H, Hisamichi S, and Nagai K Usefulness of home blood pressure measurements in assessing the effect of treatment in a single-blind placebo-controlled open trial J Hypertens 2001 19(2):179 85 11212959
Imai Y, Ohkubo T, Sakuma M, Tsuji I, Satoh H, Nagai K, Hisamichi S, and Abe K Predictive power of screening blood pressure, ambulatory blood pressure and blood pressure measured at home for overall and cardiovascular mortality: a prospective observation in a cohort from Ohasama, northern Japan Blood Press Monit 1996 1(3):251 4 10226238
Imai Y, Ohkubo T, Tsuji I, Hozawa A, Nagai K, Kikuya M, Aihara A, Sekino M, Michimata M, Matsubara M, Ito S, Satoh H, and Hisamichi S Relationships among blood pressures obtained using different measurement methods in the general population of Ohasama, Japan Hypertens Res 1999 22(4):261 72 10580392
Imai Y, Satoh H, Nagai K, Sakuma M, Sakuma H, Minami N, Munakata M, Hashimoto J, Yamagishi T, Watanabe N and others Characteristics of a community-based distribution of home blood pressure in Ohasama in northern Japan J Hypertens 1993 11(12):1441 9 8133026
Imai Y, Tsuji I, Nagai K, Sakuma M, Ohkubo T, Watanabe N, Ito O, Satoh H, Hisamichi S, and Abe K Ambulatory blood pressure monitoring in evaluating the prevalence of hypertension in adults in Ohasama, a rural Japanese community Hypertens Res 1996 19(3):207 12 8891750
Inden Y, Tsuda M, Hayashi H, Takezawa H, Iino S, Kondo T, Yoshida Y, Akahoshi M, Terasawa M, Itoh T, Saito H, and Hirai M Relationship between Joint National Committee-VI classification of hypertension and ambulatory blood pressure in patients with hypertension diagnosed by casual blood pressure Clin Cardiol 1998 21(11):801 6 9825191
Ironson GH, Gellman MD, Spitzer SB, Llabre MM, De Carlo Pasin R, Weidler DJ, and Schneiderman N Predicting home and work blood pressure measurements from resting baselines and laboratory reactivity in black and white Americans Psychophysiology 1989 26(2):174 84 2727219
Jamerson KA, Schork N, and Julius S Effect of home blood pressure and gender on estimates of the familial aggregation of blood pressure. The Tecumseh Blood Pressure Study Hypertension 1992 20(3):314 8 1516950
James GD, Pickering TG, Yee LS, Harshfield GA, Riva S, and Laragh JH The reproducibility of average ambulatory, home, and clinic pressures Hypertension 1988 11(6 Pt 1):545 9 3384470
James MA, Fotherby MD, and Potter JF Microalbuminuria in elderly hypertensives: reproducibility and relation to clinic and ambulatory blood pressure J Hypertens 1994 12(3):309 14 8021485
James MA, Fotherby MD, and Potter JF Reproducibility of the circadian systolic blood pressure variation in the elderly J Hypertens 1995 13(10):1097 103 8586801
Jermendy G, Ferenczi J, Hernandez E, Farkas K, and Nadas J Day-night blood pressure variation in normotensive and hypertensive NIDDM patients with asymptomatic autonomic neuropathy Diabetes Res Clin Pract 1996 34(2):107 14 9031813
Johannesson M, Aberg H, Agreus L, Borgquist L, and Jonsson B Cost-benefit analysis of non-pharmacological treatment of hypertension J Intern Med 1991 230(4):307 12 1919423
Johnson AL, Taylor DW, Sackett DL, Dunnett CW, and Shimizu AG Self-recording of blood pressure in the management of hypertension Can Med Assoc J 1978 119(9):1034 9 369673
Jones DW, Frohlich ED, Grim CM, Grim CE, and Taubert KA Mercury Sphygmomanometers Should Not be Abandoned: An Advisory Statement From the Council for High Blood Pressure Research, American Heart Association Hypertension 2001 37(2):185 6 11230268
Jula A, Puukka P, and Karanko H Multiple clinic and home blood pressure measurements versus ambulatory blood pressure monitoring Hypertension 1999 34(2):261 6 10454451
Julius S, Jamerson K, Gudbrandsson T, and Schork N White coat hypertension: a follow-up Clin Exp Hypertens [A] 1992 14(1-2):45 53
Julius S, Mejia A, Jones K, Krause L, Schork N, van de Ven C, Johnson E, Petrin J, Sekkarie MA, Kjeldsen SE and others "White coat" versus "sustained" borderline hypertension in Tecumseh, Michigan Hypertension 1990 16(6):617 23 2246029
Jullien V, Gosse P, Ansoborlo P, Lemetayer P, and Clementy J Relationship between left ventricular mass and serum cholesterol level in the untreated hypertensive J Hypertens 1998 16(7):1043 7 9794746
Kapuku GK, Treiber FA, Davis HC, Harshfield GA, Cook BB, and Mensah GA Hemodynamic function at rest, during acute stress, and in the field: predictors of cardiac structure and function 2 years later in youth Hypertension 1999 34(5):1026 31 10567177
Kario K, Matsuo T, Kobayashi H, Imiya M, Matsuo M, and Shimada K Nocturnal fall of blood pressure and silent cerebrovascular damage in elderly hypertensive patients. Advanced silent cerebrovascular damage in extreme dippers Hypertension 1996 27(1):130 5 8591875
Katayama S, Maruno Y, Itabashi A, Inaba M, Omoto A, and Ishii J Clinical significance of ambulatory blood pressure monitoring. Evaluation of severity of hypertension, efficacy of treatment and effects on nighttime blood pressure Jpn Heart J 1991 32(1):45 55 2038124
Khan IA, Gajaria M, Stephens D, and Balfe JW Ambulatory blood pressure monitoring in children: a large center's experience Pediatr Nephrol 2000 14(8-9):802 5 10955931
Khattar RS, Acharya DU, Kinsey C, Senior R, and Lahiri A Longitudinal association of ambulatory pulse pressure with left ventricular mass and vascular hypertrophy in essential hypertension J Hypertens 1997 15(7):737 43 9222941
Khattar RS, Senior R, Swales JD, and Lahiri A Value of ambulatory intra-arterial blood pressure monitoring in the long-term prediction of left ventricular hypertrophy and carotid atherosclerosis in essential hypertension J Hum Hypertens 1999 13(2):111 6 10100059
Khattar RS, Swales JD, Banfield A, Dore C, Senior R, and Lahiri A Prediction of coronary and cerebrovascular morbidity and mortality by direct continuous ambulatory blood pressure monitoring in essential hypertension Circulation 1999 100(10):1071 6 10477532
Khattar RS, Swales JD, Senior R, and Lahiri A Racial variation in cardiovascular morbidity and mortality in essential hypertension Heart 2000 83(3):267 71 10677402
Khoury S, Yarows SA, O'Brien TK, and Sowers JR Ambulatory blood pressure monitoring in a nonacademic setting. Effects of age and sex Am J Hypertens 1992 5(9):616 23 1418850
Kikuya M, Hozawa A, Ohokubo T, Tsuji I, Michimata M, Matsubara M, Ota M, Nagai K, Araki T, Satoh H, Ito S, Hisamichi S, and Imai Y Prognostic significance of blood pressure and heart rate variabilities: the Ohasama study Hypertension 2000 36(5):901 6 11082164
Kjeldsen SE, Hedner T, Jamerson K, Julius S, Haley WE, Zabalgoitia M, Butt AR, Rahman SN, and Hansson L Hypertension optimal treatment (HOT) study: home blood pressure in treated hypertensive subjects Hypertension 1998 31(4):1014 20 9535429
Kleinert HD, Harshfield GA, Pickering TG, Devereux RB, Sullivan PA, Marion RM, Mallory WK, and Laragh JH What is the value of home blood pressure measurement in patients with mild hypertension? Hypertension 1984 6(4):574 8 6235190
Koch VH, Colli A, Saito MI, Furusawa EA, Ignes E, Okay Y, and Mion Junior D Comparison between casual blood pressure and ambulatory blood pressure monitoring parameters in healthy and hypertensive adolescents Blood Press Monit 2000 5(5-6):281 9 11153052
Kok RH, Beltman FW, Terpstra WF, Smit AJ, May JF, de Graeff PA, and Meyboom-de Jong B Home blood pressure measurement: reproducibility and relationship with left ventricular mass Blood Press Monit 1999 4(2):65 9 10450121
Korner A, Pataki V, Dobos M, Madacsy L, Miltenyi M, and Tulassay T Reproducibility of erythrocyte sodium-lithium countertransport activity and ambulatory blood pressure measurements in type 1 diabetes mellitus Acta Diabetol 1998 35(2):104 8 9747964
Kostis JB, Davis BR, Cutler J, Grimm RH Jr, Berge KG, Cohen JD, Lacy CR, Perry HM Jr, Blaufox MD, Wassertheil-Smoller S, Black HR, Schron E, Berkson DM, Curb JD, Smith WM, McDonald R, and Applegate WB Prevention of heart failure by antihypertensive drug treatment in older persons with isolated systolic hypertension. SHEP Cooperative Research Group JAMA 1997 278(3):212 6 9218667
Kouame N, Cleroux J, Lefebvre J, Ellison R, and Lacourciere Y Incidence of overestimation and underestimation of hypertension in a large sample of Canadians with mild-to-moderate hypertension Blood Press Monit 1996 1(5):389 96 10226265
Krakoff LR, Eison H, Phillips RH, Leiman SJ, and Lev S Effect of ambulatory blood pressure monitoring on the diagnosis and cost of treatment for mild hypertension Am Heart J 1988 116(4):1152 4 3177190
Kumagai Y, Kuwajima I, Suzuki Y, Kuramoto K, Otsuka K, Cornelissen G, and Halberg F Untenable acceptance of casual systolic/diastolic blood pressure readings below 140/90 mmHg Chronobiologia 1993 20(3-4):255 60 8131675
Kuwajima I, Suzuki Y, Fujisawa A, and Kuramoto K Is white coat hypertension innocent? Structure and function of the heart in the elderly Hypertension 1993 22(6):826 31 8244514
Kuznetsova T, Malyutina S, Pello E, Thijs L, Nikitin Y, and Staessen JA Ambulatory blood pressure of adults in Novosibirsk, Russia: interim report on a population study Blood Press Monit 2000 5(5-6):291 6 11153053
Kyle PM, Clark SJ, Buckley D, Kissane J, Coats AJ, de Swiet M, and Redman CW Second trimester ambulatory blood pressure in nulliparous pregnancy: a useful screening test for pre-eclampsia? Br J Obstet Gynaecol 1993 100(10):914 9 8217973
Laffer CL and Elijovich F Predictors of the pressor response to the clinic visit in essential hypertensives with and without diabetes mellitus Clin Auton Res 1994 4(6):323 9 7711468
Langewitz W, Ruddel H, Schachinger H, and Schmieder R Standardized stress testing in the cardiovascular laboratory: has it any bearing on ambulatory blood pressure values? J Hypertens Suppl 1989 7(3):S41 8
Lantelme P, Milon H, Vernet M, and Gayet C Difference between office and ambulatory blood pressure or real white coat effect: does it matter in terms of prognosis? J Hypertens 2000 18(4):383 9 10779087
Larsen CT, Sorum C, Hansen JF, Jensen HA, and Rasmussen V Blood pressure level and relation to other cardiovascular risk factors in male hypertensive patients without clinical evidence of ischemic heart disease Blood Press 2000 9(2-3):91 7 10855730
Laughlin KD, Sherrard DJ, and Fisher L Comparison of clinic and home blood pressure levels in essential hypertension and variables associated with clinic-home differences J Chronic Dis 1980 33(4):197 206 7358822
Lee DR, Sivakumaran P, and Brown R Clinic blood pressure measurements and blood pressure load in the diagnosis of hypertension Postgrad Med J 1993 69(811):370 2 8346131
Lee DR, Swift CG, and Jackson SH Twenty-four-hour ambulatory blood pressure monitoring in healthy elderly people: reference values Age Ageing 1995 24(2):91 5 7793342
Lehnert H, Kaluza K, Vetter H, Losse H, and Dorst K Long-term effects of a complex behavioral treatment of essential hypertension Psychosom Med 1987 49(4):422 30 3615770
Lemne C, Lindvall K, Georgiades A, Fredrikson M, and de Faire U Structural cardiac changes in relation to 24-h ambulatory blood pressure levels in borderline hypertension J Intern Med 1995 238(1):49 57 7608646
Lerman CE, Brody DS, Hui T, Lazaro C, Smith DG, and Blum MJ The white-coat hypertension response: prevalence and predictors J Gen Intern Med 1989 4(3):226 31 2786060
Lerman CE, Brody DS, Hui T, Lazaro C, Smith DG, and Wolfson HG Identifying hypertensive patients with elevated systolic workplace blood pressures Am J Hypertens 1990 3(7):544 8 2363893
Liebisch B, Kletzmayr J, Webber F, and Schneider B. Reproducibility of ambulatory blood pressure measurement in renal hypertension. Dippers and non-dippers. Ann N Y Acad Sci. 1996;783:333-4. [pmid: 8853661].
Lievre M, Gueret P, Gayet C, Roudaut R, Delair S, and Boissel JP Regression of left ventricular hypertrophy with ramipril, independently of blood pressure reduction: The HYCAR study Arch Mal Coeur Vaiss 1995 88(SPEC. ISS. 2):35 42
Lievre M, Gueret P, Gayet C, Roudaut R, Haugh MC, Delair S, and Boissel JP Ramipril-induced regression of left ventricular hypertrophy in treated hypertensive individuals Hypertension 1995 25(1):92 7 7843761
Light KC and Obrist PA Cardiovascular reactivity to behavioral stress in young males with and without marginally elevated casual systolic pressures. Comparison of clinic, home, and laboratory measures Hypertension 1980 2(6):802 8 7461795
Light KC, Turner JR, and Hinderliter AL Job strain and ambulatory work blood pressure in healthy young men and women Hypertension 1992 20(2):214 8 1639463
Lip GY, Zarifis J, Farooqi IS, Page A, Sagar G, and Beevers DG Ambulatory blood pressure monitoring in acute stroke. The West Birmingham Stroke Project Stroke 1997 28(1):31 5 8996484
Liu JE, Roman MJ, Pini R, Schwartz JE, Pickering TG, and Devereux RB Cardiac and arterial target organ damage in adults with elevated ambulatory and normal office blood pressure Ann Intern Med 1999 131(8):564 72 10523216
Loimaala A, Turjanmaa V, Vuori I, Oja P, Pasanen M, and Uusitalo A Variation of ambulatory blood pressure in healthy middle-aged men J Hum Hypertens 1997 11(4):227 31 9185027
Lucatello A, Cocchi R, Degli Esposti E, Fabbri A, Sturani A, Quarello F, Boero R, Dadone C, Bruno M, Favazza A, Scanziani R, Tommasi A, and Giangrande A Myths and reality concerning hypertension in peritoneal dialysis patients: results of a multicenter study Blood Press Monit 1998 3(2):83 90 10212335
Luders S, Gerdes M, Scholz M, Heydenbluth R, Schoel G, Haupt A, Eckardt R, Zuchner C, and Schrader J First results of a long-term study comparing office blood pressure measurement (OBP) vs. ambulatory blood pressure measurement (ABPM) in patients on ramipril therapy (PLUR-study Nieren Und Hochdruckkrankheiten 1995 24(3):118 20
Lurbe E, Aguilar F, Gomez A, Tacons J, Alvarez V, and Redon J. Reproducibility of ambulatory blood pressure monitoring in children. J Hypertens Suppl. 1993;11 Suppl 5:S288-9. [pmid: 8158389].
MacDonald MB, Laing GP, Wilson MP, and Wilson TW Prevalence and predictors of white-coat response in patients with treated hypertension CMAJ 1999 161(3):265 9 10463047
Machnig T, Henneke KH, Engels G, Pongratz G, Schmalzl M, Gellert J, and Bachmann K Nitrendipine vs. captopril in essential hypertension: effects on circadian blood pressure and left ventricular hypertrophy Cardiology 1994 85(2):101 10 7954561
MacMahon S, Peto R, Cutler J, Collins R, Sorlie P, Neaton J, Abbott R, Godwin J, Dyer A, and Stamler J Blood pressure, stroke, and coronary heart disease. Part 1, Prolonged differences in blood pressure: prospective observational studies corrected for the regression dilution bias Lancet 1990 335(8692):765 74 1969518
Magometschnigg D, Brandt D, Hofmann R, Sihorsch K, Stoschitzky K, Zangeneh M, and Zenker G Treatment of left ventricular hypertrophy in hypertensive patients with a combination of verapamil and captopril--a multicenter study Int J Clin Pharmacol Ther 1997 35(9):389 96 9314093
Majahalme S, Turjanmaa V, Tuomisto M, Lu H, and Uusitalo A Blood pressure responses to exercise as predictors of blood pressure level after 5 years Am J Hypertens 1997 10(1):106 16 9008255
Mallion JM, De Gaudemaris R, Siche JP, Maitre A, and Pitiot M Day and night blood pressure values in normotensive and essential hypertensive subjects assessed by twenty-four-hour ambulatory monitoring J Hypertens Suppl 1990 8(6):S49 55
Mancia G, Sega R, Bravi C, De Vito G, Valagussa F, Cesana G, and Zanchetti A Ambulatory blood pressure normality: results from the PAMELA study J Hypertens 1995 13(12 Pt 1):1377 90 8866899
Mancia G, Sega R, Milesi C, Cesana G, and Zanchetti A Blood-pressure control in the hypertensive population Lancet 1997 349(9050):454 7 9040574
Mancia G, Zanchetti A, Agabiti-Rosei E, Benemio G, De Cesaris R, Fogari R, Pessina A, Porcellati C, Rappelli A, Salvetti A, Trimarco B, Agebiti-Rosei E$[corrected to Agabiti-Rosei E, and Pessino A$[corrected to Pessina A Ambulatory blood pressure is superior to clinic blood pressure in predicting treatment-induced regression of left ventricular hypertrophy. SAMPLE Study Group. Study on Ambulatory Monitoring of Blood Pressure and Lisinopril Evaluation Circulation 1997 95(6):1464 70 9118514
Mandal AK, Miller WG, Saklayen MG, and Markert RJ Comparison of manual versus automated blood pressure measurements in treated hypertensive patients Am J Med Sci 1997 314(3):185 9 9298044
Mann S, Millar Craig MW, and Raftery EB Superiority of 24-hour measurement of blood pressure over clinic values in determining prognosis in hypertension Clin Exp Hypertens [A] 1985 7(2-3):279 81
Mann SJ, James GD, Wang RS, and Pickering TG Elevation of ambulatory systolic blood pressure in hypertensive smokers. A case-control study JAMA 1991 265(17):2226 8 2013955
Manning G, Rushton L, Donnelly R, and Millar-Craig MW Role of ambulatory blood pressure monitoring in the assessment and prognosis of patients with borderline hypertension Blood Press 2001 10(1):33 6 11332331
Manning G, Rushton L, Donnelly R, and Millar-Craig MW Variability of diurnal changes in ambulatory blood pressure and nocturnal dipping status in untreated hypertensive and normotensive subjects Am J Hypertens 2000 13(9):1035 8 10981556
Manning G, Rushton L, and Millar-Craig MW Clinical implications of white coat hypertension: an ambulatory blood pressure monitoring study J Hum Hypertens 1999 13(12):817 22 10618670
Manning G, Rushton L, and Millar-Craig MW Twenty-four hour ambulatory blood pressure: a sample from a normal British population J Hum Hypertens 1998 12(2):123 7 9504353
Mansoor GA, McCabe EJ, and White WB Determinants of the white-coat effect in hypertensive subjects J Hum Hypertens 1996 10(2):87 92 8867561
Mansoor GA, McCabe EJ, and White WB Long-term reproducibility of ambulatory blood pressure J Hypertens 1994 12(6):703 8 7963496
Marchesi E, Baiardini R, Centeleghe P, Covini D, Frattoni A, Muggia C, Ravetta V, and Resasco T Structural changes in the heart and carotid arteries in hypertensive patients associated with cardiovascular risk factors J Cardiovasc Risk 1997 4(4):283 9 9477207
Marchesi E, Perani G, Falaschi F, Negro C, Catalano O, Ravetta V, and Finardi G Metabolic risk factors in white coat hypertensives J Hum Hypertens 1994 8(7):475 9 7932508
Marczewski K, Krawczyk W, Rozyc P, Raszewski G, Grzywna R, and Klimek K Day/night ratio of microproteinuria and blood pressure rhythm in type II diabetes Diabetes Res Clin Pract 1996 33(3):169 72 8922538
Martinez MA, Garcia-Puig J, Martin JC, Guallar-Castillon P, Aguirre de Carcer A, Torre A, Armada E, Nevado A, and Madero RS Frequency and determinants of white coat hypertension in mild to moderate hypertension: a primary care-based study. Monitorizacion Ambulatoria de la Presion Arterial (MAPA)-Area 5 Working Group Am J Hypertens 1999 12(3):251 9 10192226
Martinez MA, Moreno A, Aguirre de Carcer A, Cabrera R, Rocha R, Torre A, Nevado A, Ramos T, Neri J, Anton G, Miranda I, Fernandez P, Rodriguez E, Miquel A, Martinez JL, Rodriguez M, Eisman C, and Puig JG Frequency and determinants of microalbuminuria in mild hypertension: a primary-care-based study. MAPA--Madrid Working Group J Hypertens 2001 19(2):319 26 11212976
Mayet J, Shahi M, Hughes AD, Stanton AV, Poulter NR, Sever PS, Foale RA, and Thom SA Left ventricular structure and function in previously untreated hypertensive patients: the importance of blood pressure, the nocturnal blood pressure dip and heart rate J Cardiovasc Risk 1995 2(3):255 61 7584802
McCall WC and McCall VR Diagnostic use of ambulary blood pressure monitoring in medical practice J Fam Pract 1981 13(1):25 30 7252436
McKenney JM, Munroe WP, and Wright JT Jr Impact of an electronic medication compliance aid on long-term blood pressure control J Clin Pharmacol 1992 32(3):277 83 1564133
Meissner I, Whisnant JP, Sheps SG, Schwartz GL, O'Fallon WM, Covalt JL, Sicks JD, Bailey KR, and Wiebers DO Detection and control of high blood pressure in the community : Do we need a wake-up call? Hypertension 1999 34(3):466 71 10489395
Mejia A and Julius S Practical utility of blood pressure readings obtained by self-determination J Hypertens Suppl 1989 7(3):S53 7
Mejia AD, Julius S, Jones KA, Schork NJ, and Kneisley J The Tecumseh Blood Pressure Study. Normative data on blood pressure self-determination Arch Intern Med 1990 150(6):1209 13 2353854
Melina D, Colivicchi F, and Melina G Target organ status and cardiovascular risk in borderline hypertension Acta Cardiol 1992 47(5):481 5 1441855
Melina D, Colivicchi F, Melina G, and Pristipino C Left ventricular hypertrophy and diastolic dysfunction in alcohol-associated hypertension Minerva Cardioangiol 1993 41(7-8):293 6 8233010
Mengden T, Battig B, Edmonds D, Jeck T, Huss R, Sachindis A, Schubert M, Feltkamp H, and Vetter W Self-measured blood pressures at home and during consulting hours: are there any differences? J Hypertens Suppl 1990 8(4):S15 9
Mengden T, Battig B, and Vetter W Self-measurement of blood pressure improves the accuracy and reduces the number of subjects in clinical trials J Hypertens Suppl 1991 9(6):S336 7 1818989
Meyer-Sabellek WA, Schulte KL, Liederwald K, van Gemmeren D, and Gotzen R Blood pressure profile and cardiac risk in hypertensive patients with left ventricular hypertrophy J Hypertens Suppl 1990 8(4):S95 8
Mezzetti A, Pierdomenico SD, Costantini F, Romano F, Bucci A, Di Gioacchino M, and Cuccurullo F White-coat resistant hypertension Am J Hypertens 1997 10(11):1302 7 9397251
Midanik LT, Resnick B, Hurley LB, Smith EJ, and McCarthy M Home blood pressure monitoring for mild hypertensives Public Health Rep 1991 106(1):85 9 1899945
Middeke M and Lemmer B Office hypertension: abnormal blood pressure regulation and increased sympathetic activity compared with normotension Blood Press Monit 1996 1(5):403 7 10226267
Mikkelsen KL, Wiinberg N, Hoegholm A, Christensen HR, Bang LE, Nielsen PE, Svendsen TL, Kampmann JP, Madsen NH, and Bentzon MW Smoking related to 24-h ambulatory blood pressure and heart rate: a study in 352 normotensive Danish subjects Am J Hypertens 1997 10(5 Pt 1):483 91 9160757
Minami J, Kawano Y, Ishimitsu T, Yoshimi H, and Takishita S Seasonal variations in office, home and 24 h ambulatory blood pressure in patients with essential hypertension J Hypertens 1996 14(12):1421 5 8986924
Ming J, Sheng LL, Zhang LG, Ren QD, Xueyan C, Fen ZJ, Ru FS, and Ling WS Abnormal renal function in isolated systolic hypertension correlation with ambulatory blood pressure Int J Cardiol 1993 41(1):69 75 8225675
Mo R, Lund-Johansen P, and Omvik P The Bergen Blood Pressure Study: ambulatory blood pressure in subjects with an accurately defined family history of hypertension or normotension Blood Press 1993 2(3):197 204 8205313
Mo R, Lund-Johansen P, and Omvik P. The Bergen Blood Pressure Study: twenty-four-hour ambulatory blood pressure is increased in offspring of hypertensive parents. J Hypertens Suppl. 1993;11 Suppl 5:S70-1. [pmid: 8158440].
Mochizuki Y, Okutani M, Iwasaki H, Kohno I, Mochizuki S, Umetani K, Ishii H, Ijiri H, Komori S, and Tamura K. Reproducibility of nocturnal blood pressure reduction rate and the prevalence of "non-dippers" using 48-hour ambulatory blood pressure monitoring in patients with essential hypertension. Ann N Y Acad Sci. 1996;783:330-2. [pmid: 8853660].
Modesti PA, Pieri F, Cecioni I, Valenti R, Mininni S, Toccafondi S, Vocioni F, Salvati G, Gensini GF, and Neri Serneri GG Comparison of ambulatory blood pressure monitoring and conventional office measurement in the workers of a chemical company Int J Cardiol 1994 46(2):151 7 7814164
Mooney P, Dalton KJ, Swindells HE, Rushant S, Cartwright W, and Juett D Blood pressure measured telemetrically from home throughout pregnancy Am J Obstet Gynecol 1990 163(1 Pt 1):30 6 2197872
Mueller UK, Wells M, Radevski I, Ouwerkerk J, Tager R, Sliwa K, and Sareli P Repeated automated versus daytime ambulatory blood pressure measurement in mild, moderate and severe untreated black hypertensive patients Blood Press Monit 1997 2(1):21 5 10234086
Muiesan ML, Pasini G, Salvetti M, Calebich S, Zulli R, Castellano M, Rizzoni D, Bettoni G, Cinelli A, Porteri E, Corsetti V, and Agabiti-Rosei E Cardiac and vascular structural changes. Prevalence and relation to ambulatory blood pressure in a middle-aged general population in northern Italy: the Vobarno Study Hypertension 1996 27(5):1046 52 8621195
Muldoon MF, Nazzaro P, Sutton-Tyrrell K, and Manuck SB White-coat hypertension and carotid artery atherosclerosis: a matching study Arch Intern Med 2000 160(10):1507 12 10826466
Muna W, Kingue S, Kim KS, and Adams-Campbell LL Circadian rhythm of hypertensives in a Cameroon population: a pilot study J Hum Hypertens 1995 9(10):797 800 8576894
Munakata M, Hiraizumi T, Nunokawa T, Ito N, Taguchi F, Yamauchi Y, and Yoshinaga K Type A behavior is associated with an increased risk of left ventricular hypertrophy in male patients with essential hypertension J Hypertens 1999 17(1):115 20 10100102
Murphy MB, Fumo MT, Gretler DD, Nelson KS, and Lang RM Diurnal blood pressure variation: differences among disparate ethnic groups J Hypertens Suppl 1991 9(8):S45 7 1839038
Muscholl MW, Hense HW, Brockel U, Doring A, Riegger GA, and Schunkert H Changes in left ventricular structure and function in patients with white coat hypertension: cross sectional survey BMJ 1998 317(7158):565 70 28649 9721112
Musso NR, Giacche M, Galbariggi G, and Vergassola C Blood pressure evaluation by noninvasive and traditional methods. Consistencies and discrepancies among photoplethysmomanometry, office sphygmomanometry, and ambulatory monitoring. Effects of blood pressure measurement Am J Hypertens 1996 9(4 Pt 1):293 9 8722430
Musso NR and Lotti G Reproducibility of ambulatory blood pressure monitoring Blood Press Monit 1996 1(2):105 9 10226210
Myers MG, Oh PI, Reeves RA, and Joyner CD Prevalence of white coat effect in treated hypertensive patients in the community Am J Hypertens 1995b 8(6):591 7
Myers MG and Reeves RA White coat effect in treated hypertensive patients: sex differences J Hum Hypertens 1995a 9(9):729 33
Myers MG and Reeves RA White coat phenomenon in patients receiving antihypertensive therapy Am J Hypertens 1991 4(10 Pt 1):844 9 1747219
Myers MG, Reeves RA, Oh PI, and Joyner CD Overtreatment of hypertension in the community? Am J Hypertens 1996 9(5):419 25 8735171
Nagai K, Imai Y, Tsuji I, Ohkubo T, Sakuma M, Watanabe N, Kato J, Kikuchi N, Nishiyama A, Sekino M, Itoh O, Satoh H, Hisamichi S, and Abe K Prevalence of hypertension and rate of blood pressure control as assessed by home blood pressure measurements in a rural Japanese community, Ohasama Clin Exp Hypertens 1996 18(5):713 28 8781755
Nakamura K, Oita J, and Yamaguchi T Nocturnal blood pressure dip in stroke survivors. A pilot study Stroke 1995 26(8):1373 8 7631340
Nakano S, Fukuda M, Hotta F, Ito T, Ishii T, Kitazawa M, Nishizawa M, Kigoshi T, and Uchida K Reversed circadian blood pressure rhythm is associated with occurrences of both fatal and nonfatal vascular events in NIDDM subjects Diabetes 1998 47(9):1501 6 9726241
Nakano S, Ogihara M, Tamura C, Kitazawa M, Nishizawa M, Kigoshi T, and Uchida K Reversed circadian blood pressure rhythm independently predicts endstage renal failure in non-insulin-dependent diabetes mellitus subjects J Diabetes Complications 1999 13(4):224 31 10616863
Nakano S, Uchida K, Kigoshi T, Azukizawa S, Iwasaki R, Kaneko M, and Morimoto S Circadian rhythm of blood pressure in normotensive NIDDM subjects. Its relationship to microvascular complications Diabetes Care 1991 14(8):707 11 1954805
Nakatsuka H, Imai Y, Abe K, Nagai K, Ikeda M, Satoh H, Sasaki S, Minami N, Munakata M, Sakuma H and others Population study of ambulatory blood pressure in a rural community in northern Japan Tohoku J Exp Med 1991 163(2):119 27 2048122
Nalbantgil I, Onder R, Nalbantgil S, Yilmaz H, and Boydak B The prevalence of silent myocardial ischaemia in patients with white-coat hypertension J Hum Hypertens 1998 12(5):337 41 9655656
Narkiewicz K, Piccolo D, Borella P, Businaro R, Zonzin P, and Palatini P Response to orthostatic stress predicts office-daytime blood pressure difference, but not nocturnal blood pressure fall in mild essential hypertensives: results of the harvest trial Clin Exp Pharmacol Physiol 1995 22(10):743 7 8575111
Nathwani NC, Unwin R, Brook CG, and Hindmarsh PC Blood pressure and Turner syndrome Clin Endocrinol (Oxf) 2000 52(3):363 70 298219 10718835
Nesbitt SD, Amerena JV, Grant E, Jamerson KA, Lu H, Weder A, and Julius S Home blood pressure as a predictor of future blood pressure stability in borderline hypertension. The Tecumseh Study Am J Hypertens 1997 10(11):1270 80 9397247
Neus H, Gogolin E, Langewitz W, and von Eiff AW Intermittent ambulatory blood pressure recordings in children. Methodological aspects and influence of family history on hypertension Klin Wochenschr 1984 62(21):1038 43 6513434
Nielsen FS, Gaede P, Vedel P, Pedersen O, and Parving HH White coat hypertension in NIDDM patients with and without incipient and overt diabetic nephropathy Diabetes Care 1997 20(5):859 63 9135956
Nielsen PE, Myschetzky P, Andersen AR, and Andersen GS. Home readings of blood pressure in assessment of hypertensive subjects. Acta Med Scand Suppl. 1986;714:147-51. [pmid: 3472436].
Nishibata K, Nagashima M, Tsuji A, Hasegawa S, Nagai N, Goto M, and Hayashi H Comparison of casual blood pressure and twenty-four-hour ambulatory blood pressure in high school students J Pediatr 1995 127(1):34 9 7608808
Nordmann A, Frach B, Walker T, Martina B, and Battegay E Comparison of self-reported home blood pressure measurements with automatically stored values and ambulatory blood pressure Blood Press 2000 9(4):200 5 11055472
Nordmann A, Frach B, Walker T, Martina B, and Battegay E Reliability of patients measuring blood pressure at home: prospective observational study BMJ 1999 319(7218):28268
Novo S, Barbagallo M, Abrignani MG, Nardi E, Di Maria GU, Longo B, Mistretta A, and Strano A Increased prevalence of cardiac arrhythmias and transient episodes of myocardial ischemia in hypertensives with left ventricular hypertrophy but without clinical history of coronary heart disease Am J Hypertens 1997 10(8):843 51 9270078
Nystrom F, Malmstrom O, Karlberg BE, and Ohman KP Twenty-four hour ambulatory blood pressure in the population J Intern Med 1996 240(5):279 84 8946810
Nystrom FH, Ohman KP, Isaksson H, Schwan A, and Ostergren J Less difference between office and ambulatory blood pressure in women than in men both before and during antihypertensive treatment Blood Press 2000 9(6):340 5 11212063
O'Brien E, Beevers G, and Lip GY Blood pressure measurement. Part iv-automated sphygmomanometry: self blood pressure measurement BMJ 2001 322(7295):1167 70 11348915
O'Brien E, Murphy J, Tyndall A, Atkins N, Mee F, McCarthy G, Staessen J, Cox J, and O'Malley K Twenty-four-hour ambulatory blood pressure in men and women aged 17 to 80 years: the Allied Irish Bank Study J Hypertens 1991 9(4):355 60 1646262
O'Brien E, Waeber B, Parati G, Staessen J, and Myers MG Blood pressure measuring devices: recommendations of the European Society of Hypertension BMJ 2001 322(7285):531 6 11230071
O'Sullivan JJ, Derrick G, and Foxall RJ Tracking of 24-hour and casual blood pressure: a 1-year follow-up study in adolescents J Hypertens 2000 18(9):1193 6 10994749
O'Sullivan JJ, Derrick G, Griggs P, Foxall R, Aitkin M, and Wren C Ambulatory blood pressure in schoolchildren Arch Dis Child 1999 80(6):529 32 10332001
Ohkubo T, Hozawa A, Nagai K, Kikuya M, Tsuji I, Ito S, Satoh H, Hisamichi S, and Imai Y Prediction of stroke by ambulatory blood pressure monitoring versus screening blood pressure measurements in a general population: the Ohasama study J Hypertens 2000 18(7):847 54 10930181
Ohkubo T, Imai Y, Tsuji I, Nagai K, Ito S, Satoh H, and Hisamichi S Reference values for 24-hour ambulatory blood pressure monitoring based on a prognostic criterion: the Ohasama Study Hypertension 1998 32(2):255 9 9719051
Ohkubo T, Imai Y, Tsuji I, Nagai K, Kato J, Kikuchi N, Nishiyama A, Aihara A, Sekino M, Kikuya M, Ito S, Satoh H, and Hisamichi S Home blood pressure measurement has a stronger predictive power for mortality than does screening blood pressure measurement: a population-based observation in Ohasama, Japan J Hypertens 1998 16(7):971 5 9794737
Ohkubo T, Imai Y, Tsuji I, Nagai K, Watanabe N, Minami N, Itoh O, Bando T, Sakuma M, Fukao A, Satoh H, Hisamichi S, and Abe K Prediction of mortality by ambulatory blood pressure monitoring versus screening blood pressure measurements: a pilot study in Ohasama J Hypertens 1997b 15(4):357 64
Ohkubo T, Imai Y, Tsuji I, Nagai K, Watanabe N, Minami N, Kato J, Kikuchi N, Nishiyama A, Aihara A, Sekino M, Satoh H, and Hisamichi S Relation between nocturnal decline in blood pressure and mortality. The Ohasama Study Am J Hypertens 1997a 10(11):1201 7
Okumiya K, Matsubayashi K, Wada T, Fujisawa M, Osaki Y, Doi Y, Yasuda N, and Ozawa T A U-shaped association between home systolic blood pressure and four-year mortality in community-dwelling older men J Am Geriatr Soc 1999 47(12):1415 21 10591234
Olofsson P and Persson K A comparison between conventional and 24-hour automatic blood pressure monitoring in hypertensive pregnancy Acta Obstet Gynecol Scand 1995 74(6):429 33 7604685
Olofsson P and Poulsen H Reversed circadian blood pressure rhythm preserves fetal growth in preeclamptic pregnancy Eur J Obstet Gynecol Reprod Biol 1997 75(2):133 8 9447364
Omata K, Kanazawa M, Sato T, Abe F, Saito T, and Abe K. Therapeutic advantages of angiotensin converting enzyme inhibitors in chronic renal disease. Kidney Int Suppl. 1996;55:S57-62. [pmid: 8743512].
Omboni S, Parati G, Palatini P, Vanasia A, Muiesan ML, Cuspidi C, and Mancia G Reproducibility and clinical value of nocturnal hypotension: prospective evidence from the SAMPLE study. Study on Ambulatory Monitoring of Pressure and Lisinopril Evaluation J Hypertens 1998 16(6):733 8 9663912
Otsuka K, Cornelissen G, Halberg F, and Oehlerts G Excessive circadian amplitude of blood pressure increases risk of ischaemic stroke and nephropathy J Med Eng Technol 1997 21(1):23 30 9080358
Otsuka K and Halberg F Circadian profiles of blood pressure and heart rate of apparently healthy metropolitan Japanese Front Med Biol Eng 1994 6(2):149 55 7993856
Otsuka K, Watanabe H, Cornelissen G, Shinoda M, Uezono K, Kawasaki T, and Halberg F Gender, age and circadian blood pressure variation of apparently healthy rural vs metropolitan Japanese Chronobiologia 1990 17(4):253 65 2085993
Owens P, Atkins N, and O'Brien E Diagnosis of white coat hypertension by ambulatory blood pressure monitoring Hypertension 1999 34(2):267 72 10454452
Owens P, Lyons S, and O'Brien E Ambulatory blood pressure in the hypertensive population: patterns and prevalence of hypertensive subforms J Hypertens 1998 16(12 Pt 1):1735 43 9869006
Owens PE, Lyons SP, Rodriguez SA, and O'Brien ET Is elevation of clinic blood pressure in patients with white coat hypertension who have normal ambulatory blood pressure associated with target organ changes? J Hum Hypertens 1998 12(11):743 8 9844944
Ozdemir FN, Guz G, Sezer S, Arat Z, and Haberal M Ambulatory blood pressure monitoring in potential renal transplant donors Nephrol Dial Transplant 2000 15(7):1038 40 10862644
Padfield PL, Lindsay BA, McLaren JA, Pirie A, and Rademaker M Changing relation between home and clinic blood-pressure measurements: do home measurements predict clinic hypertension? Lancet 1987 2(8554):322 4 2886776
Padfield PL, Rademaker M, Pirie A, Lindsay BA, and McLaren JA Home monitoring of blood pressure: an alternative to repeated clinic measurement in the initial assessment of hypertension Bibl Cardiol 1987(42):107 13 3632605
Page SR, Manning G, Ingle AR, Hill P, Millar-Craig MW, and Peacock I Raised ambulatory blood pressure in type 1 diabetes with incipient microalbuminuria Diabet Med 1994 11(9):877 82 7705026
Palatini P, Dorigatti F, Roman E, Giovinazzo P, Piccolo D, De Venuto G, Mattarei M, Cozzutti E, Gregori S, Mormino P, and Pessina AC White-coat hypertension: a selection bias? Harvest Study Investigators. Hypertension and Ambulatory Recording Venetia Study J Hypertens 1998 16(7):977 84 9794738
Palatini P, Graniero GR, Canali C, Santonastaso M, Mos L, Piccolo D, D'Este D, Berton G, Zanata G, De Venuto G and others Relationship between albumin excretion rate, ambulatory blood pressure and left ventricular hypertrophy in mild hypertension J Hypertens 1995 13(12 Pt 2):1796 800 8903654
Palatini P, Graniero GR, Mormino P, Mattarei M, Sanzuol F, Cignacco GB, Gregori S, Garavelli G, Pegoraro F, Maraglino G, Bortolazzi A, Accurso V, Dorigatti F, Graniero F, Gelisio R, Businaro R, Vriz O, Dal Follo M, Camarotto A, and Pessina AC Prevalence and clinical correlates of microalbuminuria in stage I hypertension. Results from the Hypertension and Ambulatory Recording Venetia Study (HARVEST Study) Am J Hypertens 1996 9(4 Pt 1):334 41 8722436
Palatini P, Mormino P, Canali C, Santonastaso M, De Venuto G, Zanata G, and Pessina AC Factors affecting ambulatory blood pressure reproducibility. Results of the HARVEST Trial. Hypertension and Ambulatory Recording Venetia Study Hypertension 1994 23(2):211 6 8307631
Palatini P, Mormino P, Di Marco A, Libardoni M, Mos L, Munari L, Pessina AC, and Dal Palu C. Ambulatory blood pressure versus casual pressure for the evaluation of target organ damage in hypertension: complications of hypertension. J Hypertens Suppl. 1985;3 Suppl 3:S425-7. [pmid: 2856756].
Palatini P, Mormino P, Santonastaso M, Mos L, Dal Follo M, Zanata G, and Pessina AC Target-organ damage in stage I hypertensive subjects with white coat and sustained hypertension: results from the HARVEST study Hypertension 1998 31(1):57 63 9449391
Palatini P, Mormino P, Santonastaso M, Mos L, and Pessina AC Ambulatory blood pressure predicts end-organ damage only in subjects with reproducible recordings. HARVEST Study Investigators. Hypertension and Ambulatory Recording Venetia Study J Hypertens 1999 17(4):465 73 10404947
Palatini P, Penzo M, Canali C, Dorigatti F, and Pessina AC Interactive action of the white-coat effect and the blood pressure levels on cardiovascular complications in hypertension Am J Med 1997 103(3):208 16 9316553
Palatini P and Pessina AC A new approach to define the upper normal limits of ambulatory blood pressure J Hypertens Suppl 1990 8(6):S65 70 2082000
Palatini P, Visentin P, Mormino P, Pietra M, Piccolo D, Cozzutti E, Mione V, Bocca P, Perissinotto F, and Pessina AC Left ventricular performance in the early stages of systemic hypertension. HARVEST Study Group. Hypertension and Ambulatory Recording Venetia Study Am J Cardiol 1998 81(4):418 23 9485130
Palatini P, Visentin P, Nicolosi G, Mione V, Stritoni P, Canali C, Mormino P, and Pessina AC Supernormal left ventricular performance in young subjects with mild hypertension: an alerting response to the echocardiographic procedure? Clin Sci (Colch) 1996 91(3):275 81 8869409
Palatini P, Visentin P, Nicolosi G, Mione V, Stritoni P, Michieletto M, Graniero G, Mormino P, and Pessina AC Endocardial versus midwall measurement of left ventricular function in mild hypertension: an insight from the Harvest Study J Hypertens 1996 14(8):1011 7 8884557
Palmieri V, de Simone G, Roman MJ, Schwartz JE, Pickering TG, and Devereux RB Ambulatory blood pressure and metabolic abnormalities in hypertensive subjects with inappropriately high left ventricular mass Hypertension 1999 34(5):1032 40 10567178
Paran E, Landau-Salzberg M, Kobrin Y, and Viskoper R Effect of placebo on office and on 24 hour noninvasive ambulatory blood pressure measurements J Hum Hypertens 1993 7(6):567 70 8114049
Parati G, Omboni S, and Mancia G Difference between office and ambulatory blood pressure and response to antihypertensive treatment J Hypertens 1996 14(6):791 7 8793703
Parati G, Omboni S, Staessen J, Thijs L, Fagard R, Ulian L, and Mancia G Limitations of the difference between clinic and daytime blood pressure as a surrogate measure of the 'white-coat' effect. Syst-Eur investigators J Hypertens 1998 16(1):23 9 9533413
Parati G, Pomidossi G, Malaspina D, Camesasca C, and Mancia G 24-hour blood pressure measurements: methodological and clinical problems Am J Nephrol 1986 6Suppl 2:55 60 3799740
Parati G, Ulian L, Sampieri L, Palatini P, Villani A, Vanasia A, and Mancia G Attenuation of the "white-coat effect" by antihypertensive treatment and regression of target organ damage Hypertension 2000 35(2):614 20 10679506
Parrinello G, Scaglione R, Pinto A, Corrao S, Cecala M, Di Silvestre G, Amato P, Licata A, and Licata G Central obesity and hypertension: the role of plasma endothelin Am J Hypertens 1996 9(12 Pt 1):1186 91 8972889
Pavek K and Taube A Interchangeability of ambulatory and office blood pressure: limitations of reproducibility and agreement Blood Press 2000 9(4):192 9 11055471
Pearce KA, Evans GW, Summerson J, and Rao JS Comparisons of ambulatory blood pressure monitoring and repeated office measurements in primary care J Fam Pract 1997 45(5):426 33 9374969
Pecis M, Azevedo MJ, and Gross JL Glomerular hyperfiltration is associated with blood pressure abnormalities in normotensive normoalbuminuric IDDM patients Diabetes Care 1997 20(8):1329 33 9250464
Peek M, Shennan A, Halligan A, Lambert PC, Taylor DJ, and De Swiet M Hypertension in pregnancy: which method of blood pressure measurement is most predictive of outcome? Obstet Gynecol 1996 88(6):1030 3 8942848
Peixoto AJ, Santos SF, Mendes RB, Crowley ST, Maldonado R, Orias M, Mansoor GA, and White WB Reproducibility of ambulatory blood pressure monitoring in hemodialysis patients Am J Kidney Dis 2000 36(5):983 90 11054355
Penny JA, Halligan AW, Shennan AH, Lambert PC, Jones DR, de Swiet M, and Taylor DJ Automated, ambulatory, or conventional blood pressure measurement in pregnancy: which is the better predictor of severe hypertension? Am J Obstet Gynecol 1998 178(3):521 6 9539520
Perloff D and Sokolow M Ambulatory blood pressure: mortality and morbidity J Hypertens Suppl 1991 9(8):S31 3
Perloff D and Sokolow M Ambulatory blood pressure: the San Francisco experience J Hypertens Suppl 1990 8(6):S105 11 2081991
Perloff D, Sokolow M, and Cowan R The prognostic value of ambulatory blood pressure monitoring in treated hypertensive patients J Hypertens Suppl 1991 9(1):S33 9 discussion S39-40
Perloff D, Sokolow M, and Cowan R The prognostic value of ambulatory blood pressures JAMA 1983 249(20):2792 8 6842787
Perloff D, Sokolow M, Cowan RM, and Juster RP Prognostic value of ambulatory blood pressure measurements: further analyses J Hypertens Suppl 1989 7(3):S3 10
Perry HM Jr and Camel GH Survival of treated hypertensive patients as a function of compliance and control J Hypertens Suppl 1984 2(3):S197 9 6152782
Pessina AC, Palatini P, Di Marco A, Mormino P, Fazio G, Libardoni M, Mos L, Casiglia E, and Dal Palu C. Continuous ambulatory blood pressure monitoring versus casual blood pressure in borderline hypertension. J Cardiovasc Pharmacol. 1986;8 Suppl 5:S93-7.
Phillips RA, Sheinart KF, Godbold JH, Mahboob R, and Tuhrim S The association of blunted nocturnal blood pressure dip and stroke in a multiethnic population Am J Hypertens 2000 13(12):1250 5 11130767
Phillips RA, Sheinart KF, Godbold JH, Mahboob R, and Tuhrim S The association of blunted nocturnal blood pressure dip and stroke in a multiethnic population Am J Hypertens 2000 13(12):1250 5 11130767
Pickering TG, Coats A, Mallion JM, Mancia G, and Verdecchia P Blood Pressure Monitoring. Task force V: White-coat hypertension Blood Press Monit 1999 4(6):333 41 10602537
Pickering TG, Harshfield GA, Kleinert HD, Blank S, and Laragh JH Blood pressure during normal daily activities, sleep, and exercise. Comparison of values in normal and hypertensive subjects JAMA 1982 247(7):992 6 7057592
Pickering TG, Harshfield GA, Kleinert HD, and Laragh JH Ambulatory monitoring in the evaluation of blood pressure in patients with borderline hypertension and the role of the defense reflex Clin Exp Hypertens [A] 1982 4(4-5):675 93
Pickering TG and James GD Ambulatory blood pressure and prognosis J Hypertens Suppl 1994 12(8):S29 33
Pickering TG, James GD, Boddie C, Harshfield GA, Blank S, and Laragh JH How common is white coat hypertension? JAMA 1988 259(2):225 8 3336140
Pickering TG, Mann SJ, and James GD. Clinic and ambulatory blood pressure measurements for the evaluation of borderline hypertension in smokers and non-smokers. Arch Mal Coeur Vaiss. 1991;84 Spec No 3:17-9. [pmid: 1953279].
Pierce JP, Watson DS, Knights S, Gliddon T, Williams S, and Watson R A controlled trial of health education in the physician's office Prev Med 1984 13(2):185 94 6377291
Pierdomenico SD, Lapenna D, Guglielmi MD, Antidormi T, Schiavone C, Cuccurullo F, and Mezzetti A Target organ status and serum lipids in patients with white coat hypertension Hypertension 1995 26(5):801 7 7591021
Pierdomenico SD, Mezzetti A, Lapenna D, Guglielmi MD, Mancini M, Salvatore L, Antidormi T, Costantini F, and Cuccurullo F 'White-coat' hypertension in patients with newly diagnosed hypertension: evaluation of prevalence by ambulatory monitoring and impact on cost of health care Eur Heart J 1995 16(5):692 7 7588903
Polonia J, Martins L, Bravo-Faria D, Macedo F, Coutinho J, and Simoes L Higher left ventricle mass in normotensives with exaggerated blood pressure responses to exercise associated with higher ambulatory blood pressure load and sympathetic activity Eur Heart J 1992 13Suppl A:30 6
Polonia J, Santos AR, Gama GM, and Barros H Accuracy of twenty-four-hour ambulatory blood pressure monitoring (night-day values) for the diagnosis of secondary hypertension J Hypertens 1995 13(12 Pt 2):1738 41 8903643
Polonia JJ, Santos AR, Gama GM, Basto F, Bettencourt PM, and Martins LR Follow-up clinic and ambulatory blood pressure in untreated white-coat hypertensive patients (evaluation after 2-5 years) Blood Press Monit 1997 2(6):289 95 10388905
Pontremoli R, Nicolella C, Viazzi F, Ravera M, Sofia A, Berruti V, Bezante GP, Del Sette M, Martinoli C, Sacchi G, and Deferrari G Microalbuminuria is an early marker of target organ damage in essential hypertension Am J Hypertens 1998 11(4 Pt 1):430 8 9607381
Porcellati C, Schillaci G, Verdecchia P, Battistelli M, Bartoccini C, Zampi I, Guerrieri M, and Comparato E. Diurnal blood pressure changes and left ventricular mass: Influence of daytime blood pressure. High Blood Press Cardiovasc Prev. 1993;2:249-58.
Portman RJ, Yetman RJ, and West MS Efficacy of 24-hour ambulatory blood pressure monitoring in children J Pediatr 1991 118(6):842 9 2040918
Pose-Reino A, Gonzalez-Juanatey JR, Pastor C, Mendez I, Estevez JC, Alvarez D, Valdes L, and Cabezas-Cerrato J Clinical implications of white coat hypertension Blood Press 1996 5(5):264 73 8879598
Poulsen PL, Ebbehoj E, Hansen KW, and Mogensen CE 24-h blood pressure and autonomic function is related to albumin excretion within the normoalbuminuric range in IDDM patients Diabetologia 1997 40(6):718 25 9222653
Power J, Rushbrook J, and Shennan A Improving surveillance of pre-eclampsia: self assessment of blood pressure and proteinuria Prof Care Mother Child 1997 7(5):121 3 9439216
Prasad N, MacFadyen RJ, Ogston SA, and MacDonald TM Elevated blood pressure during the first two hours of ambulatory blood pressure monitoring: a study comparing consecutive twenty-four-hour monitoring periods J Hypertens 1995 13(3):291 5 7622849
Prasad N, MacFadyen RJ, Peebles L, Anderson J, and MacDonald TM The white-coat response in ambulatory blood pressure monitoring: elimination and attenuation Blood Press Monit 1996 1(6):481 4 10226279
Prattichizzo FA and Galetta F White-coat normotension and blood pressure variability Angiology 1996 47(7):663 8 8686959
Prisant LM and Carr AA Ambulatory blood pressure monitoring and echocardiographic left ventricular wall thickness and mass Am J Hypertens 1990 3(2):81 9 2137704
Prisant LM, Carr AA, Bottini PB, Thompson WO, and Rhoades RB Repeatability of automated ambulatory blood pressure measurements J Fam Pract 1992 34(5):569 74 1578206
Rasmussen SL, Torp-Pedersen C, Borch-Johnsen K, and Ibsen H Normal values for ambulatory blood pressure and differences between casual blood pressure and ambulatory blood pressure: results from a Danish population survey J Hypertens 1998 16(10):1415 24 9814611
Rave K, Bender R, Heise T, and Sawicki PT Value of blood pressure self-monitoring as a predictor of progression of diabetic nephropathy J Hypertens 1999 17(5):597 601 10403602
Redon J, Baldo E, Lurbe E, Bertolin V, Lozano JV, Miralles A, and Pascual JM. Microalbuminuria, left ventricular mass and ambulatory blood pressure in essential hypertension. Kidney Int Suppl. 1996;55:S81-4. [pmid: 8743518].
Redon J, Campos C, Narciso ML, Rodicio JL, Pascual JM, and Ruilope LM Prognostic value of ambulatory blood pressure monitoring in refractory hypertension: a prospective study Hypertension 1998 31(2):712 8 9461245
Redon J, Liao Y, Lozano JV, Miralles A, Pascual JM, and Cooper RS Ambulatory blood pressure and microalbuminuria in essential hypertension: role of circadian variability J Hypertens 1994 12(8):947 53 7814854
Redon J and Lurbe E Ambulatory blood pressure monitoring during antihypertensive treatment: the case of non-responder patients Blood Press Monit 1996 1(3):299 303 10226248
Reeves RA, Leenen FH, and Joyner CD Reproducibility of nurse-measured, exercise and ambulatory blood pressure and echocardiographic left ventricular mass in borderline hypertension J Hypertens 1992 10(10):1249 56 1335008
Reichert H, Lindinger A, Frey O, Mortzeck J, Kiefer J, Busch C, and Hoffmann W Ambulatory blood pressure monitoring in healthy schoolchildren Pediatr Nephrol 1995 9(3):282 6 7632511
Reusz GS, Hobor M, Tulassay T, Sallay P, and Miltenyi M 24 hour blood pressure monitoring in healthy and hypertensive children Arch Dis Child 1994 70(2):90 4 8129450
Rizzo V, Piccirillo G, Cicconetti P, Bianchi A, Capponi L, Salza MC, Cacciafesta M, and Marigliano V Ambulatory blood pressure and echocardiographic left ventricular dimensions in elderly hypertensive subjects Angiology 1996 47(10):981 9 8873584
Rizzoni D, Muiesan ML, Montani G, Zulli R, Calebich S, and Agabiti-Rosei E Relationship between initial cardiovascular structural changes and daytime and nighttime blood pressure monitoring Am J Hypertens 1992 5(3):180 6 1575945
Rockstroh JK, Schmieder RE, Schlaich MP, and Messerli FH Renal and systemic hemodynamics in black and white hypertensive patients Am J Hypertens 1997 10(9 Pt 1):971 8 9324101
Rogers MA, Small D, Buchan DA, Butch CA, Stewart CM, Krenzer BE, and Husovsky HL Home monitoring service improves mean arterial pressure in patients with essential hypertension. A randomized, controlled trial Ann Intern Med 2001 134(11):1024 32 11388815
Ross-McGill H, Hewison J, Hirst J, Dowswell T, Holt A, Brunskill P, and Thornton JG Antenatal home blood pressure monitoring: a pilot randomised controlled trial BJOG 2000 107(2):217 21 10688505
Rucker L, Mabourakh S, and Onishi R Treatment decisions in "white coat" hypertension: do we need the whole 24 hours? South Med J 1990 83(6):610 2 2356490
Ruddy MC, Bialy GB, Malka ES, Lacy CR, and Kostis JB The relationship of plasma renin activity to clinic and ambulatory blood pressure in elderly people with isolated systolic hypertension J Hypertens Suppl 1988 6(4):S412 5 3071579
Ruggenenti P, Perna A, Lesti M, Pisoni R, Mosconi L, Arnoldi F, Ciocca I, Gaspari F, and Remuzzi G Pretreatment blood pressure reliably predicts progression of chronic nephropathies. GISEN Group Kidney Int 2000 58(5):2093 101 11044230
Rugnath T, Pillay BJ, and Cassimjee MH Twenty-four hour ambulatory blood pressure monitoring in general practice S Afr Med J 2000 90(9):898 904 11081143
Rutan GH, McDonald RH, and Kuller LH Comparison of ambulatory and clinic blood pressure and heart rate in older persons with isolated systolic hypertension Am J Hypertens 1992 5(12 Pt 1):880 6 1285937
Sahn DJ, DeMaria A, Kisslo J, Weyman A Recommendations regarding quantitation in M-mode echocardiography: results of a survey of echocardiographic measurements Circulation 1978 Dec 58(6):1072 83
Saito I, Takeshita E, Murata K, Kawabe H, and Saruta T Serum cortisol in the white-coat phenomenon Blood Press Monit 1996 1(4):381 3 10226263
Sakuma M, Imai Y, Nagai K, Watanabe N, Sakuma H, Minami N, Satoh H, and Abe K Reproducibility of home blood pressure measurements over a 1-year period Am J Hypertens 1997 10(7 Pt 1):798 803 9234836
Sakuma M, Imai Y, Tsuji I, Nagai K, Ohkubo T, Watanabe N, Sakuma H, Satoh H, and Hisamichi S Predictive value of home blood pressure measurement in relation to stroke morbidity: a population-based pilot study in Ohasama, Japan Hypertens Res 1997 20(3):167 74 9328797
Sander D and Klingelhofer J Diurnal systolic blood pressure variability is the strongest predictor of early carotid atherosclerosis Neurology 1996 47(2):500 7 8757028
Sander D, Kukla C, Klingelhofer J, Winbeck K, and Conrad B Relationship between circadian blood pressure patterns and progression of early carotid atherosclerosis: A 3-year follow-up study Circulation 2000 102(13):1536 41 11004145
Sawicki PT, Muhlhauser I, Didjurgeit U, Baumgartner A, Bender R, and Berger M Intensified antihypertensive therapy is associated with improved survival in type 1 diabetic patients with nephropathy J Hypertens 1995 13(8):933 8 8557972
Sawicki PT, Muhlhauser I, Didjurgeit U, and Berger M Effects of intensification of antihypertensive care in diabetic nephropathy J Diabetes Complications 1995 9(4):315 7 8573755
Scarpelli PT, Livi R, Caselli GM, Di Maria L, Teghini L, Montemurro V, Toti G, and Becucci A Accelerated (malignant) hypertension: a study of 121 cases between 1974 and 1996 J Nephrol 1997 10(4):207 15 9377729
Schettini C, Bianchi M, Nieto F, Sandoya E, and Senra H Ambulatory blood pressure: normality and comparison with other measurements. Hypertension Working Group Hypertension 1999 34(4 Pt 2):818 25 10523367
Schillaci G, Verdecchia P, Borgioni C, Ciucci A, and Porcellati C Early cardiac changes after menopause Hypertension 1998 32(4):764 9 9774377
Schillaci G, Verdecchia P, Borgioni C, Ciucci A, and Porcellati C Lack of association between blood pressure variability and left ventricular mass in essential hypertension Am J Hypertens 1998 11(5):515 22 9633786
Schillaci G, Verdecchia P, Porcellati C, Cuccurullo O, Cosco C, and Perticone F Continuous relation between left ventricular mass and cardiovascular risk in essential hypertension Hypertension 2000 35(2):580 6 10679501
Schillaci G, Verdecchia P, Sacchi N, Bruni B, Benemio G, Pede S, and Porcellati C Clinical relevance of office underestimation of usual blood pressure in treated hypertension Am J Hypertens 2000 13(5 Pt 1):523 8 10826404
Schlaich MP, Klingbeil A, Hilgers K, Schobel HP, and Schmieder RE Relation between the renin-angiotensin-aldosterone system and left ventricular structure and function in young normotensive and mildly hypertensive subjects Am Heart J 1999 138(5 Pt 1):810 7 10539810
Schlaich MP, Schobel HP, Hilgers K, and Schmieder RE Impact of aldosterone on left ventricular structure and function in young normotensive and mildly hypertensive subjects Am J Cardiol 2000 85(10):1199 206 10802001
Schrader J, Luders S, Zuchner C, Herbold M, and Schrandt G Practice vs ambulatory blood pressure measurement under treatment with ramipril (PLUR Study): a randomised, prospective long-term study to evaluate the benefits of ABPM in patients on antihypertensive treatment J Hum Hypertens 2000 14(7):435 40 10918548
Schulte KL, Liederwald K, Meyer-Sabellek W, van Gemmeren D, Lenz T, and Gotzen R Relationships between ambulatory blood pressure, forearm vascular resistance, and left ventricular mass in hypertensive and normotensive subjects Am J Hypertens 1993 6(9):786 93 8110433
Schwan A Reference values for 24-hour non-invasive ambulatory blood pressure: a population study of men aged fifty Scand J Prim Health Care 1993 11(1):21 5 8484075
Schwenger V and Ritz E Audit of antihypertensive treatment in patients with renal failure Nephrol Dial Transplant 1998 13(12):3091 5 9870471
Sega G, Bravi C, Cesana G, Valagussa F, Mancia G, and Zanchetti A. Ambulatory and home blood pressure normality: the Pamela Study. J Cardiovasc Pharmacol. 1994;23 Suppl 5:S12-5. [pmid: 7609500].
Sega R, Cesana G, Bombelli M, Grassi G, Stella ML, Zanchetti A, and Mancia G Seasonal variations in home and ambulatory blood pressure in the PAMELA population. Pressione Arteriose Monitorate E Loro Associazioni J Hypertens 1998 16(11):1585 92 9856358
Sega R, Cesana G, Milesi C, Grassi G, Zanchetti A, and Mancia G Ambulatory and home blood pressure normality in the elderly: data from the PAMELA population Hypertension 1997 30(1 Pt 1):1 6 9231813
Selenta C, Hogan BE, and Linden W How often do office blood pressure measurements fail to identify true hypertension? An exploration of white-coat normotension Arch Fam Med 2000 9(6):533 40 10862216
Sennett C Implementing the new HEDIS hypertension performance measure Manag Care 2000 9(4 Suppl):2 17 quiz 18-21
Shapiro AP, Karschner JK, Glunk DJ, and Barnhill BM Clinical use of ambulatory blood pressure monitoring. A review of value in patient care Arch Fam Med 1995 4(8):691 6 7620599
Sheps SG, Bailey KR, and Zachariah PK Short-term (six hour), ambulatory blood pressure monitoring J Hum Hypertens 1994 8(12):873 8 7884784
Siamopoulos KC, Papanikolaou S, Elisaf M, Theodorou J, Pappas H, and Papanikolaou N. Ambulatory blood pressure monitoring in normotensive pregnant women. J Hum Hypertens. 1996;10 Suppl 3:S51-4.
Siegel WC, Blumenthal JA, and Divine GW Physiological, psychological, and behavioral factors and white coat hypertension Hypertension 1990 16(2):140 6 2379947
Sihm I, Schroeder AP, Aalkjaer C, Holm M, Morn B, Mulvany M, Thygesen K, and Lederballe O The relation between peripheral vascular structure, left ventricular hypertrophy, and ambulatory blood pressure in essential hypertension Am J Hypertens 1995 8(10 Pt 1):987 96 8845080
Silagy CA, McNeil JJ, Farish S, McCloud PI, and McGrath BP Components of blood pressure variability in the elderly and effects on sample size calculations for clinical trials Am J Hypertens 1992 5(7):449 58 1637517
Silagy CA, McNeil JJ, and McGrath BP Isolated systolic hypertension: does it really exist on ambulatory blood pressure monitoring? Clin Exp Pharmacol Physiol 1990 17(3):203 6 2340642
Silagy CA, McNeil JJ, McGrath BP, and Farish S Is isolated systolic hypertension a 'white coat' phenomenon in the elderly? Clin Exp Pharmacol Physiol 1992 19(5):291 3 1521359
Sochett EB, Poon I, Balfe W, and Daneman D Ambulatory blood pressure monitoring in insulin-dependent diabetes mellitus adolescents with and without microalbuminuria J Diabetes Complications 1998 12(1):18 23 9442810
Soghikian K, Casper SM, Fireman BH, Hunkeler EM, Hurley LB, Tekawa IS, and Vogt TM Home blood pressure monitoring. Effect on use of medical services and medical care costs Med Care 1992 30(9):855 65 1518317
Sokolow M, Werdegar D, Kain HK, and Hinman AT Relationship between level of blood pressure measured casually and by portable recorders and severity of complications in essential hypertension Circulation 1966 34(2):279 98 5969359
Soma J, Aakhus S, Dahl K, Slordahl S, Wiseth R, Wideroe TE, and Skjaerpe T Hemodynamics in white coat hypertension compared to ambulatory hypertension and normotension Am J Hypertens 1996 9(11):1090 8 8931834
Soma J, Wideroe TE, Dahl K, Rossvoll O, and Skjaerpe T Left ventricular systolic and diastolic function assessed with two-dimensional and doppler echocardiography in "white coat" hypertension J Am Coll Cardiol 1996 28(1):190 6 8752813
Sorof JM and Portman RJ White coat hypertension in children with elevated casual blood pressure J Pediatr 2000 137(4):493 7 11035827
Spence JD, Bass M, Robinson HC, Cheung H, Melendez LJ, Arnold JM, and Manuck SB Prospective study of ambulatory monitoring and echocardiography in borderline hypertension Clin Invest Med 1991 14(3):241 50 1893657
Spitzer SB, Llabre MM, Ironson GH, Gellman MD, and Schneiderman N The influence of social situations on ambulatory blood pressure Psychosom Med 1992 54(1):79 86 1553403
Staessen J, Bulpitt CJ, Fagard R, Mancia G, O'Brien ET, Thijs L, Vyncke G, and Amery A Reference values for the ambulatory blood pressure and the blood pressure measured at home: a population study J Hum Hypertens 1991 5(5):355 61 1770465
Staessen J, Bulpitt CJ, O'Brien E, Cox J, Fagard R, Stanton A, Thijs L, Van Hulle S, Vyncke G, and Amery A The diurnal blood pressure profile. A population study Am J Hypertens 1992 5(6 Pt 1):386 92 1524764
Staessen J, O'Brien E, Atkins N, Bulpitt CJ, Cox J, Fagard R, O'Malley K, Thijs L, and Amery A The increase in blood pressure with age and body mass index is overestimated by conventional sphygmomanometry Am J Epidemiol 1992 136(4):450 9 1415164
Staessen JA, Bieniaszewski L, O'Brien ET, Imai Y, and Fagard R An epidemiological approach to ambulatory blood pressure monitoring:the Belgian Population Study Blood Press Monit 1996 1(1):13 26 10226197
Staessen JA, Byttebier G, Buntinx F, Celis H, O'Brien ET, and Fagard R Antihypertensive treatment based on conventional or ambulatory blood pressure measurement. A randomized controlled trial. Ambulatory Blood Pressure Monitoring and Treatment of Hypertension Investigators JAMA 1997 278(13):1065 72 9315764
Staessen JA, Fagard R, Lijnen P, Thijs L, van Hulle S, Vyncke G, and Amery A. Ambulatory blood pressure and blood pressure measured at home: progress report on a population study. J Cardiovasc Pharmacol. 1994;23 Suppl 5:S5-11. [pmid: 7609507].
Staessen JA, Ginocchio G, Thijs L, and Fagard R Conventional and ambulatory blood pressure and menopause in a prospective population study J Hum Hypertens 1997 11(8):507 14 9322832
Staessen JA, O'Brien ET, Amery AK, Atkins N, Baumgart P, De Cort P, Degaute JP, Dolenc P, De Gaudemaris R, Enstrom I and others Ambulatory blood pressure in normotensive and hypertensive subjects: results from an international database J Hypertens Suppl 1994 12(7):S1 12
Staessen JA, O'Brien ET, Atkins N, and Amery AK Short report: ambulatory blood pressure in normotensive compared with hypertensive subjects. The Ad-Hoc Working Group J Hypertens 1993 11(11):1289 97 8301112
Staessen JA, O'Brien ET, Atkins N, Fagard R, Vyncke G, and Amery A A consistent reference frame for ambulatory blood pressure monitoring is found in different populations J Hum Hypertens 1994 8(6):423 31 8089827
Staessen JA, Thijs L, Fagard R, O'Brien ET, Clement D, de Leeuw PW, Mancia G, Nachev C, Palatini P, Parati G, Tuomilehto J, and Webster J Predicting cardiovascular risk using conventional vs ambulatory blood pressure in older patients with systolic hypertension. Systolic Hypertension in Europe Trial Investigators JAMA 1999 282(6):539 46 10450715
Stahl SM, Kelley CR, Neill PJ, Grim CE, and Mamlin J Effects of home blood pressure measurement on long-term BP control Am J Public Health 1984 74(7):704 9 6742256
Stamler J, Stamler R, and Neaton JD Blood pressure, systolic and diastolic, and cardiovascular risks. US population data Arch Intern Med 1993 153(5):598 615 8439223
Stergiou GS, Malakos JS, Voutsa AV, Achimastos AD, and Mountokalakis TD Home monitoring of blood pressure: limited value in general practice J Hum Hypertens 1996 10(4):219 23 8736452
Stergiou GS, Skeva II, Baibas NM, Kalkana CB, Roussias LG, and Mountokalakis TD Diagnosis of hypertension using home or ambulatory blood pressure monitoring: comparison with the conventional strategy based on repeated clinic blood pressure measurements J Hypertens 2000 18(12):1745 51 11132597
Stergiou GS, Skeva II, Zourbaki AS, and Mountokalakis TD Self-monitoring of blood pressure at home: how many measurements are needed? J Hypertens 1998b 16(6):725 31
Stergiou GS, Thomopoulou GC, Skeva II, and Mountokalakis TD Home blood pressure normalcy: the Didima study Am J Hypertens 2000 13(6 Pt 1):678 85 10912753
Stergiou GS, Voutsa AV, Achimastos AD, and Mountokalakis TD Home self-monitoring of blood pressure: is fully automated oscillometric technique as good as conventional stethoscopic technique? Am J Hypertens 1997 10(4 Pt 1):428 33 9128209
Stergiou GS, Zourbaki AS, Skeva II, and Mountokalakis TD White coat effect detected using self-monitoring of blood pressure at home: comparison with ambulatory blood pressure Am J Hypertens 1998a 11(7):820 7
Stiefel P, Gimenez J, Miranda ML, Villar J, Muniz-Grijalvo O, Pamies E, Martin-Sanz V, and Carneado J Ambulatory blood pressure monitoring in physicians working in a hospital: is there an increase in the number of subjects with high workplace blood pressures? Int J Cardiol 1994 45(3):183 9 7960263
Strogatz DS and Earp JA The determinants of dropping out of care among hypertensive patients receiving a behavioral intervention Med Care 1983 21(10):970 80 6656327
Sturrock ND, George E, Pound N, Stevenson J, Peck GM, and Sowter H Non-dipping circadian blood pressure and renal impairment are associated with increased mortality in diabetes mellitus Diabet Med 2000 17(5):360 4 10872534
Suzuki Y, Kuwajima I, Aono T, Kanemaru A, Nishinaga M, Shibata H, and Ozawa T Prognostic value of nighttime blood pressure in the elderly: a prospective study of 24-hour blood pressure Hypertens Res 2000 23(4):323 30 10912768
Suzuki Y, Kuwajima I, Kanemaru A, Shimosawa T, Hoshino S, Sakai M, Matsushita S, Ueda K, and Kuramoto K The cardiac functional reserve in elderly hypertensive patients with abnormal diurnal change in blood pressure J Hypertens 1992 10(2):173 9 1313481
Tamura K, Wu JY, Cornelissen G, and Halberg F. Agreement between consecutive ambulatory 24-hour blood pressure and heart rate profiles in Japanese hospital staff. Prog Clin Biol Res. 1990;341A:263-72. [pmid: 2217243].
ten Berge-van der Schaaf J and May JF Self-screening of blood pressure and sodium in a 24-hour urine sample as part of a school health programme J Hum Hypertens 1990 4(4):337 8 2258868
Thijs L, Amery A, Clement D, Cox J, de Cort P, Fagard R, Fowler G, Guo C, Mancia G, Marin R and others Ambulatory blood pressure monitoring in elderly patients with isolated systolic hypertension J Hypertens 1992 10(7):693 9 1321198
Thijs L, Celis H, Clement D, Gil-Extremera B, Kawecka-Jaszcz K, Mancia G, Parati G, Salvetti A, Sarti C, van den Meiracker AH, O'Brien E, Staessen JA, and Fagard R Conventional and ambulatory blood pressure measurement in older patients with isolated systolic hypertension:second progress report on the ambulatory blood pressure monitoring project in the Syst-Eur trial Blood Press Monit 1996 1(2):95 103 10226209
Thijs L, Staessen JA, Celis H, Fagard R, De Cort P, de Gaudemaris R, Enstrom I, Imai Y, Julius S, Menard J, Mion D, Palatini P, Rosenfeld J, Shapiro D, Spence D, and Stergiou G The international database of self-recorded blood pressures in normotensive and untreated hypertensive subjects Blood Press Monit 1999 4(2):77 86 10450117
Timio M, Lolli S, Verdura C, Monarca C, Merante F, and Guerrini E Circadian blood pressure changes in patients with chronic renal insufficiency: a prospective study Ren Fail 1993 15(2):231 7 8469792
Timio M, Venanzi S, Lolli S, Lippi C, Verdura E, Guerrini E, and Monarco C. Night-time blood pressure and progression of renal insufficiency. High Blood Press Cardiovasc Prev. 1994;3:39-44.
Timio M, Venanzi S, Lolli S, Lippi G, Verdura C, Monarca C, and Guerrini E "Non-dipper" hypertensive patients and progressive renal insufficiency: a 3-year longitudinal study Clin Nephrol 1995 43(6):382 7 7554522
Tochikubo O, Miyajima E, Shigemasa T, and Ishii M Relation between body fat-corrected ECG voltage and ambulatory blood pressure in patients with essential hypertension Hypertension 1999 33(5):1159 63 10334804
Torriani S, Waeber B, Petrillo A, Di Stefano R, Mooser V, Scherrer U, Nussberger J, Hofstetter JR, and Brunner HR Ambulatory blood pressure monitoring in the elderly hypertensive patient J Hypertens Suppl 1988 6(1):S25 7
Trazzi S, Mutti E, Frattola A, Imholz B, Parati G, and Mancia G Reproducibility of non-invasive and intra-arterial blood pressure monitoring: implications for studies on antihypertensive treatment J Hypertens 1991 9(2):115 9 1849525
Tseng YZ, Tseng CD, Lo HM, Chiang FT, and Hsu KL Characteristic abnormal findings of ambulatory blood pressure indicative of hypertensive target organ complications Eur Heart J 1994 15(8):1037 43 7988594
Tsuchiya M, Kojima S, Nakagawa M, Sakaguchi A, Natsume T, Kimura G, Kuroda K, Uda M, Sakamoto N, Satani M, Ito K, and Ikeda M Home blood pressure and circadian variation of blood pressure in the evaluation of hypertensive patients Jpn Circ J 1981 45(7):772 80 7021897
Tsuji I, Imai Y, Nagai K, Ohkubo T, Watanabe N, Minami N, Itoh O, Bando T, Sakuma M, Fukao A, Satoh H, Hisamichi S, and Abe K Proposal of reference values for home blood pressure measurement: prognostic criteria based on a prospective observation of the general population in Ohasama, Japan Am J Hypertens 1997 10(4 Pt 1):409 18 9128207
Tucker B, Fabbian F, Giles M, Thuraisingham RC, Raine AE, and Baker LR Left ventricular hypertrophy and ambulatory blood pressure monitoring in chronic renal failure Nephrol Dial Transplant 1997 12(4):724 8 9141001
van de Weijgert EJ and Braun JJ Experience with noninvasive ambulatory 24-hour blood pressure recording in a community hospital Neth J Med 1992 40(3-4):175 82 1603208
van der Steen MS, Lenders JW, Graafsma SJ, den Arend J, and Thien T Reproducibility of ambulatory blood pressure monitoring in daily practice J Hum Hypertens 1999 13(5):303 8 10376847
Van Egeren LF and Sparrow AW Laboratory stress testing to assess real-life cardiovascular reactivity Psychosom Med 1989 51(1):1 9 2928457
Vannucchi PL, Monaldi ML, Cipriani M, Bacalli S, di Tommaso MP, Montigiani A, and Lagi A Detection of normotension, borderline and hypertension cutoffs in a population evaluated by non invasive blood pressure monitoring Recenti Prog Med 1991 82(9):478 82 1745833
Veerman DP, de Blok K, Delemarre BJ, and van Montfrans GA Office, nurse, basal and ambulatory blood pressure as predictors of hypertensive target organ damage in male and female patients J Hum Hypertens 1996 10(1):9 15 8642194
Veerman DP and van Montfrans GA Nurse-measured or ambulatory blood pressure in routine hypertension care J Hypertens 1993 11(3):287 92 8387086
Verdecchia P Left ventricular mass in dippers and non-dippers J Hypertens 1995 13(12 Pt 1):1481 3 9110947
Verdecchia P, Borgioni C, Ciucci A, Gattobigio R, Schillaci G, Sacchi N, Santucci A, Santucci C, Reboldi G, and Porcellati C Prognostic significance of blood pressure variability in essential hypertension Blood Press Monit 1996 1(1):3 11 10226196
Verdecchia P, Gatteschi C, Benemio G, Boldrini F, Guerrieri M, and Porcellati C Home ambulatory blood pressure readings do not differ from clinic readings taken at the same time of day J Hum Hypertens 1988 2(4):235 40 3270511
Verdecchia P, Porcellati C, Schillaci G, Borgioni C, Ciucci A, Battistelli M, Guerrieri M, Gatteschi C, Zampi I, Santucci A and others Ambulatory blood pressure. An independent predictor of prognosis in essential hypertension Hypertension 1994 24(6):793 801 7995639
Verdecchia P, Porcellati C, Zampi I, Schillaci G, Gatteschi C, Battistelli M, Bartoccini C, Borgioni C, and Ciucci A Asymmetric left ventricular remodeling due to isolated septal thickening in patients with systemic hypertension and normal left ventricular masses Am J Cardiol 1994 73(4):247 52 8296754
Verdecchia P, Reboldi G, Schillaci G, Borgioni C, Ciucci A, Telera MP, Santeusanio F, Porcellati C, and Brunetti P Circulating insulin and insulin growth factor-1 are independent determinants of left ventricular mass and geometry in essential hypertension Circulation 1999 100(17):1802 7 10534468
Verdecchia P, Schillaci G, Boldrini F, Guerrieri M, Gatteschi C, Benemio G, and Porcellati C Risk stratification of left ventricular hypertrophy in systemic hypertension using noninvasive ambulatory blood pressure monitoring Am J Cardiol 1990 66(5):583 90 2144095
Verdecchia P, Schillaci G, Boldrini F, Guerrieri M, and Porcellati C Sex, cardiac hypertrophy and diurnal blood pressure variations in essential hypertension J Hypertens 1992 10(7):683 92 1321197
Verdecchia P, Schillaci G, Boldrini F, Guerrieri M, Zampi I, and Porcellati C Quantitative assessment of day-to-day spontaneous variability in non-invasive ambulatory blood pressure measurements in essential hypertension J Hypertens Suppl 1991 9(6):S322 3 1818982
Verdecchia P, Schillaci G, Boldrini F, Zampi I, and Porcellati C Variability between current definitions of 'normal' ambulatory blood pressure. Implications in the assessment of white coat hypertension Hypertension 1992 20(4):555 62 1398890
Verdecchia P, Schillaci G, Borgioni C, Ciucci A, Battistelli M, Bartoccini C, Santucci A, Santucci C, Reboldi G, and Porcellati C Adverse prognostic significance of concentric remodeling of the left ventricle in hypertensive patients with normal left ventricular mass J Am Coll Cardiol 1995 25(4):871 8 7884090
Verdecchia P, Schillaci G, Borgioni C, Ciucci A, Gattobigio R, Guerrieri M, Comparato E, Benemio G, and Porcellati C Altered circadian blood pressure profile and prognosis Blood Press Monit 1997 2(6):347 52 10234138
Verdecchia P, Schillaci G, Borgioni C, Ciucci A, Gattobigio R, Sacchi N, Guerrieri M, Comparato E, and Porcellati C Identification of subjects with white-coat hypertension and persistently normal ambulatory blood pressure Blood Press Monit 1996 1(3):217 22 10226230
Verdecchia P, Schillaci G, Borgioni C, Ciucci A, Gattobigio R, Zampi I, Reboldi G, and Porcellati C Prognostic significance of serial changes in left ventricular mass in essential hypertension Circulation 1998 97(1):48 54 9443431
Verdecchia P, Schillaci G, Borgioni C, Ciucci A, Gattobigio R, Zampi I, Santucci A, Santucci C, Reboldi G, and Porcellati C Prognostic value of left ventricular mass and geometry in systemic hypertension with left ventricular hypertrophy Am J Cardiol 1996 78(2):197 202 8712142
Verdecchia P, Schillaci G, Borgioni C, Ciucci A, Pede S, and Porcellati C Ambulatory pulse pressure: a potent predictor of total cardiovascular risk in hypertension Hypertension 1998 32(6):983 8 9856961
Verdecchia P, Schillaci G, Borgioni C, Ciucci A, and Porcellati C Prognostic significance of the white coat effect Hypertension 1997 29(6):1218 24 9180621
Verdecchia P, Schillaci G, Borgioni C, Ciucci A, and Porcellati C White-coat hypertension Lancet 1996 348(9039):1444 5 discussion 1445-6
Verdecchia P, Schillaci G, Borgioni C, Ciucci A, Sacchi N, Battistelli M, Guerrieri M, Comparato E, and Porcellati C Gender, day-night blood pressure changes, and left ventricular mass in essential hypertension. Dippers and peakers Am J Hypertens 1995 8(2):193 6 7755949
Verdecchia P, Schillaci G, Borgioni C, Ciucci A, Telera MP, Pede S, Gattobigio R, and Porcellati C Adverse prognostic value of a blunted circadian rhythm of heart rate in essential hypertension J Hypertens 1998 16(9):1335 43 9746121
Verdecchia P, Schillaci G, Borgioni C, Ciucci A, Zampi I, Battistelli M, Gattobigio R, Sacchi N, and Porcellati C Cigarette smoking, ambulatory blood pressure and cardiac hypertrophy in essential hypertension J Hypertens 1995 13(10):1209 15 8586813
Verdecchia P, Schillaci G, Borgioni C, Ciucci A, Zampi I, Gattobigio R, Sacchi N, and Porcellati C White coat hypertension and white coat effect. Similarities and differences Am J Hypertens 1995 8(8):790 8 7576395
Verdecchia P, Schillaci G, Gatteschi C, Zampi I, Battistelli M, Bartoccini C, and Porcellati C Blunted nocturnal fall in blood pressure in hypertensive women with future cardiovascular morbid events Circulation 1993 88(3):986 92 8353926
Verdecchia P, Schillaci G, Guerrieri M, Boldrini F, Gatteschi C, Benemio G, and Porcellati C Prevalence and determinants of left ventricular diastolic filling abnormalities in an unselected hypertensive population Eur Heart J 1990 11(8):679 91 2144489
Verdecchia P, Schillaci G, Guerrieri M, Gatteschi C, Benemio G, Boldrini F, and Porcellati C Circadian blood pressure changes and left ventricular hypertrophy in essential hypertension Circulation 1990 81(2):528 36 2137047
Verdecchia P, Schillaci G, and Porcellati C Dippers versus non-dippers J Hypertens Suppl 1991 9(8):S42 4
Verdecchia P, Schillaci G, Reboldi G, Franklin SS, and Porcellati C Different prognostic impact of 24-hour mean blood pressure and pulse pressure on stroke and coronary artery disease in essential hypertension Circulation 2001 103(21):2579 84 11382727
Vermeersch P, Duprez D, Packet L, and Cleament M Left ventricular hypertrophy in mild hypertension: Value of ambulatory recordings J Hypertens 1987 5(Suppl 5):S495 S496
Vetter W, Hess L, and Brignoli R Influence of self-measurement of blood pressure on the responder rate in hypertensive patients treated with losartan: results of the SVATCH Study. Standard vs Automatic Treatment Control of COSAAR in Hypertension J Hum Hypertens 2000 14(4):235 41 10805048
Vrijens B and Goetghebeur E Comparing compliance patterns between randomized treatments Control Clin Trials 1997 18(3):187 203 9204220
Vriz O, Lu H, Visentin P, Nicolosi L, Mos L, and Palatini P Gender differences in the relationship between left ventricular size and ambulatory blood pressure in borderline hypertension. The HARVEST Study Eur Heart J 1997 18(4):664 70 9129899
Waeber B, Burnier M, Perret F, Nussberger J, and Brunner HR Ambulatory blood pressure measurement and antihypertensive therapy J Hypertens Suppl 1989 7(3):S33 9
Waeber B, Jacot des Combes B, Porchet M, Biollaz J, Schaller MD, and Brunner HR Ambulatory blood pressure recording to identify hypertensive patients who truly need therapy J Chronic Dis 1984 37(1):55 7 6690459
Waeber B, Weidmann P, Wohler D, and Le Bloch Y Albuminuria in diabetes mellitus: relation to ambulatory versus office blood pressure and effects of cilazapril Am J Hypertens 1996 9(12 Pt 1):1220 7 8972894
Waeber G, Waeber B, Nussberger J, and Brunner HR Ambulatory blood pressure monitoring in adolescent untreated hypertensive patients Clin Exp Hypertens [A] 1986 8(4-5):611 4
Waugh J, Perry IJ, Halligan AW, De Swiet M, Lambert PC, Penny JA, Taylor DJ, Jones DR, and Shennan A Birth weight and 24-hour ambulatory blood pressure in nonproteinuric hypertensive pregnancy Am J Obstet Gynecol 2000 183(3):633 7 10992185
Weber MA, Drayer JI, Nakamura DK, and Wyle FA The circadian blood pressure pattern in ambulatory normal subjects Am J Cardiol 1984 54(1):115 9 6741801
Weber MA, Neutel JM, Smith DH, and Graettinger WF Diagnosis of mild hypertension by ambulatory blood pressure monitoring Circulation 1994 90(5):2291 8 7955186
Weisser B, Grune S, Burger R, Blickenstorfer H, Iseli J, Michelsen SH, Opravil R, Rageth S, Sturzenegger ER, Walker P and others The Dubendorf Study: a population-based investigation on normal values of blood pressure self-measurement J Hum Hypertens 1994 8(4):227 31 8021901
Welin L, Svardsudd K, and Tibblin G Home blood pressure measurements--feasibility and results compared to office measurements. The study of men born in 1913 Acta Med Scand 1982 211(4):275 9 7102366
Weston PJ, Robinson JE, Watt PA, and Thurston H Reproducibility of the circadian blood pressure fall at night in healthy young volunteers J Hum Hypertens 1996 10(3):163 6 8733033
White B, McCabe EJ, and Mansoor GA Comparison of office and ambulatory blood pressure measurements to assess the angiotensin II receptor antagonist eprosartan Blood Press Monit 1996 1(1):45 50 10226201
White WB Predicting hypertensive heart disease via non-invasive methodology: relationship between ambulatory blood pressure and cardiac indices derived by echocardiography and radionuclide ventriculography J Hypertens Suppl 1990 8(6):S113 8 2150531
White WB, Schulman P, McCabe EJ, and Dey HM Average daily blood pressure, not office blood pressure, determines cardiac function in patients with hypertension JAMA 1989 261(6):873 7 2521522
Wiinberg N, Hoegholm A, Christensen HR, Bang LE, Mikkelsen KL, Nielsen PE, Svendsen TL, Kampmann JP, Madsen NH, and Bentzon MW 24-h ambulatory blood pressure in 352 normal Danish subjects, related to age and gender Am J Hypertens 1995 8(10 Pt 1):978 86 8845079
Wilson MD, Barron JJ, Johnson KA, Powell RW, Sood VC, Cziraky MJ, Kalmanowicz J, Partsch DJ, and Patwell JT Determination of ambulatory blood pressure control in treated patients with controlled office blood pressures Blood Press Monit 2000 5(5-6):263 9 11153049
Winnicki M, Canali C, Accurso V, Dorigatti F, Giovinazzo P, and Palatini P Relation of 24-hour ambulatory blood pressure and short-term blood pressure variability to seasonal changes in environmental temperature in stage I hypertensive subjects. Results of the Harvest Trial Clin Exp Hypertens 1996 18(8):995 1012 8922342
Winnicki M, Canali C, Mormino P, and Palatini P Ambulatory blood pressure monitoring editing criteria: is standardization needed? Hypertension and Ambulatory Recording Venetia Study (HARVEST) Group, Italy Am J Hypertens 1997 10(4 Pt 1):419 27 9128208
Wittenberg C, Zabludowski JR, and Rosenfeld JB Overdiagnosis of hypertension in the elderly J Hum Hypertens 1992 6(5):349 51 1464890
Wong Chung MY, Smits P, Lenders JW, and Thien T Reproducibility of the blood pressure fall at night in healthy normotensive volunteers J Hypertens Suppl 1991 9(6):S324 5 1818983
Yamamoto Y, Akiguchi I, Oiwa K, Hayashi M, and Kimura J Adverse effect of nighttime blood pressure on the outcome of lacunar infarct patients Stroke 1998 29(3):570 6 9506594
Yamamoto Y, Akiguchi I, Oiwa K, Satoi H, and Kimura J Diminished nocturnal blood pressure decline and lesion site in cerebrovascular disease Stroke 1995 26(5):829 33 7740575
Zabludowski JR and Rosenfeld JB Evaluation of clinic blood pressure measurements: assessment by daytime ambulatory blood pressure monitoring Isr J Med Sci 1992 28(6):345 8 1607269
Zachariah PK, Sheps SG, Bailey KR, Wiltgen CM, and Moore AG Age-related characteristics of ambulatory blood pressure load and mean blood pressure in normotensive subjects JAMA 1991 265(11):1414 7 1999882
Zachariah PK, Sheps SG, Bailey KR, Wiltgen CM, and Moore AG Reproducibility of ambulatory blood pressure load J Hum Hypertens 1990 4(6):625 31 2096203
Zachariah PK, Sheps SG, Ilstrup DM, Long CR, Bailey KR, Wiltgen CM, and Carlson CA Blood pressure load--a better determinant of hypertension Mayo Clin Proc 1988 63(11):1085 91 3193818
Zachariah PK, Sheps SG, and Moore AG Office blood pressures in supine, sitting, and standing positions: correlation with ambulatory blood pressures Int J Cardiol 1990 28(3):353 60 2210901
Zakopoulos N, Stamatelopoulos S, Toumanidis S, Saridakis N, Trika C, and Moulopoulos S 24 h blood pressure profile affects the left ventricle independently of the pressure level. A study in untreated essential hypertension diagnosed by office blood pressure readings Am J Hypertens 1997 10(2):168 74 9037324
Zakopoulos NA, Nanas SN, Lekakis JP, Vemmos KN, Kotsis VT, Pitiriga VC, Stamatelopoulos SF, and Moulopoulos SD Reproducibility of ambulatory blood pressure measurements in essential hypertension Blood Press Monit 2001 6(1):41 5 11248760
Zakopoulos NA, Toumanidis ST, Barlas GJ, Nanas SN, Lekakis JP, Stamatelopoulos SF, and Moulopoulos SD A pressure-time index' for assessing the severity of essential hypertension J Hypertens 1999 17(10):1387 93 10526898
Zanchetti A, Bond MG, Hennig M, Neiss A, Mancia G, Dal Palu C, Hansson L, Magnani B, Rahn KH, Reid J, Rodicio J, Safar M, Eckes L, and Ravinetto R Risk factors associated with alterations in carotid intima-media thickness in hypertension: baseline data from the European Lacidipine Study on Atherosclerosis J Hypertens 1998 16(7):949 61 9794735
Zannad F, Vaur L, Dutrey-Dupagne C, Genes N, Chatellier G, Elkik F, and Menard J Assessment of drug efficacy using home self-blood pressure measurement: the SMART study. Self Measurement for the Assessment of the Response to Trandolapril J Hum Hypertens 1996 10(6):341 7 8872795
Zarnke KB, Feagan BG, Mahon JL, and Feldman RD A randomized study comparing a patient-directed hypertension management strategy with usual office-based care Am J Hypertens 1997 10(1):58 67 9008249
Zawadzka A, Bird R, Casadei B, and Conway J Audit of ambulatory blood pressure monitoring in the diagnosis and management of hypertension in practice J Hum Hypertens 1998 12(4):249 52 9607694
Zemva A and Rogel P Gender differences in athlete's heart: association with 24-h blood pressure. A study of pairs in sport dancing Int J Cardiol 2001 77(1):49 54 11150625
Zoccali C, Mallamaci F, Tripepi G, Benedetto FA, Cottini E, Giacone G, and Malatino L Prediction of left ventricular geometry by clinic, pre-dialysis and 24-h ambulatory BP monitoring in hemodialysis patients: CREED investigators J Hypertens 1999 17(12 Pt 1):1751 8 10658942
Zweiker R, Eber B, Schumacher M, Toplak H, and Klein W "Non-dipping" related to cardiovascular events in essential hypertensive patients Acta Med Austriaca 1994 21(3):86 9 7701925