# References

1 MacMahon S, Peto R Cutler J, Collins R, Sorlie P, Neaton J, Abbott R, Godwin J, Dyer A, and Stamler J Blood pressure, stroke, and coronary heart disease. Part 1, Prolonged differences in blood pressure: prospective observational studies corrected for the regression dilution bias Lancet 1990 335(8692):765 74 1969518
2 Stamler J, Stamler R, and Neaton JD Blood pressure, systolic and diastolic, and cardiovascular risks. US population data Arch Intern Med 1993 153(5):598 615 8439223
3 Burt VL, Whelton P, Roccella EJ, Brown C, Cutler JA, Higgins M, Horan MJ, and Labarthe D Prevalence of hypertension in the US adult population. Results from the Third National Health and Nutrition Examination Survey, 1988-1991 Hypertension 1995 25(3):305 13 7875754
4 Collins R, Peto R, MacMahon S, Hebert P, Fiebach NH, Eberlein KA, Godwin J, Qizilbash N, Taylor JO, and Hennekens CH Blood pressure, stroke, and coronary heart disease. Part 2, Short-term reductions in blood pressure: overview of randomised drug trials in their epidemiological context Lancet 1990 335(8693):827 38 1969567
5 Kostis JB, Davis BR, Cutler J, Grimm RH Jr, Berge KG, Cohen JD, Lacy CR, Perry HM Jr, Blaufox MD, Wassertheil-Smoller S, Black HR, Schron E, Berkson DM, Curb JD, Smith WM, McDonald R, and Applegate WB Prevention of heart failure by antihypertensive drug treatment in older persons with isolated systolic hypertension. SHEP Cooperative Research Group JAMA 1997 278(3):212 6 9218667
6 Appel LJ The role of diet in the prevention and treatment of hypertension Curr Atheroscler Rep 2000 2(6):521 8 11122788
7 Arch Intern Med 1997 157(21):2413 46 9385294
8 Sennett C Implementing the new HEDIS hypertension performance measure Manag Care 2000 9(4 Suppl):2 17 quiz 18-21
9 Appel LJ and Stason WB Ambulatory blood pressure monitoring and blood pressure self- measurement in the diagnosis and management of hypertension Ann Intern Med 1993 118(11):867 82 8093115
10 Pickering TG, Coats A, Mallion JM, Mancia G, and Verdecchia P Blood Pressure Monitoring. Task force V: White-coat hypertension Blood Press Monit 1999 4(6):333 41 10602537
11 Beevers G, Lip GY, and O'Brien E Blood pressure measurement. Part ii-conventional sphygmomanometry: technique of auscultatory blood pressure measurement BMJ 2001 322(7293):1043 1047 11325773
12 Jones DW, Frohlich ED, Grim CM, Grim CE, and Taubert KA Mercury Sphygmomanometers Should Not be Abandoned: An Advisory Statement From the Council for High Blood Pressure Research, American Heart Association Hypertension 2001 37(2):185 186 11230268
13 O'Brien E, Waeber B, Parati G, Staessen J, and Myers MG Blood pressure measuring devices: recommendations of the European Society of Hypertension BMJ 2001 322(7285):531 536 11230071
14 O'Brien E, Beevers G, and Lip GY Blood pressure measurement. Part iv-automated sphygmomanometry: self blood pressure measurement BMJ 2001 322(7295):1167 70 11348915
15 Verdecchia P, Schillaci G, and Porcellati C Dippers versus non-dippers J Hypertens Suppl 1991 9(8):S42 4
16 Carr AA, Bottini PB and Prisant LM Ambulatory blood pressure monitoring for evaluation and management of hypertensives: effect on outcome and cost effectiveness J Clin Pharmacol 1992 Jul 32(7):610 3
17 Dickersin K, Manheimer E, Wieland L, Robinson K, Lefebvre C, and McDonald S Development of a centralized register of controlled clinical trials: The Cochrane Collaboration's CENTRAL. Evaluation and the Health Professions Supplement Issue The Cochrane Collaboration 2002 25(1):38 64
18 Antivalle M, Lattuada S, Paravicini M, Rindi M, and Libretti A Twenty-four hour non-invasive ambulatory blood pressure monitoring in the assessment of early hypertension J Hypertens 1986 4(Suppl 5):S322 S324
19 Melina D, Colivicchi F, Melina G, and Pristipino C Left ventricular hypertrophy and diastolic dysfunction in alcohol-associated hypertension Minerva Cardioangiol 1993 41(7-8):293 6 8233010
20 Pickering TG, Mann SJ, and James GD Clinic and ambulatory blood pressure measurements for the evaluation of borderline hypertension in smokers and non-smokers Arch Mal Coeur Vaiss 1991 84Spec No 3:17 9 1953279
21 Abe H, Yokouchi M, Saitoh F, Deguchi F, Kimura G, Kojima S, Yoshimi H, Ito K, Kuramochi M, Ikeda M and others Hypertensive complications and home blood pressure: comparison with blood pressure measured in the doctor's office J Clin Hypertens 1987 3(4):661 9 2969039
22 Jula A, Puukka P, and Karanko H Multiple clinic and home blood pressure measurements versus ambulatory blood pressure monitoring Hypertension 1999 34(2):261 6 10454451
23 Mengden T, Battig B, and Vetter W Self-measurement of blood pressure improves the accuracy and reduces the number of subjects in clinical trials J Hypertens Suppl 1991 9(6):S336 7 1818989
24 Nielsen PE, Myschetzky P, Andersen AR, and Andersen GS. Home readings of blood pressure in assessment of hypertensive subjects. Acta Med Scand Suppl. 1986;714:147-51. [pmid: 3472436].
25 Stergiou GS, Skeva II, Zourbaki AS, and Mountokalakis TD Self-monitoring of blood pressure at home: how many measurements are needed? J Hypertens 1998b 16(6):725 31
26 Weisser B, Grune S, Burger R, Blickenstorfer H, Iseli J, Michelsen SH, Opravil R, Rageth S, Sturzenegger ER, Walker P and others The Dubendorf Study: a population-based investigation on normal values of blood pressure self-measurement J Hum Hypertens 1994 8(4):227 31 8021901
27 Ironson GH, Gellman MD, Spitzer SB, Llabre MM, De Carlo Pasin R, Weidler DJ, and Schneiderman N Predicting home and work blood pressure measurements from resting baselines and laboratory reactivity in black and white Americans Psychophysiology 1989 26(2):174 84 2727219
28 Khoury S, Yarows SA, O'Brien TK, and Sowers JR Ambulatory blood pressure monitoring in a nonacademic setting. Effects of age and sex Am J Hypertens 1992 5(9):616 23 1418850
29 Modesti PA, Pieri F, Cecioni I, Valenti R, Mininni S, Toccafondi S, Vocioni F, Salvati G, Gensini GF, and Neri Serneri GG Comparison of ambulatory blood pressure monitoring and conventional office measurement in the workers of a chemical company Int J Cardiol 1994 46(2):151 7 7814164
30 Myers MG, Oh PI, Reeves RA, and Joyner CD Prevalence of white coat effect in treated hypertensive patients in the community Am J Hypertens 1995b 8(6):591 7
31 Narkiewicz K, Piccolo D, Borella P, Businaro R, Zonzin P, and Palatini P Response to orthostatic stress predicts office-daytime blood pressure difference, but not nocturnal blood pressure fall in mild essential hypertensives: results of the harvest trial Clin Exp Pharmacol Physiol 1995 22(10):743 7 8575111
32 Staessen JA, Thijs L, Fagard R, O'Brien ET, Clement D, de Leeuw PW, Mancia G, Nachev C, Palatini P, Parati G, Tuomilehto J, and Webste, J Predicting cardiovascular risk using conventional vs ambulatory blood pressure in older patients with systolic hypertension. Systolic Hypertension in Europe Trial Investigators JAMA 1999 282(6):539 46 10450715
33 Thijs L, Celis H, Clement D, Gil-Extremera B, Kawecka-Jaszcz K, Mancia G, Parati G, Salvetti A, Sarti C, van den Meiracker AH, O'Brien E, Staessen JA, and Fagard R Conventional and ambulatory blood pressure measurement in older patients with isolated systolic hypertension:second progress report on the ambulatory blood pressure monitoring project in the Syst-Eur trial Blood Press Monit 1996 1(2):95 103 10226209
34 Zachariah PK, Sheps SG, Ilstrup DM, Long CR, Bailey KR, Wiltgen CM, and Carlson CA Blood pressure load--a better determinant of hypertension Mayo Clin Proc 1988 63(11):1085 91 3193818
35 Zachariah PK, Sheps SG, Bailey KR, Wiltgen CM, and Moore AG Age-related characteristics of ambulatory blood pressure load and mean blood pressure in normotensive subjects JAMA 1991 265(11):1414 7 1999882
36 Zawadzka A, Bird R, Casadei B, and Conway J Audit of ambulatory blood pressure monitoring in the diagnosis and management of hypertension in practice J Hum Hypertens 1998 12(4):249 52 9607694
37 Sega G, Bravi C, Cesana G, Valagussa F, Mancia G, and Zanchetti A Ambulatory and home blood pressure normality: the Pamela Study J Cardiovasc Pharmacol 1994 23Suppl 5:S12 5 7609500
38 Stergiou GS, Skeva II, Baibas NM, Kalkana CB, Roussias LG, and Mountokalakis TD Diagnosis of hypertension using home or ambulatory blood pressure monitoring: comparison with the conventional strategy based on repeated clinic blood pressure measurements J Hypertens 2000 18(12):1745 51 11132597
39 Manning G, Rushton L, and Millar-Craig MW Clinical implications of white coat hypertension: an ambulatory blood pressure monitoring study J Hum Hypertens 1999 13(12):817 22 10618670
40 MacDonald MB, Laing GP, Wilson MP, and Wilson TW Prevalence and predictors of white-coat response in patients with treated hypertension CMAJ 1999 161(3):265 9 10463047
41 Owens P, Atkins N, and O'Brien E Diagnosis of white coat hypertension by ambulatory blood pressure monitoring Hypertension 1999 34(2):267 72 10454452
42 Tochikubo O, Miyajima E, Shigemasa T, and Ishii M Relation between body fat-corrected ECG voltage and ambulatory blood pressure in patients with essential hypertension Hypertension 1999 33(5):1159 63 10334804
43 Martinez MA, Garcia-Puig J, Martin JC, Guallar-Castillon P, Aguirre de Carcer A, Torre A, Armada E, Nevado A, and Madero RS Frequency and determinants of white coat hypertension in mild to moderate hypertension: a primary care-based study. Monitorizacion Ambulatoria de la Presion Arterial (MAPA)-Area 5 Working Group Am J Hypertens 1999 12(3):251 9 10192226
44 Inden Y, Tsuda M, Hayashi H, Takezawa H, Iino S, Kondo T, Yoshida Y, Akahoshi, M, Terasawa M, Itoh, T Saito, H, and Hirai M Relationship between Joint National Committee-VI classification of hypertension and ambulatory blood pressure in patients with hypertension diagnosed by casual blood pressure Clin Cardiol 1998 21(11):801 6 9825191
45 Stergiou GS, Zourbaki AS, Skeva II, and Mountokalakis TD White coat effect detected using self-monitoring of blood pressure at home: comparison with ambulatory blood pressure Am J Hypertens 1998a 11(7):820 7
46 Myers MG and Reeves RA White coat effect in treated hypertensive patients: sex differences J Hum Hypertens 1995a 9(9):729 33
47 Verdecchia P, Schillaci G, Borgioni C, Ciucci A, Zampi I, Gattobigio R, Sacchi N, and Porcellati C White coat hypertension and white coat effect. Similarities and differences Am J Hypertens 1995 8(8):790 8 7576395
48 Pierdomenico SD, Mezzetti A, Lapenna D, Guglielmi MD, Mancini M, Salvatore L, Antidormi T, Costantini F, and Cuccurullo F 'White-coat' hypertension in patients with newly diagnosed hypertension: evaluation of prevalence by ambulatory monitoring and impact on cost of health care Eur Heart J 1995 16(5):692 7 7588903
49 Verdecchia P, Schillaci G, Boldrini F, Guerrieri, M, and Porcellati, C Sex, cardiac hypertrophy and diurnal blood pressure variations in essential hypertension J Hypertens 1992 10(7):683 92 1321197
50 Martinez MA, Moreno A, Aguirre de Carcer A, Cabrera R, Rocha R, Torre A, Nevado A, Ramos T, Neri J, Anton G, Miranda I, Fernande, P, Rodriguez E, Miquel A, Martinez JL, Rodriguez M, Eisman C, and Puig JG Frequency and determinants of microalbuminuria in mild hypertension: a primary-care-based study. MAPA--Madrid Working Group J Hypertens 2001 19(2):319 26 11212976
51 Helmers KF, Baker B, O'Kelly B, and Tobe S Anger expression, gender, and ambulatory blood pressure in mild, unmedicated adults with hypertension Ann Behav Med 2000 22(1):60 4 10892529
52 Aylett M, Marples G, and Jones K Home blood pressure monitoring: its effect on the management of hypertension in general practice Br J Gen Pract 1999 49(446):725 8 10756615
53 Hoegholm A, Kristensen KS, Bang LE, and Gustavsen PH White coat hypertension and blood pressure variability Am J Hypertens 1999 12(10 Pt 1):966 72 10560782
54 Verdecchia P, Schillaci G, Boldrini F, Zampi I, and Porcellati C Variability between current definitions of 'normal' ambulatory blood pressure. Implications in the assessment of white coat hypertension Hypertension 1992 20(4):555 62 1398890
55 Palatini P, Dorigatti F, Roman E, Giovinazzo P, Piccolo D, De Venuto G, Mattarei M, Cozzutti E, Gregori S, Mormino P, and Pessina AC White-coat hypertension: a selection bias? Harvest Study Investigators. Hypertension and Ambulatory Recording Venetia Study J Hypertens 1998 16(7):977 84 9794738
56 Verdecchia P, Schillaci G, Borgioni C, Ciucci A, Gattobigio R, Sacchi N, Guerrieri M, Comparato E, and Porcellati C Identification of subjects with white-coat hypertension and persistently normal ambulatory blood pressure Blood Press Monit 1996 1(3):217 22 10226230
57 Gosse P, Bougaleb M, and Clementy J Long term reproducibility of ambulatory blood pressure monitoring Therapie 1996 51(1):5 9 8762214
58 Sahn DJ, DeMaria A, Kisslo J, and Weyman A Recommendations regarding quantitation in M-mode echocardiography: results of a survey of echocardiographic measurements Circulation 1978 Dec 58(6):1072 83
59 Devereux RB, Alonso DR, Lutas EM, Gottlieb GJ, Campo E, Sachs I, and Reichek N Echocardiographic assessment of left ventricular hypertrophy: comparison to necropsy findings Am J Cardiol 1986 Feb 15 57(6):450 8
60 Ohkubo T, Imai Y, Tsuji I, Nagai K, Kato J, Kikuch, N, Nishiyama A, Aihara A, Sekino M, Kikuya M, Ito S, Satoh H, and Hisamichi S Home blood pressure measurement has a stronger predictive power for mortality than does screening blood pressure measurement: a population-based observation in Ohasama, Japan J Hypertens 1998 16(7):971 5 9794737
61 Sakuma M, Imai Y, Tsuji I, Naga K, Ohkubo T, Watanabe N, Sakum, H, Satoh H, and Hisamichi S Predictive value of home blood pressure measurement in relation to stroke morbidity: a population-based pilot study in Ohasama, Japan Hypertens Res 1997 20(3):167 74 9328797
62 Bailey B, Carney SL, Gillies AA, and Smith AJ Antihypertensive drug treatment: a comparison of usual care with self blood pressure measurement J Hum Hypertens 1999 13(2):147 50 10100064
63 Binstock ML and Franklin KL A comparison of compliance techniques on the control of high blood pressure Am J Hypertens 1988 1(3 Pt 3):192S 194S 3415798
64 Carnahan JE and Nugent CA The effects of self-monitoring by patients on the control of hypertension Am J Med Sci 1975 269(1):69 73 1130437
65 Earp JA, Ory MG, and Strogatz DS The effects of family involvement and practitioner home visits on the control of hypertension Am J Public Health 1982 72(10):1146 54 7114339
66 Friedman RH, Kazis LE, Jette A, Smith MB, Stollerman J, Torgerson J, and Carey K A telecommunications system for monitoring and counseling patients with hypertension. Impact on medication adherence and blood pressure control Am J Hypertens 1996 9(4 Pt 1):285 92 8722429
67 Johnson AL, Taylor DW, Sackett DL, Dunnett CW, and Shimizu AG Self-recording of blood pressure in the management of hypertension Can Med Assoc J 1978 119(9):1034 9 369673
68 Lehner, H, Kaluza K, Vetter H, Losse H, and Dorst K Long-term effects of a complex behavioral treatment of essential hypertension Psychosom Med 1987 49(4):422 30 3615770
69 Midanik LT, Resnick B, Hurley LB, Smith EJ, and McCarthy M Home blood pressure monitoring for mild hypertensives Public Health Rep 1991 106(1):85 9 1899945
70 Rogers MA, Small D, Buchan DA, Butch CA, Stewart CM, Krenzer BE, and Husovsky HL Home monitoring service improves mean arterial pressure in patients with essential hypertension. A randomized, controlled trial Ann Intern Med 2001 134(11):1024 32 11388815
71 Soghikian K, Casper SM, Fireman BH, Hunkeler EM, Hurley LB, Tekawa IS, and Vog TM Home blood pressure monitoring. Effect on use of medical services and medical care costs Med Care 1992 30(9):855 65 1518317
72 Stahl SM, Kelley CR, Neill PJ, Grim CE, and Mamlin J Effects of home blood pressure measurement on long-term BP control Am J Public Health 1984 74(7):704 9 6742256
73 Vetter W, Hess, L, and Brignoli R Influence of self-measurement of blood pressure on the responder rate in hypertensive patients treated with losartan: results of the SVATCH Study. Standard vs Automatic Treatment Control of COSAAR in Hypertension J Hum Hypertens 2000 14(4):235 41 10805048
74 Cuspidi C, Lonati L, Sampieri L, Macca G, Michev I, Salerno M, Fusi V, Leonetti G, and Zanchetti A Impact of blood pressure control on prevalence of left ventricular hypertrophy in treated hypertensive patients Cardiology 2000 93(3):149 54 10965085
75 Zakopoulos NA, Toumanidis ST, Barlas GJ, Nanas SN, Lekakis JP, Stamatelopoulos SF, and Moulopoulos SD A pressure-time index' for assessing the severity of essential hypertension J Hypertens 1999 17(10):1387 93 10526898
76 Bauduceau B, Genes N, Chamontin B, Vaur L, Renault M, Etienne S, and Marre M Ambulatory blood pressure and urinary albumin excretion in diabetic (non-insulin-dependent and insulin-dependent) hypertensive patients: relationships at baseline and after treatment by the angiotensin converting enzyme inhibitor trandolapril Am J Hypertens 1998 11(9):1065 73 9752891
77 Palatini P, Mormino P, Santonastaso M, Mos L, Dal Foll M, Zanata G, and Pessina AC Target-organ damage in stage I hypertensive subjects with white coat and sustained hypertension: results from the HARVEST study Hypertension 1998 31(1):57 63 9449391
78 Ferrara LA, Guida L, Pasanisi F, Celentano A, Palmieri V, Iannuzzi R, Gaeta I, Leccia G, and Crivaro M Isolated office hypertension and end-organ damage J Hypertens 1997 15(9):979 85 9321745
79 Gosse, P, Ansoborlo P, Lemetayer P, and Clementy J Left ventricular mass is better correlated with arising blood pressure than with office or occasional blood pressure Am J Hypertens 1997 10(5 Pt 1):505 10 9160760
80 Pose-Reino A, Gonzalez-Juanatey JR, Pastor C, Mendez I, Estevez JC, Alvarez D, Valdes L, and Cabezas-Cerrato J Clinical implications of white coat hypertension Blood Press 1996 5(5):264 73 8879598
81 Redon, J Baldo E, Lurbe E, Bertolin V, Lozano JV, Miralles A, and Pascual JM. Microalbuminuria, left ventricular mass and ambulatory blood pressure in essential hypertension. Kidney Int Suppl. 1996;55:S81-4. [pmid: 8743518].
82 Pierdomenico SD, Lapenna D, Guglielmi MD, Antidormi T, Schiavone C, Cuccurullo F, and Mezzetti A Target organ status and serum lipids in patients with white coat hypertension Hypertension 1995 26(5):801 7 7591021
83 Lemne C, Lindvall K, Georgiades A, Fredrikson M, and de Faire U Structural cardiac changes in relation to 24-h ambulatory blood pressure levels in borderline hypertension J Intern Med 1995 238(1):49 57 7608646
84 Chen CH, Ting CT, Lin SJ, Hsu TL, Chou P, Kuo HS, Wang SP, Yin FC, and Chang MS Relation between diurnal variation of blood pressure and left ventricular mass in a Chinese population Am J Cardiol 1995 75(17):1239 43 7778547
85 Weber MA, Neutel JM, Smith DH, and Graettinger WF Diagnosis of mild hypertension by ambulatory blood pressure monitoring Circulation 1994 90(5):2291 8 7955186
86 Redon J, Liao Y, Lozano JV, Miralles A, Pascual JM, and Cooper RS Ambulatory blood pressure and microalbuminuria in essential hypertension: role of circadian variability J Hypertens 1994 12(8):947 53 7814854
87 Gosse P, Promax H, Durande, P, and Clementy J 'White coat' hypertension. No harm for the heart Hypertension 1993 22(5):766 70 8225536
88 Hansen KW, Christensen CK, Andersen PH, Pedersen MM, Christiansen JS, and Mogensen CE Ambulatory blood pressure in microalbuminuric type 1 diabetic patients Kidney Int 1992 41(4):847 54 1513107
89 Verdecchia P, Schillaci G, Guerrieri M, Gatteschi C, Benemio G, Boldrini F, and Porcellati C Circadian blood pressure changes and left ventricular hypertrophy in essential hypertension Circulation 1990 81(2):528 36 2137047
90 Baguet JP, De Gaudemaris R, Antoniadis A, Tremel F, Siche JP, and Mallion JM Use of ambulatory blood pressure monitoring data to predict left ventricular mass in hypertension Blood Press Monit 2001 6(2):73 80 11433127
91 Devereux RB, Pickering TG, Harshfield GA, Kleinert HD, Denby L, Clark L, Pregibon D, Jason M, Kleiner B, Borer JS, and Laragh JH Left ventricular hypertrophy in patients with hypertension: importance of blood pressure response to regularly recurring stress Circulation 1983 68(3):470 6 6223721
92 Hoegholm A, Bang LE, Kristensen KS, Nielsen JW, and Holm J Microalbuminuria in 411 untreated individuals with established hypertension, white coat hypertension, and normotension Hypertension 1994 24(1):101 5 8020997
93 Schulte KL, Liederwald K, Meyer-Sabellek W, van Gemmeren D, Lenz T, and Gotzen R Relationships between ambulatory blood pressure, forearm vascular resistance, and left ventricular mass in hypertensive and normotensive subjects Am J Hypertens 1993 6(9):786 93 8110433
94 Amar J, Vernier I, Rossignol E, Bongard V, Arnaud C, Conte JJ, Salvador M, and Chamontin B Nocturnal blood pressure and 24-hour pulse pressure are potent indicators of mortality in hemodialysis patients Kidney Int 2000 57(6):2485 91 10844617
95 Fagard RH, Staessen JA, Thijs L, Gasowsk J, Bulpitt CJ, Clement D, de Leeuw PW, Dobovisek J, Jaaskivi M, Leonetti G, O'Brien E, Palatini P, Parati G, Rodicio JL, Vanhanen H, and Webster J Response to antihypertensive therapy in older patients with sustained and nonsustained systolic hypertension. Systolic Hypertension in Europe (Syst-Eur) Trial Investigators Circulation 2000 102(10):1139 44 10973843
96 Gosse P, Gasparoux P, Ansoborlo P, Lemetayer P, and Clementy J Prognostic value of ambulatory measurement of the timing of Korotkoff sounds in elderly hypertensives: a pilot study Am J Hypertens 1997 10(5 Pt 1):552 7 9160767
97 Nakano S, Ogihara M, Tamura C, Kitazawa M, Nishizawa M, Kigoshi T, and Uchida K Reversed circadian blood pressure rhythm independently predicts endstage renal failure in non-insulin-dependent diabetes mellitus subjects J Diabetes Complications 1999 13(4):224 31 10616863
98 Ohkubo T, Imai Y, Tsuji I, Nagai K, Watanabe N, Minami N, Kato J, Kikuchi N, Nishiyama A, Aihara A, Sekino M, Satoh H, and Hisamichi S Relation between nocturnal decline in blood pressure and mortality. The Ohasama Study Am J Hypertens 1997a 10(11):1201 7
99 Ohkubo T, Imai Y, Tsuji I, Nagai K, Watanabe N, Minami N, Itoh O, Bando T, Sakuma M, Fukao A, Satoh H, Hisamichi S, and Abe K Prediction of mortality by ambulatory blood pressure monitoring versus screening blood pressure measurements: a pilot study in Ohasama J Hypertens 1997b 15(4):357 64
100 Ohkubo T, Hozawa A, Nagai K, Kikuya M, Tsuji I, Ito S, Satoh H, Hisamichi S, and Imai Y Prediction of stroke by ambulatory blood pressure monitoring versus screening blood pressure measurements in a general population: the Ohasama study J Hypertens 2000 18(7):847 54 10930181
101 Perloff D, Sokolow M, Cowan RM, and Juste RP Prognostic value of ambulatory blood pressure measurements: further analyses J Hypertens Suppl 1989 7(3):S3 10
102 Redon J, Campos C, Narciso ML, Rodicio JL, Pascual JM, and Ruilope LM Prognostic value of ambulatory blood pressure monitoring in refractory hypertension: a prospective study Hypertension 1998 31(2):712 8 9461245
103 Suzuki Y, Kuwajima I, Aono T, Kanemaru A, Nishinaga M, Shibata H, and Ozawa T Prognostic value of nighttime blood pressure in the elderly: a prospective study of 24-hour blood pressure Hypertens Res 2000 23(4):323 30 10912768
104 Verdecchia P, Porcellati C, Schillaci G, Borgioni C, Ciucci A, Battistelli M, Guerrieri M, Gatteschi C, Zampi I, Santucci A and others Ambulatory blood pressure. An independent predictor of prognosis in essential hypertension Hypertension 1994 24(6):793 801 7995639
105 Verdecchia P, Schillaci G, Borgioni C, Ciucci A, Pede S, and Porcellati C Ambulatory pulse pressure: a potent predictor of total cardiovascular risk in hypertension Hypertension 1998 32(6):983 8 9856961
106 Zweiker R, Eber B, Schumache, M, Toplak H, and Klein W "Non-dipping" related to cardiovascular events in essential hypertensive patients Acta Med Austriaca 1994 21(3):86 9 7701925
107 Staessen JA, Byttebier G, Buntinx F, Celis H, O'Brien ET, and Fagard R Antihypertensive treatment based on conventional or ambulatory blood pressure measurement. A randomized controlled trial. Ambulatory Blood Pressure Monitoring and Treatment of Hypertension Investigators JAMA 1997 278(13):1065 72 9315764
108 Schrader J, Luders S, Zuchner C, Herbold M, and Schrandt G Practice vs ambulatory blood pressure measurement under treatment with ramipril (PLUR Study): a randomised, prospective long-term study to evaluate the benefits of ABPM in patients on antihypertensive treatment J Hum Hypertens 2000 14(7):435 40 10918548