# Acronyms

ABP | ambulatory blood pressure
AAMI | Association for the Advancement for Medical Instrumentation
BMI | body mass index
BP | blood pressure
BHS | British Hypertension Society
HTN | hypertension
LV | left ventricular
NHBPEP | National High Blood Pressured Education Program
NT | normotension
RR | relative risk
SH | sustained hypertension
SMBP | self-measured blood pressure
WCH | white coat hypertension