# Appendix F Reproducibility of White-Coat Hypertension

Utility of Blood Pressure Monitoring Outside the Clinic Setting Reproducibility of White-Coat Hypertension

Article ID#: | __________________
Reviewer 1: | __________________
Reviewer 2: | __________________

Article Eligibility

Article is not eligible for review because (check one):

O does not include human data

O not in English

O no original data

O meeting abstract (no full article for review)

O article does not apply to any of the research questions

O article does not include ambulatory or self-measured blood pressure

O article addresses reproducibility and has < 20 patients

O device evaluation was the primary purpose of the study

O study population is exclusively pregnant women

O study population is exclusively children (<20 years of age)

O article addresses research question, but does not present data in an abstractable format.

O article addresses only the prevalence of dipping versus non-dipping and no other research questions

O article does not include reproducibility of white-coat hypertension If yes, does article only address reproducibility of the difference between clinic, ABPM and/or self BP measurements

O | Yes
O | No

O other.specify:________________

If any item above checked -- STOP. If article is eligible- complete pages 2-3

1. What technique was used to assess agreement between baseline and repeat blood pressure measurements? O kappa statistic O t-test O pearson correlation coefficient O other:_______________ *If other, STOP- do not complete the rest of this form
2. Complete the following table for reproducibility of WCH defined by clinic and ABPM and/or self BP:
  | Correlation Coefficient Baseline and Repeat WCH (ABPM) | Correlation Coefficient Baseline and Repeat WCH (Self BP) | Kappa Statistic Baseline and Repeat WCH (ABPM) | Kappa Statistic Baseline and Repeat WCH (Self BP) | t-test Baseline and Repeat WCH (ABPM) | t-test Baseline and Repeat WCH (Self BP)
  Estimate:
  SE:
  95% CI: | to | to | to | to | to | to
  P value: | __________ | __________ | __________ | __________ | __________ | __________
  | O > 0.05 O < 0.05 O < 0.01 O < 0.001 | O > 0.05 O < 0.05 O < 0.01 O < 0.001 | O > 0.05 O < 0.05 O < 0.01 O < 0.001 | O > 0.05 O < 0.05 O < 0.01 O < 0.001 | O > 0.05 O < 0.05 O < 0.01 O < 0.001 | O > 0.05 O < 0.05 O < 0.01 O < 0.001
3. Was there any evidence of inconsistencies in the blood pressure protocol between baseline and repeat BP measurements? [image] different measurement technique [image] different number of measurements [image] different setting/location [image] different observer [image] different blood pressure device [image] different time of day [image] other difference: _____________ O No observed differences
4. What was the percentage of white-coat hypertensives defined by clinic and ABPM at baseline and follow-up? (% WCH is defined as percentage of all hypertensives identified as having WCH)
  WCH at Baseline | N _____ % _____
  WCH at Follow-up | N _____ % _____
  WCH at Both | N _____ % _____ | O Can't tell or not stated
5. What was the percentage of white-coat hypertensives defined by clinic and self BP at baseline and follow-up? (% WCH is defined as percentage of all hypertensives identified as having WCH)
  WCH at Baseline | N _____ % _____
  WCH at Follow-up | N _____ % _____
  WCH at Both | N _____ % _____ | O Can't tell or not stated
6. What was the mean time interval between baseline BP and the last follow-up BP? (if multiple follow-up measurements are provided-use only the first and last set of measurements)
  __________ | O days
  | O weeks
  | O months
  | O years

Comments:

Data Collection Items - Spread Sheet for Longitudinal Studies (questions #2b and #3b)

Author
Year of Publication
Group
Whole/Subgroup
Total Sample Size
Study Description:
Duration of follow up (Years):
Mean
SD
Outcome:
Description
Number of Events
Clinic Blood Pressure as Predictor
Systolic Blood Pressure Contrast Label Number P Value 95% CI
Diastolic Blood Pressure Contrast Label Number P Value 95% CI
Self-measured Blood Pressure as Predictor
Systolic Blood Pressure Contrast Label Number P Value 95% CI
Diastolic Blood Pressure Contrast Label Number P Value 95% CI
Daytime Ambulatory Blood Pressure Measurement as Predictor
Systolic Blood Pressure Contrast Label Number P Value 95% CI
Diastolic Blood Pressure Contrast Label Number P Value 95% CI
Nighttime Ambulatory Blood Pressure Measurement as Predictor
Systolic Blood Pressure Contrast Label Number P Value 95% CI
Diastolic Blood Pressure Contrast Label Number P Value 95% CI
24 Hour Ambulatory Blood Pressure Measurement as Predictor
Systolic Blood Pressure Contrast Label Number P Value 95% CI
Diastolic Blood Pressure Contrast Label Number P Value 95% CI
Pattern as Predictor:
White Coat Hypertension Contrast Label Number P Value 95% CI
Non Dippers Contrast Label Number P Value 95% CI
Incremental Gain Beyond Clinic
Ambulatory Tested Gain
Self-measured Blood Pressure Tested Gain
Adjustments
Data Adjusted For Age Gender Smoking Cholesterol Others
Comments

Data Collection Items - Spread Sheet for Clinical Trials (questions #2d and #3d)

First Author Year of Publication Total Sample Size
Study Objectives Objective
Follow Up (Months) Mean SD
The following items were abstracted for each randomized group: Group name N Description
Age (Years) Mean SD
Patient Demographic Characteristics % Male % African American % White % Other Race % Diabetics % On BP Medication % On Dialysis % History of Cardiovascular Disease % Current Smokers
BP Measurement and Management by Group Type of BP Device Frequency of Measurement Medication Titration SBP Goal DBP Goal Other Co-interventions Number of Clinic BP Visits at the End of Follow-up
Office Systolic BP by Group (mmHg) Baseline BP Mean SD Follow-up Mean SD Difference from Baseline Mean SD Between Group Difference (comparison with control group) Mean SD P Value
Offfice Diastolic Blood Pressure (mmHg) Baseline BP Mean SD Follow-up Mean SD Difference from Baseline Mean SD Between Group Difference (comparison with control group) Mean SD P Value
Self-Measured Systolic Blood Pressure (mmHg) Baseline BP Mean SD Follow-up Mean SD Difference from Baseline Mean SD Between Group Difference (comparison with control group) Mean SD P Value
Self-Measured Diastolic Blood Pressure (mmHg) Baseline BP Mean SD Follow-up Mean SD Difference from Baseline Mean SD Between Group Difference (comparison with control group) Mean SD P Value
Daytime Ambulatory Systolic Blood Pressure (mmHg) Baseline BP Mean SD Follow-up Mean SD Difference from Baseline Mean SD Between Group Difference (comparison with control group) Mean SD P Value
Daytime Ambulatroy Diastolic Blood Pressure (mmHg) Baseline BP Mean SD Follow-up Mean SD Difference from Baseline Mean SD Between Group Difference (comparison with control group) Mean SD P Value
Night time Ambulatory Systolic Blood Pressure (mmHg) Baseline BP Mean SD Follow-up Mean SD Difference from Baseline Mean SD Between Group Difference (comparison with control group) Mean SD P Value
Night time Ambulatory Diastolic Blood Pressure (mmHg) Baseline BP Mean SD Follow-up Mean SD Difference from Baseline Mean SD Between Group Difference (comparison with control group) Mean SD P Value
24 hour Ambulatory Systolic Blood Pressure (mmHg) Baseline BP Mean SD Follow-up Mean SD Difference from Baseline Mean SD Between Group Difference (comparison with control group) Mean SD P Value
24 hour Ambulatory Diastolic Blood Pressure (mmHg) Baseline BP Mean SD Follow-up Mean SD Difference from Baseline Mean SD Between Group Difference (comparison with control group) Mean SD P Value
BP Control (% at Goal): Definition of BP Control: Baseline (%) Follow-up (%) Improvement (%) P Value
Compliance Definition Baseline (%) Follow-up (%) Improvement (%) P Value
Medication Use (% on Number of Medication) Baseline (%) Follow-up (%) Improvement (%) P Value
Medication Use (Number of Anti-Hypertensive Medications) Baseline Follow-up Improvement P Value
Other Outcomes
Comments