# Appendix E Quality Assesment Form

Utility of Blood Pressure Monitoring Outside the Clinic Setting Quality Assessment Form

Article ID#: | _______________________________
Reviewer 1: | _______________________________
Reviewer 2: | _______________________________

ArticleEligibility

Article is not eligible for review because (check one):

O | | does not include human data
O | | not in English
O | | no original data
O | | meeting abstract (no full article for review)
O | | article does not apply to any of the research questions
O | | article does not include ambulatory or self-measured blood pressure
O | | has <#50 patients OR addresses reproducibility and has < 20 patients
O | | device evaluation was the primary purpose of the study
O | | study population is exclusively pregnant women
O | | study population is exclusively children (<20 years of age)
O | | article addresses research question, but does not present data in an abstractable format. [check appropriate boxes on pages 2-3, then STOP]
O | | article addresses only the prevalence of dipping versus non-dipping and no other research questions
O | | article describes cross-sectional/retrospective study, addresses only question #2 or #3, and does not include comparison with clinic measurement
O | | article describes cross-sectional study, addresses only question #2 or #3, but outcome is not LV mass (by echocardiography) or proteinuria/albuminuria
O | | article only addresses question #1, provides data for clinic BP AND ABPM, or clinic BP AND self-BP but does not include a formal within-person comparison of measurements (e.g. no p-value, SE, SD, CI)
O | | other. specify: _____________________

If any item above checked -- STOP.

Focus of Article

Instructions: Identify the focus of the article by checking the appropriate box(es) below. For each box that is checked, refer to the corresponding column(s) to identify the additional sections in Part II of the Article Review Form that need to be completed.

1 Article provides information to address following question(s): [check all that apply]
  | | | Sections To Complete in Part II
  #1Comparison of readings
  | [image] reproducibility of differences and/or patterns (#1 a,b,c)
  | [image] distribution of readings between clinic and self-measured blood pressure (#1a) | | 1,2
  | [image] distribution of readings between clinic and ambulatory blood pressure measurements (#1a) | | 1,2
  | [image] distribution of readings between self-measured and ambulatory blood pressure measurements (#1a) | | 1,2
  | [image] prevalence of white-coat hypertension defined by self-measurement devices (#1b) | | 1
  | [image] prevalence of white-coat hypertension defined by ambulatory measurement devices (#1c) | | 1
  #2 Self-measured blood pressure and clinical events
  | Self-measured blood pressure associated with LV mass (#2a)
  | | [image] mean BP levels (#2a) | 1,3
  | | [image] white-coat hypertension (#2a) | 1,3
  | | [image] incremental gain (#2c)
  | Self-measured blood pressure associated with proteinuria/albuminuria (#2a)
  | | [image] mean BP levels (#2a) | 1,4
  | | [image] white-coat hypertension (#2a) | 1,4
  | | [image] incremental gain (#2c)
  | [image] Prediction of clinical outcomes [longitudinal study] (#2b)
  | [image] Effect of treatment guided by self-measured blood pressure (#2d)
  #3 Ambulatory blood pressure and clinical events
  | Ambulatory blood pressure associated with LV mass (#3a)
  | | [image] mean BP levels (#3a) | 1,3
  | | [image] white-coat hypertension (#3a) | 1,3
  | | [image] dippers (TBD)
  | | [image] incremental gain (#3c)
  | Ambulatory blood pressure associated with proteinuria/albuminuria (#3a)
  | | [image] mean BP levels (#3a) | 1,4
  | | [image] white-coat hypertension (#3a) | 1,4
  | | [image] dippers (TBD)
  | | [image] incremental gain (#3c)
  | [image] Prediction of clinical outcomes [longitudinal study] (#3b)
  | [image] Effect of treatment guided by ambulatory blood pressure (#3d)
  #4 Does evidence for any of the above questions vary by subgroups
  | [image] comparison of readings (#1)
  | [image] self-measured and clinical events (#2)
  | [image] ambulatory and clinical events (#3)
  | Study addresses the following population(s) of interest:
  | | [image] age | Part II
  | | [image] sex | Part II
  | | [image] race | Part II
  | | [image] diabetes | Part II
  | | [image] dialysis | Part II
  | | [image] renal transplant patients | Part II
  | | [image] hypertensives | Part II
  | | [image] normotensives | Part II
  | | [image] white-coat hypertensives
  | | [image] sustained hypertensives
  | | [image] excess variability | Part II
  | | [image] anti-hypertensive medications | Part II
  | | [image] chronic renal insufficiency | Part II
  | | [image] proteinuria/albuminuria | Part II
  | | [image] active or prior cardiac or cerebrovascular disease | Part II
  | | [image] current smoking | Part II
  | | [image] obese individuals | Part II
  | | [image] drug resistant hypertension | Part II
  | | [image] autonomic dysfunction | Part II
  | | [image] other: ____________________
  | | [image] other: ____________________
  | | [image] other: ____________________

If not directed to a section in Part II- STOP If directed to a section(s) in Part II- complete page 4 and 5 of this form, then complete Part I followed by Part II

Quality Assessment Questions:

1 Type of study: O single center O multi center O can't tell
2 Source(s) of funding: [image] device manufacturer [image] other industry [image] government [image] organization other than government or industry O can't tell or not stated
3 Were the inclusion and exclusion criteria adequately reported? O yes, sufficient to replicate study design O no
4 Were recruitment procedures adequately described? O yes, sufficient to replicate study design O no
5 Does the study provide basic characteristics of participants (age, gender, % on HTN medication)? O yes, all 3 items reported O no, one or more items missing O not applicable
6 Were the individuals who collected office/clinic BP masked (blinded) to other relevant data (e.g. ambulatory measurements, self-measurements or clinical outcomes)? O yes, explicitly stated OR clinic BP measurements completed prior to other measurements (masking accomplished by study design) O no, or not reported
7 For studies with LV mass or clinical outcomes, were the assessors of these outcomes masked (blinded) to blood pressure data? (eg echo technicians) O yes, explicitly stated or implicit in design O no, or not reported O not applicable
8 For prospective studies, how complete were the follow-up data? O > 80% of data on enrolled participants O < 80% of data on enrolled participants O can't tell or not stated O not applicable
9 For the primary analyses, were both the magnitude of differences or association AND an index of variability (e.g. test statistic, p value, standard error, confidence interval) stated? O yes, both reported O no, one or both not reported
10 For observational studies, were the adjustment procedures appropriate? O yes O no O not applicable
11 Was the analytic approach appropriate? O yes O no

Comments:

Utility of Blood Pressure Monitoring Outside the Clinic Setting PART I

Article ID#: | _____________________
Reviewer 1: | _____________________
Reviewer 2: | _____________________

General Study Characteristics

1 The analysis of interest was of the following design: O randomized controlled trial O non-randomized controlled trial O cohort study O case-control O cross-sectional O before-after O case series O can't tell or not stated
2 Study was completed in: O United States O Canada O United Kingdom O Can't tell or not stated O Other. Specify: ______________________
3 Setting. Study population was drawn from (check all that apply): [image] general clinic [image] specialty hypertension clinic [image] other specialty clinic [image] general population [image] other research study unspecified [image] other. specify: ______________________ O can't tell or not stated

Clinic Blood Pressure Measurement

4 Who was the observer for blood pressure measurements? [image] medical technician [image] nurse [image] physician assistant [image] physician [image] student [image] can't tell or not stated [image] other. specify: ______________________ Note: If data are provided separately for multiple observers, use data for the observer closest to the top of above list (eg use nurse data if both nurse and physician data are provided).
5 Did the results of the study differ according to type of observer? O yes O no O not applicable
6 Was the observer trained? O yes O no O can't tell or not stated
7 What type of blood pressure measurement device was used? O mercury O mercury random zero O aneroid O automated O multiple devices, GO TO Question 9, page 4 O can't tell or not stated
8 If automated, indicate the device number from list of validated devices: __________
  1. | CAS Model 9010
  2. | Datascope Accurtorr Plus
  if device is not on list, provide following information: name and model: _____________________________________________ O can't tell or not stated O not applicable
9 If manual, indicate Korotkoff sound used for diastolic blood pressure: O K4 O K5 O can't tell or not stated O not applicable
10 Did the study use or adapt a standard technique, such as that provided by a professional society (e.g., AHA) or a major study (e.g., HDFP) O yes O no. If no, did the study specify that they utilized: [image] appropriate cuff size [image] wait of at least 2 minutes before obtaining measurements O can't tell or not stated O can't tell or not stated
11 What was the position of the participant? O supine O standing O sitting O combination O can't tell or not stated
12 What was the planned number of clinic BP measurements? __________ measurements per day for ___________ days O other: ____________ O can't tell or not stated
13 Actual number of days blood pressure measured (complete all available): mean: _____________________________ median: _____________________________ range: ___________ to ______________ O can't tell or not stated
14 Actual number of blood pressure readings per day (complete all available): mean: _____________________________ median: _____________________________ range ____________ to _____________ O can't tell or not stated
15 Actual total number of blood pressure readings (complete all available): [if total is not provided, calculate when possible: total= number of days measured times number of readings per day] mean: _____________________________ median: _____________________________ range ____________ to _____________ O calculated by reviewer O can't tell or not stated

Comments-Clinic BP:

Selft Blood Pressure Measurement

16 Was self blood pressure measured? O yes O no, STOP and GO TO Question 29, page 9
17 The blood pressure measurements were taken by: [image] patient [image] someone else O can't tell or not stated
18 Was the observer trained? O yes O no O can't tell or not stated
19 What type of blood pressure measurement device was used? O mercury O aneroid O electronic or automated O can't tell or not stated
20 If automated, indicate the device number from list of validated devices: ____________
  1 2 3 4 5 | Omron HEM-705CP Omron HEM-722C Omron HEM-735C Omron HEM-713C Omron HEM-737 Intellisense
  if device is not on list, provide following information: name and model: ______________________________________ O can't tell or not stated O not applicable
21 If auscultatory, indicate Korotkoff sound used for diastolic blood pressure: O K4 O K5 O can't tell or not stated O not applicable
22 How were the measurements recorded? O patient/observer recorded O stored electronically O can't tell or not stated
23 What were the times of recordings? [image] morning (before noon) [image] afternoon (noon to 6:00pm) [image] evening (after 6:00pm) O can't tell or not stated
24 Where were the measurements recorded? [image] work [image] home O can't tell or not stated
25 What was the planned number of self-BP measurements? __________ measurements per day for ___________ days O other: ____________ O can't tell or not stated
26 Actual number of days blood pressure measured (complete all available): mean: _____________________________ median: _____________________________ range _____________________________ O can't tell or not stated
27 O Actual number of blood pressure readings per day (complete all available): mean: _____________________________ median: _____________________________ range _____________________________ O can't tell or not stated
28 Actual total number of blood pressure readings (complete all available) [if total is not provided, calculate when possible: total= number of days measured times number of readings per day]: mean: _____________________________ median: _____________________________ range _____________________________ O calculated by reviewer O can't tell or not stated

Comments-Home BP:

Ambulatory Blood Pressure Measurement

29 Was ambulatory blood pressure measured? O yes O no, STOP and GO TO question 43, page 12
30 Was the patient given instructions? O yes (eg keep arm still and/or stop movement during measurements) O no O can't tell or not stated
31 What type of blood pressure measurement device was used? O auscultatory O oscillometric O both (if both, use auscultatory to answer all subsequent questions) O can't tell or not stated
32 O Indicate the device number from list of devices: ____________________
  1 | CH-DRUCK | 9 | Schiller BR-102 | 17 | Accutracker II
  2 | Daypress 500 | 10 | SpaceLabs 90202 | 18 | DIASYS 200
  3 | DIASYS Integra | 11 | SpaceLabs 90207 | 19 | Medilog ABP
  4 | ES-H531 | 12 | SpaceLabs 90217 | 20 | Nissei DS-240
  5 | Meditech ABPM-04 | 13 | Takeda 2430 | 21 | OSCILL-IT
  6 | Profilomat | 14 | TM-2420, model 7 | 22 | Profilomat II
  7 | QuietTrak | 15 | TM-2420,model 6 | 23 | Takeda 2421
  8 | Save 33, model 2 | 16 | TM-2421 | 24 | TM-2420, model 5
  If device is not on list, provide following information: name and model: ______________________________________ O can't tell or not stated
33 Were the presented measurements edited? O yes O no O can't tell or not stated
34 How were measurements edited? [image] device [image] during analysis O can't tell or not stated
35 Where were the measurements taken? [image] Work (work day) [image] Home (non-work day) O can't tell or not stated
36 Duration of measurement? O awake or day time only O 24 hour recording period O >24 hours (or more than 1 recording period) O can't tell or not stated
37 How did the study define daytime/awake and nighttime/asleep? Awake or daytime: Indicate period of measurement: O awake hours as reported by patient O daytime defined by:
  start time: | __________________________________
  O am O pm
  end time: | __________________________________
  O am O pm
  O can't tell or not stated Asleep or nighttime Indicate period of measurement: O asleep hours as reported by patient O nighttime defined by:
  start time: | __________________________________
  O am O pm
  end time: | __________________________________
  O am O pm
  O can't tell or not stated
38 What was the time interval on the monitor between measurements during daytime/awake hours? O 1 reading every __________ minutes O not applicable O can't tell or not stated
39 What was time interval on the monitor between measurements during nighttime/sleep hours? O 1 reading every __________ minutes O not applicable O can't tell or not stated
40 Actual number of daytime blood pressure readings per 24-hour period (complete all available): mean:________________________________ median:________________________________ range:________________________________ O not applicable O can't tell or not stated
41 Actual number of nighttime blood pressure readings per 24-hour period (complete all available): mean:________________________________ median:________________________________ range:________________________________ O not applicable O can't tell or not stated
42 Total number of blood pressure readings per 24-hour period (including day and night, complete all available): mean:________________________________ median:________________________________ range:________________________________ O calculated by reviewer O can't tell or not stated

Comments-Ambulatory BP:

Definitions of hypertension

43 How was hypertension defined?
  O Definition of hypertension not applicable for this study [image] Cut-off values for HT -- Clinic BP SBP: > ____________(mmHg) DBP: > ____________(mmHg) [image] Cut-off values for HT -- Self-BP SBP: >____________(mmHg) DBP: >____________(mmHg) [image] Cut-off values for HT -- ABPM SBP: >____________(mmHg) O Based on Daytime BP O Based on 24-Hour BP DBP: >____________(mmHg) O Based on Daytime BP O Based on 24-Hour BP
44 How was white coat-hypertension defined? O not applicable for this study O cross-tabulation of clinic BP and self-BP O cross-tabulation of clinic BP and ABPM O other method:__________________________ O applicable for this study, but definition not stated

Echocardiographic Assessment of LV mass

45 What type of echocardiograph was used to assess LV mass? O not applicable for this study- STOP and go to Question 51 O M-mode (with or without Doppler) O Other - Specify: ______________ O Unknown
46 Number of cycles averaged to assess LV mass: ______________ O Unknown
47 Use of Penn convention for measurement: O yes O no O unknown
48 Method used to estimate LV mass: O Devereaux O Other - Specify: _______________ O Unknown
49 Units for LV mass index: O LV mass by surface area (g/m^2^) O LV mass by height (g/m) O LV mass by height^2^ (g/m^2^) O LV mass by height^2.7^ (g/m^2.7^) O LV mass (g) O Other - Specify: __________________ O Unknown
50 Cut-off value for LV hypertrophy: O males: _________________ O females: ______________________ O unknown O not applicable

Assessment of Urine Protein/Albumin

51 Measures of protein excretion? O not applicable for this study O mg of protein/ 24 hours O mg of protein/ mg creatinine O not measured
52 Measures of albuminuria? O not applicable for this study O mg of albumin/ 24 hours O mg of albumin/ mg creatinine O not measured
53 Cut-off values for proteinuria? O not applicable for this study O males: ________________ O females: _______________
54 Cut-off values for microalbuminuria? O not applicable for this study O males: ________________ O females: _______________
55 Type of urine collection? O not applicable for this study O 24-Hour O spot O timed collection for _________ hours O can't tell or not stated

Formal Comparison of BP readings

56 What was the order of measurement for the comparison of clinic BP and self BP? O not applicable for this study O clinic BP measured first O self BP measured first O random order of measurement O non-random order O other, including multiple O can't tell or not specified
57 What was the order of measurement for the comparison of clinic BP and ABPM? O not applicable for this study O clinic BP measured first O daytime BP measured first O random order of measurement O non-random order O other, including multiple O can't tell or not specified
58 What was the order of measurement for the comparison of self BP and ABPM? O not applicable for this study O self BP measured first O nighttime BP measured first O random order of measurement O non-random order O other, including multiple O can't tell or not specified

Patient Characteristics

59 Complete the following information for the entire study population. (Record data as it is presented- N or % or both. If only subgroup data is provided, calculate data for the entire study population when possible.)
  | N | %
  Number of Patients
  Males
  African-American
  Asian
  White
  Other race
  Diabetics
  On BP medication
  On dialysis
  Active or prior cardiac or cerebrovascular disease
  Current Smokers
  Hypertension- defined by clinic BP
  Hypertension-defined by self BP
  Hypertension- defined by ABPM
  Normotension- Normal clinic BP and normal self BP
  Normotension-Normal clinic BP and normal ABPM
  White-coat HTN (high clinic but normal self BP)
  White-coat HTN (high clinic but normal ABPM)
  Sustained HTN (high clinic and high self)
  Sustained HTN (high clinic and high ABPM)
60 Please indicate the exclusion criteria, as well as, if appropriate, the specific population(s) included in the study. [Check all that apply]
  Exclusion Criteria | Specific Population Targeted | Criteria
  [image] | [image] | Age <__________years
  [image] | [image] | Age > _________ years
  [image] | [image] | Males
  [image] | [image] | Females
  [image] | [image] | One or more racial or ethnic groups
  [image] | [image] | Pregnancy
  [image] | [image] | Hypertensives
  [image] | [image] | Normotensives
  [image] | [image] | Anti-hypertensive medication
  [image] | [image] | Diabetes
  [image] | [image] | Dialysis
  [image] | [image] | Chronic renal insufficiency (not on dialysis)
  [image] | [image] | Renal transplant patients
  [image] | [image] | Proteinuria/albuminuria
  [image] | [image] | Excess variability
  [image] | [image] | Active or prior cardiac or cerebrovascular disease
  [image] | [image] | Current smoking
  [image] | [image] | Obese individuals
  [image] | [image] | Drug resistant hypertension
  [image] | [image] | Autonomic dysfunction
  [image] | [image] | Other: __________________________________
  [image] | [image] | Other: __________________________________
  O | Exclusion criteria not stated or can't tell
  | O | no specific population
61 Summarize in one sentence the main aim of this study.
62 Summarize in one or two sentences the main finding(s) of this study that is/are relevant to any of our research questions
63 General Comments:
64 Provide number of people for which each of the following completed:
  Clinic BP | ___________________ | O not applicable
  Self BP | ____________________ | O not applicable
  AMBP | ____________________ | O not applicable
  Echocardiograph | __________________ | O not applicable
  Urine protein/albuminuria | _________________ | O not applicable
65 Study included results presented as: [image] one group or whole group [image] subgroups. If subgroups, specify the number abstracted in Part II (see page 3, Quality Assessment Form) Number of subgroups: ___________

Provide names for each subgroup to be abstracted in Part II (see page 3, Quality Assessment Form)

| Name
Group A
Group B
Group C
Group D
Group E

Utility of Blood Pressure Monitoring Outside the Clinic Setting PART II- RESULTS

Article ID#: | ________________________
Reviewer 1: | ________________________
Reviewer 2: | ________________________

Complete and submit separate results sections for each required group (refer to page 3 of the Quality Assessment Form) and for the entire study population. Results on this form completed for (circle one):
Whole Group | Group A | Group B | Group C | Group D | Group E

OUTLINE

| | Page
SECTION 1- Demographic Characteristics and Blood Pressure | | 2
SECTION 2- Distribution of Readings between Clinic Blood Pressure, Self-Measured Blood Pressure and Ambulatory Blood Pressure
2.1 | Comparison of self-measured BP and clinic BP........................ | 4
2.2 | Comparison of ABPM and clinic BP .................................... | 5
2.3 | Comparison of ABPM and self-measured BP........................... | 8
SECTION 3- Association of Blood Pressure with LV Mass
3.1 | Clinic BP and LV mass ..................................................... | 12
3.2 | Self-measured and LV mass .............................................. | 14
3.3 | ABPM and LV mass ..................................................... | 21
SECTION 4- Association of Blood Pressure with Urine Protein
4.1 | Clinic BP and urine protein ................................................. | 29
4.2 | Self-measured BP and urine protein ....................................... | 31
4.3 | ABPM and urine protein ................................................ | 38

SECTION 1 PATIENT DEMOGRAPHICS

1 Complete the following information for each required group (this question should NOT be completed for the entire study population). Record data only as it is presented-N or % or both.
  | N | %
  Number of Patients
  Males
  African-American
  Asian
  White
  Other race
  Diabetics
  On BP medication
  On dialysis
  Active or prior cardiac or cerebrovascular disease
  Current Smokers
  Hypertension- defined by clinic BP
  Hypertension-defined by self BP
  Hypertension- defined by ABPM
  Normotension- Normal clinic BP and normal self BP
  Normotension-Normal clinic BP and normal ABPM
  White-coat HTN (high clinic but normal self BP)
  White-coat HTN (high clinic but normal ABPM)
  Sustained HTN (high clinic and high self)
  Sustained HTN (high clinic and high ABPM)

SECTION 1 PATIENT DEMOGRAPHICS

1 Complete the following information for each required group (this question should NOT be completed for the entire study population). Record data only as it is presented-N or % or both.
  | N | %
  Number of Patients | | X
  Males
  African-American
  Asian
  White
  Other race
  Diabetics
  On BP medication
  On dialysis
  Active or prior cardiac or cerebrovascular disease
  Current Smokers
  Hypertension- defined by clinic BP
  Hypertension-defined by self BP
  Hypertension- defined by ABPM
  Normotension- Normal clinic BP and normal self BP
  Normotension-Normal clinic BP and normal ABPM
  White-coat HTN (high clinic but normal self BP)
  White-coat HTN (high clinic but normal ABPM)
  Sustained HTN (high clinic and high self BP)
  Sustained HTN (high clinic and high ABPM)
2 Complete the following table: - only record other data if mean and SD are NOT provided - if clinic BP data are provided for various positions, only record sitting BP
  | Mean | SD | Median | Range | SE | upper 95% CI | lower 95% CI
  Age
  Clinic SBP
  Clinic DBP
  Self SBP
  Self DBP
  Day SBP
  Day DBP
  Night SBP
  Night DBP
  24-hour SBP
  24-hour DBP
  D Day-night SBP
  D Day-night DBP

SECTION 2 COMPARISON OF CLINIC, SELF AND AMBULATORY BLOOD PRESSURE MEASUREMENTS If study does not compare BP measurements, STOP and GO TO Question 26, page 14

3 Does study address distribution of readings between CLINIC BP and SELF-MEASURED BP? O Yes O No, STOP and go to Question 6, page 5

SECTION 2.1 FORMAL COMPARISON OF SELF-MEASURED BP AND CLINIC BP (Distribution of readings between clinic and self-measured blood pressure-#1a)

For each study that reports the blood pressure difference between CLINIC BP and SELF BP indicate the following information:

4 BP Difference (difference is defined as clinic BP minus self BP):
  | SBP Difference | DBP Difference
  Mean (Difference)
  SD (Difference)
  SE (Difference)
  95%CI (Difference) | to | to
  Range (Difference) | to | to
  P-Value (Difference)
  | O p>0.05 | O p>0.05
  | O p<0.05 | O p<0.05
  | O p<0.01 | O p<0.01
  | O p<0.001 | O p<0.001
5 Correlation Coefficient for Clinic BP and Self BP:
  | SBP | DBP
  Estimate
  SE
  95%CI | to | to
  P-Value
  | O p>0.05 | O p>0.05
  | O p<0.05 | O p<0.05
  | O p<0.01 | O p<0.01
  | O p<0.001 | O p<0.001

SECTION 2.2 COMPARISON OF ABPM AND CLINIC BP Distribution of readings between clinic and ambulatory blood pressure (#1a)

6 Does the study address distribution of readings between CLINIC BP and ABPM? O Yes O No, STOP and GO TO question 16, page 8
7 Does the study address distribution of readings between CLINIC BP and DAYTIME BP measurements (#1a)? O Yes O No, STOP and GO TO question 10, page 6

For each study that reports the blood pressure difference between CLINIC BP and DAYTIME BP indicate the following information:

8 BP Difference (difference is defined as clinic BP minus daytime BP)
  | SBP Difference | DBP Difference
  Mean (Difference)
  SD (Difference)
  SE (Difference)
  95%CI (Difference) | to | to
  Range (Difference) | to | to
  P-Value (Difference)
  | O p>0.05 | O p>0.05
  | O p<0.05 | O p<0.05
  | O p<0.01 | O p<0.01
  | O p<0.001 | O p<0.001
9 Correlation Coefficient for Clinic BP and Daytime BP
  | SBP | DBP
  Estimate
  SE
  95%CI | to | to
  P-Value
  | O p>0.05 | O p>0.05
  | O p<0.05 | O p<0.05
  | O p<0.01 | O p<0.01
  | O p<0.001 | O p<0.001
10 Does the study address distribution of readings between CLINIC BP and NIGHTTIME BP blood pressure measurements? O Yes O No, STOP and go to question 13, page 7

For each study that reports the blood pressure difference between CLINIC BP and NIGHTTIME BP indicate the following information:

11 BP Difference (difference is defined as clinic BP minus nighttime BP)
  | SBP Difference | DBP Difference
  Mean (Difference)
  SD (Difference)
  SE (Difference)
  95%CI (Difference) | to | to
  Range (Difference) | to | to
  P-Value (Difference)
  | O p>0.05 | O p>0.05
  | O p<0.05 | O p<0.05
  | O p<0.01 | O p<0.01
  | O p<0.001 | O p<0.001
12 Correlation Coefficient for Clinic BP and Nighttime BP
  | SBP | DBP
  Estimate
  SE
  95%CI | to | to
  P-Value
  | O p>0.05 | O p>0.05
  | O p<0.05 | O p<0.05
  | O p<0.01 | O p<0.01
  | O p<0.001 | O p<0.001
13 Does the study address the blood pressure difference between CLINIC BP and 24-HOUR BP? O Yes O No, STOP and GO TO Question 16, page 8

For each study that reports the blood pressure difference between CLINIC BP and 24 HOUR BP indicate the following information:

14 BP Difference (difference is defined as clinic BP minus 24-Hour BP)
  | SBP Difference | DBP Difference
  Mean (Difference)
  SD (Difference)
  SE (Difference)
  95% CI (Difference) | to | to
  Range (Difference) | to | to
  P-Value (Difference)
  | O p>0.05 | O p>0.05
  | O p<0.05 | O p<0.05
  | O p<0.01 | O p<0.01
  | O p<0.001 | O p<0.001
15 Correlation Coefficient for Clinic BP and 24-Hour BP
  | SBP | DBP
  Estimate
  SE
  95% CI | to | to
  P-Value
  | O p>0.05 | O p>0.05
  | O p<0.05 | O p<0.05
  | O p<0.01 | O p<0.01
  | O p<0.001 | O p<0.001

SECTION 2.3 COMPARISON OF ABPM AND SELF BP Distribution of readings between ABPM and self-BP (#1a)

16 Does the study address distribution of readings between SELF BP and ABPM? O Yes O No, STOP and GO TO question 26, page 11
17 Does the study address distribution of readings between SELF BP and DAYTIME BP measurements (#1a)? O Yes O No, STOP and GO TO question 20, page 9

For each study that reports the blood pressure difference between SELF BP and DAYTIME BP indicate the following information:

18 BP Difference (difference is defined as self BP minus daytime BP)
  | SBP Difference | DBP Difference
  Mean (Difference)
  SD (Difference)
  SE (Difference)
  95%CI (Difference) | to | to
  Range (Difference) | to | to
  P-Value (Difference)
  | O p>0.05 | O p>0.05
  | O p<0.05 | O p<0.05
  | O p<0.01 | O p<0.01
  | O p<0.001 | O p<0.001
19 Correlation Coefficient for Self BP and Daytime BP
  | SBP | DBP
  Estimate
  SE
  95%CI | to | to
  P-Value
  | O p>0.05 | O p>0.05
  | O p<0.05 | O p<0.05
  | O p<0.01 | O p<0.01
  | O p<0.001 | O p<0.001
20 Does the study address distribution of readings between SELF BP and NIGHTTIME BP blood pressure measurements? O Yes O No, STOP and go to question 23, page 10

For each study that reports the blood pressure difference between SELF BP and NIGHTTIME BP indicate the following information:

21 BP Difference (difference is defined as self BP minus nighttime BP)
  | SBP Difference | DBP Difference
  Mean (Difference)
  SD (Difference)
  SE (Difference)
  95%CI (Difference) | to | to
  Range (Difference) | to | to
  P-Value (Difference)
  | O p>0.05 | O p>0.05
  | O p<0.05 | O p<0.05
  | O p<0.01 | O p<0.01
  | O p<0.001 | O p<0.001
22 Correlation Coefficient for Self BP and Nighttime BP
  | SBP | DBP
  Estimate
  SE
  95%CI | to | to
  P-Value
  | O p>0.05 | O p>0.05
  | O p<0.05 | O p<0.05
  | O p<0.01 | O p<0.01
  | O p<0.001 | O p<0.001
23 Does the study address the blood pressure difference between SELF BP and 24-HOUR BP? O Yes O No, STOP and GO TO Question 26, page 11

For each study that reports the blood pressure difference between SELF BP and 24 HOUR BP indicate the following information:

24 BP Difference (difference is defined as self BP minus 24-Hour BP)
  | SBP Difference | DBP Difference
  Mean (Difference)
  SD (Difference)
  SE (Difference)
  95%CI (Difference) | to | to
  Range (Difference) | to | to
  P-Value (Difference)
  | O p>0.05 | O p>0.05
  | O p<0.05 | O p<0.05
  | O p<0.01 | O p<0.01
  | O p<0.001 | O p<0.001
25 Correlation Coefficient for Self BP and 24-Hour BP
  | SBP | DBP
  Estimate
  SE
  95% CI | to | to
  P-Value
  | O p>0.05 | O p>0.05
  | O p<0.05 | O p<0.05
  | O p<0.01 | O p<0.01
  | O p<0.001 | O p<0.001

SECTION 3 LV MASS AND BP

26 Does the paper address the association between LV mass and ambulatory BP and/or self-measured BP AND provide a comparison with clinic BP? O Yes O No, STOP and GO TO Question 69, page 29
27 Is LV mass measured by echocardiogram? O Yes O No, STOP and GO TO Question 69, page 29
28 LV mass index:
  [image] mean: | ____________________
  [image] SD: | ____________________
  [image] SE: | ____________________
  [image] median: | ____________________
  [image] IQR: | ____________________ | to ____________________
  [image] 95% CI: | ____________________ | to ____________________
  [image] Range: | ____________________ | to ____________________
  O Unknown: | ____________________ | to ____________________
29 Proportion of patients with LV hypertrophy __________ (%) O Unknown

SECTION 3.1 CLINIC BP AND LV MASS: CROSS-SECTIONAL STUDIES (Question #2a and Question #3a)

Instructions: In the following sections, a paper may present the same association with different degrees of adjustment. Please, abstract always the maximally adjusted model (EXCEPT if separate subgroups are being reported -- in this case, abstract the subgroup specific data rather than the overall model).

30 Clinic BP and LV mass:
  Estimate:
  SE
  95% CI: | to | to | to | to | to | to
  P value: | __________ | __________ | __________ | __________ | __________ | __________
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
31 Clinic BP and LV mass:
  | Correlation Coefficient | Variance Explained (R^2^) | Regression Coefficient
  Type of coefficient:
  Pearson (Parametric) | O | O | O
  Spearman (Non-Parametric) | O | O | O
  Unknown | O | O | O
  Adjustment:
  Unadjusted-Crude | O | O | O
  Adjusted for (check all that apply):
  Age | [image] | [image] | [image]
  Gender | [image] | [image] | [image]
  Race | [image] | [image] | [image]
  Weight, BMI or WHR | [image] | [image] | [image]
  ABPM | [image] | [image] | [image]
  SELF BP | [image] | [image] | [image]
  Other:___________ | [image] | [image] | [image]
  Other:___________ | [image] | [image] | [image]
  Unknown | O | O | O
  Considered variables (matched, adjusted but not reported, restricted etc.):
  None | O | O | O
  Age | [image] | [image] | [image]
  Gender | [image] | [image] | [image]
  Race | [image] | [image] | [image]
  Weight, BMI or WHR | [image] | [image] | [image]
  Other:___________ | [image] | [image] | [image]
  Other:___________ | [image] | [image] | [image]
  Unknown | O | O | O

SECTION 3.2 SELF BP AND LV MASS: CROSS-SECTIONAL STUDIES Self-measured BP and association with blood pressure-related target organ damage (Question #2a)

32 Does study address self-measured BP and LV mass? O Yes O No, STOP and GO TO Question 49, page 21
33 Self BP and LV mass:
  Estimate:
  SE
  95% CI: | to | to | to | to | to | to
  P value
    __________
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
    __________
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
    __________
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
    __________
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
    __________
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
    __________
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
34 Self BP and LV mass:
  | Correlation Coefficient | Variance Explained (R^2^) | Regression Coefficient
  Type of coefficient:
  Pearson (Parametric) | O | O | O
  Spearman (Non-Parametric) | O | O | O
  Unknown | O | O | O
  Adjustment:
  Unadjusted-Crude | O | O | O
  Adjusted for (check all that apply):
  Age | [image] | [image] | [image]
  Gender | [image] | [image] | [image]
  Race | [image] | [image] | [image]
  Weight, BMI or WHR | [image] | [image] | [image]
  Clinic BP | [image] | [image] | [image]
  ABPM | [image] | [image] | [image]
  Other:___________ | [image] | [image] | [image]
  Other:___________ | [image] | [image] | [image]
  Unknown | O | O | O
  Considered variables (matched, adjusted but not reported, restricted etc.):
  None | O | O | O
  Age | [image] | [image] | [image]
  Gender | [image] | [image] | [image]
  Race | [image] | [image] | [image]
  Weight, BMI or WHR | [image] | [image] | [image]
  Other:___________ | [image] | [image] | [image]
  Other:___________ | [image] | [image] | [image]
  Unknown | O | O | O
35 Did this study address the incremental gain in prediction of LV mass from self measurement devices beyond prediction from clinic BP alone? (e.g. are both variables in the same model?) O Yes O No O Can't tell or not stated

CROSS SECTIONAL COMPARISON OF LV MASS IN NORMOTENSIVES, WHITE-COAT HYPERTENSIVES AND SUSTAINED HYPERTENSIVES- SELF BP (Question #2a)

36 Does the study compare LV mass in normotensives, white-coat hypertensives and/or sustained hypertensives, assessed by SELF BP? O Yes O No, STOP and GO TO Question 49, page 21

BLOOD PRESSURE BY CATEGORY OF HYPERTENSION-BASED ON SELF BP

Instructions:

- Only record other data if mean and SD are NOT provided

- If clinic BP is provided for various positions-record only sitting BP

37 Blood pressure in clinic and self normotensives:
  | Mean | SD | SE | Median | IQR | 95% CI | Range
  Clinic SBP | _________ | _______ | ______ | _______ | ____to_____ | ____to_____ | ____to___
  O No Information Provided
  Clinic DBP | _________ | _______ | ______ | _______ | ____to_____ | ____to_____ | ____to___
  O No Information Provided
  SELF BP SBP | _________ | _______ | ______ | _______ | ____to_____ | ____to_____ | ____to___
  O No Information Provided
  SELF BPDBP | ________ | _______ | ______ | _______ | ____to_____ | ____to_____ | ____to___
  O No Information Provided
38 For clinic and self normotensives, indicate the following additional information:
  Males: | N_________ (%) _________
  Race:
  African-American: | N_________ (%) _________
  Asian | N_________ (%) _________
  White | N_________ (%) _________
  Other | N_________ (%) _________
  Mean Age: | _____________
39 Blood pressure in white-coat hypertensives (Self BP)
  | Mean | SD | SE | Median | IQR | 95% CI | Range
  Clinic SBP | _________ | _______ | ______ | _______ | ____to_____ | ____to_____ | ____to___
  O No Information Provided
  Clinic DBP | _________ | _______ | ______ | _______ | ____to_____ | ____to_____ | ____to___
  O No Information Provided
  SELF BP SBP | _________ | _______ | ______ | _______ | ____to_____ | ____to_____ | ____to___
  O No Information Provided
  SELF BPDBP | ________ | _______ | ______ | _______ | ____to_____ | ____to_____ | ____to___
  O No Information Provided
40 For self-BP white-coat hypertensives, indicate the following additional information:
  Males: | N_________ (%) _________
  Race:
  African-American: | N_________ (%) _________
  Asian | N_________ (%) _________
  White | N_________ (%) _________
  Other | N_________ (%) _________
  Mean Age: | _____________
41 Blood pressure in Self BP sustained
  | Mean | SD | SE | Median | IQR | 95% CI | Range
  Clinic SBP | _________ | _______ | ______ | _______ | ____to_____ | ____to_____ | ____to___
  O No Information Provided
  Clinic DBP | _________ | _______ | ______ | _______ | ____to_____ | ____to_____ | ____to___
  O No Information Provided
  SELF BP SBP | _________ | _______ | ______ | _______ | ____to_____ | ____to_____ | ____to___
  O No Information Provided
  SELF BPDBP | ________ | _______ | ______ | _______ | ____to_____ | ____to_____ | ____to___
  O No Information Provided
42 For clinic and Self BP sustained hypertensives, indicate the following additional information:
  Males: | N_________ (%) _________
  Race:
  African-American: | N_________ (%) _________
  Asian | N_________ (%) _________
  White | N_________ (%) _________
  Other | N_________ (%) _________
  Mean Age: | _____________

LV MASS INDEX BY CATEGORY OF HYPERTENSION- BASED ON SELF BP

43 Complete the following table for LV Mass by category of hypertension: -- Only record other measurements if mean and SD are NOT provided
  | Mean | SD | SE | Median | IQR | 95% CI | Range
  Clinic & SELF BP Normotensive | _______ | _____ | ______ | _______ | ____to_____ | ____to_____ | ____to___
  O No Information Provided
  SELF BP White-coat Hypertensive | _______ | _____ | ______ | _______ | ____to_____ | ____to_____ | ____to___
  O No Information Provided
  SELF BP sustained Hypertensive | _______ | _____ | ______ | _______ | ____to_____ | ____to_____ | ____to___
  O No Information Provided
44 Proportion of clinic & Self BP normotensives with LV hypertrophy: (%) O Can't tell or not stated
45 Proportion of Self BP white-coat hypertensives with LV hypertrophy: (%) O Can't tell or not stated
46 Proportion of Self BP sustained hypertensives with LV hypertrophy: (%) O Can't tell or not stated

DIFFERENCE IN LV MASS BY CATEGORY OF HYPERTENSION-BASED ON SELF-BP If study does not address difference in LV mass, STOP and GO TO Question 49, page 21

47 Complete the following table:
  | White-coat hypertensives minus normotensives (Self BP) | Sustained hypertensives minus normotensives (Self BP) | Sustained hypertensives minus white-coat hypertensives (Self BP)
  Estimate: | ______________ | _______________ | _______________
  SE: | ______________ | _______________ | _______________
  95% CI: | _______to______ | _______to_______ | _______to_______
  P value:
    ________________
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
    ________________
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
    ________________
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
  Adjustment:
  Unadjusted, Crude | O | O | O
  Adjusted for:
  Clinic BP | O | O | O
  Other, Specify: | ______________ | _______________ | _______________
  Other, Specify | ______________ | ________________ | ________________
48 Complete the following table for the OR of LV hypertrophy by category of hypertension, assessed by Self BP:
  | White-coat hypertensives vs. normotensive (Self BP) | Sustained hypertensives vs. normotensives (Self BP) | Sustained hypertensives vs. white-coat hypertensives (Self BP)
  OR:
  95% CI: | _______to________ | ________to_________ | ________to_________
  P value:
    ________________
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
    ________________
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
    ________________
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
  Adjustment:
  Unadjusted-Crude | O | O | O
  Adjusted for (check all that apply):
  Age | [image] | [image] | [image]
  Gender | [image] | [image] | [image]
  Race | [image] | [image] | [image]
  Weight, BMI or WHR | [image] | [image] | [image]
  Clinic BP | [image] | [image] | [image]
  Other, Specify | _____________ | ________________ | ________________
  Other, Specify | _____________ | ________________ | ________________
  Unknown | O | O | O
  Considered variables (matched, adjusted but not reported, etc.):
  None | O | O
  Age | [image] | [image] | [image]
  Gender | [image] | [image] | [image]
  Race | [image] | [image] | [image]
  Weight, BMI or WHR | [image] | [image] | [image]
  Other, Specify | ______________ | ______________ | ______________
  Other, Specify | ______________ | ______________ | ______________
  Unknown | O | O | O

Comments: Self BP and LV Mass

SECTION 3.3 AMBULATORY BP AND LV MASS: CROSS-SECTIONAL STUDIES (ABPM and association with blood pressure-related target organ damage- #3a)

49 Does study address the association between ABPM and LV mass? O Yes O No, STOP and GO TO Question 69, page 29
50 24-Hour BP and LV mass:
  Estimate:
  SE
  95% CI: | to | to | to | to | to | to
  P value: | __________ | __________ | __________ | __________ | __________ | __________
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
51 Daytime BP and LV mass:
  Estimate:
  SE
  95% CI: | to | to | to | to | to | to
  P value
    __________
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
    __________
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
    __________
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
    __________
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
    __________
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
    __________
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
52 Nighttime BP and LV mass index:
  Estimate:
  SE
  95% CI: | to | to | to | to | to | to
  P value
    __________
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
    __________
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
    __________
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
    __________
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
    __________
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
    __________
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
53 ABPM and LV mass index:
  | Correlation Coefficient | Variance Explained (R^2^) | Regression Coefficient
  Type of coefficient:
  Pearson (Parametric) | O | O | O
  Spearman (Non-Parametric) | O | O | O
  Unknown | O | O | O
  Adjustment:
  Unadjusted-Crude | O | O | O
  Adjusted for (check all that apply):
  Age | [image] | [image] | [image]
  Gender | [image] | [image] | [image]
  Race | [image] | [image] | [image]
  Weight, BMI or WHR | [image] | [image] | [image]
  Clinic BP | [image] | [image] | [image]
  Self-measured BP | [image] | [image] | [image]
  Other:___________ | [image] | [image] | [image]
  Other:___________ | [image] | [image] | [image]
  Unknown | O | O | O
  Considered variables (matched, adjusted but not reported, restricted etc.):
  None | O | O | O
  Age | [image] | [image] | [image]
  Gender | [image] | [image] | [image]
  Race | [image] | [image] | [image]
  Weight, BMI or WHR | [image] | [image] | [image]
  Other:___________ | [image] | [image] | [image]
  Other:___________ | [image] | [image] | [image]
  Unknown | O | O | O
54 Did this study address the incremental gain in prediction of LV mass from ambulatory devices beyond prediction from clinic BP alone? (e.g. are both variables in the same model?) O Yes O No O Can't tell or not stated

CROSS-SECTIONAL COMPARISON OF LV MASS IN NORMOTENSIVES, WHITE-COAT HYPERTENSIVES AND SUSTAINED HYPERTENSIVES-ABPM (Question #2a)

55 Does the study compare LV mass in normotensives, white-coat hypertensives and/or sustained hypertensives, assessed by ABPM? O Yes O No, STOP and GO TO Question 69, page

BLOOD PRESSURE BY CATEGORY OF HYPERTENSION

Instuctions:

- Only record other measurements if mean and SD are NOT provided

-If BP pressure data are provided for various positions- use only sitting BP

56 Blood pressure in clinic and ABPM normotensives:
  | Mean | SD | SE | Median | IQR | 95% CI | Range
  Clinic SBP | ________ | _______ | ______ | _______ | _____to_____ | _____to____ | ____to____
  O No Information Provided
  Clinic DBP | ________ | _______ | ______ | _______ | _____to_____ | _____to____ | ____to____
  O No Information Provided
  24-Hour SBP | ________ | _______ | ______ | _______ | _____to_____ | _____to____ | ____to____
  O No Information Provided
  24-Hour DBP | ________ | _______ | ______ | _______ | _____to_____ | _____to____ | ____to____
  O No Information Provided
  Day SBP | ________ | _______ | ______ | _______ | _____to_____ | _____to____ | ____to____
  O No Information Provided
  Day DBP | ________ | _______ | ______ | _______ | _____to_____ | _____to____ | ____to____
  O No Information Provided
  Night SBP | ________ | _______ | ______ | _______ | _____to_____ | _____to____ | ____to____
  O No Information Provided
  Night DBP | ________ | _______ | ______ | _______ | _____to_____ | _____to____ | ____to____
  O No Information Provided
57 For clinic and ABPM normotensives, indicate the following additional information:
  Males: | N_________ (%) _________
  Race:
  African-American: | N_________ (%) _________
  Asian | N_________ (%) _________
  White | N_________ (%) _________
  Other | N_________ (%) _________
  Mean Age: | _____________
58 Blood pressure in ABPM white-coat hypertensives
  | Mean | SD | SE | Median | IQR | 95% CI | Range
  Clinic SBP | ________ | _______ | ______ | _______ | _____to_____ | _____to____ | ____to____
  O No Information Provided
  Clinic DBP | ________ | _______ | ______ | _______ | _____to_____ | _____to____ | ____to____
  O No Information Provided
  24-Hour SBP | ________ | _______ | ______ | _______ | _____to_____ | _____to____ | ____to____
  O No Information Provided
  24-Hour DBP | ________ | _______ | ______ | _______ | _____to_____ | _____to____ | ____to____
  O No Information Provided
  Day SBP | ________ | _______ | ______ | _______ | _____to_____ | _____to____ | ____to____
  O No Information Provided
  Day DBP | ________ | _______ | ______ | _______ | _____to_____ | _____to____ | ____to____
  O No Information Provided
  Night SBP | ________ | _______ | ______ | _______ | _____to_____ | _____to____ | ____to____
  O No Information Provided
  Night DBP | ________ | _______ | ______ | _______ | _____to_____ | _____to____ | ____to____
  O No Information Provided
59 For ABPM white-coat hypertensives, indicate the following additional information:
  Males: | N_________ (%) _________
  Race:
  African-American: | N_________ (%) _________
  Asian | N_________ (%) _________
  White | N_________ (%) _________
  Other | N_________ (%) _________
  Mean Age: | _____________
60 Blood pressure in ABPM sustained hypertensives
  | Mean | SD | SE | Median | IQR | 95% CI | Range
  Clinic SBP | ________ | _______ | ______ | _______ | _____to_____ | _____to____ | ____to____
  O No Information Provided
  Clinic DBP | ________ | _______ | ______ | _______ | _____to_____ | _____to____ | ____to____
  O No Information Provided
  24-Hour SBP | ________ | _______ | ______ | _______ | _____to_____ | _____to____ | ____to____
  O No Information Provided
  24-Hour DBP | ________ | _______ | ______ | _______ | _____to_____ | _____to____ | ____to____
  O No Information Provided
  Day SBP | ________ | _______ | ______ | _______ | _____to_____ | _____to____ | ____to____
  O No Information Provided
  Day DBP | ________ | _______ | ______ | _______ | _____to_____ | _____to____ | ____to____
  O No Information Provided
  Night SBP | ________ | _______ | ______ | _______ | _____to_____ | _____to____ | ____to____
  O No Information Provided
  Night DBP | ________ | _______ | ______ | _______ | _____to_____ | _____to____ | ____to____
  O No Information Provided
61 For ABPM sustained hypertensives, indicate the following additional information:
  Males: | N_________ (%) _________
  Race:
  African-American: | N_________ (%) _________
  Asian | N_________ (%) _________
  White | N_________ (%) _________
  Other | N_________ (%) _________
  Mean Age: | _____________
  LV MASS BY CATEGORY OF HYPERTENSION BASED ON ABPM (Question #3a)
62 Complete the following table for the mean LV mass index by category of hypertension: - Only report other variables if Mean and SD are NOT provided
  | | Mean | SD | SE | Median | IQR | 95% CI | Range
  Clinic & ABPM normotensives | | _______ | _____ | ______ | _______ | _____to_____ | _____to____ | ____to____
  O No Information Provided
  ABPM White-coat Hypertensives | | _______ | _____ | ______ | _______ | _____to_____ | _____to____ | ____to____
  O No Information Provided
  ABPM Sustained Hypertensives | | _______ | _____ | ______ | _______ | _____to_____ | _____to____ | ____to____
  O No Information Provided
63 Proportion of clinic & ABPM normotensives with LV hypertrophy: (%) O Unknown
64 Proportion of ABPM white-coat hypertensives with LV hypertrophy (%)O Unknown
65 Proportion of ABPM sustained hypertensives with LV hypertrophy: (%) O Can't tell or not stated

DIFFERENCE IN LV MASS BY CATEGORY OF HYPERTENSION- BASED ON ABPM If study does not address difference in LV mass, STOP and GO TO Question 69 page 29

66 Complete the following table for the difference in LV by category of hypertension:
  | White-coat hypertensives minus normotensives (ABPM) | Sustained hypertensives minus normotensives (ABPM) | Sustained hypertensives minus white-coat hypertensives (ABPM)
  Estimate: | ______________ | _______________ | _______________
  SE: | ______________ | _______________ | _______________
  95% CI: | _______to______ | _______to_______ | _______to_______
  P value:
    ________________
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
    ________________
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
    ________________
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
  Adjustment:
  Unadjusted, Crude | O | O | O
  Adjusted for:
  Clinic BP | O | O | O
  Other, Specify: | ______________ | _______________ | _______________
  Other, Specify | ______________ | ________________ | ________________

ODDS RATIOS OF LV HYPERTROPHY IN NORMOTENSIVES, WHITE-COAT HYPERTENSIVES AND SUSTAINED HYPERTENSIVES-ABPM

67 Does the study present the OR of LV hypertrophy in normotensives, white-coat hypertensives or sustained hypertensives, assessed by ABPM? O Yes O No, STOP and GO TO Question 69, page 29
68 Complete the following table for the OR of LV hypertrophy by category of hypertension assessed by ABPM
  | White-coat hypertensives vs. normotensive (ABPM) | Sustained hypertensives vs. normotensives (ABPM) | Sustained hypertensives vs. white-coat hypertensives (ABPM)
  OR:
  95% CI: | _______to________ | ________to_________ | ________to_________
  P value:
    ________________
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
    ________________
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
    ________________
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
  Adjustment:
  Unadjusted-Crude | O | O | O
  Adjusted for (check all that apply):
  Age | [image] | [image] | [image]
  Gender | [image] | [image] | [image]
  Race | [image] | [image] | [image]
  Weight, BMI or WHR | [image] | [image] | [image]
  Clinic BP | [image] | [image] | [image]
  Other, Specify | _____________ | ________________ | ________________
  Other, Specify | _____________ | ________________ | ________________
  Unknown | O | O | O
  Considered variables (matched, adjusted but not reported, etc.):
  None | O | O
  Age | [image] | [image] | [image]
  Gender | [image] | [image] | [image]
  Race | [image] | [image] | [image]
  Weight, BMI or WHR | [image] | [image] | [image]
  Other, Specify | ______________ | ______________ | ______________
  Other, Specify | ______________ | ______________ | ______________
  Unknown | O | O | O
  Comments: Self ABPM and LV Mass

SECTION 4 URINE PROTEIN AND BP BP and association with blood pressure-related target organ damage (#2)

69 Does the paper address the association between urine protein and self-BP and/or ABPM AND provide a comparison with clinic BP? O Yes O No, STOP- this form is complete

SECTION 4.1 CLINIC BP AND URINE PROTEIN: CROSS-SECTIONAL STUDIES

Instructions: In this section, a paper may present the same association with different degrees of adjustment.Please, abstract always the maximally adjusted model (EXCEPT if separate subgroups are being reported -- in this case, abstract the subgroup specific data rather than the overall model).

70 Correlation Coefficient, variance and regression coefficient between clinic BP and urine protein or albumin:
  Estimate:
  SE
  95% CI: | to | to | to | to | to | to
  P value
    __________
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
    __________
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
    __________
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
    __________
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
    __________
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
    __________
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
71 Clinic BP and urine protein or albumin:
  | Correlation Coefficient | Variance Explained (R^2^) | Regression Coefficient
  Type of coefficient:
  Pearson (Parametric) | O | O | O
  Spearman (Non-Parametric) | O | O | O
  Unknown | O | O | O
  Adjustment:
  Unadjusted-Crude | O | O | O
  Adjusted for (check all that apply):
  Age | [image] | [image] | [image]
  Gender | [image] | [image] | [image]
  Race | [image] | [image] | [image]
  Weight, BMI or WHR | [image] | [image] | [image]
  ABPM | [image] | [image] | [image]
  Self-measured BP | [image] | [image] | [image]
  Other:___________ | [image] | [image] | [image]
  Other:___________ | [image] | [image] | [image]
  Unknown | O | O | O
  Considered variables (matched, adjusted but not reported, restricted etc.):
  None | O | O | O
  Age | [image] | [image] | [image]
  Gender | [image] | [image] | [image]
  Race | [image] | [image] | [image]
  Weight, BMI or WHR | [image] | [image] | [image]
  Other:___________ | [image] | [image] | [image]
  Other:___________ | [image] | [image] | [image]
  Unknown | O | O | O
  SECTION 4.2 SELF-BP AND URINE PROTEIN: CROSS-SECTIONAL STUDIES Self-measured blood pressure associated with proteinuria/albuminuria (#2a)
72 Does study address self-measured BP and Urine protein or albumin? O Yes O No, STOP and GO TO Question 89, page 38
73 Self BP and Urine protein or albumin:
  Estimate:
  SE
  95% CI: | to | to | to | to | to | to
  P value
    __________
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
    __________
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
    __________
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
    __________
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
    __________
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
    __________
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
74 Self BP and Urine protein or albumin:
  | Correlation Coefficient | Variance Explained (R^2^) | Regression Coefficient
  Type of coefficient:
  Pearson (Parametric) | O | O | O
  Spearman (Non-Parametric) | O | O | O
  Unknown | O | O | O
  Adjustment:
  Unadjusted-Crude | O | O | O
  Adjusted for (check all that apply):
  Age | [image] | [image] | [image]
  Gender | [image] | [image] | [image]
  Race | [image] | [image] | [image]
  Weight, BMI or WHR | [image] | [image] | [image]
  Clinic BP | [image] | [image] | [image]
  ABPM | [image] | [image] | [image]
  Other:___________ | [image] | [image] | [image]
  Other:___________ | [image] | [image] | [image]
  Unknown | O | O | O
  Considered variables (matched, adjusted but not reported, restricted etc.):
  None | O | O | O
  Age | [image] | [image] | [image]
  Gender | [image] | [image] | [image]
  Race | [image] | [image] | [image]
  Weight, BMI or WHR | [image] | [image] | [image]
  Other:___________ | [image] | [image] | [image]
  Other:___________ | [image] | [image] | [image]
  Unknown | O | O | O
75 Did this study address the incremental gain in prediction of urine protein from self-measured devices beyond prediction from clinic BP alone? (e.g. are both variables in the same model?) O Yes O No O Can't tell or not stated

CROSS-SECTIONAL COMPARISONS OF URINE PROTEIN IN NORMOTENSIVES, WHITE-COAT HYPERTENSIVES AND SUSTAINED HYPERTENSIVES-SELF BP (Question #2a)

76 Does the study compare urine protein in normotensives, white-coat hypertensives and/or sustained hypertensives, assessed by SELF BP? O Yes O No, STOP and GO TO Question 89, page 38

Instructions:

- Only record other measurements if mean and SD are NOT provided

- If BP pressure measurements are provided for various positions- use only sitting BP for the following items.

77 Blood pressure in clinic and SELF BP normotensives:
  | Mean | SD | SE | Median | IQR | 95% CI | Range
  Clinic SBP | _________ | _______ | ______ | _______ | ____to_____ | ____to_____ | ____to___
  O No Information Provided
  Clinic DBP | _________ | _______ | ______ | _______ | ____to_____ | ____to_____ | ____to___
  O No Information Provided
  SELF BP SBP | _________ | _______ | ______ | _______ | ____to_____ | ____to_____ | ____to___
  O No Information Provided
  SELF BPDBP | ________ | _______ | ______ | _______ | ____to_____ | ____to_____ | ____to___
  O No Information Provided
78 For clinic and SBPM normotensives, indicate the following additional information:
  Males: | N_________ (%) _________
  Race:
  African-American: | N_________ (%) _________
  Asian | N_________ (%) _________
  White | N_________ (%) _________
  Other | N_________ (%) _________
  Mean Age: | _____________
79 Blood pressure in SELF BP white-coat hypertensives
  | Mean | SD | SE | Median | IQR | 95% CI | Range
  Clinic SBP | _________ | _______ | ______ | _______ | ____to_____ | ____to_____ | ____to___
  O No Information Provided
  Clinic DBP | _________ | _______ | ______ | _______ | ____to_____ | ____to_____ | ____to___
  O No Information Provided
  SELF BP SBP | _________ | _______ | ______ | _______ | ____to_____ | ____to_____ | ____to___
  O No Information Provided
  SELF BPDBP | ________ | _______ | ______ | _______ | ____to_____ | ____to_____ | ____to___
  O No Information Provided
80 For SELF BP white-coat hypertensives, indicate the following additional information:
  Males: | N_________ (%) _________
  Race:
  African-American: | N_________ (%) _________
  Asian | N_________ (%) _________
  White | N_________ (%) _________
  Other | N_________ (%) _________
  Mean Age: | _____________
81 Blood pressure in SELF BP sustained
  | Mean | SD | SE | Median | IQR | 95% CI | Range
  Clinic SBP | _________ | _______ | ______ | _______ | ____to_____ | ____to_____ | ____to___
  O No Information Provided
  Clinic DBP | _________ | _______ | ______ | _______ | ____to_____ | ____to_____ | ____to___
  O No Information Provided
  SELF BP SBP | _________ | _______ | ______ | _______ | ____to_____ | ____to_____ | ____to___
  O No Information Provided
  SELF BPDBP | ________ | _______ | ______ | _______ | ____to_____ | ____to_____ | ____to___
  O No Information Provided
82 For clinic and SELF BP sustained hypertensives, indicate the following additional information:
  Males: | N_________ (%) _________
  Race:
  African-American: | N_________ (%) _________
  Asian | N_________ (%) _________
  White | N_________ (%) _________
  Other | N_________ (%) _________
  Mean Age: | _____________
  URINE PROTEIN BY CATEGORY OF HYPERTENSION BASED ON SELF BP
83 Complete the following table for urine protein by category of hypertension: -- Only record other measurements if mean and SD are NOT provided
  | Mean | SD | SE | Median | IQR | 95% CI | Range
  Clinic & SELF BP normotensive | _______ | _____ | ______ | _______ | ____to_____ | ____to_____ | ____to___
  O No Information Provided
  SELF BP White-coat hypertensive | _______ | _____ | ______ | _______ | ____to_____ | ____to_____ | ____to___
  O No Information Provided
  SELF BP sustained Hypertensive | _______ | _____ | ______ | _______ | ____to_____ | ____to_____ | ____to___
  O No Information Provided
84 Proportion of clinic & SELF BP normotensives with LV hypertrophy: (%) O Can't tell or not stated
85 Proportion of SELF BP white-coat hypertensives with LV hypertrophy: (%) O Unknown
86 Proportion of SELF BP sustained hypertensives with LV hypertrophy: (%) O Can't tell or not stated

DIFFERENCE IN URINE PROTEIN BY CATEGORY OF HYPERTENSION- BASED ON SELF BP If study does not address difference in urine protein, STOP and GO TO Question 89, page 38

87 Complete the following table for the adjusted difference in urine protein between normotensives, white-coat hypertensives and sustained hypertensives assessed by self-measured BP:
  | White-coat hypertensives minus normotensives (Self BP) | Sustained hypertensives minus normotensives (Self BP) | Sustained hypertensives minus white-coat hypertensives (Self BP)
  Estimate: | ______________ | _______________ | _______________
  SE: | ______________ | _______________ | _______________
  95% CI: | _______to______ | _______to_______ | _______to_______
  P value:
    ________________
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
    ________________
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
    ________________
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
  Adjustment:
  Unadjusted, Crude | O | O | O
  Adjusted for:
  Clinic BP | O | O | O
  Other, Specify: | ______________ | _______________ | _______________
  Other, Specify | ______________ | ________________ | ________________

ODDS RATIOS OF PROTEINURIA IN NORMOTENSIVES, WHITE-COAT HYPERTENSIVES AND SUSTAINED HYPERTENSIVES-SELF BP

88 Complete the following table for the OR of proteinuria or albuminuria by category of hypertension, assessed by self BP:
  | White-coat hypertensives vs. normotensive (Self BP) | Sustained hypertensives vs. normotensives (Self BP) | Sustained hypertensives vs. white-coat hypertensives (Self BP)
  OR:
  95% CI: | _______to________ | ________to_________ | ________to_________
  P value:
    ________________
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
    ________________
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
    ________________
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
  Adjustment:
  Unadjusted-Crude | O | O | O
  Adjusted for (check all that apply):
  Age | [image] | [image] | [image]
  Gender | [image] | [image] | [image]
  Race | [image] | [image] | [image]
  Weight, BMI or WHR | [image] | [image] | [image]
  Clinic BP | [image] | [image] | [image]
  Other, Specify | _____________ | ________________ | ________________
  Other, Specify | _____________ | ________________ | ________________
  Unknown | O | O | O
  Considered variables (matched, adjusted but not reported, etc.):
  None | O | O
  Age | [image] | [image] | [image]
  Gender | [image] | [image] | [image]
  Race | [image] | [image] | [image]
  Weight, BMI or WHR | [image] | [image] | [image]
  Other, Specify | ______________ | ______________ | ______________
  Other, Specify | ______________ | ______________ | ______________
  Unknown | O | O | O

Comments: Self BP and Proteinuria

SECTION 4.3 ABPM AND URINE PROTEIN: CROSS-SECTIONAL STUDIES (ABPM and association with blood pressure-related target organ damage- #3a)

89 Does study address the association between ABPM and Urine protein? O Yes O No, STOP this form is complete
90 24-Hour BP and Urine protein:
  Estimate:
  SE
  95% CI: | to | to | to | to | to | to
  P value: | __________ | __________ | __________ | __________ | __________ | __________
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
91 Daytime BP and Urine protein:
  Estimate:
  SE
  95% CI: | to | to | to | to | to | to
  P value
    __________
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
    __________
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
    __________
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
    __________
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
    __________
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
    __________
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
92 Nighttime BP and Urine protein
  Estimate:
  SE
  95% CI: | to | to | to | to | to | to
  P value
    __________
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
    __________
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
    __________
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
    __________
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
    __________
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
    __________
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
93 ABPM and Urine protein:
  | Correlation Coefficient | Variance Explained (R^2^) | Regression Coefficient
  Type of coefficient:
  Pearson (Parametric) | O | O | O
  Spearman (Non-Parametric) | O | O | O
  Unknown | O | O | O
  Adjustment:
  Unadjusted-Crude | O | O | O
  Adjusted for (check all that apply):
  Age | [image] | [image] | [image]
  Gender | [image] | [image] | [image]
  Race | [image] | [image] | [image]
  Weight, BMI or WHR | [image] | [image] | [image]
  Clinic BP | [image] | [image] | [image]
  SELF BP | [image] | [image] | [image]
  Other:___________ | [image] | [image] | [image]
  Other:___________ | [image] | [image] | [image]
  Unknown | O | O | O
  Considered variables (matched, adjusted but not reported, restricted etc.):
  None | O | O | O
  Age | [image] | [image] | [image]
  Gender | [image] | [image] | [image]
  Race | [image] | [image] | [image]
  Weight, BMI or WHR | [image] | [image] | [image]
  Other:___________ | [image] | [image] | [image]
  Other:___________ | [image] | [image] | [image]
  Unknown | O | O | O
94 Did this study address the incremental gain in prediction of urine protein from ambulatory devices beyond prediction from clinic BP alone? (e.g. are both variables in the same model?) O Yes O No O Can't tell or not stated

CROSS-SECTIONAL COMPARISON OF URINE PROTEIN IN NORMOTENSIVES, WHITE-COAT HYPERTENSIVES AND SUSTAINED HYPERTENSIVES-ABPM

95 Does the study compare urine protein in normotensives, white-coat hypertensives and/or sustained hypertensives, assessed by ABPM? O Yes O No, STOP this form is complete

BP BY CATEGORY OF HYPERTENSION

Instructions

- Only record other data if mean and SD are NOT provided

- If clinic BP measurements are provided for various positions- use only sitting BP

96 Blood pressure in clinic and ABPM normotensives:
  | Mean | SD | SE | Median | IQR | 95% CI | Range
  Clinic SBP | _______ | _____ | ______ | _______ | ____to_____ | ____to_____ | ____to___
  O No Information Provided
  Clinic DBP | _______ | _____ | ______ | _______ | ____to_____ | ____to_____ | ____to___
  O No Information Provided
  24-Hour SBP | _______ | _____ | ______ | _______ | ____to_____ | ____to_____ | ____to___
  O No Information Provided
  24-Hour DBP | _______ | _____ | ______ | _______ | ____to_____ | ____to_____ | ____to___
  O No Information Provided
  Day SBP | _______ | _____ | ______ | _______ | ____to_____ | ____to_____ | ____to___
  O No Information Provided
  Day DBP | _______ | _____ | ______ | _______ | ____to_____ | ____to_____ | ____to___
  O No Information Provided
  Night SBP | _______ | _____ | ______ | _______ | ____to_____ | ____to_____ | ____to___
  O No Information Provided
  Night DBP | _______ | _____ | ______ | _______ | ____to_____ | ____to_____ | ____to___
  O No Information Provided
97 For clinic and ABPM normotensives, indicate the following additional information:
  Males: | N_________ (%) _________
  Race:
  African-American: | N_________ (%) _________
  Asian | N_________ (%) _________
  White | N_________ (%) _________
  Other | N_________ (%) _________
  Mean Age: | _____________
98 Blood pressure in ABPM white-coat hypertensives
  | Mean | SD | SE | Median | IQR | 95% CI | Range
  Clinic SBP | _______ | _____ | ______ | _______ | ____to_____ | ____to_____ | ____to___
  O No Information Provided
  Clinic DBP | _______ | _____ | ______ | _______ | ____to_____ | ____to_____ | ____to___
  O No Information Provided
  24-Hour SBP | _______ | _____ | ______ | _______ | ____to_____ | ____to_____ | ____to___
  O No Information Provided
  24-Hour DBP | _______ | _____ | ______ | _______ | ____to_____ | ____to_____ | ____to___
  O No Information Provided
  Day SBP | _______ | _____ | ______ | _______ | ____to_____ | ____to_____ | ____to___
  O No Information Provided
  Day DBP | _______ | _____ | ______ | _______ | ____to_____ | ____to_____ | ____to___
  O No Information Provided
  Night SBP | _______ | _____ | ______ | _______ | ____to_____ | ____to_____ | ____to___
  O No Information Provided
  Night DBP | _______ | _____ | ______ | _______ | ____to_____ | ____to_____ | ____to___
  O No Information Provided
99 For ABPM white-coat hypertensives, indicate the following additional information:
  Males: | N_________ (%) _________
  Race:
  African-American: | N_________ (%) _________
  Asian | N_________ (%) _________
  White | N_________ (%) _________
  Other | N_________ (%) _________
  Mean Age: | _____________
100 Blood pressure in ABPM sustained hypertensives
  | Mean | SD | SE | Median | IQR | 95% CI | Range
  Clinic SBP | _______ | _____ | ______ | _______ | ____to_____ | ____to_____ | ____to___
  O No Information Provided
  Clinic DBP | _______ | _____ | ______ | _______ | ____to_____ | ____to_____ | ____to___
  O No Information Provided
  24-Hour SBP | _______ | _____ | ______ | _______ | ____to_____ | ____to_____ | ____to___
  O No Information Provided
  24-Hour DBP | _______ | _____ | ______ | _______ | ____to_____ | ____to_____ | ____to___
  O No Information Provided
  Day SBP | _______ | _____ | ______ | _______ | ____to_____ | ____to_____ | ____to___
  O No Information Provided
  Day DBP | _______ | _____ | ______ | _______ | ____to_____ | ____to_____ | ____to___
  O No Information Provided
  Night SBP | _______ | _____ | ______ | _______ | ____to_____ | ____to_____ | ____to___
  O No Information Provided
  Night DBP | _______ | _____ | ______ | _______ | ____to_____ | ____to_____ | ____to___
  O No Information Provided
101 For ABPM sustained hypertensives, indicate the following additional information:
  Males: | N_________ (%) _________
  Race:
  African-American: | N_________ (%) _________
  Asian | N_________ (%) _________
  White | N_________ (%) _________
  Other | N_________ (%) _________
  Mean Age: | _____________

Urine protein by category of hypertension based on ABPM (Question #3a)

102 Complete the following table for urine protein by category of hypertension: - Only report other variables if Mean and SD are NOT provided
  | Mean | SD | SE | Median | IQR | 95% CI | Range
  Clinic & ABPM normotensives | _______ | _____ | ______ | _______ | ____to_____ | ____to_____ | ____to___
  O No Information Provided
  ABPM White-coat Hypertensives | _______ | _____ | ______ | _______ | ____to_____ | ____to_____ | ____to___
  O No Information Provided
  ABPM Sustained Hypertensives | _______ | _____ | ______ | _______ | ____to_____ | ____to_____ | ____to___
  O No Information Provided
103 Proportion of clinic & ABPM normotensives with proteinuria: (%) O Unknown
104 Proportion of ABPM white-coat hypertensives with proteinuria: (%) O Unknown
105 Proportion of ABPM sustained hypertensives with proteinuria: (%) O Can't tell or not stated

DIFFERENCES IN URINE PROTEIN IN NORMOTENSIVES, WHITE-COAT HYPERTENSIVES AND SUSTAINED HYPERTENSIVES-ABPM

106 Does the study report differences in urine protein in normotensives, white-coat hypertensives and sustained hypertensives, assessed by ABPM? O Yes O No, STOP this form is complete
107 Complete the following table for the adjusted difference in urine protein between normotensives, white-coat hypertensives and sustained hypertensives assessed by ABPM:
  | White-coat hypertensives minus normotensives (ABPM) | Sustained hypertensives minus normotensives (ABPM) | Sustained hypertensives minus white-coat hypertensives (ABPM)
  Estimate: | ______________ | _______________ | _______________
  SE: | ______________ | _______________ | _______________
  95% CI: | _______to______ | _______to_______ | _______to_______
  P value:
    ________________
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
    ________________
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
    ________________
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
  Adjustment:
  Unadjusted, Crude | O | O | O
  Adjusted for:
  Clinic BP | O | O | O
  Other, Specify: | ______________ | _______________ | _______________
  Other, Specify | ______________ | ________________ | ________________

ODD RATIOS OF PROTEINURIA/ALBUMINURIA IN NORMOTENSIVES, WHITE-COAT HYPERTENSIVES AND SUSTAINED HYPERTENSIVES- ABPM

108 Does the study present the OR of proteinuria/albuminuria in normotensives, white-coat hypertensives or sustained hypertensives, assessed by ABPM? O Yes O No, STOP this form is complete
109 Complete the following table for the OR of proteinuria/albuminuria by category of hypertension assessed by ABPM:
  | White-coat hypertensives vs. normotensive (ABPM) | Sustained hypertensives vs. normotensives (ABPM) | Sustained hypertensives vs. white-coat hypertensives (ABPM)
  OR:
  95% CI: | _______to________ | ________to_________ | ________to_________
  P value:
    ________________
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
    ________________
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
    ________________
    O > 0.05
    O < 0.05
    O < 0.01
    O < 0.001
  Adjustment:
  Unadjusted-Crude | O | O | O
  Adjusted for (check all that apply):
  Age | [image] | [image] | [image]
  Gender | [image] | [image] | [image]
  Race | [image] | [image] | [image]
  Weight, BMI or WHR | [image] | [image] | [image]
  Clinic BP | [image] | [image] | [image]
  Other, Specify | _____________ | ________________ | ________________
  Other, Specify | _____________ | ________________ | ________________
  Unknown | O | O | O
  Considered variables (matched, adjusted but not reported, etc.):
  None | O | O
  Age | [image] | [image] | [image]
  Gender | [image] | [image] | [image]
  Race | [image] | [image] | [image]
  Weight, BMI or WHR | [image] | [image] | [image]
  Other, Specify | ______________ | ______________ | ______________
  Other, Specify | ______________ | ______________ | ______________
  Unknown | O | O | O
  Comments: ABPM and Urine Protein