# Appendix D Abstract Review Form

<print date> | Utility of BP Measurement Outside of Clinic Abstract Review Form | Reviewer: _________ Data Entry: _________
<Record #> <title> <abstract>

Delete, because article (check one): [image] does not include ambulatory or self-measurement [image] does not include human data [image] not in English [image] no original data [image]< 20 patients [image] meeting abstract (no full article for review) [image] other: (specify) ________________________ [image] Unclear: get article to decide Do not go on if any item above is checked. | [image] This article does not apply to any above study topics. [image] Article pertains to clinic or standard measurement only [image] Article pertains to invasive or intra-arterial measurement only [image] Get article for reference regarding:____________________________ Any comments to be tagged:______________________________________
  Study Topics (check all that apply) [image] comparison of readings (#1) [image] self-measured and clinical events (#2) [image] ambulatory and clinical events (#3) can only select remaining items if article addresses questions 1, 2 or 3: [image] subgroups (#4) If appropriate, select specific study population: [image] pregnant women [image] transplants [image] children (<18 years old)

<print date> | Utility of BP Measurement Outside of Clinic Second Level Abstract Review Form | Reviewer: _________ Data Entry: _________
<Record #> <title> <abstract>

Delete, because article (check one):

[image] does not include ambulatory or self-measurement [image] does not include human data [image] not in English [image] no original data [image] meeting abstract (no full article for review) [image] other: (specify) ________________________ [image] Unclear: get article to decide | [image] has <50 patients or addresses reproducibility and has < 20 patients [image] describes cross-sectional/retrospective study, addresses only question #2 or #3, and does not include comparison with clinic measurement [image] describes cross-sectional/retrospective study with outcome other than left ventricular mass or proteinuria/albuminuria [image] addresses only the prevalence of dipping versus non-dipping and no other research questions [image] describes clinical trial that does not have longitudinal analysis of clinical outcomes other than blood pressure [image] does not address any of the research questions Any comments to be tagged:______________________________________