# Appendix C Search Strategies

## Search Strategies

### PubMed Strategy

("blood pressure monitors"[mh]OR ((monitor*[tw] AND blood pressure[tw]) OR blood pressure measure*[tw]) OR "blood pressure determination"[mh] OR ("monitoring, ambulatory"[mh] AND ("blood pressure"[mh] OR "hypertension"[mh])) AND (self[tw] OR home[tiab] OR ambulatory[tiab] OR portable[tiab] OR 24-h*[tw] OR 24 h*[tw] OR automat*[tiab] OR "white-coat"[tw] OR "white coat"[tw] OR nocturnal[tiab] OR diurnal[tiab] OR circadian[tw] OR dipper[tiab]) AND eng[la] AND journal article[pt] NOT (animal[mh] NOT human[mh])

### Cochrane CENTRAL Register of Controlled Trials Strategy

1. BLOOD-PRESSURE-MONITORS*:ME
2. MONITOR*
3. (BLOOD and PRESSURE)
4. (#2 and #3)
5. (BLOOD next (PRESSURE next MEASURE*))
6. BLOOD-PRESSURE-DETERMINATION*:ME
7. BLOOD-PRESSURE-MONITORING-AMBULATORY*:ME
8. BLOOD-PRESSURE*:ME
9. HYPERTENSION*:ME
10. (#8 or #9)
11. (#7 and #10)
12. ((((#1 or #4) or #5) or #6) or #11)
13. SELF
14. HOME
15. AMBULATORY
16. PORTABLE
17. WHITE-COAT
18. (WHITE next COAT)
19. NOCTURNAL
20. DIURNAL
21. CIRCADIAN
22. DIPPER
23. (((((((((#13 or #14) or #15) or #16) or #17) or #18) or #19) or #20) or #21) or #22)
24. (#23 and #12)

### HealthSTAR Strategy

blood pressure determination OR blood pressure monitor*

limits: English language, exclude MEDLINE^®^ overlap