# Appendix B Journals Searched

## Journals Hand Searched

All journals searched January 2001 to May 2001, unless otherwise noted.

## Journal Title

American Journal of Hypertension

Annals of Internal Medicine

Archives of Internal Medicine

Blood Pressure Monitoring

Blood Pressure

Blood Pressure Supplementum

British Medical Journal

Circulation

Hypertension

Journal of American Medical Association

Journal of Clinical Hypertension^*^

* Searched from January 1999 to May 2001.

Journal of Hypertension

Journal of Hypertension Supplementum

Journal of Human Hypertension

Lancet

New England Journal of Medicine